# Appendix D Excluded Studies

(2013). Use of opioids to control arthritis pain under scrutiny. Increase in falls, fractures in older adults attributed to narcotic painkillers, such as oxycodone, Vicodin or Percocet. Duke Med Health News.
Abrahamsen B, Brixen K. (2009). Mapping the prescriptiome to fractures in men--a national analysis of prescription history and fracture risk. Osteoporos Int.
Adams EH, Breiner S, Cicero TJ, et al. (2006). A comparison of the abuse liability of tramadol, NSAIDs, and hydrocodone in patients with chronic pain. J Pain Symptom Manage.
Afilalo M, Etropolski MS, Kuperwasser B, et al. (2010). Efficacy and safety of Tapentadol extended release compared with oxycodone controlled release for the management of moderate to severe chronic pain related to osteoarthritis of the knee: a randomized, double-blind, placebo- and active-controlled phase III study. Clin Drug Investig.
Agarwal S, Polydefkis M, Block B, et al. (2007). Transdermal fentanyl reduces pain and improves functional activity in neuropathic pain states. Pain Med.
Albert S, Brason FW, Sanford CK, et al. (2011). Project Lazarus: community-based overdose prevention in rural North Carolina. Pain Med.
Amass L, Bickel WK, Higgins ST, et al. (1994). A preliminary investigation of outcome following gradual or rapid buprenorphine detoxification. J Addict Dis.
Amass L, Ling W, Freese TE, et al. (2004). Bringing buprenorphine-naloxone detoxification to community treatment providers: the NIDA Clinical Trials Network field experience. American Journal on Addictions.
Amato J-N, Marie S, Lelong-Boulouard V, et al. (2013). Effects of three therapeutic doses of codeine/paracetamol on driving performance, a psychomotor vigilance test, and subjective feelings. Psychopharmacology.
Amato P. (2010). Clinical experience with fortnightly buprenorphine/naloxone versus buprenorphine in Italy: preliminary observational data in an office-based setting. Clin Drug Investig.
Anderson VC, Burchiel KJ. (1999). A prospective study of long-term intrathecal morphine in the management of chronic nonmalignant pain. Neurosurgery.
Annemans L. (2011). Pharmacoeconomic impact of adverse events of long-term opioid treatment for the management of persistent pain. Clin Drug Investig.
(2014). Tapentadol. Acute or chronic pain: No therapeutic advance. Prescrire Int.
Aoki T, Kuroki Y, Kageyama T, et al. (1983). Multicentre double-blind comparison of piroxicam and indomethacin in the treatment of lumbar diseases. Eur J Rheumatol Inflamm.
Apolone G, Deandrea S, Montanari M, et al. (2012). Evaluation of the comparative analgesic effectiveness of transdermal and oral opioids in cancer patients: a propensity score analysis. Eur J Pain.
Arner S, Meyerson BA. (1988). Lack of analgesic effect of opioids on neuropathic and idiopathic forms of pain. Pain.
Ashworth J, Green DJ, Dunn KM, et al. (2013). Opioid use among low back pain patients in primary care: Is opioid prescription associated with disability at 6-month follow-up?. Pain.
Assadi SM, Hafezi M, Mokri A, et al. (2004). Opioid detoxification using high doses of buprenorphine in 24 hours: a randomized, double blind, controlled clinical trial. J Subst Abuse Treat.
Attal N, Guirimand F, Brasseur L, et al. (2002). Effects of IV morphine in central pain: a randomized placebo-controlled study. Neurology.
Babul N, Noveck R, Chipman H, et al. (2004). Efficacy and safety of extended-release, once-daily tramadol in chronic pain: a randomized 12-week clinical trial in osteoarthritis of the knee. J Pain Symptom Manage.
Ballantyne JC. (2013). Treating pain in patients with drug-dependence problems. BMJ.
Banning A, Sjogren P. (1990). Cerebral effects of long-term oral opioids in cancer patients measured by continuous reaction time. Clin J Pain.
Banning A, Sjogren P, Kaiser F. (1992). Reaction time in cancer patients receiving peripherally acting analgesics alone or in combination with opioids. Acta Anaesthesiol Scand.
Barrera-Chacon JM, Mendez-Suarez JL, Jàuregui-Abrisqueta ML, et al. (2011). Oxycodone improves pain control and quality of life in anticonvulsant-pretreated spinal cord-injured patients with neuropathic pain. Spinal Cord.
Baumblatt JAG, Wiedeman C, Dunn JR, et al. (2014). High-risk use by patients prescribed opioids for pain and its role in overdose deaths. JAMA Intern Med.
Becker WC, O'Connor PG. (2010). The safety of opioid analgesics in the elderly: new data raise new concerns: comment on “the comparative safety of opioids for nonmalignant pain in older adults”. Arch Intern Med.
Becker WC, Sullivan LE, Tetrault JM, et al. (2008). Non-medical use, abuse and dependence on prescription opioids among U.S. adults: psychiatric, medical and substance use correlates. Drug Alcohol Depend.
Benavidez DC, Flores AM, Fierro I, et al. (2013). Road rage among drug dependent patients. Accid Anal Prev.
Benitez-Rosario MA, Feria M, Salinas-Martin A, et al. (2004). Opioid switching from transdermal fentanyl to oral methadone in patients with cancer pain. Cancer.
Benitez-Rosario MA, Salinas-Martin A, Aguirre-Jaime A, et al. (2009). Morphine-methadone opioid rotation in cancer patients: analysis of dose ratio predicting factors. J Pain Symptom Manage.
Bickel WK, Stitzer ML, Bigelow GE, et al. (1988). A clinical trial of buprenorphine: comparison with methadone in the detoxification of heroin addicts. Clin Pharmacol Ther.
Binsfeld H, Szczepanski L, Waechter S, et al. (2010). A randomized study to demonstrate noninferiority of once-daily OROS((R)) hydromorphone with twice-daily sustained-release oxycodone for moderate to severe chronic noncancer pain. Pain Pract.
Binswanger IA, Blatchford PJ, Mueller SR, et al. (2013). Mortality after prison release: opioid overdose and other causes of death, risk factors, and time trends from 1999 to 2009. Ann Intern Med.
Biondi D, Xiang J, Benson C, et al. (2013). Tapentadol immediate release versus oxycodone immediate release for treatment of acute low back pain. Pain Physician.
Biondi D, Xiang J, Etropolski M, et al. (2011). A post hoc pooled data analysis to evaluate blood pressure (bp) and heart rate (hr) measurements in patients with a current or prior history of hypertension who received tapentadol er, oxycodone cr, or placebo in chronic pain studies. J Pain.
Bjorkman R, Ullman A, Hedner J. (1993). Morphine-sparing effect of diclofenac in cancer pain. Eur J Clin Pharmacol.
Blalock SJ, Casteel C, Roth MT, et al. (2010). Impact of enhanced pharmacologic care on the prevention of falls: a randomized controlled trial. Am J Geriatr Pharmacother.
Block C, Cianfrini L. (2013). Neuropsychological and neuroanatomical sequelae of chronic non-malignant pain and opioid analgesia. Neurorehabilitation.
Blondell RD, Ashrafioun L, Dambra CM, et al. (2010). A clinical trial comparing tapering doses of buprenorphine with steady doses for chronic pain and co-existent opioid addiction. J Addict Med.
Bohnert ASB, Valenstein M, Bair MJ, et al. (2011). Association between opioid prescribing patterns and opioid overdose-related deaths. JAMA.
Boscarino JA, Rukstalis MR, Hoffman SN, et al. (2011). Prevalence of prescription opioid-use disorder among chronic pain patients: comparison of the DSM-5 vs. DSM-4 diagnostic criteria. J Addict Dis.
Bosek V, Miguel R. (1994). Comparison of morphine and ketorolac for intravenous patient-controlled analgesia in postoperative cancer patients. Clin J Pain.
Braden JB, Russo J, Fan MY, et al. (2010). Emergency department visits among recipients of chronic opioid therapy. Arch Intern Med.
Bramness JG, Skurtveit S, Morland J, et al. (2012). An increased risk of motor vehicle accidents after prescription of methadone. Addiction.
Breckenridge J, Clark JD. (2003). Patient characteristics associated with opioid versus nonsteroidal anti-inflammatory drug management of chronic low back pain. J Pain.
Breivik H, Ljosaa TM, Stengaard-Pedersen K, et al. (2010). A 6-months, randomised, placebo-controlled evaluation of efficacy and tolerability of a low-dose 7-day buprenorphine transdermal patch in osteoarthritis patients naive to potent opioids. Scand J Pain.
Brookoff D, Polomano R. (1992). Treating sickle cell pain like cancer pain. Ann Intern Med.
Brown J, Setnik B, Lee K, et al. (2011). Assessment, stratification, and monitoring of the risk for prescription opioid misuse and abuse in the primary care setting. J Opioid Manag.
Brown RT, Zuelsdorff M, Fleming M. (2006). Adverse effects and cognitive function among primary care patients taking opioids for chronic nonmalignant pain. J Opioid Manag.
Bruera E, Belzile M, Pituskin E, et al. (1998). Randomized, double-blind, cross-over trail comparing safety and efficacy or oral controlled-release oxycodone with controlled-release morphine in patients with cancer pain. J Clin Oncol.
Bruera E, Macmillan K, Hanson J, et al. (1989). The cognitive effects of the administration of narcotic analgesics in patients with cancer pain. Pain.
Buckeridge D, Huang A, Hanley J, et al. (2010). Risk of injury associated with opioid use in older adults. J Am Geriatr Soc.
Buelow AK, Haggard R, Gatchel RJ. (2009). Additional validation of the pain medication questionnaire in a heterogeneous sample of chronic pain patients. Pain Pract.
Butler SF, Budman SH, Fanciullo GJ, et al. (2010). Cross validation of the current opioid misuse measure to monitor chronic pain patients on opioid therapy. Clin J Pain.
Butler SF, Budman SH, Fernandez K, et al. (2004). Validation of a screener and opioid assessment measure for patients with chronic pain. Pain.
Butler SF, Budman SH, Fernandez KC, et al. (2009). Cross-validation of a screener to predict opioid misuse in chronic pain patients (SOAPP-R). J Addict Med.
Butler SF, Budman SH, Fernandez KC, et al. (2007). Development and validation of the current opioid misuse measure. Pain.
Butler SF, Fernandez K, Benoit C, et al. (2008). Validation of the revised screener and opioid assessment for patients with pain (soapp-r). J Pain.
Buynak R, Shapiro D, Okamoto A, et al. (2009). Efficacy, safety, and gastrointestinal tolerability of tapentadol er in a randomized, double-blind, placebo- and active-controlled phase III study of patients with chronic low back pain. J Pain.
Buynak R, Shapiro DY, Okamoto A, et al. (2010). Efficacy and safety of tapentadol extended release for the management of chronic low back pain: results of a prospective, randomized, double-blind, placebo- and active-controlled Phase III study. Expert Opin Pharmacother.
Byas-Smith MG, Chapman SL, Reed B, et al. (2005). The effect of opioids on driving and psychomotor performance in patients with chronic pain. Clin J Pain.
Caldwell JR, Rapoport RJ, Davis JC, et al. (2002). Efficacy and safety of a once-daily morphine formulation in chronic, moderate-to-severe osteoarthritis pain: results from a randomized, placebo-controlled, double-blind trial and an open-label extension trial. J Pain Symptom Manage.
Callaghan RC, Gatley JM, Veldhuizen S, et al. (2013). Alcohol- or drug-use disorders and motor vehicle accident mortality: a retrospective cohort study. Accid Anal Prev.
Carlson RW, Borrison RA, Sher HB, et al. (1990). A multiinstitutional evaluation of the analgesic efficacy and safety of ketorolac tromethamine, acetaminophen plus codeine, and placebo in cancer pain. Pharmacotherapy.
Carr DB, Goudas LC, Denman WT, et al. (2004). Safety and efficacy of intranasal ketamine for the treatment of breakthrough pain in patients with chronic pain: a randomized, double-blind, placebo-controlled, crossover study. Pain.
Cepeda M, Fife D, Ma Q, et al. (2013). Comparison of the risks of opioid abuse or dependence between tapentadol and oxycodone: Results from a cohort study. J Pain.
Chabal C, Erjavec MK, Jacobson L, et al. (1997). Prescription opiate abuse in chronic pain patients: clinical criteria, incidence, and predictors. Clin J Pain.
Chaparro EL, Furlan AD, Deshpande A, et al. (2013). Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev.
Chaparro LEMD, Furlan ADMDP, Deshpande AMD, et al. (2014). Opioids compared with placebo or other treatments for chronic low back pain: an update of the cochrane review. Spine.
Chary S, Goughnour BR, Moulin DE, et al. (1994). The dose-response relationship of controlled-release codeine (codeine contin) in chronic cancer pain. J Pain Symptom Manage.
Chelminski PR, Ives TJ, Felix KM, et al. (2005). A primary care, multi-disciplinary disease management program for opioid-treated patients with chronic non-cancer pain and a high burden of psychiatric comorbidity. BMC Health Serv Res.
Chen L, Vo T, Seefeld L, et al. (2013). Lack of correlation between opioid dose adjustment and pain score change in a group of chronic pain patients. J Pain.
Cheskin LJ, Fudala PJ, Johnson RE. (1994). A controlled comparison of buprenorphine and clonidine for acute detoxification from opioids. Drug Alcohol Depend.
Chu LF, D'Arcy N, Brady C, et al. (2012). Analgesic tolerance without demonstrable opioid-induced hyperalgesia: a double-blinded, randomized, placebo-controlled trial of sustained-release morphine for treatment of chronic nonradicular low-back pain. Pain.
Cicero TJ, Lynskey M, Todorov A, et al. (2008). Co-morbid pain and psychopathology in males and females admitted to treatment for opioid analgesic abuse. Pain.
Clemons M, Regnard C, Appleton T. (1996). Alertness, cognition and morphine in patients with advanced cancer. Cancer Treat Rev.
Coffey RJ, Owens ML, Broste SK, et al. (2009). Mortality associated with implantation and management of intrathecal opioid drug infusion systems to treat noncancer pain. Anesthesiology.
Collins ED, Kleber HD, Whittington RA, et al. (2005). Anesthesia-assisted vs buprenorphine- or clonidine-assisted heroin detoxification and naltrexone induction: a randomized trial. JAMA.
Collins ED, Whittington RA, Heitler NE, et al. (2002). A randomised comparison of anaesthesia-assisted heroin detoxification with buprenorphine- and clonidine-assisted detoxifications.
Corli O, Cozzolino A, Scaricabarozzi I. (1993). Nimesulide and diclofenac in the control of cancer-related pain. comparison between oral and rectal administration. Drugs.
Couto JE, Romney MC, Leider HL, et al. (2009). High rates of inappropriate drug use in the chronic pain population. Popul Health Manag.
Crisostomo RA, Schmidt JE, Hooten WM, et al. (2008). Withdrawal of analgesic medication for chronic low-back pain patients: improvement in outcomes of multidisciplinary rehabilitation regardless of surgical history. Am J Phys Med Rehabil.
Currie SR, Hodgins DC, Crabtree A, et al. (2003). Outcome from integrated pain management treatment for recovering substance abusers. J Pain.
Dagtekin O, Gerbershagen HJ, Wagner W, et al. (2007). Assessing cognitive and psychomotor performance under long-term treatment with transdermal buprenorphine in chronic noncancer pain patients. Anesth Analg.
Daitch J, Frey ME, Silver D, et al. (2012). Conversion of chronic pain patients from full-opioid agonists to sublingual buprenorphine. Pain Physician.
D'Amore A, Romano F, Biancolillo V, et al. (2012). Evaluation of buprenorphine dosage adequacy in opioid receptor agonist substitution therapy for heroin dependence: first use of the buprenorphine-naloxone dosage adequacy evaluation (buava) questionnaire. Clin Drug Investig.
Daniell HW. (2002). Hypogonadism in men consuming sustained-action oral opioids. J Pain.
Daniell HW. (2006). DHEAS deficiency during consumption of sustained-action prescribed opioids: evidence for opioid-induced inhibition of adrenal androgen production. J Pain.
Daniell HW. (2008). Opioid endocrinopathy in women consuming prescribed sustained-action opioids for control of nonmalignant pain. J Pain.
Daniels S, Casson E, Stegmann JU, et al. (2009). A randomized, double-blind, placebo-controlled phase 3 study of the relative efficacy and tolerability of tapentadol IR and oxycodone IR for acute pain. Curr Med Res Opin.
Daniels SE, Upmalis D, Okamoto A, et al. (2009). A randomized, double-blind, phase III study comparing multiple doses of tapentadol IR, oxycodone IR, and placebo for postoperative (bunionectomy) pain. Curr Med Res Opin.
Danninger R, Jaske R, Beubler E. (1993). Randomized crossovercomparison of 2g- and 4g- doses of paracetamol per day in the case of mild to moderate pain caused by head and neck cancers.
Dassanayake T, Michie P, Carter G, et al. (2011). Effects of benzodiazepines, antidepressants and opioids on driving: a systematic review and meta-analysis of epidemiological and experimental evidence. Drug Saf.
Davis MP. (2011). Fentanyl for breakthrough pain: a systematic review. Expert Rev Neurother.
De Conno F, Groff L, Brunelli C, et al. (1996). Clinical experience with oral methadone administration in the treatment of pain in 196 advanced cancer patients. J Clin Oncol.
Dellemijn PL, Vanneste JA. (1997). Randomised double-blind active-placebo-controlled crossover trial of intravenous fentanyl in neuropathic pain. Lancet.
Dellemijn PL, Verbiest HB, van Vliet JJ, et al. (1994). Medical herapy of malignant nerve pain. A randomised double-blind explanatory trial with naproxen versus slow-release morphine. Eur J Cancer.
Dersh J, Mayer TG, Gatchel RJ, et al. (2008). Prescription opioid dependence is associated with poorer outcomes in disabling spinal disorders. Spine.
Devulder J, Jacobs A, Richarz U, et al. (2009). Impact of opioid rescue medication for breakthrough pain on the efficacy and tolerability of long-acting opioids in patients with chronic non-malignant pain. Br J Anaesth.
Doyon S. (2011). Opioid overdose-related deaths. JAMA.
Dubois S, Bedard M, Weaver B. (2010). The association between opioid analgesics and unsafe driving actions preceding fatal crashes. Accid Anal Prev.
Duehmke MR, Hollingshead J, Cornblath DR. (2009). Tramadol for neuropathic pain. Cochrane Database Syst Rev.
Dunbar SA, Katz NP. (1996). Chronic opioid therapy for nonmalignant pain in patients with a history of substance abuse: report of 20 cases. J Pain Symptom Manage.
Dunn KM, Hay EM. (2010). Opioids for chronic musculoskeletal pain. BMJ.
DuPont RL, Graham NA, Gold MS. (2007). Opioid treatment for chronic back pain and its association with addiction. Ann Intern Med.
Dupouy J, Dassieu L, Bourrel R, et al. (2013). Effectiveness of drug tests in outpatients starting opioid substitution therapy. J Subst Abuse Treat.
Edlund MJ, Martin BC, Fan M-Y, et al. (2010). Risks for opioid abuse and dependence among recipients of chronic opioid therapy: results from the TROUP study. Drug Alcohol Depend.
Edlund MJ, Steffick D, Hudson T, et al. (2007). Risk factors for clinically recognized opioid abuse and dependence among veterans using opioids for chronic non-cancer pain. Pain.
Edlund MJ, Sullivan M, Steffick D, et al. (2007). Do users of regularly prescribed opioids have higher rates of substance use problems than nonusers?. Pain Med.
Eide PK, Jorum E, Stubhaug A, et al. (1994). Relief of post-herpetic neuralgia with the N-methyl-D-aspartic acid receptor antagonist ketamine: a double-blind, cross-over comparison with morphine and placebo. Pain.
Eide PK, Stubhaug A, Stenehjem AE. (1995). Central dysesthesia pain after traumatic spinal cord injury is dependent on N-methyl-D-aspartate receptor activation. Neurosurgery.
Elander J, Lusher J, Bevan D, et al. (2003). Pain management and symptoms of substance dependence among patients with sickle cell disease. Soc Sci Med.
Ensrud KE, Blackwell T, Mangione CM, et al. (2003). Central nervous system active medications and risk for fractures in older women. Arch Intern Med.
Estape J, Vinolas N, Gonzalez B, et al. (1990). Ketorolac, a new non-opioid analgesic: a double-blind trial versus pentazocine in cancer pain. J Int Med Res.
Etropolski M, Kelly K, Okamoto A, et al. (2011). Comparable efficacy and superior gastrointestinal tolerability (nausea, vomiting, constipation) of tapentadol compared with oxycodone hydrochloride. Adv Ther.
Etropolski M, Lange B, Goldberg J, et al. (2013). A pooled analysis of patient-specific factors and efficacy and tolerability of tapentadol extended release treatment for moderate to severe chronic pain. J Opioid Manag.
Etropolski M, Kuperwasser B, Flügel M, et al. (2014). Safety and tolerability of tapentadol extended release in moderate to severe chronic osteoarthritis or low back pain management: Pooled analysis of randomized controlled trials. Adv Ther.
Evans DP, Burke MS, Newcombe RG. (1980). Medicines of choice in low back pain. Curr Med Res Opin.
Farrar JT, Messina J, Xie F, et al. (2010). A novel 12-week study, with three randomized, double-blind placebo-controlled periods to evaluate fentanyl buccal tablets for the relief of breakthrough pain in opioid-tolerant patients with noncancer-related chronic pain. Pain Med.
Ferrer-Brechner T, Ganz P. (1984). Combination therapy with ibuprofen and methadone for chronic cancer pain. Am J Med.
Fine PG. (2010). Overdose risk with opioids for chronic noncancer pain. J Pain Palliat Care Pharmacother.
Fine PG, Fishman SM. (2011). Reducing opioid abuse and diversion. JAMA.
Fine PG, Narayana A, Passik SD. (2010). Treatment of breakthrough pain with fentanyl buccal tablet in opioid-tolerant patients with chronic pain: appropriate patient selection and management. Pain Med.
Fishbain DA, Cutler RB, Rosomoff HL, et al. (2002). Can patients taking opioids drive safely? A structured evidence-based review. J Pain Palliat Care Pharmacother.
Fishbain DA, Cutler RB, Rosomoff HL, et al. (2003). Are opioid-dependent/tolerant patients impaired in driving-related skills? a structured evidence-based review. J Pain Symptom Manage.
Fishman SM. (2011). Strategies for selecting treatment and mitigating risk in patients with chronic pain. J Clin Psychiatry.
Fishman SM, Mahajan G, Jung S, et al. (2002). The trilateral opioid contract: bridging the pain clinic and the primary care physician through the opioid contract. J Pain Symptom Manage.
Frank B, Serpell MG, Hughes J, et al. (2008). Comparison of analgesic effects and patient tolerability of nabilone and dihydrocodeine for chronic neuropathic pain: randomised, crossover, double blind study. BMJ.
Franklin GM, Stover BD, Turner JA, et al. (2008). Early opioid prescription and subsequent disability among workers with back injuries: The disability risk identification study cohort. Spine.
Fraser LA, Morrison D, Morley-Forster P, et al. (2009). Oral opioids for chronic non-cancer pain: higher prevalence of hypogonadism in men than in women. Exp Clin Endocrinol Diabetes.
Fredheim OM, Kaasa S, Dale O, et al. (2006). Opioid switching from oral slow release morphine to oral methadone may improve pain control in chronic non-malignant pain: a nine-month follow-up study. Palliat Med.
French DD, Campbell R, Spehar A, et al. (2007). National outpatient medication profiling: medications associated with outpatient fractures in community-dwelling elderly veterans. Br J Clin Pharmacol.
Frich LM, Sorensen J, Jacobsen S, et al. (2012). Outcomes of follow-up visits to chronic nonmalignant pain patients. Pain Manag Nurs.
Friedmann N, Klutzaritz V, Webster L. (2011). Efficacy and safety of an extended-release oxycodone (remoxy) formulation in patients with moderate to severe osteoarthritic pain. J Opioid Manag.
Friedmann N, Klutzaritz V, Webster L. (2011). Long-term safety of Remoxy (extended-release oxycodone) in patients with moderate to severe chronic osteoarthritis or low back pain. Pain Med.
Furlan A, Chaparro LE, Irvin E, et al. (2011). A comparison between enriched and nonenriched enrollment randomized withdrawal trials of opioids for chronic noncancer pain. Pain Res Manag.
Furlan AD, Sandoval JA, Mailis-Gagnon A, et al. (2006). Opioids for chronic noncancer pain: a meta-analysis of effectiveness and side effects. CMAJ.
Gabrail NY, Dvergsten C, Ahdieh H. (2004). Establishing the dosage equivalency of oxymorphone extended release and oxycodone controlled release in patients with cancer pain: a randomized controlled study. Curr Med Res Opin.
Gaertner J, Frank M, Bosse B, et al. (2006). [Oral controlled-release oxycodone for the treatment of chronic pain. data from 4196 patients]. Schmerz.
Gaertner J, Radbruch L, Giesecke T, et al. (2006). Assessing cognition and psychomotor function under long-term treatment with controlled release oxycodone in non-cancer pain patients. Acta Anaesthesiol Scand.
Gajria K, Kosinski M, Schein J, et al. (2008). Health-related quality-of-life outcomes in patients treated with push-pull OROS hydromorphone versus extended-release oxycodone for chronic hip or knee osteoarthritis pain: a randomized, open-label, parallel-group, multicenter study. Patient.
Galer BS, Lee D, Ma T, et al. (2005). MorphiDex (morphine sulfate/dextromethorphan hydrobromide combination) in the treatment of chronic pain: three multicenter, randomized, double-blind, controlled clinical trials fail to demonstrate enhanced opioid analgesia or reduction in tolerance. Pain.
Gallucci M, Toscani F, Mapelli A, et al. (1992). Nimesulide in the treatment of advanced cancer pain. double-blind comparison with naproxen. Arzneimittelforschung.
Galski T, Williams JB, Ehle HT. (2000). Effects of opioids on driving ability. J Pain Symptom Manage.
Gana TJ, Pascual ML, Fleming RR, et al. (2006). Extended-release tramadol in the treatment of osteoarthritis: a multicenter, randomized, double-blind, placebo-controlled clinical trial. Curr Med Res Opin.
Gatti A, Longo G, Sabato E, et al. (2011). Long-term controlled-release oxycodone and pregabalin in the treatment of non-cancer pain: an observational study. Eur Neurol.
Gatti A, Reale C, Luzi M, et al. (2010). Effects of opioid rotation in chronic pain patients: ORTIBARN study. Clin Drug Investig.
Gatti A, Reale C, Occhioni R, et al. (2009). Standard therapy with opioids in chronic pain management: ORTIBER study. Clin Drug Investig.
Garland EL, Manusov EG, Froeliger B, et al. (2014). Mindfulness-oriented recovery enhancement for chronic pain and prescription opioid misuse: Results from an early-stage randomized controlled trial. J Consult Clin Psychol.
Gerra G, Fantoma A, Zaimovic A. (2006). Naltrexone and buprenorphine combination in the treatment of opioid dependence. J Psychopharmacol.
Gerra G, Saenz E, Busse A, et al. (2011). Supervised daily consumption, contingent take-home incentive and non-contingent take-home in methadone maintenance. Prog Neuropsychopharmacol Biol Psychiatry.
Gianutsos L, Safrenek S. (2008). Is there a well-tested tool to detect drug-seeking behaviors in chronic pain patients?. J Fam Pract.
Gimbel JS, Richards P, Portenoy RK. (2003). Controlled-release oxycodone for pain in diabetic neuropathy: a randomized controlled trial. Neurology.
Gordon A, Callaghan D, Spink D, et al. (2010). Buprenorphine transdermal system in adults with chronic low back pain: a randomized, double-blind, placebo-controlled crossover study, followed by an open-label extension phase. Clin Ther.
Gordon A, Rashiq S, Moulin DE, et al. (2010). Buprenorphine transdermal system for opioid therapy in patients with chronic low back pain. Pain Res Manag.
Gourlay GK, Plummer JL, Cherry DA, et al. (1991). Comparison of intermittent bolus with continuous infusion of epidural morphine in the treatment of severe cancer pain. Pain.
Gowing L, Ali R, White JM. (2009). Buprenorphine for the management of opioid withdrawal. Cochrane Database Syst Rev.
Grattan A, Sullivan MD, Saunders KW, et al. (2012). Depression and prescription opioid misuse among chronic opioid therapy recipients with no history of substance abuse. Ann Fam Med.
Gravolin M, Rowell K, de Groot J. (2007). Interventions to support the decision-making process for older people facing the possibility of long-term residential care. Cochrane Database Syst Rev.
Gregory TB. (2013). Chronic pain perspectives: How to safely prescribe long-acting opioids. J Fam Pract.
Grellner W, Rettig-Sturmer A, Kuhn-Becker H, et al. (2002). Daytime sleepiness and traffic-relevant psychophysical capability of patients with chronic pain under long-term therapy with opioids. 16th international conference on alcohol, drugs and traffic safety.
Grider JS, Harned ME, Etscheidt MA. (2011). Patient selection and outcomes using a low-dose intrathecal opioid trialing method for chronic nonmalignant pain. Pain Physician.
Guo Z, Wills P, Viitanen M, et al. (1998). Cognitive impairment, drug use, and the risk of hip fracture in persons over 75 years old: a community-based prospective study. Am J Epidemiol.
Hagen NA, Babul N. (1997). Comparative clinical efficacy and safety of a novel controlled-release oxycodone formulation and controlled-release hydromorphone in the treatment of cancer pain. Cancer.
Hale M, Khan A, Kutch M, et al. (2010). Once-daily OROS hydromorphone ER compared with placebo in opioid-tolerant patients with chronic low back pain. Curr Med Res Opin.
Hale M, Speight K, Harsanyi Z, et al. (1997). Efficacy of 12 hourly controlled-release codeine compared with as required dosing of acetaminophen plus codeine in patients with chronic low back pain. Pain Res Manag.
Hale M, Upmalis D, Okamoto A, et al. (2009). Tolerability of tapentadol immediate release in patients with lower back pain or osteoarthritis of the hip or knee over 90 days: a randomized, double-blind study. Curr Med Res Opin.
Hale ME, Fleischmann R, Salzman R, et al. (1999). Efficacy and safety of controlled-release versus immediate-release oxycodone: randomized, double-blind evaluation in patients with chronic back pain. Clin J Pain.
Hale ME, Wallace MS, Taylor DR, et al. (2012). Safety and tolerability of OROS hydromorphone er in adults with chronic noncancer and cancer pain: pooled analysis of 13 studies. J Opioid Manag.
Hamann S, Sloan P. (2007). Oral naltrexone to enhance analgesia in patients receiving continuous intrathecal morphine for chronic pain: a randomized, double-blind, prospective pilot study. J Opioid Manag.
Hambleton S. (2013). Opioids for chronic noncancer pain: are they safe and effective?. J Miss State Med Assoc.
Hanlon JT, Boudreau RM, Roumani YF, et al. (2009). Number and dosage of central nervous system medications on recurrent falls in community elders: the Health, Aging and Body Composition study. J Gerontol A Biol Sci Med Sci.
Hanna M, Thipphawong J. (2008). A randomized, double-blind comparison of OROS hydromorphone and controlled-release morphine for the control of chronic cancer pain. BMC Palliat Care.
Harke H, Gretenkort P, Ladleif HU, et al. (2001). The response of neuropathic pain and pain in complex regional pain syndrome I to carbamazepine and sustained-release morphine in patients pretreated with spinal cord stimulation: a double-blinded randomized study. Anesth Analg.
Haroutiunian S, McNicol ED, Lipman AG. (2012). Methadone for chronic non-cancer pain in adults. Cochrane Database Syst Rev.
Hartrick C, Van Hove I, Stegmann JU, et al. (2009). Efficacy and tolerability of tapentadol immediate release and oxycodone HCl immediate release in patients awaiting primary joint replacement surgery for end-stage joint disease: a 10-day, phase III, randomized, double-blind, active- and placebo-controlled study. Clin Ther.
Hausmann LR, Gao S, Lee ES, et al. (2013). Racial disparities in the monitoring of patients on chronic opioid therapy. Pain.
Havens JR, Walker R, Leukefeld CG. (2008). Prescription opioid use in the rural Appalachia: a community-based study. J Opioid Manag.
Havens JR, Leukefeld CG, DeVeaugh-Geiss AM, et al. (2014). The impact of a reformulation of extended-release oxycodone designed to deter abuse in a sample of prescription opioid abusers. Drug Alcohol Depend.
Haythornthwaite JA, Menefee LA, Quatrano-Piacentini AL, et al. (1998). Outcome of chronic opioid therapy for non-cancer pain. J Pain Symptom Manage.
Heiskanen T, Kalso E. (1997). Controlled-release oxycodone and morphine in cancer related pain. Pain.
Hendler N, Cimini C, Ma T, et al. (1980). A comparison of cognitive impairment due to benzodiazepines and to narcotics. Am J Psychiatry.
Hermos JA, Lawler EV. (2011). Opioid overdose-related deaths. JAMA.
Hermos JA, Young MM, Gagnon DR, et al. (2004). Characterizations of long-term oxycodone/acetaminophen prescriptions in veteran patients. Arch Intern Med.
Hetland A, Carr DB. (2014). Medications and Impaired Driving. Ann Pharmacother.
Hirsch A, Proescholdbell SK, Bronson W, et al. (2014). Prescription histories and dose strengths associated with overdose deaths. Pain Med.
Hochman JS, Pergolizzi J. (2010). Cohort study finds nine times increased overdose risk (fatal plus non-fatal) in patients receiving 100 mg/day for 90 days compared with 1-20 mg/day opioids for chronic non-cancer pain, but wide CI and possibility of unmeasured confounders. Evid Based Nurs.
Hojsted J, Nielsen PR, Kendall S, et al. (2011). Validation and usefulness of the Danish version of the pain medication questionnaire in opioid-treated chronic pain patients. Acta Anaesthesiol Scand.
Hojsted J, Ekholm O, Kurita GP, et al. (2013). Addictive behaviors related to opioid use for chronic pain: A population-based study. Pain.
Holmes CP. (2004). An opioid screening instrument: Long-term evaluation of the utility of the ain medication questionnaire: Holmes, Cara Pearson: U Texas Southwestern Medical Center At Dallas, US.
Holmes CP, Gatchel RJ, Adams LL, et al. (2006). An opioid screening instrument: long-term evaluation of the utility of the pain medication questionnaire. Pain Pract.
Hopper JA, Wu J, Martus W, et al. (2005). A randomized trial of one-day vs. three-day buprenorphine inpatient detoxification protocols for heroin dependence. J Opioid Manag.
Howe CQ, Sullivan MD. (2014). The missing 'p' in pain management: How the current opioid epidemic highlights the need for psychiatric services in chronic pain care. Gen Hosp Psychiatry.
Hser YI, Li J, Jiang H, et al. (2011). Effects of a randomized contingency management intervention on opiate abstinence and retention in methadone maintenance treatment in China. Addiction.
Huffman KL, Sweis GW, Gase A, et al. (2013). Opioid use 12 months following interdisciplinary pain rehabilitation with weaning. Pain Med.
Humeniuk R, Ali R, Babor T, et al. (2012). A randomized controlled trial of a brief intervention for illicit drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction.
Huse E, Larbig W, Flor H, et al. (2001). The effect of opioids on phantom limb pain and cortical reorganization. Pain.
Iraurgi Castillo I, Gonzalez Saiz F, Lozano Rojas O, et al. (2010). Estimation of cutoff for the severity of dependence scale (SDS) for opiate dependence by ROC analysis. Actas Esp Psiquiatr.
Ivanova JI, Birnbaum HG, Yushkina Y, et al. (2013). The prevalence and economic impact of prescription opioid-related side effects among patients with chronic noncancer pain. J Opioid Manage.
Ives TJ, Chelminski PR, Hammett-Stabler CA, et al. (2006). Predictors of opioid misuse in patients with chronic pain: a prospective cohort study. BMC Health Serv Res.
Jacobson J. (2012). Controlling chronic noncancer pain in an era of opioid misuse. Am J Nurs.
Jadad AR, Carroll D, Glynn CJ, et al. (1992). Morphine responsiveness of chronic pain: double-blind randomised crossover study with patient-controlled analgesia. Lancet.
James IG, O'Brien CM, McDonald CJ. (2010). A randomized, double-blind, double-dummy comparison of the efficacy and tolerability of low-dose transdermal buprenorphine (BuTrans seven-day patches) with buprenorphine sublingual tablets (Temgesic) in patients with osteoarthritis pain. J Pain Symptom Manage.
Jamison RN, Butler SF, Budman SH, et al. (2010). Gender differences in risk factors for aberrant prescription opioid use. J Pain.
Jamison RN, Edwards RR. (2013). Risk factor assessment for problematic use of opioids for chronic pain. Clinical Neuropsychologist.
Jamison RN, Edwards RR, Liu X, et al. (2013). Relationship of negative affect and outcome of an opioid therapy trial among low back pain patients. Pain Pract.
Jamison RN, Link CL, Marceau LD. (2009). Do pain patients at high risk for substance misuse experience more pain? A longitudinal outcomes study. Pain Med.
Jamison RN, Ross EL, Michna E, et al. (2010). Substance misuse treatment for high-risk chronic pain patients on opioid therapy: a randomized trial. Pain.
Jamison RN, Schein JR, Vallow S, et al. (2003). Neuropsychological effects of long-term opioid use in chronic pain patients. J Pain Symptom Manage.
Janiri L, Mannelli P, Persico AM, et al. (1994). Opiate detoxification of methadone maintenance patients using lefetamine, clonidine and buprenorphine. Drug Alcohol Depend.
Janiri L, Mannelli P, Serretti A, et al. (1994). Low-dose buprenorphine detoxification in long term methadone addicts.
Jawahar R, Oh U, Yang S, et al. (2013). A systematic review of pharmacological pain management in multiple sclerosis. Drugs.
Jenkins DG, Ebbutt AF, Evans CD. (1976). Tofranil in the treatment of low back pain. J Int Med Res.
Jensen E, Ginsberg F. (1994). Tramadol versus dextropropoxyphene in the treatment of osteoarthritis. Drug Investigation.
Johnson Johnson Pharmaceutical R, GrA'Anenthal G. (2010). A Study to evaluate the effectiveness and safety of tapentadol (CG5503) extended release (ER) in patients with moderate to severe chronic low back pain.
Johnson JR, Miller AJ. (1994). The efficacy of choline magnesium trisalicylate (CMT) in the management of metastatic bone pain: a pilot study. Palliat Med.
Jones T, Moore T. (2013). Preliminary data on a new opioid risk assessment measure: the Brief Risk Interview. J Opioid Manag.
Jones T, Passik SD. (2011). A comparison of methods of administering the Opioid Risk Tool. J Opioid Manag.
Jorum E, Warncke T, Stubhaug A. (2003). Cold allodynia and hyperalgesia in neuropathic pain: the effect of N-methyl-D-aspartate (NMDA) receptor antagonist ketamine--a double-blind, cross-over comparison with alfentanil and placebo. Pain.
Juárez Pichardo JS, Kassian Rank AA, Hernández Pérez AL, et al. (2009). Comparación de la eficacia en el alivio de dolor neuropático crónico agudizado con oxicodona más lidocaína intravenosas frente a tramadol más lidocaína intravenosas. Revista de la Sociedad Española del Dolor.
Jungquist CR. (2009). The relationship among chronic pain, opiates, and sleep: Jungquist, Carla R: U Rochester School of Nursing, US.
Jungquist CR, Flannery M, Perlis ML, et al. (2012). Relationship of chronic pain and opioid use with respiratory disturbance during sleep. Pain Management Nursing.
Kalso E, Edwards JE, Moore RA, et al. (2004). Opioids in chronic non-cancer pain: systematic review of efficacy and safety. Pain.
Kalso E, Vainio A. (1990). Morphine and oxycodone hydrochloride in the management of cancer pain. Clin Pharmacol Ther.
Kamal-Bahl SJ, Stuart BC, Beers MH. (2006). Propoxyphene use and risk for hip fractures in older adults. Am J Geriatr Pharmacother.
Kapil RP, Cipriano A, Friedman K, et al. (2013). Once-weekly transdermal buprenorphine application results in sustained and consistent steady-state plasma levels. J Pain Symptom Manage.
Kaplan R, Slywka J, Slagle S, et al. (2000). A titrated morphine analgesic regimen comparing substance users and non-users with AIDS-related pain. J Pain Symptom Manage.
Kapural L, Kapural M, Bensitel T, et al. (2010). Opioid-sparing effect of intravenous outpatient ketamine infusions appears short-lived in chronic-pain patients with high opioid requirements. Pain Physician.
Karlsson M, Berggren AC. (2009). Efficacy and safety of low-dose transdermal buprenorphine patches (5, 10, and 20 microg/h) versus prolonged-release tramadol tablets (75, 100, 150, and 200 mg) in patients with chronic osteoarthritis pain: a 12-week, randomized, open-label, controlled, parallel-group noninferiority study. Clin Ther.
Katz N, Hale M, Morris D, et al. (2010). Morphine sulfate and naltrexone hydrochloride extended release capsules in patients with chronic osteoarthritis pain. Postgrad Med.
Katz N, Sun S, Johnson F, et al. (2010). ALO-01 (morphine sulfate and naltrexone hydrochloride) extended-release capsules in the treatment of chronic pain of osteoarthritis of the hip or knee: pharmacokinetics, efficacy, and safety. J Pain.
Katz NP, Birnbaum HG, Castor A. (2010). Volume of prescription opioids used nonmedically in the United States. J Pain Palliat Care Pharmacother.
Katz NP, Sherburne S, Beach M, et al. (2003). Behavioral monitoring and urine toxicology testing in patients receiving long-term opioid therapy. Anesth Analg.
Kendall SE, Sjogren P, Pimenta CAdM, et al. (2010). The cognitive effects of opioids in chronic non-cancer pain. Pain.
Kennedy JA, Crowley TJ. (1990). Chronic pain and substance abuse: a pilot study of opioid maintenance. J Subst Abuse Treat.
Keskinbora K, Aydinli I. (2009). Perineural morphine in patients with chronic ischemic lower extremity pain: efficacy and long-term results. J Anesth.
Khan BA, James K, Stickevers S. (2014). Retrospective review of opiate abuse in a veterans administration pain clinic. Am J Phys Med Rehabil.
Khatami M, Woody G, O'Brien C. (1979). Chronic pain and narcotic addiction: a multitherapeutic approach--a pilot study. Compr Psychiatry.
Kinney MA, Hooten WM, Cassivi SD, et al. (2012). Chronic postthoracotomy pain and health-related quality of life. Ann Thorac Surg.
Kleinert R, Lange C, Steup A, et al. (2008). Single dose analgesic efficacy of tapentadol in postsurgical dental pain: the results of a randomized, double-blind, placebo-controlled study. Anesth Analg.
Koeppe J, Lyda K, Armon C. (2013). Association between opioid use and health care utilization as measured by emergency room visits and hospitalizations among persons living with HIV. Clin J Pain.
Korkmazsky M, Ghandehari J, Sanchez A, et al. (2011). Feasibility study of rapid opioid rotation and titration. Pain Physician.
Kragh A, Elmstahl S, Atroshi I. (2011). Older adults' medication use 6 months before and after hip fracture: a population-based cohort study. J Am Geriatr Soc.
Krebs EE, Ramsey DC, Miloshoff JM, et al. (2011). Primary care monitoring of long-term opioid therapy among veterans with chronic pain. Pain Med.
Kress HG, Orońska A, Kaczmarek Z, et al. (2009). Efficacy and tolerability of intranasal fentanyl spray 50 to 200 μg for breakthrough pain in patients with cancer: a phase III, multinational, randomized, double-blind, placebo-controlled, crossover trial with a 10-month, open-label extension treatment period. Clin Ther.
Kroenke K, Krebs E, Wu J, et al. (2013). Stepped care to optimize pain care rffectiveness (SCOPE) trial study design and sample characteristics. Contemp Clin Trials.
Kroenke K, Krebs EE, Wu J, et al. (2014). Telecare collaborative management of chronic pain in primary care: A randomized clinical trial. JAMA.
Krumova EK, Bennemann P, Kindler D, et al. (2013). Low pain intensity after opioid withdrawal as a first step of a comprehensive pain rehabilitation program predicts long-term nonuse of opioids in chronic noncancer pain. Clin J Pain.
Krymchantowski A, Moreira P. (2003). Out-patient detoxification in chronic migraine: comparison of strategies. Cephalalgia.
Kuijpers T, van Middelkoop M, Rubinstein SM, et al. (2011). A systematic review on the effectiveness of pharmacological interventions for chronic non-specific low-back pain. Eur Spine J.
Kupers RC, Konings H, Adriaensen H, et al. (1991). Morphine differentially affects the sensory and affective pain ratings in neurogenic and idiopathic forms of pain. Pain.
Kurita GP, de Mattos Pimenta CA. (2008). Cognitive impairment in cancer pain patients receiving opioids: a pilot study. Cancer Nurs.
Lake AE, Saper JR, Hamel RL. (2009). Comprehensive inpatient treatment of refractory chronic daily headache. Headache.
Landro NI, Fors EA, Vapenstad LL, et al. (2013). The extent of neurocognitive dysfunction in a multidisciplinary pain centre population. Is there a relation between reported and tested neuropsychological functioning?. Pain.
Lange B, Kuperwasser B, Okamoto A, et al. (2010). Efficacy and safety of tapentadol prolonged release for chronic osteoarthritis pain and low back pain. Adv Ther.
Langley PC, Patkar AD, Boswell KA, et al. (2010). Adverse event profile of tramadol in recent clinical studies of chronic osteoarthritis pain. Curr Med Res Opin.
Lara NA, Teixeira MJ, Fonoff ET. (2011). Long term intrathecal infusion of opiates for treatment of failed back surgery syndrome. Acta Neurochir Suppl.
Lauretti GR, Oliveira GM, Pereira NL. (2003). Comparison of sustained-release morphine with sustained-release oxycodone in advanced cancer patients. Br J Cancer.
Layne RD, Pellegrino RJ, Lerfald NM. (2009). Prescription opioids and overdose deaths. JAMA.
LeFort SM. (2005). Review: intravenous and oral opioids reduce chronic non-cancer pain but are associated with high rates of constipation, nausea, and sleepiness. Evid Based Nurs.
Lemberg KK, Heiskanen TE, Neuvonen M, et al. (2010). Does co-administration of paroxetine change oxycodone analgesia: an interaction study in chronic pain patients. Scand J Pain.
Lemming D, Sorensen J, Graven-Nielsen T, et al. (2007). Managing chronic whiplash associated pain with a combination of low-dose opioid (remifentanil) and NMDA-antagonist (ketamine). Eur J Pain.
Lennernàs B, Frank-Lissbrant I, Lennernàs H, et al. (2010). Sublingual administration of fentanyl to cancer patients is an effective treatment for breakthrough pain: results from a randomized phase II study. Palliat Med.
Leonard R, Kourlas H. (2008). Too much of a good thing? treating the emerging syndrome of opioid-induced hyperalgesia. J Pharm Pract.
Leppert W. (2009). The role of methadone in opioid rotation-a Polish experience. Support Care Cancer.
Leslie H, Shapiro DY, Okamoto A, et al. (2009). Tapentadol ER for chronic low back pain: brief pain inventory (BPI) results. Ann Neurol.
Leung A, Wallace MS, Ridgeway B, et al. (2001). Concentration-effect relationship of intravenous alfentanil and ketamine on peripheral neurosensory thresholds, allodynia and hyperalgesia of neuropathic pain. Pain.
Levick S, Jacobs C, Loukas DF, et al. (1988). Naproxen sodium in treatment of bone pain due to metastatic cancer. Pain.
Li L. (2012). Safety of opioids for non-cancer pain: Li, Lin: Boston U, US.
Lieb JG, Shuster JJ, Theriaque D, et al. (2009). A pilot study of octreotide lar vs. octreotide tid for pain and quality of life in chronic pancreatitis. JOP.
Liguori S, Gottardi M, Micheletto G, et al. (2010). Pharmacological approach to chronic visceral pain. Focus on oxycodone controlled release: an open multicentric study. Eur Rev Med Pharmacol Sci.
Likar R, Vadlau E-M, Breschan C, et al. (2008). Comparable analgesic efficacy of transdermal buprenorphine in patients over and under 65 years of age. Clin J Pain.
Lin TC, Hsu CH, Lu CC, et al. (2010). Chronic opioid therapy in patients with chronic noncancer pain in Taiwan. J Anesth.
Ling W, Amass L, Shoptaw S, et al. (2005). A multi-center randomized trial of buprenorphine-naloxone versus clonidine for opioid detoxification: findings from the National Institute on Drug Abuse Clinical Trials Network. Addiction.
Ling W, Hillhouse M, Jenkins J, et al. (2012). Comparisons of analgesic potency and side effects of buprenorphine and buprenorphine with ultra-low-dose naloxone. J Addict Med.
Lintzeris N, Bell J, Bammer G, et al. (2002). A randomized controlled trial of buprenorphine in the management of short-term ambulatory heroin withdrawal. Addiction.
Littlejohn C, Baldacchino A, Bannister J. (2004). Chronic non-cancer pain and opioid dependence. J R Soc Med.
Lo Presti C, Roscetti A, Muriess D, et al. (2010). Time to pain relief after immediate-release morphine in episodic pain: the TIME study. Clin Drug Investig.
Loeber S, Nakovics H, Kniest A, et al. (2012). Factors affecting cognitive function of opiate-dependent patients. Drug Alcohol Depend.
Lomen PL, Samal BA, Lamborn KR, et al. (1986). Flurbiprofen for the treatment of bone pain in patients with metastatic breast cancer. Am J Med.
Lotsch J, Freynhagen R, von Hentig N, et al. (2010). Higher pain scores, similar opioid doses and side effects associated with antipyretic analgesics in specialised tertiary pain care. Inflamm Res.
Lowenstein O, Leyendecker P, Hopp M, et al. (2009). Combined prolonged-release oxycodone and naloxone improves bowel function in patients receiving opioids for moderate-to-severe non-malignant chronic pain: a randomised controlled trial. Expert Opin Pharmacother.
Madadi P, Hildebrandt D, Lauwers AE, et al. (2013). Characteristics of opioid-users whose death was related to opioid-toxicity: a population-based study in Ontario, Canada. PLoS ONE.
Magnelli F, Biondi L, Calabria R, et al. (2010). Safety and efficacy of buprenorphine/naloxone in opioid-dependent patients: an Italian observational study. Clin Drug Investig.
Mailis-Gagnon A, Lakha SF, Furlan A, et al. (2012). Systematic review of the quality and generalizability of studies on the effects of opioids on driving and cognitive/psychomotor performance. Clin J Pain.
Maltoni M, Scarpi E, Modonesi C, et al. (2005). A validation study of the WHO analgesic ladder: a two-step vs three-step strategy. Support Care Cancer.
Manchikanti L, Ailinani H, Koyyalagunta D, et al. (2011). A systematic review of randomized trials of long-term opioid management for chronic non-cancer pain. Pain Physician.
Manchikanti L, Cash KA, Damron KS, et al. (2006). Controlled substance abuse and illicit drug use in chronic pain patients: An evaluation of multiple variables. Pain Physician.
Manchikanti L, Fellows B, Ailinani H, et al. (2010). Therapeutic use, abuse, and nonmedical use of opioids: a ten-year perspective. Pain Physician.
Manchikanti L, Giordano J, Boswell MV, et al. (2007). Psychological factors as predictors of opioid abuse and illicit drug use in chronic pain patients. J Opioid Manag.
Manchikanti L, Helm S, Fellows B, et al. (2012). Opioid epidemic in the United States. Pain Physician.
Manchikanti L, Manchikanti KN, Pampati V, et al. (2009). Prevalence of side effects of prolonged low or moderate dose opioid therapy with concomitant benzodiazepine and/or antidepressant therapy in chronic non-cancer pain. Pain Physician.
Manchikanti L, Manchukonda R, Damron KS, et al. (2006). Does adherence monitoring reduce controlled substance abuse in chronic pain patients?. Pain Physician.
Manchikanti L, Manchukonda R, Pampati V, et al. (2005). Evaluation of abuse of prescription and illicit drugs in chronic pain patients receiving short-acting (hydrocodone) or long-acting (methadone) opioids. Pain Physician.
Manchikanti L, Pampati V, Damron KS, et al. (2003). Prevalence of prescription drug abuse and dependency in patients with chronic pain in western Kentucky. J Ky Med Assoc.
Manchikanti L, Pampati V, Damron KS, et al. (2001). Prevalence of opioid abuse in interventional pain medicine practice settings: a randomized clinical evaluation. Pain Physician.
Manchikanti L, Vallejo R, Manchikanti KN, et al. (2011). Effectiveness of long-term opioid therapy for chronic non-cancer pain. Pain Physician.
Manterola C, Vial M, Moraga J, et al. (2011). Analgesia in patients with acute abdominal pain. Cochrane Database Syst Rev.
Mariconti P, Collini R. (2008). Tramadol SR in arthrosic and neuropathic pain. Minerva Anestesiol.
Marino EN, Rosen KD, Gutierrez A, et al. (2013). Impulsivity but not sensation seeking is associated with opioid analgesic misuse risk in patients with chronic pain. Addict Behav.
Marsch LA, Bickel WK, Badger GJ, et al. (2005). Comparison of pharmacological treatments for opioid-dependent adolescents: a randomized controlled trial. Arch Gen Psychiatry.
Martel M, Wasan A, Jamison R, et al. (2013). Catastrophic thinking and increased risk for prescription opioid misuse in patients with chronic pain. Drug Alcohol Depend.
Martel MO, Dolman AJ, Edwards RR, et al. (2014). The association between negative affect and prescription opioid misuse in patients with chronic pain: The mediating role of opioid craving. J Pain.
Martell BA, O'Connor PG, Kerns RD, et al. (2007). Systematic review: opioid treatment for chronic back pain: prevalence, efficacy, and association with addiction. Ann Intern Med.
Martin BC, Fan MY, Edlund MJ, et al. (2011). Long-term chronic opioid therapy discontinuation rates from the troup study. J Gen Intern Med.
Martino G, Ventafridda V, Parini J, et al. (1976). A controlled study on the analgesic activity of indoprofen in patients with cancer pain. Adv Pain Res Ther.
Matthews ML, Lufkin R. (2011). Tapentadol: a novel, centrally acting analgesic for moderate-to-severe acute pain. J Pharm Technol.
Max MB, Byas-Smith MG, Gracely RH, et al. (1995). Intravenous infusion of the NMDA antagonist, ketamine, in chronic posttraumatic pain with allodynia: a double-blind comparison to alfentanil and placebo. Clin Neuropharmacol.
Max MB, Schafer SC, Culnane M, et al. (1988). Association of pain relief with drug side effects in postherpetic neuralgia: a single-dose study of clonidine, codeine, ibuprofen, and placebo. Clin Pharmacol Ther.
Mayyas F, Fayers P, Kaasa S, et al. (2010). A systematic review of oxymorphone in the management of chronic pain. J Pain Symptom Manage.
McCann B, Lange R, Wagner B, et al. Patient global impression of change results from a 1-year open-label extension study of tapentadol extended release in patients with chronic osteoarthritis or low back pain.
Arthritis Rheum. (2010). Conference: American College of Rheumatology/Association of Rheumatology Health Professionals Annual Scientific Meeting.
McKay L, Pritham UA, Radzyminski S, et al. (2013). Safe use of opioid analgesics for chronic pain in pregnancy. J Obstet Gynecol Neonatal Nurs.
McNamara P. (2002). Opioid switching from morphine to transdermal fentanyl for toxicity reduction in palliative care. Palliat Med.
McNicol ED, Midbari A, Eisenberg E. (2013). Opioids for neuropathic pain. Cochrane Database Syst Rev.
McNicol ED, Strassels S, Goudas L, et al. (2011). NSAIDS or paracetamol, alone or combined with opioids, for cancer pain. Cochrane Database Syst Rev.
Meghani SH, Wiedemer NL, Becker WC, et al. (2009). Predictors of resolution of aberrant drug behavior in chronic pain patients treated in a structured opioid risk management program. Pain Med.
Meissner W, Leyendecker P, Mueller-Lissner S, et al. (2009). A randomised controlled trial with prolonged-release oral oxycodone and naloxone to prevent and reverse opioid-induced constipation. Eur J Pain.
Meissner W, Schmidt U, Hartmann M, et al. (2000). Oral naloxone reverses opioid-associated constipation. Pain.
Meltzer EC, Rybin D, Meshesha LZ, et al. (2012). Aberrant drug-related behaviors: unsystematic documentation does not identify prescription drug use disorder. Pain Med.
Meltzer EC, Rybin D, Saitz R, et al. (2011). Identifying prescription opioid use disorder in primary care: diagnostic characteristics of the current opioid misuse measure (COMM). Pain.
Menefee LA, Frank ED, Crerand C, et al. (2004). The effects of transdermal fentanyl on driving, cognitive performance, and balance in patients with chronic nonmalignant pain conditions. Pain Med.
Mercadante S, Caraceni A. (2011). Conversion ratios for opioid switching in the treatment of cancer pain: a systematic review. Palliat Med.
Mercadante S, Casuccio A, Calderone L. (1999). Rapid switching from morphine to methadone in cancer patients with poor response to morphine. J Clin Oncol.
Mercadante S, Casuccio A, Fulfaro F, et al. (2001). Switching from morphine to methadone to improve analgesia and tolerability in cancer patients: a prospective study. J Clin Oncol.
Mercadante S, Casuccio A, Tirelli W, et al. (2009). Equipotent doses to switch from high doses of opioids to transdermal buprenorphine. Support Care Cancer.
Mercadante S, Ferrera P, Villari P, et al. (2005). Rapid switching between transdermal fentanyl and methadone in cancer patients. J Clin Oncol.
Mercadante S, Ferrera P, Villari P, et al. (2009). Frequency, indications, outcomes, and predictive factors of opioid switching in an acute palliative care unit. J Pain Symptom Manage.
Mercadante S, Porzio G, Ferrera P, et al. (2008). Sustained-release oral morphine versus transdermal fentanyl and oral methadone in cancer pain management. Eur J Pain.
Mercadante S, Porzio G, Fulfaro F, et al. (2007). Switching from transdermal drugs: an observational “N of 1” study of fentanyl and buprenorphine. J Pain Symptom Manage.
Mercadante S, Radbruch L, Davies A, et al. (2009). A comparison of intranasal fentanyl spray with oral transmucosal fentanyl citrate for the treatment of breakthrough cancer pain: an open-label, randomised, crossover trial. Curr Med Res Opin.
Mercadante S, Villari P, Ferrera P, et al. (2007). Opioid plasma concentrations during a switch from transdermal fentanyl to methadone. J Palliat Med.
Merchant S, Provenzano D, Mody S, et al. (2013). Composite measure to assess efficacy/gastrointestinal tolerability of tapentadol er versus oxycodone cr for chronic pain: pooled analysis of randomized studies. J Opioid Manag.
Merrill JO, Von Korff M, Banta-Green CJ, et al. (2012). Prescribed opioid difficulties, depression and opioid dose among chronic opioid therapy patients. Gen Hosp Psychiatry.
Merza Z, Edwards N, Walters S, et al. (2003). Patients with chronic pain and abnormal pituitary function require investigation. Lancet.
Messina J, Darwish M, Fine PG. (2008). Fentanyl buccal tablet. Drugs Today.
Meuleners LB, Duke J, Lee AH, et al. (2011). Psychoactive medications and crash involvement requiring hospitalization for older drivers: a population-based study. J Am Geriatr Soc.
Miller M, Sturmer T, Azrael D, et al. (2011). Opioid analgesics and the risk of fractures in older adults with arthritis. J Am Geriatr Soc.
Milligan K, Lanteri-Minet M, Borchert K, et al. (2001). Evaluation of long-term efficacy and safety of transdermal fentanyl in the treatment of chronic noncancer pain. J Pain.
Minotti V, Betti M, Ciccarese G, et al. (1998). A double-blind study comparing two single-dose regimens of ketorolac with diclofenac in pain due to cancer. Pharmacotherapy.
Minotti V, De Angelis V, Righetti E, et al. (1998). Double-blind evaluation of short-term analgesic efficacy of orally administered diclofenac, diclofenac plus codeine, and diclofenac plus imipramine in chronic cancer pain. Pain.
Minotti V, Patoia L, Roila F, et al. (1989). Double-blind evaluation of analgesic efficacy of orally administered diclofenac, nefopam, and acetylsalicylic acid (asa) plus codeine in chronic cancer pain. Pain.
Minozzi S, Amato L, Davoli M. (2013). Development of dependence following treatment with opioid analgesics for pain relief: A systematic review. Addiction.
Moden B, Merlo J, Ohlsson H, et al. (2010). Psychotropic drugs and falling accidents among the elderly: a nested case control study in the whole population of Scania, Sweden. J Epidemiol Community Health.
Moertel CG, Ahmann DL, Taylor WF, et al. (1971). Aspirin and pancreatic cancer pain. Gastroenterology.
Moertel CG, Ahmann DL, Taylor WF, et al. (1974). Relief of pain by oral medications. A controlled evaluation of analgesic combinations. JAMA.
Monterubbianesi MC, Capuccini J, Ferioli I, et al. (2012). High opioid dosage rapid detoxification of cancer patient in palliative care with the Raffaeli model. J Opioid Manag.
Moore AR, Edwards J, Derry S, et al. (2011). Single dose oral dihydrocodeine for acute postoperative pain. Cochrane Database Syst Rev.
Moore KT, Adams HD, Natarajan J, et al. (2011). Bioequivalence and safety of a novel fentanyl transdermal matrix system compared with a transdermal reservoir system. J Opioid Manag.
Moore RA, McQuay HJ. (2005). Prevalence of opioid adverse events in chronic non-malignant pain: systematic review of randomised trials of oral opioids. Arthritis Res Ther.
Morasco BJ, Dobscha SK. (2008). Prescription medication misuse and substance use disorder in VA primary care patients with chronic pain. Gen Hosp Psychiatry.
Morasco BJ, Duckart JP, Dobscha SK. (2011). Adherence to clinical guidelines for opioid therapy for chronic pain in patients with substance use disorder. J Gen Intern Med.
Morasco BJ, Gritzner S, Lewis L, et al. (2011). Systematic review of prevalence, correlates, and treatment outcomes for chronic non-cancer pain in patients with comorbid substance use disorder. Pain.
Morasco BJ, Turk DC, Donovan DM, et al. (2013). Risk for prescription opioid misuse among patients with a history of substance use disorder. Drug Alcohol Depend.
Morasco BJ, Cavanagh R, Gritzner S, et al. (2013). Care management practices for chronic pain in veterans prescribed high doses of opioid medications. Fam Pract.
Moriarty M, McDonald CJ, Miller AJ. (1999). A randomized crossover comparison of controlled release hydromorphone tablets with controlled release morphine tablets in patients with cancer pain. J Drug Assessment.
Morley JS, Bridson J, Nash TP, et al. (2003). Low-dose methadone has an analgesic effect in neuropathic pain: a double-blind randomized controlled crossover trial. Palliat Med.
Morrison RA. (1991). Update on sickle cell disease: incidence of addiction and choice of opioid in pain management. Pediatr Nurs.
Moryl N, Pope J, Obbens E. (2013). Hypoglycemia during rapid methadone dose escalation. J Opioid Manag.
Moser HR, Giesler GJ. (2013). Itch and analgesia resulting from intrathecal application of morphine: Contrasting effects on different populations of trigeminothalamic tract neurons. J Neurosci.
Mosher HJ, Jiang L, Vaughan Sarrazin MS, et al. (2014). Prevalence and characteristics of hospitalized adults on chronic opioid therapy. J Hosp Med.
Moulin DE, Iezzi A, Amireh R, et al. (1996). Randomised trial of oral morphine for chronic non-cancer pain. Lancet.
Moulin DE, Johnson NG, Murray-Parsons N, et al. (1992). Subcutaneous narcotic infusions for cancer pain: treatment outcome and guidelines for use. CMAJ.
Moulin DE, Richarz U, Wallace M, et al. (2010). Efficacy of the sustained-release hydromorphone in neuropathic pain management: pooled analysis of three open-label studies. J Pain Palliat Care Pharmacother.
Mowatt G, Glazener C, Jarrett M. (2007). Sacral nerve stimulation for faecal incontinence and constipation in adults. Cochrane Database Syst Rev.
Mucci-LoRusso P, Berman BS, Silberstein PT, et al. (1998). Controlled-release oxycodone compared with controlled-release morphine in the treatment of cancer pain: A randomized, double-blind, parallel-group study. Eur J Pain.
Murphy JL, Clark ME, Banou E. (2013). Opioid cessation and multidimensional outcomes after interdisciplinary chronic pain treatment. Clin J Pain.
Mystakidou K, Parpa E, Tsilika E, et al. (2003). Long-term management of noncancer pain with transdermal therapeutic system-fentanyl. J Pain.
Mystakidou K, Tsilika E, Parpa E, et al. (2003). Long-term cancer pain management in morphine pre-treated and opioid naive patients with transdermal fentanyl. Int J Cancer.
Nalamachu SR, Kutch M, Hale ME. (2012). Safety and tolerability of once-daily OROS hydromorphone extended-release in opioid-tolerant adults with moderate-to-severe chronic cancer and noncancer pain: pooled analysis of 11 clinical studies. J Pain Symptom Manage.
Nalamachu SR, Narayana A, Janka L. (2011). Long-term dosing, safety, and tolerability of fentanyl buccal tablet in the management of noncancer-related breakthrough pain in opioid-tolerant patients. Curr Med Res Opin.
Narabayashi M, Saijo Y, Takenoshita S, et al. (2008). Opioid rotation from oral morphine to oral oxycodone in cancer patients with intolerable adverse effects: an open-label trial. Jpn J Clin Oncol.
Neumann AM, Blondell RD, Jaanimagi U, et al. (2013). A preliminary study comparing methadone and buprenorphine in patients with chronic pain and coexistent opioid addiction. J Addict Dis.
Newshan G, Lefkowitz M. (2001). Transdermal fentanyl for chronic pain in AIDS: A pilot study. J Pain Symptom Manage.
Nicholson B, Ross E, Sasaki J, et al. (2006). Randomized trial comparing polymer-coated extended-release morphine sulfate to controlled-release oxycodone HCl in moderate to severe nonmalignant pain. Curr Med Res Opin.
Nielsen S, Larance B, Lintzeris N, et al. (2013). Correlates of pain in an in-treatment sample of opioid-dependent people. Drug Alcohol Rev.
Nigam AK, Ray R, Tripathi BM. (1993). Buprenorphine in opiate withdrawal: a comparison with clonidine. J Subst Abuse Treat.
Njee TB, Irthum B, Roussel P, et al. (2004). Intrathecal morphine infusion for chronic non-malignant pain: a multiple center retrospective survey. Neuromodulation.
Noble M, Schoelles K. (2007). Opioid treatment for chronic back pain and its association with addiction. Ann Intern Med.
Noble M, Tregear SJ, Treadwell JR, et al. (2008). Long-term opioid therapy for chronic noncancer pain: a systematic review and meta-analysis of efficacy and safety. J Pain Symptom Manage.
Notley C, Blyth A, Maskrey V, et al. (2013). The experience of long-term opiate maintenance treatment and reported barriers to recovery: A qualitative systematic review. Eur Addict Res.
Oberleitner LMS. (2012). Emotional risk factors for substance abuse in a chronic pain population: developing a predictive model and testing methods for assessing stigmatized behaviors: Oberleitner, Lindsay M S: Wayne State U, US.
O'Connor PG, Carroll KM, Shi JM, et al. (1997). Three methods of opioid detoxification in a primary care setting. a randomized trial. Ann Intern Med.
O'Donnell JB, Ekman EF, Spalding WM, et al. (2009). The effectiveness of a weak opioid medication versus a cyclo-oxygenase-2 (COX-2) selective non-steroidal anti-inflammatory drug in treating flare-up of chronic low-back pain: results from two randomized, double-blind, 6-week studies. J Int Med Res.
Oosterman JM, Derksen LC, van Wijck AJ, et al. (2012). Executive and attentional functions in chronic pain: Does performance decrease with increasing task load?. Pain Res Manag.
Oreskovich MR, Saxon AJ, Ellis ML, et al. (2005). A double-blind, double-dummy, randomized, prospective pilot study of the partial mu opiate agonist, buprenorphine, for acute detoxification from heroin. Drug Alcohol Depend.
Palangio M, Northfelt DW, Portenoy RK, et al. (2002). Dose conversion and titration with a novel, once-daily, OROS osmotic technology, extended-release hydromorphone formulation in the treatment of chronic malignant or nonmalignant pain. J Pain Symptom Manage.
Pani PP, Trogu E, Maremmani I, et al. (2013). Qtc interval screening for cardiac risk in methadone treatment of opioid dependence. Cochrane Database Syst Rev.
Pannuti F, Robustelli della Cuna G, Ventaffrida V, et al. (1999). A double-blind evaluation of the analgesic efficacy and toxicity of oral ketorolac and diclofenac in cancer pain. the TD/10 recordati protocol study group. Tumori.
Park J, Clement R, Lavin R. (2011). Factor structure of pain medication questionnaire in community-dwelling older adults with chronic pain. Pain Pract.
Passik SD, Kirsh KL, Donaghy KB, et al. (2006). Pain and aberrant drug-related behaviors in medically ill patients with and without histories of substance abuse. Clin J Pain.
Passik SD, Messina J, Golsorkhi A, et al. (2011). Aberrant drug-related behavior observed during clinical studies involving patients taking chronic opioid therapy for persistent pain and fentanyl buccal tablet for breakthrough pain. J Pain Symptom Manage.
Paulozzi LJ, Kilbourne EM, Shah NG, et al. (2012). A history of being prescribed controlled substances and risk of drug overdose death. Pain Med.
Pedersen L, Borchgrevink PC, Breivik HP, et al. (2014). A randomized, double-blind, double-dummy comparison of short- and long-acting dihydrocodeine in chronic non-malignant pain. Pain.
Peloso PM, Fortin L, Beaulieu A, et al. (2004). Analgesic efficacy and safety of tramadol/acetaminophen combination tablets (ultracet) in treatment of chronic low back pain: a multicenter, outpatient, randomized, double blind, placebo controlled trial. J Rheumatol.
Pergolizzi JV, Labhsetwar SA, Puenpatom RA, et al. (2011). Exposure to potential CYP450 pharmacokinetic drug-drug interactions among osteoarthritis patients: incremental risk of multiple prescriptions. Pain Pract.
Phifer J, Skelton K, Weiss T, et al. (2011). Pain symptomatology and pain medication use in civilian PTSD. Pain.
Pink LR, Smith AJ, Peng PWH, et al. (2012). Intake assessment of problematic use of medications in a chronic noncancer pain clinic. Pain Res Manag.
Pinn S. (2009). Fewer opioid-related side effects with tapentadol. Br J Hosp Med.
Ponizovsky AM, Grinshpoon A, Margolis A, et al. (2006). Well-being, psychosocial factors, and side-effects among heroin-dependent inpatients after detoxification using buprenorphine versus clonidine. Addict Behav.
Portenoy RK, Bruns D, Shoemaker B, et al. (2010). Breakthrough pain in community-dwelling patients with cancer pain and noncancer pain, part 2: impact on function, mood, and quality of life. J Opioid Manag.
Portenoy RK, Burton AW, Gabrail N, et al. (2010). A multicenter, placebo-controlled, double-blind, multiple-crossover study of fentanyl pectin nasal spray (fpsn) in the treatment of breakthrough cancer pain. Pain.
Portenoy RK, Foley KM. (1986). Chronic use of opioid analgesics in non-malignant pain: report of 38 cases. Pain.
Portenoy RK, Ganae-Motan ED, Allende S, et al. (2012). Nabiximols for opioid-treated cancer patients with poorly-controlled chronic pain: a randomized, placebo-controlled, graded-dose trial. J Pain.
Portenoy RK, Raffaeli W, Torres LM, et al. (2010). Long-term safety, tolerability, and consistency of effect of fentanyl pectin nasal spray for breakthrough cancer pain in opioid-tolerant patients. J Opioid Manag.
Proctor SL, Estroff TW, Empting LD, et al. (2013). Prevalence of substance use and psychiatric disorders in a highly select chronic pain population. J Addict Med.
Przeklasa-Muszynska A, Dobrogowski J. (2011). Transdermal buprenorphine for the treatment of moderate to severe chronic pain: results from a large multicenter, non-interventional post-marketing study in Poland. Curr Med Res Opin.
Pycha C, Resnick RB, Galanter M, et al. (1994). Buprenorphine: rapid and slow dose-reductions for heroin detoxification.
Quang-Cantagrel ND, Wallace MS, Magnuson SK. (2000). Opioid substitution to improve the effectiveness of chronic noncancer pain control: a chart review. Anesth Analg.
Quigley C. (2002). Hydromorphone for acute and chronic pain. Cochrane Database Syst Rev.
Quigley C. (2009). Hydromorphone for acute and chronic pain. Cochrane Database Syst Rev.
Quigley C. (2010). Opioid switching to improve pain relief and drug tolerability. Cochrane Database Syst Rev.
Rabben T, Skjelbred P, Oye I. (1999). Prolonged analgesic effect of ketamine, an N-methyl-D-aspartate receptor inhibitor, in patients with chronic pain. J Pharmacol Exp Ther.
Radat F, Creac'h C, Guegan-Massardier E, et al. (2008). Behavioral dependence in patients with medication overuse headache: a cross-sectional study in consulting patients using the DSM-IV criteria. Headache.
Radner H, Ramiro S, Buchbinder R, et al. (2012). Pain management for inflammatory arthritis (rheumatoid arthritis, psoriatic arthritis, ankylosing spondylitis and other spondyloarthritis) and gastrointestinal or liver comorbidity. Cochrane Database Syst Rev.
Raffaeli W, Pari C, Corvetta A, et al. (2010). Oxycodone/acetaminophen at low dosage: an alternative pain treatment for patients with rheumatoid arthritis. J Opioid Manag.
Raistrick D, West D, Finnegan O, et al. (2005). A comparison of buprenorphine and lofexidine for community opiate detoxification: results from a randomized controlled trial. Addiction.
Raja SN, Haythornthwaite JA, Pappagallo M, et al. (2002). Opioids versus antidepressants in postherpetic neuralgia: a randomized, placebo-controlled trial. Neurology.
Rauck R, Deer T, Rosen S, et al. (2013). Long-term follow-up of a novel implantable programmable infusion pump. Neuromodulation.
Rauck R, Ma T, Kerwin R, et al. (2008). Titration with oxymorphone extended release to achieve effective long-term pain relief and improve tolerability in opioid-naive patients with moderate to severe pain. Pain Med.
Rauck R, North J, Gever LN, et al. (2010). Fentanyl buccal soluble film (fbsf) for breakthrough pain in patients with cancer: a randomized, double-blind, placebo-controlled study. Ann Oncol.
Rauck R, Rapoport R, Thipphawong J. (2013). Results of a double-blind, placebo-controlled, fixed-dose assessment of once-daily OROS^®^ hydromorphone ER in Patients with moderate to severe pain associated with chronic osteoarthritis. Pain Pract.
Rauck RL, Bookbinder SA, Bunker TR, et al. (2007). A randomized, open-label, multicenter trial comparing once-a-dayAvinza (morphine sulfate extended-release capsules) versus twice-a-day oxy- Contin (oxycodone hydrochloride controlled release tablets) for the treatment of chronic, moderate to severe low back pain: Improved physical functioning in the ACTION trial. J Opioid Manag.
Rauck RL, Tark M, Reyes E, et al. (2009). Efficacy and long-term tolerability of sublingual fentanyl orally disintegrating tablet in the treatment of breakthrough cancer pain. Curr Med Res Opin.
Rawool V, Dluhy C. (2011). Auditory sensitivity in opiate addicts with and without a history of noise exposure. Noise Health.
Reguly P, Dubois S, Bédard M. (2014). Examining the impact of opioid analgesics on crash responsibility in truck drivers involved in fatal crashes. Forensic Sci Int.
Reid M, Henderson CR, Papaleontiou M, et al. (2010). Characteristics of older adults receiving opioids in primary care: treatment duration and outcomes. Pain Med.
Rhodin A, Gronbladh A, Ginya H, et al. (2013). Combined analysis of circulating -endorphin with gene polymorphisms in OPRM1, CACNAD2 and ABCB1 reveals correlation with pain, opioid sensitivity and opioid-related side effects. Mol Brain.
Rhodin A, Gronbladh L, Nilsson LH, et al. (2006). Methadone treatment of chronic non-malignant pain and opioid dependence--a long-term follow-up. Eur J Pain.
Rhodin A, Stridsberg M, Gordh T. (2010). Opioid endocrinopathy: a clinical problem in patients with chronic pain and long-term oral opioid treatment. Clin J Pain.
Rice JB, White AG, Birnbaum HG, et al. (2012). A model to identify patients at risk for prescription opioid abuse, dependence, and misuse. Pain Med.
Richardson LP, Russo JE, Katon W, et al. (2012). Mental health disorders and long-term opioid use among adolescents and young adults with chronic pain. J Adolesc Health.
Richarz U, Waechter S, Sabatowski R, et al. (2013). Sustained safety and efficacy of once-daily hydromorphone extended-release (OROS hydromorphone ER) compared with twice-daily oxycodone controlled-release over 52 weeks in patients with moderate to severe chronic noncancer pain. Pain Pract.
Riemsma R, Forbes C, Harker J, et al. (2011). Systematic review of tapentadol in chronic severe pain. Curr Med Res Opin.
Riley J, Ross JR, Rutter D, et al. (2006). No pain relief from morphine? individual variation in sensitivity to morphine and the need to switch to an alternative opioid in cancer patients. Support Care Cancer.
Riley JL, Hastie BA, Glover TL, et al. (2010). Cognitive-affective and somatic side effects of morphine and pentazocine: side-effect profiles in healthy adults. Pain Med.
Ringe JD, Schafer S, Wimmer AM, et al. (2012). Use of OROS hydromorphone in the treatment of osteoarthritis and osteoporosis: a pooled analysis of three non-interventional studies focusing on different starting doses. Wien Klin Wochenschr.
Ripamonti C, Groff L, Brunelli C, et al. (1998). Switching from morphine to oral methadone in treating cancer pain: what is the equianalgesic dose ratio?. J Clin Oncol.
Robbins L. (1999). Long-acting opioids for severe chronic daily headache. Headache Q-curr Trea.
Robinson RC, Gatchel RJ, Polatin P, et al. (2001). Screening for problematic prescription opioid use. Clin J Pain.
Robinson-Papp J, Elliott K, Simpson DM, et al. (2012). Problematic prescription opioid use in an HIV-infected cohort: the importance of universal toxicology testing. J Acquir Immune Defic Syndr.
Rodriguez M, Barutell C, Rull M, et al. (1994). Efficacy and tolerance of oral dipyrone versus oral morphine for cancer pain. Eur J Cancer.
Rodriguez RF, Castillo JM, Castillo MP, et al. (2008). Hydrocodone/acetaminophen and tramadol chlorhydrate combination tablets for the management of chronic cancer pain: a double-blind comparative trial. Clin J Pain.
Rodriguez RF, Castillo JM, Castillo MP, et al. (2008). “Hydrocodone/acetaminophen and tramadol chlorhydrate combination tablets for the management of chronic cancer pain: a double-blind comparative trial”: Correction. Clin J Pain.
Rodriguez RF, Castillo JM, del Pilar Castillo M, et al. (2007). Codeine/acetaminophen and hydrocodone/acetaminophen combination tablets for the management of chronic cancer pain in adults: a 23-day, prospective, double-blind, randomized, parallel-group study. Clin Ther.
Roelofs PD, Deyo RA, Koes BW, et al. (2008). Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine.
Roland CL, Setnik B, Cleveland JM, et al. (2011). Clinical outcomes during opioid titration following initiation with or conversion to Remoxy(R), an extended-release formulation of oxycodone. Postgrad Med.
Rosenblum A, Cruciani RA, Strain EC, et al. (2012). Sublingual buprenorphine/naloxone for chronic pain in at-risk patients: development and pilot test of a clinical protocol. J Opioid Manag.
Rosenthal M, Moore P, Groves E, et al. (2007). Sleep improves when patients with chronic OA pain are managed with morning dosing of once a day extended-release morphine sulfate (AVINZA): findings from a pilot study. J Opioid Manag.
Rosti G, Gatti A, Costantini A, et al. (2010). Opioid-related bowel dysfunction: prevalence and identification of predictive factors in a large sample of Italian patients on chronic treatment. Eur Rev Med Pharmacol Sci.
Roth SH, Fleischmann RM, Burch FX, et al. (2000). Around-the-clock, controlled-release oxycodone therapy for osteoarthritis-related pain: placebo-controlled trial and long-term evaluation. Arch Intern Med.
Rowbotham MC, Reisner-Keller LA, Fields HL. (1991). Both intravenous lidocaine and morphine reduce the pain of postherpetic neuralgia. Neurology.
Rowbotham MC, Twilling L, Davies PS, et al. (2003). Oral opioid therapy for chronic peripheral and central neuropathic pain. N Engl J Med.
Rubinstein AL, Carpenter DM, Minkoff JR. (2013). Hypogonadism in men with chronic pain linked to the use of long-acting rather than short-acting opioids. Clin J Pain.
Ruoff GE, Rosenthal N, Jordan D, et al. (2003). Tramadol/acetaminophen combination tablets for the treatment of chronic lower back pain: a multicenter, randomized, double-blind, placebo-controlled outpatient study. Clin Ther.
Saadat H, Ziai SA, Ghanemnia M, et al. (2012). Opium addiction increases interleukin 1 receptor antagonist (IL-1Ra) in the coronary artery disease patients. PLoS ONE.
Saarialho-Kere U, Julkunen H, Mattila MJ, et al. (1988). Psychomotor performance of patients with rheumatoid arthritis: cross-over comparison of dextropropoxyphene, dextropropoxyphene plus amitriptyline, indomethacin, and placebo. Pharmacol Toxicol.
Sabatowski R, Schwalen S, Rettig K, et al. (2003). Driving ability under long-term treatment with transdermal fentanyl. J Pain Symptom Manage.
Sacchetti G, Camera P, Rossi AP, et al. (1984). Injectable ketoprofen vs. acetylsalicylic acid for the relief of severe cancer pain: a double-blind, crossover trial. Drug Intell Clin Pharm.
Salengros JC, Huybrechts I, Ducart A, et al. (2010). Different anesthetic techniques associated with different incidences of chronic post-thoracotomy pain: low-dose remifentanil plus presurgical epidural analgesia is preferable to high-dose remifentanil with postsurgical epidural analgesia. J Cardiothorac Vasc Anesth.
Sanders JC, Gerstein N, Torgeson E, et al. (2009). Intrathecal baclofen for postoperative analgesia after total knee arthroplasty. J Clin Anesth.
Sandner-Kiesling A, Leyendecker P, Hopp M, et al. (2010). Long-term efficacy and safety of combined prolonged-release oxycodone and naloxone in the management of non-cancer chronic pain. Int J Clin Pract.
Santiago-Palma J, Khojainova N, Kornick C, et al. (2001). Intravenous methadone in the management of chronic cancer pain: safe and effective starting doses when substituting methadone for fentanyl. Cancer.
Saper JR, Lake AE, Bain PA, et al. (2010). A practice guide for continuous opioid therapy for refractory daily headache: patient selection, physician requirements, and treatment monitoring. Headache.
Sator-Katzenschlager SM, Schiesser AW, Kozek-Langenecker SA, et al. (2003). Does pain relief improve pain behavior and mood in chronic pain patients?. Anesth Analg.
Saunders KW, Von Korff M, Campbell CI, et al. (2012). Concurrent use of alcohol and sedatives among persons prescribed chronic opioid therapy: prevalence and risk factors. J Pain.
Sawe J, Hansen J, Ginman C, et al. (1981). Patient-controlled dose regimen of methadone for chronic cancer pain. Br Med J.
Saxon AJ, Wells EA, Fleming C, et al. (1996). Pre-treatment characteristics, program philosophy and level of ancillary services as predictors of methadone maintenance treatment outcome. Addiction.
Saxon AJ, Ling W, Hillhouse M, et al. (2013). Buprenorphine/naloxone and methadone effects on laboratory indices of liver health: A randomized trial. Drug Alcohol Depend.
Schackman BR, Leff JA, Polsky D, et al. (2012). Cost-effectiveness of long-term outpatient buprenorphine-naloxone treatment for opioid dependence in primary care. J Gen Intern Med.
Schein JR, Kosinski MR, Janagap-Benson C, et al. (2008). Functionality and health-status benefits associated with reduction of osteoarthritis pain. Curr Med Res Opin.
Scher A, Lipton R, Stewart W, et al. (2010). Patterns of medication use by chronic and episodic headache sufferers in the general population: Results from the frequent headache epidemiology study. Cephalalgia.
Scherbaum N, Specka M. (2008). Factors influencing the course of opiate addiction. Int J Methods Psychiatr Res.
Schmader K. (2006). Treatment and prevention strategies for herpes zoster and postherpetic neuralgia in older adults. Clin Geriatr.
Schmittner J, Schroeder JR, Epstein DH, et al. (2009). Electrocardiographic effects of lofexidine and methadone coadministration: secondary findings from a safety study. Pharmacotherapy.
Schneider U, Paetzold W, Eronat V, et al. (2000). Buprenorphine and carbamazepine as a treatment for detoxification of opiate addicts with multiple drug misuse: a pilot study. Addiction Biology.
Schnitzer TJ, Gray WL, Paster RZ, et al. (2000). Efficacy of tramadol in treatment of chronic low back pain. J Rheumatol.
Schoedel KA, McMorn S, Chakraborty B, et al. (2011). Positive and negative subjective effects of extended-release oxymorphone versus controlled-release oxycodone in recreational opioid users. J Opioid Manag.
Scholes CF, Gonty N, Trotman IF. (1999). Methadone titration in opioid-resistant cancer pain. Eur J Cancer Care (Engl).
Schottenfeld RS, Chawarski MC, Pakes JR, et al. (2005). Methadone versus buprenorphine with contingency management or performance feedback for cocaine and opioid dependence. Am J Psychiatry.
Schottenfeld RS, Pakes JR, Kosten TR. (1998). Prognostic factors in buprenorphine- versus methadone-maintained patients. J Nerv Ment Dis.
Schutter U, Grunert S, Meyer C, et al. (2010). Innovative pain therapy with a fixed combination of prolonged-release oxycodone/naloxone: a large observational study under conditions of daily practice. Curr Med Res Opin.
Schwartz RP, Kelly SM, O'Grady KE, et al. (2011). Antecedents and correlates of methadone treatment entry: a comparison of out-of-treatment and in-treatment cohorts. Drug Alcohol Depend.
Schwittay A, Schumann C, Litzenburger BC, et al. (2013). Tapentadol Prolonged Release for Severe Chronic Pain: Results of a Noninterventional study involving general practitioners and internists. J Pain Palliat Care Pharmacother.
Seal K, Krebs E, Neylan T. (2012). “Posttraumatic stress disorder and opioid use among US veterans”: In reply. JAMA.
Seal KH, Shi Y, Cohen G, et al. (2012). Association of mental health disorders with prescription opioids and high-risk opioid use in US veterans of Iraq and Afghanistan. JAMA.
Seidel S, Aigner M, Ossege M, et al. (2008). Antipsychotics for acute and chronic pain in adults. Cochrane Database Syst Rev.
Seifert J, Metzner C, Paetzold W, et al. (2005). Mood and affect during detoxification of opiate addicts: a comparison of buprenorphine versus methadone. Addict Biol.
Seifert J, Metzner C, Paetzold W, et al. (2002). Detoxification of opiate addicts with multiple drug abuse: a comparison of buprenorphine vs. methadone. Pharmacopsychiatry.
Sekhon R, Aminjavahery N, Davis CN, et al. (2013). Compliance with opioid treatment guidelines for chronic non-cancer pain (CNCP) in primary care at a Veterans Affairs Medical Center (VAMC). Pain Med.
Senay EC, Barthwell A, Marks R, et al. (1994). Medical maintenance: an interim report. J Addict Dis.
Setnik B, Roland CL, Cleveland JM, et al. (2011). The abuse potential of remoxy((r)), an extended-release formulation of oxycodone, compared with immediate- and extended- release oxycodone. Pain Med.
Shapiro BJ, Lynch KL, Toochinda T, et al. (2013). Promethazine misuse among methadone maintenance patients and community-based injection drug users. J Addict Med.
Shapiro D, Buynak R, Okamoto A, et al. (2010). Results of a randomized, double-blind, placebo- and active-controlled trial of tapentadol extended release for chronic low back pain. Rheumatology Conference Proceedings.
Sharek PJ, McClead RE, Taketomo C, et al. (2008). An intervention to decrease narcotic-related adverse drug events in children's hospitals. Pediatrics.
Sharkey KM, Kurth ME, Corso RP, et al. (2009). Home polysomnography in methadone maintenance patients with subjective sleep complaints. Am J Drug Alcohol Abuse.
Sheard L, Wright NM, El-Sayeh HG, et al. (2009). The leeds evaluation of efficacy of detoxification Study (LEEDS) prisons project: a randomised controlled trial comparing dihydrocodeine and buprenorphine for opiate detoxification. Subst Abuse Treat Prev Policy.
Shi L, Liu J, Zhao Y. (2012). Comparative effectiveness in pain-related outcomes and health care utilizations between veterans with major depressive disorder treated with duloxetine and other antidepressants: a retrospective propensity score-matched comparison. Pain Pract.
Shorr RI, Griffin MR, Daugherty JR, et al. (1992). Opioid analgesics and the risk of hip fracture in the elderly: codeine and propoxyphene. J Gerontol.
Shram MJ, Sathyan G, Khanna S, et al. (2010). Evaluation of the abuse potential of extended release hydromorphone versus immediate release hydromorphone. J Clin Psychopharmacol.
Sia AT, Sng BL, Lim EC, et al. (2010). The influence of ATP-binding cassette sub-family B member -1 (ABCB1) genetic polymorphisms on acute and chronic pain after intrathecal morphine for caesarean section: a prospective cohort study. Int J Obstet Anesth.
Siddall PJ, Gray M, Rutkowski S, et al. (1994). Intrathecal morphine and clonidine in the management of spinal cord injury pain: A case report. Pain.
Singh K, Phillips FM, Kuo E, et al. (2007). A prospective, randomized, double-blind study of the efficacy of postoperative continuous local anesthetic infusion at the iliac crest bone graft site after posterior spinal arthrodesis: a minimum of 4-year follow-up. Spine.
Sittl R, Griessinger N, Likar R. (2003). Analgesic efficacy and tolerability of transdermal buprenorphine in patients with inadequately controlled chronic pain related to cancer and other disorders: a multicenter, randomized, double-blind, placebo-controlled trial. Clin Ther.
Sjogren P, Banning A. (1989). Pain, sedation and reaction time during long-term treatment of cancer patients with oral and epidural opioids. Pain.
Sjogren P, Banning AM, Christensen CB, et al. (1994). Continuous reaction time after single dose, long-term oral and epidural opioid administration. Eur J Anaesthesiol.
Sjogren P, Christrup LL, Petersen MA, et al. (2005). Neuropsychological assessment of chronic non-malignant pain patients treated in a multidisciplinary pain centre. Eur J Pain.
Sjogren P, Gronbaek M, Peuckmann V, et al. (2010). A population-based cohort study on chronic pain: the role of opioids. Clin J Pain.
Sjogren P, Thomsen AB, Olsen AK. (2000). Impaired neuropsychological performance in chronic nonmalignant pain patients receiving long-term oral opioid therapy. J Pain Symptom Manage.
Skinner MA, Lewis ET, Trafton JA. (2012). Opioid use patterns and association with pain severity and mental health functioning in chronic pain patients. Pain Med.
Skurtveit S, Furu K, Borchgrevink P, et al. (2011). To what extent does a cohort of new users of weak opioids develop persistent or probable problematic opioid use?. Pain.
Skurtveit S, Furu K, Bramness J, et al. (2010). Benzodiazepines predict use of opioids--a follow-up study of 17,074 men and women. Pain Med.
Skurtveit S, Furu K, Kaasa S, et al. (2009). Introduction of low dose transdermal buprenorphine - did it influence use of potentially addictive drugs in chronic non-malignant pain patients?. Eur J Pain.
Slatkin NE. (2009). Opioid switching and rotation in primary care: implementation and clinical utility. Curr Med Res Opin.
Sloan PA, Barkin RL. (2008). Oxymorphone and oxymorphone extended release: a pharmacotherapeutic review. J Opioid Manag.
Sloots CE, Rykx A, Cools M, et al. (2010). Efficacy and safety of prucalopride in patients with chronic noncancer pain suffering from opioid-induced constipation. Dig Dis Sci.
Smith H. (2012). A comprehensive review of rapid-onset opioids for breakthrough pain. CNS Drugs.
Smith H, Bruckenthal P. (2010). Implications of opioid analgesia for medically complicated patients. Drugs Aging.
Smith HS. (2011). Morphine sulfate and naltrexone hydrochloride extended release capsules for the management of chronic, moderate-to-severe pain, while reducing morphine-induced subjective effects upon tampering by crushing. Expert Opin Pharmacother.
Smith HS, Kirsh KL, Passik SD. (2009). Chronic opioid therapy issues associated with opioid abuse potential. J Opioid Manag.
Smith JB, Ridpath LC, Steele KM. (2012). A research protocol to determine if OMM is effective in decreasing pain in chronic paint patients and decreasing opiod use: brief report. AAO Journal.
Smith K, Hopp M, Mundin G, et al. (2008). Single- and multiple-dose pharmacokinetic evaluation of oxycodone and naloxone in an opioid agonist/antagonist prolonged-release combination in healthy adult volunteers. Clin Ther.
Smith MY, Irish W, Wang J, et al. (2008). Detecting signals of opioid analgesic abuse: application of a spatial mixed effect poisson regression model using data from a network of poison control centers. Pharmacoepidemiology & Drug Saf.
Smith MY, Kleber HD, Katz N, et al. (2008). Reducing opioid. analgesic abuse: models for successful collaboration among government, industry and other key stakeholders. Drug Alcohol Depend.
Smith-Spangler CM, Asch SM. (2012). Commentary on Vickerman etal. (2012): Reducing hepatitis C virus among injection drug users through harm reduction programs. Addiction.
Smyth BP, Barry J, Keenan E, et al. (2010). Lapse and relapse following inpatient treatment of opiate dependence. Ir Med J.
Snyder ML, Jarolim P, Melanson SEF. (2011). A new automated urine fentanyl immunoassay: technical performance and clinical utility for monitoring fentanyl compliance. Clin Chim Acta.
Soderberg KC, Laflamme L, Moller J. (2013). Newly initiated opioid treatment and the risk of fall-related injuries. A nationwide, register-based, case-crossover study in Sweden. CNS Drugs.
Soin A, Cheng J, Brown L, et al. (2008). Functional outcomes in patients with chronic nonmalignant pain on long-term opioid therapy. Pain Pract.
Solomon DH, Rassen JA, Glynn RJ, et al. (2010). The comparative safety of opioids for nonmalignant pain in older adults. Arch Intern Med.
Solomon DH, Rassen JA, Glynn RJ, et al. (2010). The comparative safety of analgesics in older adults with arthritis. Arch Intern Med.
Somerville S, Hay E, Lewis M, et al. (2008). Content and outcome of usual primary care for back pain: a systematic review. Br J Gen Pract.
Sorge J, Sittl R. (2004). Transdermal buprenorphine in the treatment of chronic pain: results of a phase III, multicenter, randomized, double-blind, placebo-controlled study. Clin Ther.
Soyka M. (2012). Buprenorphine and buprenorphine/naloxone soluble-film for treatment of opioid dependence. Expert Opin Drug Deliv.
Spano MS, Fadda P, Fratta W, et al. (2010). Cannabinoid-opioid interactions in drug discrimination and self-administration: effect of maternal, postnatal, adolescent and adult exposure to the drugs. Curr Drug Targets.
Spector W, Shaffer T, Potter DE, et al. (2007). Risk factors associated with the occurrence of fractures in U.S. nursing homes: resident and facility characteristics and prescription medications. J Am Geriatr Soc.
Spitz A, Moore AA, Papaleontiou M, et al. (2011). Primary care providers' perspective on prescribing opioids to older adults with chronic non-cancer pain: a qualitative study. BMC Geriatr.
Spoth R, Trudeau L, Shin C, et al. (2013). Longitudinal effects of universal preventive intervention on prescription drug misuse: three randomized controlled trials with late adolescents and young adults. Am J Public Health.
Srivastava A, Kahan M, Jiwa A. (2012). Prescription opioid use and misuse: piloting an educational strategy for rural primary care physicians. Can Fam Physician.
Stallvik M, Nordstrand B, Kristensen O, et al. (2013). Corrected qt interval during treatment with methadone and buprenorphine--relation to doses and serum concentrations. Drug Alcohol Depend.
Stambaugh J, Drew J. (1988). A double-blind parallel evaluation of the efficacy and safety of a single dose of ketoprofen in cancer Pain. J Clin Pharmacol.
Stambaugh JE. (1982). Additive analgesia of oral butorphanol/acetaminophen in patients with pain due to metastaticcarcinoma. Curr Ther Res.
Stambaugh JE, Drew J. (1988). The combination of ibuprofen and oxycodone/acetaminophen in the management of chronic cancer pain. Clin Pharmacol Ther.
Stanos S. (2012). Evolution of opioid risk management and review of the classwide REMS for extended-release/long-acting opioids. Phys Sportsmed.
Stanos S. (2012). Continuing evolution of opioid use in primary care practice: implications of emerging technologies. Curr Med Res Opin.
Stanos SP, Bruckenthal P, Barkin RL. (2012). Strategies to reduce the tampering and subsequent abuse of long-acting opioids: potential risks and benefits of formulations with physical or pharmacologic deterrents to tampering. Mayo Clin Proc.
Staquet M, Renaud A. (1993). Double-blind, randomized trial of piroxicam and codeine in cancer pain. Curr Ther Res Clin Exp.
Staquet MJ. (1989). A double-blind study with placebo control of intramuscular ketorolac tromethamine in the treatment of cancer pain. J Clin Pharmacol.
Starrels JL, Becker WC, Alford DP, et al. (2010). Systematic review: treatment agreements and urine drug testing to reduce opioid misuse in patients with chronic pain. Ann Intern Med.
Starrels JL, Becker WC, Weiner MG, et al. (2011). Low use of opioid risk reduction strategies in primary care even for high risk patients with chronic pain. J Gen Intern Med.
Staud R. (2010). Pharmacological treatment of fibromyalgia syndrome: new developments. Drugs.
Stauffer J, Setnik B, Sokolowska M, et al. (2009). Subjective effects and safety of whole and tampered morphine sulfate and naltrexone hydrochloride (ALO-01) extended-release capsules versus morphine solution and placebo in experienced non-dependent opioid users: a randomized, double-blind, placebo-controlled, crossover study. Clin Drug Investig.
Stefaniak T, Vingerhoets A, Makarewicz W, et al. (2008). Opioid use determines success of videothoracoscopic splanchnicectomy in chronic pancreatic pain patients. Langenbecks Arch Surg.
Steigerwald I, Schenk M, Lahne U, et al. (2013). Effectiveness and tolerability of tapentadol prolonged release compared with prior opioid therapy for the management of severe, chronic osteoarthritis pain. Clin Drug Invest.
Stein C, Reinecke H, Sorgatz H. (2010). Opioid use in chronic noncancer pain: guidelines revisited. Curr Opin Anaesthesiol.
Steiner D, Munera C, Hale M, et al. (2011). Efficacy and safety of buprenorphine transdermal system (BTDS) for chronic moderate to severe low back pain: a randomized, double-blind study. J Pain.
Steiner DJ, Sitar S, Wen W, et al. (2011). Efficacy and safety of the seven-day buprenorphine transdermal system in opioid-naive patients with moderate to severe chronic low back pain: An enriched, randomized, double-blind, placebo-controlled study. J Pain Symptom Manage.
Stepanovic A, Pirc J, Lahajnar Cavlovic S. (2011). Clinical efficacy of OROS hydromorphone in patients suffering from severe chronic pain: a study undertaken in routine clinical practice. Wien Klin Wochenschr.
Strand MC, Fjeld B, Arnestad M, et al. (2013). Can patients receiving opioid maintenance therapy safely drive? a systematic review of epidemiological and experimental studies on driving ability with a focus on concomitant methadone or buprenorphine administration. Traffic Inj Prev.
Sullivan MD, Edlund MJ, Fan M-Y, et al. (2010). Risks for possible and probable opioid misuse among recipients of chronic opioid therapy in commercial and medicaid insurance plans: the TROUP Study. Pain.
Sunshine A, Olson NZ. (1988). Analgesic efficacy of ketoprofen in postpartum, general surgery, and chronic cancer pain. J Clin Pharmacol.
Takkouche B, Montes-Martinez A, Gill SS, et al. (2007). Psychotropic medications and the risk of fracture: a meta-analysis. Drug Saf.
Tassain V, Attal N, Fletcher D, et al. (2003). Long term effects of oral sustained release morphine on neuropsychological performance in patients with chronic non-cancer pain. Pain.
Taylor D, Galan V, Weinstein SM, et al. (2010). Fentanyl pectin nasal spray in breakthrough cancer pain. J Support Oncol.
Taylor R, Pergolizzi JV, Raffa RB. (2013). Tapentadol extended release for chronic pain patients. Adv Ther.
Toscani F, Piva L, Corli O, et al. (1994). Ketorolac versus diclofenac sodium in cancer pain. Arzneimittelforschung.
Tse DM, Sham MM, Ng DK, et al. (2003). An ad libitum schedule for conversion of morphine to methadone in advanced cancer patients: an open uncontrolled prospective study in a Chinese population. Palliat Med.
Turnbull R, Hills LJ. (1986). Naproxen versus aspirin as analgesics in advanced malignant disease. J Palliat Care.
Uberall MA, Mueller-Schwefe GH, Terhaag B. (2012). Efficacy and safety of flupirtine modified release for the management of moderate to severe chronic low back pain: results of SUPREME, a prospective randomized, double-blind, placebo- and active-controlled parallel-group phase IV study. Curr Med Res Opin.
Umbricht A, Hoover DR, Tucker MJ, et al. (2003). Opioid detoxification with buprenorphine, clonidine, or methadone in hospitalized heroin-dependent patients with HIV infection. Drug Alcohol Depend.
Vaglienti RM, Huber SJ, Noel KR, et al. (2003). Misuse of prescribed controlled substances defined by urinalysis. W V Med J.
Vainio A, Ollila J, Matikainen E, et al. (1995). Driving ability in cancer patients receiving long-term morphine analgesia. Lancet.
Ventafridda V, De Conno F, Panerai AE, et al. (1990). Non-steroidal anti-inflammatory drugs as the first step in cancer pain therapy: double-blind, within-patient study comparing nine drugs. J Int Med Res.
Ventafridda V, Martino G, Mandelli V, et al. (1975). Indoprofen, a new analgesic and anti-inflammatory drug in cancer pain. Clin Pharmacol Ther.
Ventafridda V, Toscani F, Tamburini M, et al. (1990). Sodium naproxen versus sodium diclofenac in cancer pain control. Arzneimittelforschung.
Vestergaard P, Hermann P, Jensen JEB, et al. (2012). Effects of paracetamol, non-steroidal anti-inflammatory drugs, acetylsalicylic acid, and opioids on bone mineral density and risk of fracture: results of the Danish osteoporosis prevention study (DOPS). Osteoporos Int.
Vestergaard P, Rejnmark L, Mosekilde L. (2006). Fracture risk associated with the use of morphine and opiates. J Intern Med.
Von Korff M, Merrill JO, Rutter CM, et al. (2011). Time-scheduled vs. pain-contingent opioid dosing in chronic opioid therapy. Pain.
Von Korff MR. (2013). Long-term use of opioids for complex chronic pain. Best Pract Res Clin Rheumatol.
Vondrackova D, Leyendecker P, Meissner W, et al. (2008). Analgesic efficacy and safety of oxycodone in combination with naloxone as prolonged release tablets in patients with moderate to severe chronic pain. J Pain.
Wallace M, Rauck RL, Moulin D, et al. (2008). Conversion from standard opioid therapy to once-daily oral extended-release hydromorphone in patients with chronic cancer pain. J Int Med Res.
Wallace M, Thipphawong J. (2010). Open-label study on the long-term efficacy, safety, and impact on quality of life of OROS hydromorphone er in patients with chronic low back pain. Pain Med.
Wallace MS, Charapata SG, Fisher R, et al. (2006). Intrathecal ziconotide in the treatment of chronic nonmalignant pain: A randomized, double-blind, placebo-controlled clinical trial. Neuromodulation.
Wallace MS, Moulin D, Clark AJ, et al. (2006). A Phase II, multicenter, randomized, double-blind, placebo-controlled crossover study of CJC-1008--a long-acting, parenteral opioid analgesic--in the treatment of postherpetic neuralgia. J Opioid Manag.
Wang H, Akbar M, Weinsheimer N, et al. (2011). Longitudinal observation of changes in pain sensitivity during opioid tapering in patients with chronic low-back pain. Pain Med.
Wasan AD, Ross EL, Michna E, et al. (2012). Craving of prescription opioids in patients with chronic pain: a longitudinal outcomes trial. J Pain.
Watson CP, Babul N. (1998). Efficacy of oxycodone in neuropathic pain: a randomized trial in postherpetic neuralgia. Neurology.
Watson CP, Moulin D, Watt-Watson J, et al. (2003). Controlled-release oxycodone relieves neuropathic pain: a randomized controlled trial in painful diabetic neuropathy. Pain.
Webster LR, Brewer R, Wang C, et al. (2010). Long-term safety and efficacy of morphine sulfate and naltrexone hydrochloride extended release capsules, a novel formulation containing morphine and sequestered naltrexone, in patients with chronic, moderate to severe pain. J Pain Symptom Manage.
Webster LR, Butera PG, Moran LV, et al. (2006). Oxytrex minimizes physical dependence while providing effective analgesia: a randomized controlled trial in low back pain. J Pain.
Webster LR, Fine PG. (2012). Review and critique of opioid rotation practices and associated risks of toxicity. Pain Med.
Weingart WA, Sorkness CA, Earhart RH. (1985). Analgesia with oral narcotics and added ibuprofen in cancer patients. Clin Pharm.
Weinstein SM, Shi M, Buckley BJ, et al. (2006). Multicenter, open-label, prospective evaluation of the conversion from previous opioid analgesics to extended-release hydromorphone hydrochloride administered every 24 hours to patients with persistent moderate to severe pain. Clin Ther.
Weisner CM, Campbell CI, Ray GT, et al. (2009). Trends in prescribed opioid therapy for non-cancer pain for individuals with prior substance use disorders. Pain.
White AG, Birnbaum HG, Schiller M, et al. (2009). Analytic models to identify patients at risk for prescription opioid abuse. Am J Manag Care.
White AP, Arnold PM, Norvell DC, et al. (2011). Pharmacologic management of chronic low back pain: synthesis of the evidence. Spine.
White KT, Dillingham TR, Gonzalez-Fernandez M, et al. (2009). Opiates for chronic nonmalignant pain syndromes: can appropriate candidates be identified for outpatient clinic management?. Am J Phys Med Rehabil.
Whitehead AJ, Dobscha SK, Morasco BJ, et al. (2008). Pain, substance use disorders and opioid analgesic prescription patterns in veterans with hepatitis C. J Pain Symptom Manage.
Whittle SL, Richards BL, Buchbinder R. (2013). Opioid analgesics for rheumatoid arthritis pain. JAMA.
Whittle SL, Richards BL, Husni E, et al. (2011). Opioid therapy for treating rheumatoid arthritis pain. Cochrane Database Syst Rev.
Wiedemer NL, Harden PS, Arndt IO, et al. (2007). The opioid renewal clinic: a primary care, managed approach to opioid therapy in chronic pain patients at risk for substance abuse. Pain Med.
Wiffen PJ. (2008). Evidence-based pain management and palliative care in Issue Three for 2007 of The Cochrane Library. J Pain Palliat Care Pharmacother.
Wiffen PJ. (2013). Methadone for chronic noncancer pain (cncp) in adults. J Pain Palliat Care Pharmacother.
Wilsey BL, Fishman S, Li CS, et al. (2009). Markers of abuse liability of short- vs long-acting opioids in chronic pain patients: a randomized cross-over trial. Pharmacol Biochem Behav.
Wilsey BL, Fishman SM, Casamalhuapa C, et al. (2009). Documenting and improving opioid treatment: the Prescription Opioid Documentation and Surveillance (PODS) System. Pain Med.
Wilsey BL, Fishman SM, Casamalhuapa C, et al. (2010). Computerized progress notes for chronic pain patients receiving opioids; the Prescription Opioid Documentation System (PODS). Pain Med.
Wilsey BL, Fishman SM, Tsodikov A, et al. (2008). Psychological comorbidities predicting prescription opioid abuse among patients in chronic pain presenting to the emergency department. Pain Med.
Wirz S, Wartenberg HC, Elsen C, et al. (2006). Managing cancer pain and symptoms of outpatients by rotation to sustained-release hydromorphone: a prospective clinical trial. Clin J Pain.
Witkin LR, Diskina D, Fernandes S, et al. (2013). Usefulness of the opioid risk tool to predict aberrant drug-related behavior in patients receiving opioids for the treatment of chronic pain. J Opioid Manag.
Wolff RF, Aune D, Truyers C, et al. (2012). Systematic review of efficacy and safety of buprenorphine versus fentanyl or morphine in patients with chronic moderate to severe pain. Curr Med Res Opin.
Wool C, Prandoni P, Polistena P, et al. (1991). Ketorolac suppositories in the treatment of neoplastic pain: a randomized clinical trial versus diclofenac. Curr Ther Res Clin Exp.
Wu CL, Agarwal S, Tella PK, et al. (2008). Morphine versus mexiletine for treatment of postamputation pain: a randomized, placebo-controlled, crossover trial. Anesthesiology.
Wu CL, Tella P, Staats PS, et al. (2002). Analgesic effects of intravenous lidocaine and morphine on postamputation pain: a randomized double-blind, active placebo-controlled, crossover trial. Anesthesiology.
Wu LT, Ringwalt CL, Mannelli P, et al. (2008). Prescription pain reliever abuse and dependence among adolescents: a nationally representative study. J Am Acad Child Adolesc Psychiatry.
Wu SM, Compton P, Bolus R, et al. (2006). The addiction behaviors checklist: validation of a new clinician-based measure of inappropriate opioid use in chronic pain. J Pain Symptom Manage.
Yalcin S, Gullu I, Tekuzman G, et al. (1997). Ketorolac tromethamine in cancer pain. Acta Oncol.
Yalcin S, Gullu IH, Tekuzman G, et al. (1998). A comparison of two nonsteroidal antiinflammatory drugs (diflunisal versus dipyrone) in the treatment of moderate to severe cancer pain: a randomized crossover study. Am J Clin Oncol.
Yarlas A, Miller K, Wen W, et al. (2013). A randomized, placebo-controlled study of the impact of the 7-day buprenorphine transdermal system on health-related quality of life in opioid-naive patients with moderate-to-severe chronic low back pain. J Pain.
Ytterberg SR, Mahowald ML, Woods SR. (1998). Codeine and oxycodone use in patients with chronic rheumatic disease pain. Arthritis Rheum.
Yulug B, Ozan E. (2009). Buprenorphine: a safe agent for opioid dependent patients who are under the increased risk of stroke?. J Opioid Manag.
Zanis DA, McLellan AT, Randall M. (1994). Can you trust patient self-reports of drug use during treatment?. Drug Alcohol Depend.
Zedler B, Xie L, Wang L, et al. (2014). Risk factors for serious prescription opioid-related toxicity or overdose among veterans health administration patients. Pain Med.
Zenz M, Strumpf M, Tryba M. (1992). Long-term oral opioid therapy in patients with chronic nonmalignant pain. J Pain Symptom Manage.
Zerbini C, Ozturk ZE, Grifka J, et al. (2005). Efficacy of etoricoxib 60 mg/day and diclofenac 150 mg/day in reduction of pain and disability in patients with chronic low back pain: results of a 4-week, multinational, randomized, double-blind study. Curr Med Res Opin.
Ziedonis DM, Amass L, Steinberg M, et al. (2009). Predictors of outcome for short-term medically supervised opioid withdrawal during a randomized, multicenter trial of buprenorphine-naloxone and clonidine in the NIDA clinical trials network drug and alcohol dependence. Drug Alcohol Depend.
Zin CS, Nissen LM, O'Callaghan JP, et al. (2010). A randomized, controlled trial of oxycodone versus placebo in patients with postherpetic neuralgia and painful diabetic neuropathy treated with pregabalin. J Pain.
Zorba Paster R. (2010). Chronic pain management issues in the primary care setting and the utility of long-acting opioids. Expert Opin Pharmacother.