# Appendix C Included Studies^*^

Akbik H, Butler SF, Budman SH, et al. (2006). Validation and clinical application of the screener and opioid assessment for patients with pain (SOAPP). J Pain Symptom Manage.
Allan L, Richarz U, Simpson K, et al. (2005). Transdermal fentanyl versus sustained release oral morphine in strong-opioid naive patients with chronic low back pain. Spine.
Ashburn MA, Slevin KA, Messina J, et al. (2011). The efficacy and safety of fentanyl buccal tablet compared with immediate-release oxycodone for the management of breakthrough pain in opioid-tolerant patients with chronic pain. Anesth Analg.
Banta-Green CJ, Merrill JO, Doyle SR, et al. (2009). Opioid use behaviors, mental health and pain--development of a typology of chronic pain patients. Drug Alcohol Depend.
Boscarino JA, Rukstalis M, Hoffman SN, et al. (2010). Risk factors for drug dependence among out-patients on opioid therapy in a large us health-care system. Addiction.
Carman WJ, Su S, Cook SF, et al. (2011). Coron0ary heart disease outcomes among chronic opioid and cyclooxygenase-2 users compared with a general population cohort. Pharmacoepidemiol Drug Saf.
Compton PA, Wu SM, Schieffer B, et al. (2008). Introduction of a self-report version of the prescription drug use questionnaire and relationship to medication agreement noncompliance. J Pain Symptom Manage.
Cowan DT, Wilson-Barnett J, Griffiths P, et al. (2003). A survey of chronic noncancer pain patients prescribed opioid analgesics. Pain Med.
Cowan DT, Wilson-Barnett J, Griffiths P, et al. (2005). A randomized, double-blind, placebo-controlled, cross-over pilot study to assess the effects of long-term opioid drug consumption and subsequent abstinence in chronic noncancer pain patients receiving controlled-release morphine. Pain Med.
Davies A, Sitte T, Elsner F, et al. (2011). Consistency of efficacy, patient acceptability, and nasal tolerability of fentanyl pectin nasal spray compared with immediate-release morphine sulfate in breakthrough cancer pain. J Pain Symptom Manage.
Deyo RA, Smith DH, Johnson ES, et al. (2013). Prescription opioids for back pain and use of medications for erectile dysfunction. Spine.
Dunn KM, Saunders KW, Rutter CM, et al. (2010). Opioid prescriptions for chronic pain and overdose: a cohort study.[summary for patients in Ann Intern Med. 2010;152(2):I-42]. Ann Intern Med.
Edlund MJ, Martin BC, Russo JE, et al. (2014). The role of opioid prescription in incident opioid abuse and dependence among individuals with chronic noncancer pain. Clin J Pain.
Fleming MF, Balousek SL, Klessig CL, et al. (2007). Substance use disorders in a primary care sample receiving daily opioid therapy. J Pain.
Gomes T, Mamdani MM, Dhalla IA, et al. (2011). Opioid dose and drug-related mortality in patients with nonmalignant pain. Arch Intern Med.
Gomes T, Redelmeier DA, Juurlink DN, et al. (2013). Opioid dose and risk of road trauma in Canada: a population-based study. JAMA Intern Med.
Hartung DM, Middleton L, Haxby DG, et al. (2007). Rates of adverse events of long-acting opioids in a state Medicaid program. Ann Pharmacother.
Hojsted J, Nielsen PR, Guldstrand SK, et al. (2010). Classification and identification of opioid addiction in chronic pain patients. Eur J Pain.
Jamison RN, Raymond SA, Slawsby EA, et al. (1998). Opioid therapy for chronic noncancer back pain. a randomized prospective study. Spine.
Jones T, Moore T. (2013). Preliminary data on a new opioid risk assessment measure: the Brief Risk Interview. J Opioid Manag.
Krebs EE, Becker WC, Zerzan J, et al. (2011). Comparative mortality among Department of Veterans Affairs patients prescribed methadone or long-acting morphine for chronic pain. Pain.
Li L, Setoguchi S, Cabral H, et al. (2013). Opioid use for noncancer pain and risk of myocardial infarction amongst adults. J Intern Med.
Li L, Setoguchi S, Cabral H, et al. (2013). Opioid use for noncancer pain and risk of fracture in adults: a nested case- control study using the general practice research database. Am J Epidemiol.
Mitra F, Chowdhury S, Shelley M, et al. (2013). A feasibility study of transdermal buprenorphine versus transdermal fentanyl in the long-term management of persistent non-cancer pain. Pain Med.
Moore TM, Jones T, Browder JH, et al. (2009). A comparison of common screening methods for predicting aberrant drug-related behavior among patients receiving opioids for chronic pain management. Pain Med.
Naliboff BD, Wu SM, Schieffer B, et al. (2011). A randomized trial of 2 prescription strategies for opioid treatment of chronic nonmalignant pain. J Pain.
Portenoy RK, Farrar JT, Backonja MM, et al. (2007). Long-term use of controlled-release oxycodone for noncancer pain: results of a 3-year registry study. Clin J Pain.
Portenoy RK, Messina J, Xie F, et al. (2007). Fentanyl buccal tablet (FBT) for relief of breakthrough pain in opioid-treated patients with chronic low back pain: a randomized, placebo-controlled study. Curr Med Res Opin.
Ralphs JA, Williams AC, Richardson PH, et al. (1994). Opiate reduction in chronic pain patients: a comparison of patient-controlled reduction and staff controlled cocktail methods. Pain.
Reid MC, Engles-Horton LL, Weber MB, et al. (2002). Use of opioid medications for chronic noncancer pain syndromes in primary care. J Gen Intern Med.
Saffier K, Colombo C, Brown D, et al. (2007). Addiction severity index in a chronic pain sample receiving opioid therapy. J Subst Abuse Treat.
Salzman RT, Roberts MS, Wild J, et al. (1999). Can a controlled-release oral dose form of oxycodone be used as readily as an immediate-release form for the purpose of titrating to stable pain control?. J Pain Symptom Manage.
Saunders KW, Dunn KM, Merrill JO, et al. (2010). Relationship of opioid use and dosage levels to fractures in older chronic pain patients. J Gen Intern Med.
Schneider JP, Kirsh KL. (2010). Defining clinical issues around tolerance, hyperalgesia, and addiction: a quantitative and qualitative outcome study of long-term opioid dosing in a chronic pain practice. J Opioid Manag.
Simpson DM, Messina J, Xie F, et al. (2007). Fentanyl buccal tablet for the relief of breakthrough pain in opioid-tolerant adult patients with chronic neuropathic pain: a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther.
Tennant FS, Rawson RA. (1982). Outpatient treatment of prescription opioid dependence: comparison of two methods. Arch Intern Med.
Wasan AD, Butler SF, Budman SH, et al. (2009). Does report of craving opioid medication predict aberrant drug behavior among chronic pain patients?. Clin J Pain.
Webster LR, Slevin KA, Narayana A, et al. (2013). Fentanyl buccal tablet compared with immediate-release oxycodone for the management of breakthrough pain in opioid-tolerant patients with chronic cancer and noncancer pain: a randomized, double-blind, crossover study followed by a 12-week open-label phase to evaluate patient outcomes. Pain Med.
Webster LR, Webster RM. (2005). Predicting aberrant behaviors in opioid-treated patients: preliminary validation of the Opioid Risk Tool. Pain Med.
Wild JE, Grond S, Kuperwasser B, et al. (2010). Long-term safety and tolerability of tapentadol extended release for the management of chronic low back pain or osteoarthritis pain. Pain Pract.

* Appendix C is the reference list for all appendixes.