# Appendix B PICOTS

PICOT | Include | Exclude
Population and Conditions of Interest | - For all KQs: Adults (age >18 years) with various types of chronic pain (defined as pain lasting >3 months), including patients with acute exacerbations of chronic pain (KQ Ig); - For KQs 1 b, 2b: Subgroups as defined by specific pain condition, patient demographics (e.g., age, race, ethnicity, sex), comorbidities (including medical comorbidities and mental health disorders, including past or current alcohol or substance abuse and related disorders, and those at high risk for addiction);; - For KQ 2b: Subgroups also defined by the dose of opioids used | - Patients with pain at end of life, acute pain, pregnant or breastfeeding, patients treated with opioids for addiction
Interventions | - For KQs 1, 2, 3: Long- or short-acting opioids (including tapentadol) used as long-term therapy (defined as use of opioids on most days for >3months); - For KQ 1d: Also include combination of opioid plus nonopioid therapy (pharmacological or nonpharmacological); - For KQ 1Va, b: Risk prediction instruments; - For KQ 1 Vc: Opioid management plans, patient education, urine drug screening, use of prescription drug monitoring program data, use of monitoring instruments, more frequent monitoring intervals, pill counts, use of abuse deterrent formulations; - For KQ 1 Vd: Opioid management strategies | - Intravenous or intramuscular administration of opioids; - Tramadol
Comparators | - For KQs 1a, 1b, 2a, 2b: Opioid vs. placebo or nonopioid therapy (including usual care); - For KQ 1c: Opioid vs. nonopioid therapy (pharmacological or nonpharmacological [e.g., exercise therapy, cognitive behavioral therapy, interdisciplinary rehabilitation]); - For KQ 1d: Opioid plus nonopioid therapy (pharmacological or nonpharmacological) vs. opioid or nonopioid therapy alone; - For KQ 3a: Comparisons of different dose initiation and titration strategies; - For KQ 3b: Short- vs. long-acting opioids; - For KQ 3c: One long-acting opioid vs. another long-acting opioid; - For KQ 3d: Short- plus long-acting opioid vs. long-acting opioid; - For KQ 3e: Scheduled, continuous vs. as-needed dosing of opioid; - For KQ 3f: Dose escalation vs. dose maintenance or use of maximum dosing thresholds; - For KQ 3g: Opioid rotation vs. continuation of current opioid; - For KQ 3h: Comparisons of different methods for treating acute exacerbations of chronic pain; - For KQ 3i: Decreasing or tapering opioid doses vs. continuation of opioids; - For KQ 3j: Comparisons of different tapering protocols and strategies; - For KQ 4a: Risk prediction instruments vs. reference standard for overdose oropioid addiction, abuse or misuse; - For KQ 4b: Risk prediction instruments vs. nonuse of risk prediction instruments; - For KQ 4c: Risk mitigation strategies (see Interventions above) vs. nonuse of risk mitigation strategies; - For KQ 4d: Comparisons of treatment strategies for managing patients with addiction to prescription opioids
Outcomes | - For KQs 1, 3, 4: Pain (intensity, severity, bothersomeness), function (physical disability, activity limitations, activity interference, work function), and quality of life (including depression), doses of opioids used; - Also for KQs 2, 3, 4: Overdose, opioid use disorder, addiction, abuse, and misuse; other opioid-related harms (including gastrointestinal, falls, fractures, motor vehicle accidents, endocrinological harms, infections, cardiovascular events, cognitive harms, and psychological harms (e.g., depression) | - Intermediate outcomes (e.g., pharmacokinetics/pharmac odynamics, drug-drug interactions, dose conversions)
Timing | - Any duration for outcomes related to overdose and injuries (falls, fractures, motor vehicle accidents), studies on treatment of acute exacerbations of chronic pain, studies on dose initiation and titration, and studies on discontinuation of opioid therapy; - For other outcomes: >1 year
Setting | - Outpatient settings (e.g., primary care, pain clinics, other specialty clinics) | - Addiction treatment settings, inpatient settings
Study Design | - For all KQs, randomized controlled trials, controlled cohort studies, and case-control studies (controlled observational studies must have performed adjustment on potential confounders); - For all KQs, we excluded uncontrolled observational studies, case series, and case reports, with the exception of KQ 2a for which we included uncontrolled observational studies of patients with chronic pain prescribed long-term opioid therapy for at least one year that used predefined methods to assess rates of abuse, misuse, or addiction; - For KQ 4a, we included studies that evaluated the predictive ability of risk prediction instruments, and excluded studies that did not evaluate the performance of a risk prediction instrument against a reference standard.

KQ, key question; PICOT=populations, interventions, comparators, outcomes, timing, setting.