# Appendix A Search Strategies

## Database: Ovid MEDLINE(R) Without Revisions

### KQ 1 and 2: Comparative Effectiveness and Harms

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphin$ or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. exp Chronic Pain/
6. (chronic adj2 pain).mp.
7. 5 or 6
8. 4 and 7
9. limit 8 to yr="2008 - 2013"
10. limit 9 to (clinical trial, all or clinical trial or comparative study or controlled clinical trial or multicenter study or randomized controlled trial)
11. 9 and random$.mp.
12. 10 or 11

### KQ 2a: Supplemental Search – Abuse and Addiction Detection

1. Analgesics, Opioid/
2. 1 and 2
3. Substance Abuse Detection/
4. Opioid-Related Disorders/ or Substance-Related Disorders/
5. 3 and (4 or 5)
6. (chronic adj3 pain).mp.
7. 1 and 7
8. 8 not 3
9. 9 and (4 or 5)
10. 6 or 10

### KQ 3a-3g; 3i: Dosing Strategies

1. exp Analgesics, Opioid/
2. opioid*.mp. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
3. or/1-3
4. Opioid-Related Disorders/
5. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
6. Drug Administration Schedule/
7. Pain Management/
8. Clinical Protocols/
9. Breakthrough Pain/
10. Dose-Response Relationship, Drug/
11. ((dose$ or dosing) adj7 (strateg$ or adjust$ or titrat$ or taper$)).mp.
12. exp Chronic Pain/
13. (chronic adj2 pain).mp.
14. or/4-6
15. or/7-12
16. 15 and 16
17. (or/13-14) and 17
18. 18 and (random$ or control$ or trial or cohort or prospective or retrospective).mp.
19. limit 19 to yr="2008 - 2013"

### KQ 3h: Dosing Strategies – Tapered Dosing

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. Opioid-Related Disorders/
6. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
7. Drug Administration Schedule/
8. Pain Management/
9. Clinical Protocols/
10. Breakthrough Pain/
11. Dose-Response Relationship, Drug/
12. ((dose$ or dosing) adj7 (strateg$ or adjust$ or titrat$ or taper$)).mp.
13. exp Chronic Pain/
14. (chronic adj2 pain).mp.
15. or/4-6
16. or/7-12
17. 15 and 16
18. (or/13-14) and 17
19. 18 and (random$ or control$ or trial or cohort or prospective or retrospective).mp.
20. 19 and (taper$ or decreas$ or reduc$).mp.
21. limit 20 to yr="1902 - 2007"

### KQ 4a-4b: Risk Prediction

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. exp Chronic Pain/
6. (chronic adj2 pain).mp.
7. Opioid-Related Disorders/
8. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
9. 4 and (5 or 6)
10. 7 or 8
11. 9 or 10
12. Decision Support Techniques/
13. "Predictive Value of Tests"/
14. Prognosis/
15. Risk Assessment/
16. Risk Factors/
17. Proportional Hazards Models/
18. "Reproducibility of Results"/
19. "Sensitivity and Specificity"/
20. (sensitivity or specificity).mp.
21. (risk and (predict$ or assess$)).mp.
22. or/12-21
23. 11 and 22
24. limit 23 to yr="2008 - 2013"

### KQ 4c: Risk Mitigation

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. exp Chronic Pain/
6. (chronic adj2 pain).mp.
7. Opioid-Related Disorders/
8. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
9. 4 and (5 or 6)
10. 7 or 8
11. 9 or 10
12. Patient Compliance/
13. Health Services Misuse/
14. Substance Abuse Detection/
15. Drug Monitoring/
16. (urine adj7 (screen$ or test$ or detect$)).mp.
17. (abus$ or misus$ or diversion$ or divert$).mp.
18. (opioid$ adj7 (contract$ or agree$)).mp.
19. Contracts/
20. Patient Education as Topic/
21. Drug Overdose/
22. or/12-21
23. ((risk$ adj7 mitigat$) or reduc$).mp.
24. ("risk evaluation and mitigation" or "rems").mp.
25. Risk Reduction Behavior/ or Risk/
26. or/23-25
27. 11 and 22 and 26
28. limit 27 to yr="2008 - 2013"

### KQ 4d: Treatment Strategies

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. Opioid-Related Disorders/
6. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
7. Patient Compliance/
8. Health Services Misuse/
9. Substance Abuse Detection/
10. Drug Monitoring/
11. (urine adj7 (screen$ or test$ or detect$)).mp.
12. (abus$ or misus$ or diversion$ or divert$).mp.
13. (opioid$ adj7 (contract$ or agree$)).mp.
14. Contracts/
15. Patient Education as Topic/
16. Drug Overdose/
17. or/7-16
18. Substance Abuse Detection/
19. Opiate Substitution Treatment/
20. Risk Management/
21. or/18-20
22. or/4-6
23. 17 and 21 and 22
24. treatment outcome.mp. or Treatment Outcome/
25. (treatment and (strateg$ or plan$)).mp.
26. 23 and (24 or 25)

### All KQs: Systematic Reviews

1. meta-analysis.mp. or exp Meta-Analysis/
2. (cochrane or medline).tw.
3. search$.tw.
4. 1 or 2 or 3
5. "Review Literature as Topic"/ or systematic review.mp.
6. 4 or 5
7. xp Analgesics, Opioid/
8. opioid*.mp.
9. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
10. 10 (chronic and pain).mp.
11. or/7-9
12. 6 and 10 and 11
13. limit 12 to yr="2008 - 2013"

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials

### KQ 1 and 2: Comparative Effectiveness and Harms

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphin$ or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. exp Chronic Pain/
6. (chronic adj2 pain).mp.
7. 5 or 6
8. 4 and 7
9. limit 8 to yr="2008 - 2013"

### KQ 3a-3g, 3i: Dosing Strategies

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. Opioid-Related Disorders/
6. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
7. Drug Administration Schedule/
8. Pain Management/
9. Clinical Protocols/
10. Breakthrough Pain/
11. Dose-Response Relationship, Drug/
12. ((dose$ or dosing) adj7 (strateg$ or adjust$ or titrat$ or taper$)).mp.
13. exp Chronic Pain/
14. (chronic adj2 pain).mp.
15. or/4-6
16. or/7-12
17. 15 and 16
18. (or/13-14) and 17
19. limit 18 to yr="2008 - 2013"

### KQ 3h: Tapered Dosing

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. Opioid-Related Disorders/
6. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
7. Drug Administration Schedule/
8. Pain Management/
9. Clinical Protocols/
10. Breakthrough Pain/
11. Dose-Response Relationship, Drug/
12. ((dose$ or dosing) adj7 (strateg$ or adjust$ or titrat$ or taper$)).mp.
13. exp Chronic Pain/
14. (chronic adj2 pain).mp.
15. or/4-6
16. or/7-12
17. 15 and 16
18. (or/13-14) and 17
19. 18 and (random$ or control$ or trial or cohort or prospective or retrospective).mp.
20. 19 and (taper$ or decreas$ or reduc$).mp.
21. limit 20 to yr="1902 - 2007"

### KQ 4a-b: Risk Prediction

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. exp Chronic Pain/
6. (chronic adj2 pain).mp.
7. Opioid-Related Disorders/
8. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
9. 4 and (5 or 6)
10. 7 or 8
11. 9 or 10
12. Decision Support Techniques/
13. "Predictive Value of Tests"/
14. Prognosis/
15. Risk Assessment/
16. Risk Factors/
17. Proportional Hazards Models/
18. "Reproducibility of Results"/
19. "Sensitivity and Specificity"/
20. (sensitivity or specificity).mp.
21. (risk and (predict$ or assess$)).mp.
22. or/12-21
23. 11 and 22
24. limit 23 to yr="2008 - 2013"

### KQ 4c: Risk Mitigation

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp. (20690)
4. or/1-3 (22725)
5. exp Chronic Pain/ (79)
6. (chronic adj2 pain).mp. (2585)
7. Opioid-Related Disorders/ (571)
8. (opioid adj2 (abuse or addict* or misuse or diversion)).mp. (116)
9. 4 and (5 or 6) (523)
10. 7 or 8 (630)
11. 9 or 10 (1139)
12. Patient Compliance/
13. Health Services Misuse/
14. Substance Abuse Detection/
15. Drug Monitoring/
16. (urine adj7 (screen$ or test$ or detect$)).mp.
17. (abus$ or misus$ or diversion$ or divert$).mp.
18. (opioid$ adj7 (contract$ or agree$)).mp.
19. Contracts/
20. Patient Education as Topic/
21. Drug Overdose/
22. or/12-21
23. ((risk$ adj7 mitigat$) or reduc$).mp.
24. ("risk evaluation and mitigation" or "rems").mp.
25. Risk Reduction Behavior/ or Risk/
26. or/23-25
27. 11 and 22 and 26
28. limit 27 to yr="2008 - 2013"

### KQ 4d: Treatment Strategies

1. exp Analgesics, Opioid/
2. opioid*.mp.
3. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
4. or/1-3
5. Opioid-Related Disorders/
6. (opioid adj2 (abuse or addict* or misuse or diversion)).mp.
7. Patient Compliance/
8. Health Services Misuse/
9. Substance Abuse Detection/
10. Drug Monitoring/
11. (urine adj7 (screen$ or test$ or detect$)).mp.
12. (abus$ or misus$ or diversion$ or divert$).mp.
13. (opioid$ adj7 (contract$ or agree$)).mp.
14. Contracts/
15. Patient Education as Topic/
16. Drug Overdose/
17. or/7-16
18. Substance Abuse Detection/
19. Opiate Substitution Treatment/
20. Risk Management/
21. or/18-20
22. or/4-6
23. 17 and 21 and 22
24. treatment outcome.mp. or Treatment Outcome/
25. (treatment and (strateg$ or plan$)).mp.
26. 23 and (24 or 25)

## Database: PsycINFO

### KQ 1 and 2: Comparative Effectiveness and Harms

1. opioid*.mp.
2. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
3. (chronic and pain).mp.
4. (1 or 2) and 3
5. (random$ or control$ or trial or cohort or prospective or retrospective).mp.
6. 4 and 5
7. limit 6 to yr="2008 - 2014"
8. limit 7 to human

### KQ 3a-3g, 3i: Dosing Strategies

1. opioid*.mp.
2. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
3. (chronic and pain).mp.
4. (1 or 2) and 3
5. 4 and (dose or dosing or dosage).mp.
6. limit 5 to human
7. limit 6 to yr="2008 - 2014"

### KQ 3h: Tapered Dosing

1. opioid*.mp.
2. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
3. (chronic and pain).mp.
4. (1 or 2) and 3
5. 4 and (taper$ or decreas$).mp.
6. limit 5 to human

### KQ 4a-4c: Risk Prediction and Mitigation

1. opioid*.mp.
2. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp.
3. (chronic and pain).mp.
4. (1 or 2) and 3
5. risk.mp.
6. 4 and
7. limit 6 to human
8. limit 7 to yr="2008 - 2014"

### KQ 4d: Treatment Strategies

1. opioid*.mp
2. (alfentanil or alphaprodine or beta-casomorphins or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).mp
3. (chronic and pain).mp
4. (1 or 2) and 3
5. 4 and ((treatment and (strateg$ or plan$).mp
6. 5 and (overdose or abuse or misuse or pain or function or “quality of life” or “qol”).mp
7. limit 6 to human

## Database: EBSCO CINAHL Plus with Full Text

### All Key Questions (except 3h, 4d)

1. (MH "Analgesics, Opioid") OR (MH "Narcotics") OR (MH "Alfentanil" ) OR "alfentanil" (MH "Alphaprodine") OR "alphaprodine" OR "beta-casomorphins" (MH "Buprenorphine") OR "buprenorphine" OR "carfentanil" (MH "Codeine") OR "codeine" OR (MH "Oxycodone") OR "deltorphin" OR (MH "Dextromethorphan") OR "dextromethorphan" OR "dezocine" OR "dihydrocodeine" OR "dihydromorphine" OR (MH "Enkephalins") OR "enkephalin" OR "ethylketocyclazocine" OR "ethylmorphine" "etorphine" OR (MH "Fentanyl" ) OR "fentanyl" (MH "Heroin") OR "heroin" "hydrocodone" OR (MH "Dihydromorphinone") OR "hydromorphone" OR "ketobemidone" OR "levorphanol" OR "lofentanil" OR (MH "Meperidine") OR "meperidine" OR "meptazinol" OR (MH "Methadone") OR "methadone" OR "methadyl acetate" OR (MH "Morphine") OR "morphine" OR (MH "Nalbuphine") OR (MH "Opium") OR "oxycodone" OR "oxymorphone" OR (MH "Pentazocine") OR "pentazocine" OR "phenazocine" OR "phenoperidine" OR "pirinitramide" OR "promedol" OR (MH "Propoxyphene") OR "propoxyphene" OR "remifentanil" OR (MH "Sufentanil") OR "sufentanil" OR "tilidine" OR (MH "Tapentadol") OR "tapentadol"
2. (MH "Chronic Pain") OR "chronic pain"
3. 1 and 2
4. "random*" OR "control*" OR "trial" OR "cohort" OR "prospective" OR "retrospective"
5. 3 and 4
6. Limit 4 to published date 20080101-20131015

### KQ 3h: Tapered Dosing

1. (MH "Analgesics, Opioid") OR (MH "Narcotics") OR (MH "Alfentanil" ) OR "alfentanil" (MH "Alphaprodine") OR "alphaprodine" OR "beta-casomorphins" (MH "Buprenorphine") OR "buprenorphine" OR "carfentanil" (MH "Codeine") OR "codeine" OR (MH "Oxycodone") OR "deltorphin" OR (MH "Dextromethorphan") OR "dextromethorphan" OR "dezocine" OR "dihydrocodeine" OR "dihydromorphine" OR (MH "Enkephalins") OR "enkephalin" OR "ethylketocyclazocine" OR "ethylmorphine" "etorphine" OR (MH "Fentanyl" ) OR "fentanyl" (MH "Heroin") OR "heroin" "hydrocodone" OR (MH "Dihydromorphinone") OR "hydromorphone" OR "ketobemidone" OR "levorphanol" OR "lofentanil" OR (MH "Meperidine") OR "meperidine" OR "meptazinol" OR (MH "Methadone") OR "methadone" OR "methadyl acetate" OR (MH "Morphine") OR "morphine" OR (MH "Nalbuphine") OR (MH "Opium") OR "oxycodone" OR "oxymorphone" OR (MH "Pentazocine") OR "pentazocine" OR "phenazocine" OR "phenoperidine" OR "pirinitramide" OR "promedol" OR (MH "Propoxyphene") OR "propoxyphene" OR "remifentanil" OR (MH "Sufentanil" ) OR "sufentanil" OR "tilidine" OR (MH "Tapentadol" ) OR "tapentadol"
2. (MH "Chronic Pain") OR "chronic pain"
3. 1 and 2
4. "random*" OR "control*" OR "trial" OR "cohort" OR "prospective" OR "retrospective"
5. 3 and 4
6. "taper*" OR "decreas*"
7. 5 and 6
8. Limit 6 to published date 19920101-20071231

### KQ 4d: Treatment Strategies

1. (MH "Analgesics, Opioid") OR (MH "Narcotics") OR (MH "Alfentanil" ) OR "alfentanil" (MH "Alphaprodine") OR "alphaprodine" OR "beta-casomorphins" (MH "Buprenorphine") OR "buprenorphine" OR "carfentanil" (MH "Codeine") OR "codeine" OR (MH "Oxycodone") OR "deltorphin" OR (MH "Dextromethorphan") OR "dextromethorphan" OR "dezocine" OR "dihydrocodeine" OR "dihydromorphine" OR (MH "Enkephalins") OR "enkephalin" OR "ethylketocyclazocine" OR "ethylmorphine" "etorphine" OR (MH "Fentanyl" ) OR "fentanyl" (MH "Heroin") OR "heroin" "hydrocodone" OR (MH "Dihydromorphinone") OR "hydromorphone" OR "ketobemidone" OR "levorphanol" OR "lofentanil" OR (MH "Meperidine") OR "meperidine" OR "meptazinol" OR (MH "Methadone") OR "methadone" OR "methadyl acetate" OR (MH "Morphine") OR "morphine" OR (MH "Nalbuphine") OR (MH "Opium") OR "oxycodone" OR "oxymorphone" OR (MH "Pentazocine") OR "pentazocine" OR "phenazocine" OR "phenoperidine" OR "pirinitramide" OR "promedol" OR (MH "Propoxyphene") OR "propoxyphene" OR "remifentanil" OR (MH "Sufentanil") OR "sufentanil" OR "tilidine" OR (MH "Tapentadol") OR "tapentadol"
2. (MH "Chronic Pain") OR "chronic pain"
3. 1 and 2
4. "random*" OR "control*" OR "trial" OR "cohort" OR "prospective" OR "retrospective"
5. 3 and 4
6. "treatment" AND ("strateg*" OR "plan*")
7. 5 and 6
8. Limit 7 to published date 19920101-20071231

## Database: EBM Reviews – Cochrane Database of Systematic Reviews

### All KQs: Systematic Reviews

1. (opioid$ or alfentanil or alphaprodine or beta-casomorphin$ or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol).ti.
2. 1 and (chronic and pain).mp.
3. limit 2 to full systematic reviews