# Abbreviations and Acronyms

AUROC: area under receiver operating characteristic curve
ASA: aspirin
ASI: Addiction Severity Index
APS: American Pain Society
BID: twice daily
CI: confidence interval
CIDI: Composite International Diagnostic Interview
CR: controlled release
DASS21: Depression, Anxiety, and Stress Scale-21 Items
DIRE: Diagnosis, Intractability, Risk, and Efficacy Inventory
DSM-V: Diagnostic and Statistical Manual, Fourth Edition DSM-
IV: Diagnostic and Statistical Manual, Fifth Edition
ER: extended release
GC/M: gas chromatography mass spectrometry
HR: hazard ratio
ICD-10: International Statistical Classification of Diseases and Related Health Problems Version 10 IRR incidence rate ratio
ITT: intent to treat
MED: morphine equivalent dose
MS: long-acting morphine sulfate
NA: not applicable
NLR: negative likelihood ratio
NR: not reported
NSAID: nonsteroidal anti-inflammatory drug
ODI: Oswestry Disability Index
OR: odds ratio
ORT: Opioid Risk Tool
PDI: Physical Disability Index
PDUQ: Prescription Drug Use Questionnaire
PLR: positive likelihood ratio
PMQ: Pain Medication Questionnaire
POTQ: Prescription Opioid Therapy Questionnaire
RCT: randomized controlled trial
SE: standard error
SDSS: Dependence Severity Scale
SOAPP: Screening and Opioid Assessment for Patients with Pain
SOAPP-R: Screening and Opioid Assessment for Patients with Pain-Revised
SOE: strength of evidence
SUQ: Self-report Substance Use Questionnaire
TDB: transdermal buprenorphine
TDF: transdermal fentanyl
U.S.: United States
UDT: urine drug test
VA: Veterans Affairs
VAS: Visual Analogue Scale