# Results

## Organization of the Results Section

The Results section is organized in the following way:

- Nutrient (vitamin D | calcium | combined calcium and vitamin D)
  ○ Outcome (e.g., growth, cardiovascular diseases)
    ■ Synopsis
    ■ Detailed presentation (depending on availability of data)
      - Findings per calcium intake level / vitamin D concentration
      - Findings per age and sex
    ■ Findings by life stage

The findings of the studies identified for this update report are in boldface type in the text and summary tables.

## Literature Search Results

For the 2009 report, the original MEDLINE^®^ and Cochrane Central database search for primary studies yielded 15,621 citations of EAR outcomes and 194 citations of UL outcomes. The update search for primary studies published between September, 2008 and April, 2009 yielded 918 citations. We identified 654 of these as potentially relevant and retrieved the full-text articles for further evaluation. Of these, 478 did not meet eligibility criteria (Appendix F); thus, a total of 165 primary study articles met the inclusion criteria and were included in this report (Figure 5a). Of the 165 primary study articles, 60 were randomized controlled trials (RCTs), 3 were nonrandomized comparative studies, and 102 were observational studies (either cohort or nested case-control studies). The publication dates of the 165 primary study articles ranged from 1980 to 2009.

Figure 5a Literature flow for the original report

Figure 5a is the flow chart from the original report that summarizes the study retrieval and selection process for articles. The figure displays the same information described in the first three paragraphs of the Results chapter.

The MEDLINE^®^, Cochrane Database of Systemic Reviews, and the Health Technology Assessments database search for systematic reviews yielded 1,746 citations. We identified 68 of these as potentially relevant and retrieved the full-text articles for further evaluation. Of these, 46 did not meet eligibility criteria. After examining the 22 qualifying systematic reviews, 11 were excluded for various reasons (Appendix D; Figure 5a).

The grand overview tables (Tables 1, 2, and 3) detailed how many studies reported an outcome (either as a primary or secondary outcome) that is of interest and also listed the total number of unique studies (including those from systematic reviews) as each study may have provided data for more than one outcome.

Table 1 Number of primary studies on vitamin D intake or concentration and specific health outcomes that could be applicable to certain life stages [updated for the current report]

| Growth | CVD Clinical | Body Weight (Adults) | Total Cancer | Prostate Cancer | Colorectal Cancer | Colorectal Adenoma | Breast Cancer | Breast Mammographic Density | Pancreatic Cancer | Immune Function Clinical Outcomes | Preeclampsia & Pregnancy Outcomes | All-Cause Mortality | Bone Health Clinical Outcomes | Bone Mineral Density or Content | Hypertension | Blood Pressure
0–6 mo | 8 | | | | | | | | | | 5 | | | | 1
7 mo–2 y | 1 | | | | | | | | | | 4^B^
3–8 y | | | | | | | | | | | 7
9–18 y | 3 | | | 1 | | | | | | | 8 | | | 2 | 5
19–50 y | | 19 | 1 | 9 | 6 | 3 | | 8 | | 1 | 9 | | 10 | 3 | 6 | 3 | 8
51–70 y | | 31 | 2 | 14 | 17 | 11 | 1 | 11 | | 4 | 7 | | 31 | 13 | 5 | 3 | 5
≥71 y | | 20 | | 10 | 5 | 5 | | 4 | | 1 | 3 | | 26 | 17 | 1 | 2 | 5
Pregnant & lactating women | 16 | | | | | | | | | | 6 | 9
Postmenopause | | 4 | 1 | 2 | | 1 | | 1 | 2 | | 2^B^ | | 2 | 3 | 3 | 1 | 4
Total unique studies per outcome | 18 | 36 | 3 | 16 | 19 | 14 | 1 | 12 | 2 | 4 | 27 | 9 | 34 | 22 | 12 | 4 C | 13
[Total number of RCTs per outcome] | [10] | [1] | [3 A ] | [2] | [0] | [1] | [0] | [0] | [1] | [0] | [7] | [1] | [8] | [9] | [12 A ] | [0] | [13 A ]
Systematic reviews (unique studies) per outcome | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4) | 1 (73) | | 0 | 0

Note: Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

Abbreviations: CVD = cardiovascular disease; RCT = randomized controlled trial

A Only RCTs were eligible for this outcome.

B Relationship between maternal 25(OH)D concentration and atopic eczema in infants.

C 1 study was a combined analysis of Nurses' Health Study and Health Professionals Followup Study.

Table 2 Number of primary studies on calcium intake and specific health outcomes that could be applicable to certain life stages [not updated in the current report]

| Growth | CVD Clinical | Body Weight (Adults) | Total Cancer | Prostate Cancer | Colorectal Cancer | Colorectal Adenoma | Breast Cancer | Breast Mammographic Density | Pancreatic Cancer | Immune Function Clinical Outcomes | Preeclampsia & Pregnancy Outcomes | All-Cause Mortality | Bone Health Clinical Outcomes | Bone Mineral Density or Content | Hypertension | Blood Pressure
0–6 mo | 1
7 mo–2 y
3–8 y | 1 | | | | | 1^B^
9–18 y | 3
19–50 y | | 2 | 3 | 1 | | 3 | | 1 | 1 | 1 | | | 1 | | | 5 | 3
51–70 y | | 9 | 5 | 1 | 12 | 17 | 6 | 5 | | 2 | | | 1 | | | 4 | 2
≥71 y | | 1 | 1 | 1 | | 1^B^ | | | | 1 | | | | | | | 2
Pregnant & lactating women | 1 | | | | | | | | | | | 14
Postmenopause | | 1 | 4 | 1 | | | | 4 | | | | | | | | 1 | 2
Total unique studies per outcome | 3 | 11 | 8 | 3 | 12 | 21 | 6 | 6 | 1 | 2 C | 0 | 14 | 1 | | | 5 D | 5
[Total number of RCTs per outcome] | [1] | [0] | [8 A ] | [2] | [0] | [0] | [1] | [0] | [0] | [0] | 0 | 14 | 1 | | | [0] | [5 A ]
Systematic reviews (unique studies) per outcome | 1 (17) | 0 | 3 (41) | 0 | 0 | 1 (2) | 1 (2) | 0 | 0 | 0 | 0 | 1 (12) | 0 | | | 0 | 6 (64)

Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

A Only RCTs were eligible for this outcome.

B Association between total calcium intake in childhood and colorectal cancer after 65 years of followup.

C 1 study was a combined analysis of Nurses' Health Study and Health Professionals Followup Study.

D 6 analyses, including 2 separate analyses of NHANES I.

Table 3 Number of primary studies on combined vitamin D and calcium intake and specific health outcomes that are relevant to certain life stages [updated for the current report]

| Growth | CVD Clinical | Body Weight (Adults) | Total Cancer | Prostate Cancer | Colorectal Cancer | Colorectal Adenoma | Breast Cancer | Breast Mammographic Density | Pancreatic Cancer | Immune Function Clinical Outcomes | Preeclampsia & Pregnancy Outcomes | All-Cause Mortality | Bone Health Clinical Outcomes | Bone Mineral Density or Content | Hypertension | Blood Pressure
0–6 mo | 1
7 mo–2 y
3–8 y
9–18 y | | | | | | | | | | | | | | | 3
19–50 y | | | 1 | | | | | | | | | | | 1 | 3 | | 1
51–70 y | | 1 | 1 | 1 | | 1 | 1 | 1 | | 1 | | | 3 | 3 | 5 | 1 | 1
≥71 y | | | 1 | 1 | | 1 | | 1 | | 1 | | | 8 | 2 | 3
Pregnant & lactating women | 1 | | | | | | | | | | | 1
Postmenopause | | 2 | 1 | 4 | | 2 | 1 | 2 | | 1 | | | 9 | 2 | 6 | 1 | 1
Total unique studies per outcome | 1 | 2 B | 2 B | 4 B | 0 | 2 B | 2 B | 2 B | 0 | 1 | 0 | 1 | 12 B ^C^ | 6 B | 11 | 1 B | 2 B
[Total number of RCTs per outcome] | | [2] | [2 A ] | [4] | | [2] | [1] | [2] | 0 | [1] | 0 | 1 | [12] | [6] | [11 A ] | [1] | [2 A ]
Systematic reviews (unique studies) per outcome | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (10 B ) | 1 (119 B ) | | 0 | 0

Shaded cells indicate that either the eligibility criteria excluded outcomes in those life stages or the outcomes are not applicable to those life stages. Blank unshaded cells indicate no primary studies were identified in this report in those life stages.

A Only RCTs were eligible for this outcome.

B Including the Women's Health Initiative (WHI) trial.

A de novo reanalysis of the 10 RCTs in a previous systematic review and one newly added trial.

For this update, the original MEDLINE^®^ and Cochrane Database searches yielded 6,154 titles for EAR and UL outcomes, combined. An additional 11 titles were identified from reference mining and hand searching, for a total of 6,165 titles and abstracts that underwent dual review. Of this 6,165, 5,058 abstracts were rejected and 1,107 went on for full text review. Of that 1,107, 10 were identified as background, 772 failed to meet inclusion criteria and were rejected, and 154 articles with 156 studies went on for detailed abstraction and are included in this report ( Figure 5b ). In addition, 171 systematic reviewers were looked at of which 2 were included in the update report

Figure 5b Literature flow for the current report

Figure 5b is the flow chart from the current report that summarizes the study retrieval and selection process for articles. The figure displays the same information described in the first last paragraph of the Results chapter.

## Vitamin D and Health Outcomes

### Vitamin D and Growth

The original report reviewed primary studies that evaluated relationships between vitamin D and growth parameters in infants and children. That topic was not updated in the current report; only the original findings are reported here for those outcomes. The current report did review the evidence on the outcomes of birth weight and length.

#### Synopsis

For the current report, we identified five RCTs (reported in four articles) and two observational studies that evaluated intake of or exposure to vitamin D, respectively, on birth weight and/or length. One of the five RCTs found a significant association of maternal vitamin D intake from supplements with birth weight and birth length; one of the four remaining studies was not powered to measure differences in birth weight or length; the remaining three observed no difference. Of the two observational cohort studies, one observed a significant association of second trimester maternal 25(OH)D concentrations and one found no association.

In the original report, seven intervention studies and two observational studies evaluated intake of or exposure to vitamin D and growth parameters in infants and children. Two intervention studies from the same center found a significant association of maternal vitamin D intakes with infant birth weights. Study methodologies were incompletely reported in these two studies. The rest of the studies did not find a significant association between either maternal or offspring vitamin D intake and offspring's weight or height. No overall conclusions could be drawn as the studies reviewed had diverse populations and methodological approaches.

#### Detailed Presentation

(Tables 4, 5, 6, & 7)

Table 4 Vitamin D and growth outcomes: Characteristics of interventional studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
RCTs
Maxwell 1981^51^ Brooke 1980^47^ UK (51°N) [6793058] [6989438] | - Health status | pregnancy | 25(OH)D at 28–32 wk: 20.1 nmol/L | Vit D 1000 IU/d 3^rd^ trimester only | nd | First generation Asian immigrants only
Maxwell 1981^51^ Brooke 1980^47^ UK (51°N) [6793058] [6989438] | - Mean age (range/SD), y | nd | 25(OH)D at 28–32 wk: 20.1 nmol/L | Vit D 1000 IU/d 3^rd^ trimester only | nd | First generation Asian immigrants only
Maxwell 1981^51^ Brooke 1980^47^ UK (51°N) [6793058] [6989438] | - Male (%) | 0 | 25(OH)D at 28–32 wk: 20.1 nmol/L | Vit D 1000 IU/d 3^rd^ trimester only | nd | First generation Asian immigrants only
Feliciano 1994^49^ China (22°N to 47°N) [8078115] | - Health status | healthy term | 86% infant breastfed until 5–6 mo | Vit D 100 IU/d vs. 200 IU/d vs. 400 IU/d | nd
Feliciano 1994^49^ China (22°N to 47°N) [8078115] | - Mean age (range/SD), y | newborn | 86% infant breastfed until 5–6 mo | Vit D 100 IU/d vs. 200 IU/d vs. 400 IU/d | nd
Feliciano 1994^49^ China (22°N to 47°N) [8078115] | - Male (%) | nd | 86% infant breastfed until 5–6 mo | Vit D 100 IU/d vs. 200 IU/d vs. 400 IU/d | nd
El-Hajj 2006^48^ Lebanon (33°N) [16278262] | - Health status | healthy | 25(OH)D 35 nmol/L; dietary Ca 677 mg/d | Vit D_3_ 200 IU/d vs. 2000 IU/d vs. placebo × 1 y | 98% in placebo; 98% in low dose; 97% in high dose | 7.4 h sun exposure/wk
El-Hajj 2006^48^ Lebanon (33°N) [16278262] | - Mean age (range/SD), y | 13.2 (10–17) | 25(OH)D 35 nmol/L; dietary Ca 677 mg/d | Vit D_3_ 200 IU/d vs. 2000 IU/d vs. placebo × 1 y | 98% in placebo; 98% in low dose; 97% in high dose | 7.4 h sun exposure/wk
El-Hajj 2006^48^ Lebanon (33°N) [16278262] | - Male (%) | 0 | 25(OH)D 35 nmol/L; dietary Ca 677 mg/d | Vit D_3_ 200 IU/d vs. 2000 IU/d vs. placebo × 1 y | 98% in placebo; 98% in low dose; 97% in high dose | 7.4 h sun exposure/wk
Wagner 2006^52^ Charleston, US (32°N) [17661565] | - Health status | Fully lactating; <1 mo postpartum | Lactating mother's dietary Vit D 273 IU/d; dietary calcium intake: 1125 mg/d; | Mother Vit D_3_ 400 IU/d + infant 300 IU/d vs. mother 6400 IU/d + infant 0 IU/d | ≥80% in mothers; as low as 61% for infants | 78% white; 11% black; 11% Hispanic
Wagner 2006^52^ Charleston, US (32°N) [17661565] | - Mean age (range/SD), y | 29 | Lactating mother's dietary Vit D 273 IU/d; dietary calcium intake: 1125 mg/d; | Mother Vit D_3_ 400 IU/d + infant 300 IU/d vs. mother 6400 IU/d + infant 0 IU/d | ≥80% in mothers; as low as 61% for infants | 78% white; 11% black; 11% Hispanic
Wagner 2006^52^ Charleston, US (32°N) [17661565] | - Male (%) | 0 | Lactating mother's dietary Vit D 273 IU/d; dietary calcium intake: 1125 mg/d; | Mother Vit D_3_ 400 IU/d + infant 300 IU/d vs. mother 6400 IU/d + infant 0 IU/d | ≥80% in mothers; as low as 61% for infants | 78% white; 11% black; 11% Hispanic
Marya 1988^50^ India (28°N) [3243609] | - Health status | no pregnancy-related complications | Expectant mother's dietary Vit D 35 IU/d; calcium 429 mg/d | Mother Vit D 1.2 mil IU (total; 600,000 IU vit D_2_ in 7^th^ & 8^th^ mo) vs. no supplement | nd
Marya 1988^50^ India (28°N) [3243609] | - Mean age (range/SD), y | 24 | Expectant mother's dietary Vit D 35 IU/d; calcium 429 mg/d | Mother Vit D 1.2 mil IU (total; 600,000 IU vit D_2_ in 7^th^ & 8^th^ mo) vs. no supplement | nd
Marya 1988^50^ India (28°N) [3243609] | - Male (%) | 0 | Expectant mother's dietary Vit D 35 IU/d; calcium 429 mg/d | Mother Vit D 1.2 mil IU (total; 600,000 IU vit D_2_ in 7^th^ & 8^th^ mo) vs. no supplement | nd
Mallet 1986^53^ France (48°N) [3755517] | - Health status | pregnancy | Ca intake 550 to 1000 mg/d in 55% of the subjects | Vit D 1000 IU/d vs. 200,000 IU 1× dose | nd
Mallet 1986^53^ France (48°N) [3755517] | - Mean age (range/SD), y | newborn | Ca intake 550 to 1000 mg/d in 55% of the subjects | Vit D 1000 IU/d vs. 200,000 IU 1× dose | nd
Mallet 1986^53^ France (48°N) [3755517] | - Male (%) | nd | Ca intake 550 to 1000 mg/d in 55% of the subjects | Vit D 1000 IU/d vs. 200,000 IU 1× dose | nd
Nonrandomized comparative study
Marya 1981^54^ India (28°N) [7239350] | - Health status | no pregnancy-related complications | Expectant mother's daily milk intake <500 mL; dietary Vit D <30 IU/d | Vit D 1200 IU/d + Ca 375 mg/d (3^rd^ trimester) or Vit D 1.2 mil IU (total; 600,000 IU in 7^th^ & 8^th^ mo) or no supplement | nd
Marya 1981^54^ India (28°N) [7239350] | - Mean age (range/SD), y | nd | Expectant mother's daily milk intake <500 mL; dietary Vit D <30 IU/d | Vit D 1200 IU/d + Ca 375 mg/d (3^rd^ trimester) or Vit D 1.2 mil IU (total; 600,000 IU in 7^th^ & 8^th^ mo) or no supplement | nd
Marya 1981^54^ India (28°N) [7239350] | - Male (%) | 0 | Expectant mother's daily milk intake <500 mL; dietary Vit D <30 IU/d | Vit D 1200 IU/d + Ca 375 mg/d (3^rd^ trimester) or Vit D 1.2 mil IU (total; 600,000 IU in 7^th^ & 8^th^ mo) or no supplement | nd
New Studies
Hollis, 2011^1^ Charleston, US | - Health status | Healthy 27 (18–41/5.6) | serum: delivered group- 59.5 23.8 nmol/L (6.0–172.5) exited group- 50.5 25.1nmol/L (6.5–120.5) vit D intake: 400 IU group- 181.6 +/-108.4 IU/d, 2000 IU group- 195.8 +/-135.0, 4000 IU group- 204.2 +/-148.2 calcium intake: 400 IU group-1063.6 +/-539.6 mg/d, 2000 IU group- 993.9 +/-514.0 mg/d, 4000 IU group- 1073.6+/- 491.9 mg/d | Birth weight: Vit D 4000 IU vs. Vit D 2000 IU vs. Vit D 400 IU | 69% (400-IU group), 68% (2000-IU group), and 69% (4000-IU group, p¼0.9) | Assignment to the interventions was only partially random: Baseline serum 25(OH)D also partly determined assignment
Hollis, 2011^1^ Charleston, US | - Mean age (range/SD), y | 0% | | Birth weight: Vit D 4000 IU vs. Vit D 2000 IU vs. Vit D 400 IU | 69% (400-IU group), 68% (2000-IU group), and 69% (4000-IU group, p¼0.9) | Assignment to the interventions was only partially random: Baseline serum 25(OH)D also partly determined assignment
Hollis, 2011^1^ Charleston, US | - Male (%) | | | Birth weight: Vit D 4000 IU vs. Vit D 2000 IU vs. Vit D 400 IU | 69% (400-IU group), 68% (2000-IU group), and 69% (4000-IU group, p¼0.9) | Assignment to the interventions was only partially random: Baseline serum 25(OH)D also partly determined assignment
Kalra, 2012^43^ India | - Health status | nd | Table 2: Group 1 – 31.7 nmol/L (14.0–57.2) Group 2– 32.0 nmol/L (14.5–45.7) | Birth weight: 3000 mg cholecalciferol (one dose 2nd trimester and 28 weeks gestation) vs. 1500 mg cholecalciferol (one dose 2nd trimester) Length at Birth: 3000 mg cholecalciferol (one dose 2nd trimester and 28 weeks gestation) vs. 1500 mg cholecalciferol (one dose 2nd trimester) | nd
Kalra, 2012^43^ India | - Mean age (range/SD), y | 26.7 (SD 4.0) | Table 2: Group 1 – 31.7 nmol/L (14.0–57.2) Group 2– 32.0 nmol/L (14.5–45.7) | | nd
Kalra, 2012^43^ India | - Male (%) | 0% | Table 2: Group 1 – 31.7 nmol/L (14.0–57.2) Group 2– 32.0 nmol/L (14.5–45.7) | | nd
Roth 2013^44^ Bangladesh | - Health status | | Healthy 22.4 (SD 3.5) | Serum 25(OH)D placebo: 44.0 ± 20.9 nmol/l vitamin D: 45.4 ± 18.4 nmol/l | Birth weight: 35000 IU Vit D3 3rd trimester vs. Placebo Length at birth: 35000 IU Vit D3 3rd trimester vs. Placebo | 99.2 ± 2.7%
Roth 2013^44^ Bangladesh | - Mean age (range/SD), y | | | Serum 25(OH)D placebo: 44.0 ± 20.9 nmol/l vitamin D: 45.4 ± 18.4 nmol/l | Birth weight: 35000 IU Vit D3 3rd trimester vs. Placebo Length at birth: 35000 IU Vit D3 3rd trimester vs. Placebo | 99.2 ± 2.7%
Roth 2013^44^ Bangladesh | - Male (%) | | 0% | Serum 25(OH)D placebo: 44.0 ± 20.9 nmol/l vitamin D: 45.4 ± 18.4 nmol/l | Birth weight: 35000 IU Vit D3 3rd trimester vs. Placebo Length at birth: 35000 IU Vit D3 3rd trimester vs. Placebo | 99.2 ± 2.7%
NEW Cohort study
Wagner 2013^42^ US | - Health status | | nd | 61.5 nmol/L | 2000 IU vit D3 vs. 4000 IU vit D3 vs. control | NR
Wagner 2013^42^ US | - Mean age (range/SD), y | | 27 (18–41) | 61.5 nmol/L | 2000 IU vit D3 vs. 4000 IU vit D3 vs. control | NR
Wagner 2013^42^ US | - Male (%) | | 0% | 61.5 nmol/L | 2000 IU vit D3 vs. 4000 IU vit D3 vs. control | NR

Table 5 Vitamin D and growth outcomes: Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demographics | Anthropometric Measures | Medical | UV Exposure | Lifestyle | Comments
Morley 2006^56^ Australia (38°S) [16352684] | - Health status | singleton pregnancy; no disease | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | O | X | X | 0 | X | X | 99% white; excluded dark skin or women with concealing clothing
Morley 2006^56^ Australia (38°S) [16352684] | - Mean age (range/ SD), y | 29 | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | O | X | X | 0 | X | X | 99% white; excluded dark skin or women with concealing clothing
Morley 2006^56^ Australia (38°S) [16352684] | - Male (%) | 0 | - Season blood drawn | winter & summer | Length and weight in offspring stratified by mother's 25(OH)D | O | X | X | 0 | X | X | 99% white; excluded dark skin or women with concealing clothing
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Health status | singleton pregnancy <17 wk | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | 0 | X | 0 | 0 | X | 0 | White only
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Mean age (range/ SD), y | 26.3 | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | 0 | X | 0 | 0 | X | 0 | White only
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Male (%) | 0 | - Season blood drawn | nd | Length and weight in offspring stratified by mother's 25(OH)D | 0 | X | 0 | 0 | X | 0 | White only
New Studies
Burris 2012 45 Massachusetts, US | - Health status | nd | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | 0
Burris 2012 45 Massachusetts, US | - Mean age (range/SD), y | 33 (SD 4.5) | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | 0
Burris 2012 45 Massachusetts, US | - Male (%) | 0% | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | 0
Gernand, 2013^46^ US | - Health status | Singleton gestation | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | X
Gernand, 2013^46^ US | - Mean age (range/SD), y | nd | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | X
Gernand, 2013^46^ US | - Male (%) | 0% | | | Weight in offspring stratified by mother's 25(OH)D | 0 | X | X | 0 | X | X

Abbreviations: X = factor adjusted for in analysis; O = factor not adjusted for.

Table 6 Vitamin D and growth outcomes: Results of RCTs (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change (SD) | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth weight | 2° | until delivery | Vit D 1000 IU | 59 | g | NA | Final 3157 | 3037, 3277 | Diff 123 | -50, 296^A^ | NS | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth weight | 2° | until delivery | | | | | | | | | | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth weight | 2° | until delivery | Control | 67 | | NA | 3034 | 2909, 3159 | | | | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | | | | | | | | | | | | | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth length | 2° | until delivery | Vit D 1000 IU | 59 | cm | NA | Final 49.7 | 49.6, 49.8 | Diff 0.2 | 0.1, 0.3^A^ | NS | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth length | 2° | until delivery | | | | | | | | | | B
Maxwell 1981^51^ Brooke 1980^47^ [6793058] [6989438] | Pregnant women & infant 0–6 mo (Asians) | Infant birth length | 2° | until delivery | Control | 67 | | NA | 49.5 | 49.4, 49.6 | | | | B
Feliciano 1994^49^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^B^ | 1° | 6 mo | Vit D 400 IU | 12 | g | nd | 3745 | 2613, 4877 | -463 | ‐1852, 926^A^ | NS | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^B^ | 1° | 6 mo | | | | | | | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^B^ | 1° | 6 mo | Vit D 200 IU | 13 | | nd | 5296 | 4718, 5874 | 1088 | 96, 2080^A^ | NS | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^B^ | 1° | 6 mo | | | | | | | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Weight gain born in spring, N. China^B^ | 1° | 6 mo | Vit D 100 IU | 17 | | nd | 4208 | 3402, 5013 | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | | | | | | | | | | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 400 IU | 12 | cm | nd | 18.8 | 17.4, 20.2 | -0.5 | -2.7, 1.7^A^ | NS | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | | | | | | | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 200 IU | 13 | | nd | 19 | 18.1, 19.9 | -0.3 | -2.2, 1.6^A^ | NS | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | | | | | | | | | | C
Feliciano 1994^49^ [8078115] | 0–6 mo | Length gain born in spring, N. China | 1° | 6 mo | Vit D 100 IU | 15 | | nd | 19.3 | 17.6, 21.0 | | | | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Vit D_3_ 2000 IU | nd, ≤34 total | % | nd | 5.60% | ∼4.8, 6.4^C^ | ∼1.8% | ∼0.6, 3.0^A^ | 0.07 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | | nd, ≤34 total | | | | | | | 0.07 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Vit D_3_ 200 IU | nd, ≤34 total | | nd | 5.00% | ∼4.2, 5.8^C^ | ∼1.2% | ∼‐0.01, 2.4^A^ | 0.07 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | | nd, ≤34 total | | | | | | | 0.07 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Height | 2° | 1 y | Placebo | nd, ≤34 total | | nd | 3.80% | ∼0.9, 6.7^C^ | | | 0.07 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | | | | | | | | | | | | | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Vit D_3_ 2000 IU | nd, ≤34 total | % | nd | 18.40% | ∼14.7, 22.1^C^ | ∼3.5% | ∼‐1.3, 8.3^A^ | 0.25 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | | nd, ≤34 total | | | | | | | 0.25 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Vit D_3_ 200 IU | nd, ≤34 total | | nd | 15.30% | ∼12.5, 18.1^C^ | ∼0.4 | -3.7, 4.5^A^ | 0.25 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | | nd, ≤34 total | | | | | | | 0.25 | C
El-Hajj 2006^48^ [16278262] | 9–18 y female, premenarche | Weight | 2° | 1 y | Placebo | nd, ≤34 total | | nd | 14.90% | ∼11.8, 18.0^C^ | | | 0.25 | C
Wagner 2006^52^ [17661565] | Lactating mothers & infant | Infant weight^C^ | 1° | 7 mo | Mother (400) +infant (300) | 10 | g | NA | Final 7600 | 7100, 8100 | Diff -800 | ‐2300, 700^A^ | 0.3 | C
Wagner 2006^52^ [17661565] | Lactating mothers & infant | Infant weight^C^ | 1° | 7 mo | | | | | | | | | | C
Wagner 2006^52^ [17661565] | Lactating mothers & infant | Infant weight^C^ | 1° | 7 mo | Mother (6400) +infant (0) | 9 | | NA | 8400 | 7700, 9100 | | | | C
Wagner 2006^52^ [17661565] | | | | | | | | | | | | | | C
Wagner 2006^52^ [17661565] | 0–6 mo; 7 mo–2 y | Infant length | 1° | 7 mo | Mother (400) +infant (300) | 10 | cm | NA | Final 65.5 | 64.4, 66.6 | Diff -3.8 | -7.8, 0.2^A^ | 0.06 | C
Wagner 2006^52^ [17661565] | 0–6 mo; 7 mo–2 y | Infant length | 1° | 7 mo | | | | | | | | | | C
Wagner 2006^52^ [17661565] | 0–6 mo; 7 mo–2 y | Infant length | 1° | 7 mo | Mother (6400) +infant (0) | 9 | | NA | 69.3 | 67.4, 71.2 | | | | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth weight | 1° | Delivery | Vit D 1.2 mil IU total | 100 | g | NA | Final 2990 | 2920, 3060 | Diff 190 | 90, 290^A^ | <0.001 | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth weight | 1° | Delivery | | | | | | | | | | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth weight | 1° | Delivery | No supplement | 100 | | NA | 2800 | 2730, 2870 | | | | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | | | | | | | | | | | | | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth length | 2° | | Vit D 1.2 mil IU total | 100 | cm | NA | Final 50.06 | 49.7, 50.4 | Diff 1.6 | 1.1, 2.1^A^ | <0.001 | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth length | 2° | | | | | | | | | | | C
Marya 1988^50^ India [3243609] | Pregnant women & infant 0–6 mo | Birth length | 2° | | No supplement | 100 | | NA | 48.45 | 48.1, 48.8 | | | | C
Marya 1981^54^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | Vit D 1.2 mil IU total | 20 | g | NA | Final 3140 | 2940, 3340 | Diff 410 | 166, 654^A^ | 0.001 | C
Marya 1981^54^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | | | | | | | | | | C
Marya 1981^54^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | Vit D 1200 IU + 375 mg Ca (3^rd^ trimester) | 25 | g | NA | Final 2890 | 2760, 3020 | Diff 160 | 0, 320^A^ | 0.05 | C
Marya 1981^54^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | | | | | | | | | | C
Marya 1981^54^ [7239350]^E^ | Pregnant women & infant 0–6 mo | Birth weight | 2° | Delivery | No supplement | 75 | | NA | 2730 | 2650, 2810 | | | | C
Mallet 1986^53^ France (48° N) [3755517] | Pregnant women & infant 0–6 mo | Birth weight | 2° | delivery | Vit D 1000 IU | 21^D^ | g | NA | Final 3370 (80) | | Diff 160 | | NS | C
Mallet 1986^53^ France (48° N) [3755517] | Pregnant women & infant 0–6 mo | Birth weight | 2° | delivery | | | | | | | | | | C
Mallet 1986^53^ France (48° N) [3755517] | Pregnant women & infant 0–6 mo | Birth weight | 2° | delivery | Vit D 200,000 IU 1× dose | 27^D^ | | NA | 3210 (90) | | | | | C
NEW Studies
Hollis 2011^1^ | Pregnant or lactating women | Birth weight | 2° | Delivery | Vit D 4000 IU | 117 | g | NR | Final 3284.6 | 3175.2, 3394.0 | +62.8 | -103.4, 229.0 | 0.23 | A
Hollis 2011^1^ | Pregnant or lactating women | Birth weight | 2° | Delivery | | | g | NR | | | | | | A
Hollis 2011^1^ | Pregnant or lactating women | Birth weight | 2° | Delivery | Vit D 2000 IU | 122 | g | NR | Final 3360.1 | 3255.2, 3465.0 | +138.3 | -24.4, 301.0 | | A
Hollis 2011^1^ | Pregnant or lactating women | Birth weight | 2° | Delivery | | | g | NR | | | | | | A
Hollis 2011^1^ | Pregnant or lactating women | Birth weight | 2° | Delivery | Vit D 400 IU | 111 | g | NR | Final 3221.8 | 3094.9, 3348.8 | | | | A
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Birth weight | 1° | Delivery | 3000 mg cholecalciferol (one dose 2nd trimester and 28 weeks gestation) | 35 | kg | NR | Final 3.03 | 1.71, 4.35 | -0.05 | -1.92, 1.82 | 0.96 | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Birth weight | 1° | Delivery | | | | NR | | | | | | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Birth weight | 1° | Delivery | 1500 mg cholecalciferol (one dose 2nd trimester) | 36 | kg | NR | Final 3.08 | 1.71, 4.45 | | | | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | | | | | | | | | | | | | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Length at birth | 1° | Delivery | 3000 mg cholecalciferol (one dose 2nd trimester and 28 weeks gestation) | 35 | cm | NR | Final 50.1 | 49.8, 50.4 | -0.2 | -0.6, 0.2 | 0.35 | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Length at birth | 1° | Delivery | | | | NR | | | | | | C
Kalra 2012^43^ | Pregnant or lactating women between 12–24 weeks gestation | Length at birth | 1° | Delivery | 1500 mg cholecalciferol (one dose 2nd trimester) | 36 | cm | NR | Final 50.3 | 50.0, 50.6 | | | | C
Roth 2013^44^ | | Birth weight | 2° | Delivery | 35000 IU Vit D^3^ 3rd trimester | 73 | g | NR | Final 2802 | 2675, 2929 | +14 | -138, 166 | 0.86 | A
Roth 2013^44^ | | Birth weight | 2° | Delivery | | | | NR | | | | | | A
Roth 2013^44^ | | Birth weight | 2° | Delivery | Placebo | 74 | g | NR | Final 2788 | 2700, 2876 | | | | A
Roth 2013^44^
Roth 2013^44^ | | Length at birth | 2° | Delivery | 35000 IU Vit D^3^ 3rd trimester | 73 | cm | NR | Final 48.2 | 47.6, 48.8 | +0.2 | -0.5, 0.9 | 0.55
Roth 2013^44^ | | Length at birth | 2° | Delivery | Placebo | 74 | cm | NR | Final 48 | 47.5, 48.5
Wagner 2013^42^ | | neonatal birth weight | 1° | | 2000 IU vit D^3^ | 201 | g | NR | Final 3382 | sd=759 | +149 | -21, 319 | 0.09 | B
Wagner 2013^42^ | | neonatal birth weight | | | 4000 IU vit D^3^ | 193 | g | NR | Final 3231 | sd=632 | -2 | -154, 150 | 0.98 | B
Wagner 2013^42^ | | neonatal birth weight | | | control | 110 | g | NR | Final 3233 | sd=668 | | | | B

Note: Outcomes cells are shaded for the Control rows.

A Estimated from available data.

B See Table 1 in original paper for complete results stratified by North vs. South China and birth in spring vs. fall.

C See Table 3 in original paper for results on 1 mo and 4 mo.

D Estimated from number of mothers; number of infants not reported.

E This is not an RCT; the supplemented groups were randomized, but not the control (non-supplemented group); data from comparisons between the supplemented groups not reported.

Table 7 Vitamin D and growth outcomes: Results of cohort studies (updated from original report)

Author Year Study Name PMID | Life Stage | Outcome (n/N; Incidence) | Followup Duration | Maternal 25(OH)D Concentration, nmol/L | No. in Category | Final Value | Final SD | P Value | Study Quality
Morley 2006^56^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth weight (N=374) | Delivery | <28 at 28–32 wk | 27 | 3397 g | 57 | NS | B
Morley 2006^56^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth weight (N=374) | Delivery | ≥28 at 28–32 wk | 347 | 3555 | 52 | NS | B
Morley 2006^56^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth length (N=374) | Delivery | <28 at 28–32 wk | 27 | 49.8 cm | 2.7 | NS | B
Morley 2006^56^ Australia [16352684] | Pregnant women; infant 0–6 mo | Birth length (N=374) | Delivery | ≥28 at 28–32 wk | 347 | 50.4 | 2.4 | | B
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | <30 (Quartile) | nd | 3.38 kg | 0.46 | 0.25^A^ | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | 30–50 | nd | 3.4 | 0.56 | 0.25^A^ | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | 50–75 | nd | 3.49 | 1.57 | 0.25^A^ | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth weight (N=466) | Delivery | >75 | nd | 3.43 | 0.51 | 0.25^A^ | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | <30 | nd | 15.9 | 1.14 | 0.58 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | 30–50 | nd | 15.8 | 1.26 | 0.58 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | 50–75 | nd | 16.1 | 1.34 | 0.58 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 mo (N=440) | 9 mo | >75 | nd | 15.9 | 1.09 | 0.58 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | <30 | nd | 27.4 kg | 1.19 | 0.1 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | 30–50 | nd | 29.4 | 1.21 | 0.1 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | 50–75 | nd | 30 | 1.2 | 0.1 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Weight at 9 y (N=178) | 9 y | >75 | nd | 29.3 | 1.19 | 0.1 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | <30 | nd | 50 cm | 1.83 | 0.15 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | 30–50 | nd | 50 | 2.29 | 0.15 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | 50–75 | nd | 50.5 | 2.25 | 0.15 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Birth length (N=466) | Delivery | >75 | nd | 50.1 | 2.09 | 0.15 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | <30 | nd | 71.2 cm | 2.85 | 0.86 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | 30–50 | nd | 71.4 | 2.6 | 0.86 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | 50–75 | nd | 71.7 | 2.89 | 0.86 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Length at 9 mo (N=440) | 9 mo | >75 | nd | 71.1 | 2.67 | 0.86 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | <30 | nd | 129.6 cm | 5.88 | 0.19 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | 30–50 | nd | 131.5 | 6.66 | 0.19 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | 50–75 | nd | 131.8 | 5.09 | 0.19 | C
Gale 2008^55^ PAHSG, UK [17311057] | Pregnant women; infant 0–6 mo | Height at 9 y (N=178) | 9 y | >75 | nd | 130.6 | 6.45 | 0.19 | C
NEW Studies
Burris 2012^45^ | Pregnant or lactating women | Birth weight | Delivery | <25 | 47 | 3.46kg | SD=0.68 | ND
Burris 2012^45^ | Pregnant or lactating women | Birth weight | Delivery | 25–50 | 314 | 3.55kg | SD=0.52 | ND
Burris 2012^45^ | Pregnant or lactating women | Birth weight | Delivery | 50–75 | 543 | 3.53kg | SD=0.51 | ND
Burris 2012^45^ | Pregnant or lactating women | Birth weight | Delivery | ≥75 | 229 | 3.51kg | SD=0.52 | ND
Gernand 2013^46^ | singleton gestation | Birth weight | Delivery | <37.5 | 747 | 3127g | SD=15 | 0.014
Gernand 2013^46^ | singleton gestation | Birth weight | Delivery | ≥37.5 | 1399 | 3215g | SD=11 | 0.014

In the current report, five RCTs (reported in four articles)1,42-44 reported on the effect of vitamin D supplementation during pregnancy on birth weight and/or length. Two cohort studies reported on the association between maternal serum 25(OH)D concentration and birth weight and/or length.45,46 The number of participants in the RCTs ranged from 140 to 504; the two cohort studies followed 1,113 and 2,146 mother-infant pairs. One U.S. RCT divided 350 women who were already receiving prenatal vitamins that provided 400IU per day at 16 weeks gestation or earlier into three groups, who were given an addition 0, 1,600, or 3,600 IU vitamin D per day through the remainder of gestation; the study found no difference in birth weight among interventional arms (rated A).1 The second study, a pseudo-RCT conducted in India, divided 140 pregnant women at 12 to 24 weeks gestation into two groups: one was administered one 1,500 microgram dose of vitamin D, and the other received two doses of 3,000 micrograms vitamin D. A group of untreated women who were 24 week pregnant or more served as the controls. Both of the treated groups gave birth to infants who were significantly heavier than the usual care group (p=0.003) (rated C, largely attributable to incomplete reporting and the fact that the study was not a truly randomized study).43 The third RCT, the AViDD study, conducted in Bangladesh randomly divided 160 women at 26 to less than 30 weeks gestation to receive 35,000IU vitamin D per week or no supplement; no difference was seen in birth weight or length, although the study was not powered to see differences in these outcomes (rated A).44 For the fourth and fifth studies, data from the National Institute of Child Health and Disease (NICHD) and Thrasher Research Fund Vitamin D_3_ Supplementation studies, in which pregnant women were randomized to receive 0, 2000, or 4000 IU vitamin D per day in addition to their prenatal vitamins, were analyzed in combination: No differences were observed in birth weight among the groups (rated B).42

In the original report, six RCTs47-53 and one nonrandomized comparative study54 in eight publications reported on the effect of vitamin D supplementation on growth parameters in infants and children. Two cohort studies reported on the association between maternal serum 25(OH)D concentration and her offspring's growth parameters.55,56 The number of subjects in the RCTs ranged from 19 to 200. The two cohort studies had 374 and 466 subjects, respectively. The latitudes of the studies ranged from 38° to 51°. Four studies administered vitamin D exclusively to expectant mothers during the third trimester of pregnancy. One study administered vitamin D to both the lactating mothers and her offspring. Two studies administered vitamin D only to the infants or children. Follow up ranged from delivery until 9 years. Methodological quality of two studies were rated B and seven studies were rated C. The studies were limited by such factors as incomplete reporting and small sample sizes.

##### Infant 0–6 Months; 7 Months–2 Years; Pregnant or Lactating Women

For the current report, five RCTs (reported in four articles) were identified that administered supplemental vitamin D to pregnant women and assessed the effect on birth weight of the offspring. One U.S. RCT divided 350 women who were already receiving prenatal vitamins that provided 400IU per day at 16 weeks gestation or earlier into three groups, who were given an addition 0, 1600, or 3600IU vitamin D per day through the remainder of gestation (assignment to the interventions was only partially random: Baseline serum 25(OH)D partly determined assignment); the study found no difference in birth weight among interventional arms.1 A pseudo-RCT conducted in India divided 140 pregnant women at 12 to 24 weeks gestation into two groups: one was administered one 1,500 microgram dose of vitamin D, and the other received two doses of 3,000 micrograms vitamin D. A group of untreated women who were 24 week pregnant or more served as the controls. Both of the treated groups gave birth to infants who were significantly heavier than the usual care group (p=0.003).43 A third RCT, the AViDD study, conducted in Bangladesh randomly divided 160 women at 26 to less than 30 weeks gestation to receive 35,000IU vitamin D per week or no supplement; no difference was seen in birth weight or length, although the study was not powered to see differences in these outcomes. Data from the National Institute of Child Health and Disease (NICHD) and Thrasher Research Fund Vitamin D_3_ Supplementation studies, in which pregnant women were randomized to receive 0, 2000, or 4000 IU vitamin D per day in addition to their prenatal vitamins, were analyzed in combination: No differences were observed in birth weight among the intervention groups.42 Two cohort studies assessed the effects of maternal serum 25(OH)D concentrations on birth weight in the United States. One study of 1,113 mother-infant pairs assessed the association between second trimester 25(OH)D and birth weight and the effect of race. No association was seen between quartile of maternal 25(OH)D and birth weight; but the higher risk for low birth weight among black mothers was reduced significantly when adjusted for maternal 25(OH)D (study rated A). The other cohort study, of 2,146 mother-infant pairs found a significant association between low serum 25(OH) D concentrations and lower birth weight (study rated B).46

In the original report, one RCT from UK administered vitamin D 1000 IU/d or placebo to 126 expectant mothers (first generation Asian immigrants) during the third trimester and found no significant difference between the infants' birth weights or birth lengths and those of the control population.47,51 There were twice as many low birth weight infants (<2500 g) in the control group compared to the supplemented group (21.7% vs. 11.9%); however, this difference was not significant. A study from U.S. supplemented 10 lactating mothers with vitamin D 400 IU/d and their infants with 300 IU/d for 6 months. Compared to the group where nine mothers received 6400 IU/d and their infants none, there was no significant difference in the infants' weight or length at 1 month, 4 months, and 7 months of age.52 A study from China randomly assigned 255 newborn infants to 100, 200, or 400 IU/d of vitamin D for 6 months and reported no significant difference in weight or length among the three groups at 6 months of age.49 One study from India randomly selected 100 expectant mothers to receive a total of 1.2 million IU of vitamin D (600,000 IU of vitamin D_2_ in 7th and 8th month) during the third trimester. The newborns' birth weight was significantly increased compared to those from 100 unsupplemented expectant mothers (difference 190 g).50 Important elements of the study methodology like randomization technique and any blinding of outcome assessors were not reported. An earlier nonrandomized comparison from the same study center involving smaller samples reported similar findings.54 The estimated baseline mean dietary vitamin D intake in the expectant mothers from these two studies was less than 30 to 35 IU/d (the validity of these measures is unclear). An RCT from France supplemented 48 expectant mothers with either vitamin D 1000 IU/d in the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants' birth weights between the two methods.53 A cohort study from Australia analyzed the maternal serum 25(OH)D concentration in 374 women at 28–32 week gestation (geometric mean in winter 48 nmol/L; summer 69 nmol/L) and found no association with infant birth weight or length.56 One cohort study from UK analyzed the serum 25(OH)D concentration in 466 white women in late pregnancy (∼33 wk) and found the concentrations (from <30 to >75 nmol/L) were not related to their offspring's weight or height at birth, 9 months, and 9 years.55

##### 9–18 Years

One RCT of vitamin D_3_ (placebo, 200, or 2000 IU/d for 1 year) on girls in Lebanon aged 10–17 years found no significant difference at 1 year follow up in weight or height among the 34 girls who were premenarchal at time of enrollment.48

#### Findings by Life Stage

- 0–6 mo
  For the current report, the results for birth weight and length are reported above. In the original report, one RCT found that supplementing expectant mothers with vitamin D 1000 IU/d during the 3^rd^ trimester has no effect on infant birth weight or length. Another RCT found that supplementing expectant mothers with a total of 1.2 million IU of vitamin D during the 3^rd^ trimester affected a significant increase in birth weight (+190 g). Background diet is low in vitamin D in this study. A study compared supplementing lactating mothers with vitamin D 400 IU/d and their infants 300 IU/d for 6 months with mothers supplemented with 6400 IU/d and their infants none, there was no significant difference in the infants' weight or length at 1 month, 4 months, and 7 months of age. Another study compared supplementing newborn infants with 100, 200, or 400 IU/d of vitamin D for 6 months and reported no significant difference in weight or length at 6 months of age. An RCT supplemented expectant mothers with either vitamin D 1000 IU/d during the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants' birth weights between the two methods. A cohort study analyzed the maternal serum 25(OH)D concentration at 28–32 week gestation (geometric mean in winter 48 nmol/L; summer 69 nmol/L) and found no association with infant birth weight or length. Another cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (∼33 wk) was not related to the newborn's weight or height at birth, 9 months, and 9 years.
- 7 mo–2 y
  A cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (∼33 wk) was not related to the newborn's weight or height at birth, 9 months, and 9 years.
- 3–8 y
  No study covered this life stage.
- 9–18 y
  A cohort study found that serum 25(OH)D concentration (ranged from <30 to >75 nmol/L) in late pregnancy (∼33 wk) was not related to the newborn's weight or height at birth, 9 months, and 9 years. One RCT of vitamin D_3_ (placebo, 200, or 2000 IU/d for 1 year) on girls 10–17 years old found no significant difference at 1 year follow up in weight or height among the girls who were premenarchal at time of enrollment.
- 19–50 y
  Not reviewed
- 51–70 y
  Not reviewed
- ≥71 y
  Not reviewed
- Postmenopause
  Not reviewed
- Pregnant & lactating women: The results for the current study are reported above. For the original study, one RCT found that supplementing expectant mothers with vitamin D 1000 IU/d during the 3^rd^ trimester has no effect on infant birth weight or length. Another RCT found that supplementing expectant mothers with a total of 1.2 million IU of vitamin D during the 3^rd^ trimester affected a significant increase in birth weight (+190 g). Background diet is low in vitamin D in this study. A study compared supplementing lactating mothers with vitamin D 400 IU/d and their infants 300 IU/d for 6 months with mothers supplemented with 6400 IU/d and their infants none, there was no significant difference in the infants' weight or length at 1 month, 4 months, and 7 months of age. An RCT supplemented expectant mothers with either vitamin D 1000 IU/d during the third trimester or 200,000 IU one time dose at 7 month pregnancy and found no significant difference in the infants' birth weights between the two methods.

### Vitamin D and Cardiovascular Disease

#### Synopsis

One qualified systematic review of prospective studies identified for the current report found a significant association between low serum 25(OH)D concentrations and a number of clinical cardiovascular outcomes, including total cardiovascular disease, coronary heart disease, cardiovascular disease mortality, and stroke. No RCTs identified for the current report evaluated the effects of vitamin D on clinical cardiovascular disease outcomes. Observational studies identified for the current report found mixed associations between 25(OH)D and total cardiovascular events, cardiovascular death, myocardial infarction, stroke, and fatal stroke. Significant associations were found between progressively lower 25(OH)D concentration and increased risk for cardiovascular events in two studies of people approximately 40 to 75 years old. No significant associations were found between serum 25(OH)D concentrations and cardiovascular death, myocardial infarction, or stroke in one study each.

For the original report, no qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and incidence of hypertension. One RCT of almost 2700 elderly British who received either vitamin D_3_ 100,000 IU every 4 months or placebo for 5 years found no statistically significant difference in event rates for various cardiovascular outcomes, including total events and cardiovascular deaths. No effects were also found in subgroup analyses of men and women. Three cohort and one nested case-control studies have analyzed the association between serum 25(OH)D concentrations and cardiovascular outcomes (cardiovascular events, nonfatal myocardial infarction or fatal coronary heart disease, cardiovascular death, myocardial infarction, and stroke). Significant associations were found between progressively lower 25(OH)D concentration and progressively increased risk of cardiovascular events in two studies of people approximately 40 to 75 years old. No significant associations were found between serum 25(OH)D concentrations and cardiovascular death, myocardial infarction, or stroke in one study each.

#### Detailed Presentation

(Tables 8, 9, 10,and 11a-b; Figures 6a-h)

Table 8 Vitamin D and cardiovascular outcomes: Characteristics of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Trivedi 2003^66^ Ipswich, UK (52°N) [12609940] | - Health status | General population | 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | 76% with at least 80% compliance; 66% at last dose (80% if excluding deaths)
Trivedi 2003^66^ Ipswich, UK (52°N) [12609940] | - Mean age (range), y | 75 (65–85) | 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | 76% with at least 80% compliance; 66% at last dose (80% if excluding deaths)
Trivedi 2003^66^ Ipswich, UK (52°N) [12609940] | - Male (%) | 76% | 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | 76% with at least 80% compliance; 66% at last dose (80% if excluding deaths)

Table 9 Vitamin D and cardiovascular outcomes: Results of RCTs [no new studies in the current report]

Author Year Study Name [PMID] | Age Range, Sex (Subgroup) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CVD, total | 2° | 5 y | Vit D_3_ 100,000 IU every 4 mo | 477 | 1345 | Age adj RR (Vit D/ Placebo) | 0.90^A^ | 0.77, 1.06 | 0.22 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CVD, total | 2° | 5 y | Placebo | 503 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | IHD, total | 2° | 5 y | Vit D_3_ | 224 | 1345 | Age adj RR (Vit D/ Placebo) | 0.94^A^ | 0.77, 1.15 | 0.57 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | IHD, total | 2° | 5 y | Placebo | 233 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CeVD, total | 2° | 5 y | Vit D_3_ | 105 | 1345 | Age adj RR (Vit D/ Placebo) | 1.02^A^ | 0.77, 1.36 | 0.87 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CeVD, total | 2° | 5 y | Placebo | 101 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CVD death | 1° | 5 y | Vit D_3_ | 101 | 1345 | Age adj RR (Vit D/ Placebo) | 0.84^A^ | 0.65, 1.10 | 0.20 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CVD death | 1° | 5 y | Placebo | 117 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | IHD death | 1° | 5 y | Vit D_3_ | 42 | 1345 | Age adj RR (Vit D/ Placebo) | 0.84^A^ | 0.56, 1.27 | 0.41 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | IHD death | 1° | 5 y | Placebo | 49 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CeVD death | 1° | 5 y | Vit D_3_ | 28 | 1345 | Age adj RR (Vit D/ Placebo) | 1.04^A^ | 0.61, 1.20 | 0.89 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both | CeVD death | 1° | 5 y | Placebo | 26 | 1341 | | | | | B

Note: Outcomes cells are shaded for the Control rows.

Similar results for subgroups of men and women

Table 10 Vitamin D and cardiovascular outcomes: Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Specific CVD Outcomes
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Specific CVD Outcomes
Wang 2008^67^ Framingham Offspring Framingham, MA (mostly) (42°N) [18180395] | - Health status | No CVD | - Assay method | RIA (DiaSorin) | Outcome stratified by 2 or 3 categories | X^A^ | X | X | X | X^A^ | X | CVD event
Wang 2008^67^ Framingham Offspring Framingham, MA (mostly) (42°N) [18180395] | - Mean age (SD), y | 59 (9) | - Assay method | RIA (DiaSorin) | Outcome stratified by 2 or 3 categories | X^A^ | X | X | X | X^A^ | X | CVD event
Wang 2008^67^ Framingham Offspring Framingham, MA (mostly) (42°N) [18180395] | - Male (%) | 45 | - Season blood drawn | All | Outcome stratified by 2 or 3 categories | X^A^ | X | X | X | X^A^ | X | CVD event
Giovannucci 2008^68^ HPFS US (various) [18541825] | - Health status | No CVD | - Dietary assessment method | RIA (Hollis 1993) | Outcome stratified by 4 categories^B^ | X | X | X | X | X | X | Nonfatal MI or fatal CHD
Giovannucci 2008^68^ HPFS US (various) [18541825] | - Mean age (range), y | 64 (40‐75) | - Dietary assessment method | RIA (Hollis 1993) | Outcome stratified by 4 categories^B^ | X | X | X | X | X | X | Nonfatal MI or fatal CHD
Giovannucci 2008^68^ HPFS US (various) [18541825] | - Male (%) | 100 | - Internal validation? (y/n) | All | Outcome stratified by 4 categories^B^ | X | X | X | X | X | X | Nonfatal MI or fatal CHD
Melamed 2008^85^ NHANES III US (various) [18695076] | - Health status | Any | - Assay method | RIA (DiaSorin) | Outcome stratified by 4 categories | X | X | X | X | X | X | CVD death
Melamed 2008^85^ NHANES III US (various) [18695076] | - Mean age (range), y | 45 (≥20) | - Assay method | RIA (DiaSorin) | Outcome stratified by 4 categories | X | X | X | X | X | X | CVD death
Melamed 2008^85^ NHANES III US (various) [18695076] | - Male (%) | 46 | - Season blood drawn | All (even distribution) | Outcome stratified by 4 categories | X | X | X | X | X | X | CVD death
Marniemi 2005^89^ Turku, Finland (60°N) [15955467] | - Health status | Any | - Assay method | RIA (Incstar) | Outcome stratified by tertiles | | X | | | | X | MI Stroke
Marniemi 2005^89^ Turku, Finland (60°N) [15955467] | - Mean age (range), y | 79 (65‐99) | - Assay method | RIA (Incstar) | Outcome stratified by tertiles | | X | | | | X | MI Stroke
Marniemi 2005^89^ Turku, Finland (60°N) [15955467] | - Male (%) | 48 | - Season blood drawn | All | Outcome stratified by tertiles | | X | | | | X | MI Stroke
New Studies:
Bolland, 2010^58^ New Zealand | - Health status | Healthy Post-menopausal | | | Outcome stratified by 2 categories | | X | X | X | | X | MI Stroke MI, Stroke, or sudden death TIA Congestive heart failure Death
Bolland, 2010^58^ New Zealand | - Mean age (SD), y | 74 (SD 4.2) | | | Outcome stratified by 2 categories | | X | X | X | | X | MI Stroke MI, Stroke, or sudden death TIA Congestive heart failure Death
Bolland, 2010^58^ New Zealand | - Male (%) | 0% | | | Outcome stratified by 2 categories | | X | X | X | | X | MI Stroke MI, Stroke, or sudden death TIA Congestive heart failure Death
Brondum-Jacobsen, 2012^69^ Copenhagen, Denmark | - Health status | nd | | | Outcome stratified by 4 categories | | X | X | X | X | X | Nonfatal ischemic heart disease Nonfatal MI Fatal ischemic heart disease/MI
Brondum-Jacobsen, 2012^69^ Copenhagen, Denmark | - Mean age (range), y | 57 (49–66) | | | Outcome stratified by 4 categories | | X | X | X | X | X | Nonfatal ischemic heart disease Nonfatal MI Fatal ischemic heart disease/MI
Brondum-Jacobsen, 2012^69^ Copenhagen, Denmark | - Male (%) | 44% | | | Outcome stratified by 4 categories | | X | X | X | X | X | Nonfatal ischemic heart disease Nonfatal MI Fatal ischemic heart disease/MI
Brondum-Jacobsen, 2013^92^ Copenhagen, Denmark | - Health status | nd | | | Outcome stratified by 4 categories | | X | X | X | X | X | Ischemic stroke
Brondum-Jacobsen, 2013^92^ Copenhagen, Denmark | - Mean age (range), y | 56 (48–65) | | | Outcome stratified by 4 categories | | X | X | X | X | X | Ischemic stroke
Brondum-Jacobsen, 2013^92^ Copenhagen, Denmark | - Male (%) | 44% | | | Outcome stratified by 4 categories | | X | X | X | X | X | Ischemic stroke
deBoer, 2012^87^ US (various) | - Health status | nd | | | Outcome stratified by 2 categories | | X | X | | | X | MI
deBoer, 2012^87^ US (various) | - Mean age (SD), y | 74 (SD 4.6) | | | Outcome stratified by 2 categories | | X | X | | | X | MI
deBoer, 2012^87^ US (various) | - Male (%) | 30% | | | Outcome stratified by 2 categories | | X | X | | | X | MI
Deo, 2011^78^ Cardiovascular Health Study US (various) | - Health status | nd | | | Outcome stratified by 2 categories | | X | X | X | X | X | Sudden Cardiac Death
Deo, 2011^78^ Cardiovascular Health Study US (various) | - Mean age (SD), y | 74 (SD 4) | | | Outcome stratified by 2 categories | | X | X | X | X | X | Sudden Cardiac Death
Deo, 2011^78^ Cardiovascular Health Study US (various) | - Male (%) | 30% | | | Outcome stratified by 2 categories | | X | X | X | X | X | Sudden Cardiac Death
Eaton, 2011^70^ US (various) | - Health status | nd | | | Outcome stratified by 4 categories | | | X | X | X | X | Cardiovascular Disease Mortality
Eaton, 2011^70^ US (various) | - Mean age (SD), y | 65.1 (7.6) | | | Outcome stratified by 4 categories | | | X | X | X | X | Cardiovascular Disease Mortality
Eaton, 2011^70^ US (various) | - Male (%) | 0% | | | Outcome stratified by 4 categories | | | X | X | X | X | Cardiovascular Disease Mortality
Fiscella, 2010^71^ NHANES-III nd | - Health status | nd | | | Outcome stratified by 2 or 4 categories | | X | X | X | X | X | Cardiovascular Death
Fiscella, 2010^71^ NHANES-III nd | - Mean age, y | 43.64 | | | Outcome stratified by 2 or 4 categories | | X | X | X | X | X | Cardiovascular Death
Fiscella, 2010^71^ NHANES-III nd | - Male (%) | 48% | | | Outcome stratified by 2 or 4 categories | | X | X | X | X | X | Cardiovascular Death
Ginde, 2009^72^ US (various) | - Health status | nd | | | Outcome stratified by 5 categories | | X | X | X | X | X | Cardiovascular Death
Ginde, 2009^72^ US (various) | - Mean age (SD), y | 73 (0.2) | | | Outcome stratified by 5 categories | | X | X | X | X | X | Cardiovascular Death
Ginde, 2009^72^ US (various) | - Male (%) | 44% | | | Outcome stratified by 5 categories | | X | X | X | X | X | Cardiovascular Death
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Health Status | nd | | | Outcome stratified by 4 categories | | X | X | X | | X | CVD Mortality
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Mean age (SD), y | nd | | | Outcome stratified by 4 categories | | X | X | X | | X | CVD Mortality
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Male (%) | nd | | | Outcome stratified by 4 categories | | X | X | X | | X | CVD Mortality
Jassal, 2010^80^ San Diego, CA | - Health status | nd | | | Outcome stratified by 2 categories | | | | X | | | Cardiovascular Mortality
Jassal, 2010^80^ San Diego, CA | - Mean age (SD), y | 74 (SD 10) | | | Outcome stratified by 2 categories | | | | X | | | Cardiovascular Mortality
Jassal, 2010^80^ San Diego, CA | - Male (%) | 38% | | | Outcome stratified by 2 categories | | | | X | | | Cardiovascular Mortality
Karakas, 2013^61^ MONICA/KORA Augsburg case-cohort study | - Health status | Healthy | | | Outcome stratified by 3 categories | | X | | | X | | Coronary Heart Disease
Karakas, 2013^61^ MONICA/KORA Augsburg case-cohort study | - Mean age (SD), y | 51.9 (SD 0.42) Range: 35–74 | | | Outcome stratified by 3 categories | | X | | | X | | Coronary Heart Disease
Karakas, 2013^61^ MONICA/KORA Augsburg case-cohort study | - Male (%) | 75.5% | | | Outcome stratified by 3 categories | | X | | | X | | Coronary Heart Disease
Kestenbaum, 2011^81^ CHS US (various) | - Health status | nd | | | Outcome stratified by 4 categories | | | | | | | Cardiovascular Mortality Incident heart mortality Incident myocardial infarction
Kestenbaum, 2011^81^ CHS US (various) | - Mean age (SD), y | 73 (SD 4) | | | Outcome stratified by 4 categories | | | | | | | Cardiovascular Mortality Incident heart mortality Incident myocardial infarction
Kestenbaum, 2011^81^ CHS US (various) | - Male (%) | 42% | | | Outcome stratified by 4 categories | | | | | | | Cardiovascular Mortality Incident heart mortality Incident myocardial infarction
Kilkkinen, 2009^82^ Finland | - Health status | nd | | | Outcomes stratified by 5 categories | | X | | X | | | Cardiovascular Death Cerebrovascular Death Coronary Disease Death
Kilkkinen, 2009^82^ Finland | - Mean age (SD), y | 49.4 (SD 13.6) | | | Outcomes stratified by 5 categories | | X | | X | | | Cardiovascular Death Cerebrovascular Death Coronary Disease Death
Kilkkinen, 2009^82^ Finland | - Male (%) | 45.3% | | | Outcomes stratified by 5 categories | | X | | X | | | Cardiovascular Death Cerebrovascular Death Coronary Disease Death
Lin, 2012^83^ Linxian, China | - Health status | Healthy, Hypertension 27% | | | Outcome stratified by 3 categories | | X | X | X | | X | Cerebrovascular Death Cardiovascular Death
Lin, 2012^83^ Linxian, China | - Mean age (SD), y | 56.5 (SD 7.9) | | | Outcome stratified by 3 categories | | X | X | X | | X | Cerebrovascular Death Cardiovascular Death
Lin, 2012^83^ Linxian, China | - Male (%) | 55% | | | Outcome stratified by 3 categories | | X | X | X | | X | Cerebrovascular Death Cardiovascular Death
Messenger 2012^59^ MrOS US (various) | - Health status | nd | | | Outcome stratified by 4 categories | | X | | | | | Cardiovascular disease (CHD & CVA)
Messenger 2012^59^ MrOS US (various) | - Mean age (SD), y | 76.1 (SD 5.6) | | | Outcome stratified by 4 categories | | X | | | | | Cardiovascular disease (CHD & CVA)
Messenger 2012^59^ MrOS US (various) | - Male (%) | 100% | | | Outcome stratified by 4 categories | | X | | | | | Cardiovascular disease (CHD & CVA)
Michaelsson 2010^84^ Uppsala, Sweden | - Health status | More than 1/3 being treated for hypertension | | | Outcome stratified by 3 categories | X | X | X | X | X | X | Cardiovascular mortality
Michaelsson 2010^84^ Uppsala, Sweden | - Mean age (SD), y | 71 (SD 0.6) | | | Outcome stratified by 3 categories | X | X | X | X | X | X | Cardiovascular mortality
Michaelsson 2010^84^ Uppsala, Sweden | - Male (%) | 100% | | | Outcome stratified by 3 categories | X | X | X | X | X | X | Cardiovascular mortality
Prentice 2013^2^ WHI US (various) | - Health status | Post-menopausal 50–54: 14.2%; 55–59: 22.8%; 60–69: 45.5%; 70–79: 17.5% 0% | | | Outcome stratified by 2 categories | X | X | | | | | MI Coronary heart disease Total heart disease Stroke Total cardiovascular disease
Prentice 2013^2^ WHI US (various) | - Mean age (SD), y | Post-menopausal 50–54: 14.2%; 55–59: 22.8%; 60–69: 45.5%; 70–79: 17.5% 0% | | | Outcome stratified by 2 categories | X | X | | | | | MI Coronary heart disease Total heart disease Stroke Total cardiovascular disease
Prentice 2013^2^ WHI US (various) | - Male (%) | Post-menopausal 50–54: 14.2%; 55–59: 22.8%; 60–69: 45.5%; 70–79: 17.5% 0% | | | Outcome stratified by 2 categories | X | X | | | | | MI Coronary heart disease Total heart disease Stroke Total cardiovascular disease
Schierbeck, 2012^88^ Danish Osteoporosis Prevention Study Denmark | - Health status | Post-menopausal | | | Outcome stratified by 2 categories | | X | X | | | X | Heart failure Myocardial Infarction Stroke
Schierbeck, 2012^88^ Danish Osteoporosis Prevention Study Denmark | - Mean age (SD), y | 50 (SD 2.8) | | | Outcome stratified by 2 categories | | X | X | | | X | Heart failure Myocardial Infarction Stroke
Schierbeck, 2012^88^ Danish Osteoporosis Prevention Study Denmark | - Male (%) | 0% | | | Outcome stratified by 2 categories | | X | X | | | X | Heart failure Myocardial Infarction Stroke
Signorello, 2010^74^ US | - Health status | nd | | | Outcome stratified by 4 categories | | | X | | | X | Circulatory disease death
Signorello, 2010^74^ US | - Mean age (SD), y | nd (nd) | | | Outcome stratified by 4 categories | | | X | | | X | Circulatory disease death
Signorello, 2010^74^ US | - Male (%) | nd | | | Outcome stratified by 4 categories | | | X | | | X | Circulatory disease death
Sun, 2012^90^ Nurses' Health Study US (multiple) | - Health status | nd | | | Outcome stratified by 3 categories | | | | | | | Ischemic stroke
Sun, 2012^90^ Nurses' Health Study US (multiple) | - Mean age (SD), y | 60.8 (5.9) | | | Outcome stratified by 3 categories | | | | | | | Ischemic stroke
Sun, 2012^90^ Nurses' Health Study US (multiple) | - Male (%) | 0% | | | Outcome stratified by 3 categories | | | | | | | Ischemic stroke
Welsh 2012^60^ MIDSPAN Family Study UK | - Health status | Vitamin D deficient/depleted Vitamin D not deficient | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Cardiovascular event
Welsh 2012^60^ MIDSPAN Family Study UK | - Mean age (SD), y | 45.2 (6.2) | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Cardiovascular event
Welsh 2012^60^ MIDSPAN Family Study UK | - Male (%) | 46% | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Cardiovascular event
Formiga 2014^77^ Octabaix Spain | - Health status | Oldest old | | | Outcome stratified by 4 categories | | X | | X | | | Cardiovascular mortality
Formiga 2014^77^ Octabaix Spain | - Mean age | 85 | | | Outcome stratified by 4 categories | | X | | X | | | Cardiovascular mortality
Formiga 2014^77^ Octabaix Spain | - Male (%) | 39.4% | | | Outcome stratified by 4 categories | | X | | X | | | Cardiovascular mortality
Tomson 2013^75^ Whitehall study London, UK | - Health status | self-reported health good/excellent 77.4% 76.9 (SD 4.9) | | | Outcome stratified by 4 categories | | | X | X | | X | Death, ischemic heart disease Death, stroke Death, other vascular Death, all vascular
Tomson 2013^75^ Whitehall study London, UK | - Mean age | 100% | | | Outcome stratified by 4 categories | | | X | X | | X | Death, ischemic heart disease Death, stroke Death, other vascular Death, all vascular
Tomson 2013^75^ Whitehall study London, UK | - Male (%) | | | | Outcome stratified by 4 categories | | | X | X | | X | Death, ischemic heart disease Death, stroke Death, other vascular Death, all vascular
Skaaby 2013^86^ Monica10 and Inter99 Denmark | - Health status | NR | | | Outcome stratified by 4 categories | | X | | X | X | X | Ischemic Heart Disease Stroke
Skaaby 2013^86^ Monica10 and Inter99 Denmark | - Mean age | Monica 10: 55.4 (41–72.8) Inter99: 46.1(29.7–61.3) | | | Outcome stratified by 4 categories | | X | | X | X | X | Ischemic Heart Disease Stroke
Skaaby 2013^86^ Monica10 and Inter99 Denmark | - Male (%) | 50.2% | | | Outcome stratified by 4 categories | | X | | X | X | X | Ischemic Heart Disease Stroke
Schottker 2013^76^ ESTHER Germany | - Health status | NR | | | Outcome stratified by 3 categories | | X | | X | X | X | CVD mortality
Schottker 2013^76^ ESTHER Germany | - Mean age | 62 (SD 6.5) | | | Outcome stratified by 3 categories | | X | | X | X | X | CVD mortality
Schottker 2013^76^ ESTHER Germany | - Male (%) | 43.8% | | | Outcome stratified by 3 categories | | X | | X | X | X | CVD mortality
Robinson-Cohen 2013^62^ MESA US | - Health status | NR | | | Outcome stratified by 4 categories | X | X | X | X | | X | Incident coronary heart disease events
Robinson-Cohen 2013^62^ MESA US | - Mean age | 63.3 (SD 10.2) | | | Outcome stratified by 4 categories | X | X | X | X | | X | Incident coronary heart disease events
Robinson-Cohen 2013^62^ MESA US | - Male (%) | 47% | | | Outcome stratified by 4 categories | X | X | X | X | | X | Incident coronary heart disease events
Perna 2013^63^ ESTHER Saarland, Germany | - Health status | 46.3% hypertension | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Total CVD Nonfatal CVD Fatal CVD Total CHD Nonfatal CHD Fatal CHD Total Stroke Nonfatal Stroke Fatal Stroke
Perna 2013^63^ ESTHER Saarland, Germany | - Mean age | NR (range 50–74) | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Total CVD Nonfatal CVD Fatal CVD Total CHD Nonfatal CHD Fatal CHD Total Stroke Nonfatal Stroke Fatal Stroke
Perna 2013^63^ ESTHER Saarland, Germany | - Male (%) | 40.7% | | | Outcome stratified by 4 categories | X | X | X | X | X | X | Total CVD Nonfatal CVD Fatal CVD Total CHD Nonfatal CHD Fatal CHD Total Stroke Nonfatal Stroke Fatal Stroke
Kuhn 2013^65^ EPIC-Germany Heidelberg, Potsdam | - Health status | NR NR | | | Outcome stratified by 4 categories | | X | X | | X | X | Myocardial Infarction Stroke CVD as composite endpoint
Kuhn 2013^65^ EPIC-Germany Heidelberg, Potsdam | - Mean age | NR NR | | | Outcome stratified by 4 categories | | X | X | | X | X | Myocardial Infarction Stroke CVD as composite endpoint
Kuhn 2013^65^ EPIC-Germany Heidelberg, Potsdam | - Male (%) | NR NR | | | Outcome stratified by 4 categories | | X | X | | X | X | Myocardial Infarction Stroke CVD as composite endpoint
Brodin 2013^91^ Tromso study Norway | - Health status | NR | | | Outcome stratified by 5 categories | | X | X | | | X | Total Venous Thromboembolism
Brodin 2013^91^ Tromso study Norway | - Mean age | 62 (SD 10) | | | Outcome stratified by 5 categories | | X | X | | | X | Total Venous Thromboembolism
Brodin 2013^91^ Tromso study Norway | - Male (%) | 37% | | | Outcome stratified by 5 categories | | X | X | | | X | Total Venous Thromboembolism

A Not in 3-category analysis

B Case-control study

Table 11a Vitamin D and cardiovascular outcomes: Results of cohort studies (updated from original report)

Author Year Study Name [PMID] | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
CVD Events
Both Sexes
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | <37.5 | 50 | 481 | 1.7 | 1.08, 2.67^*^ | 0.02^A^ | A
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | | | | | | 0.02^A^ | A
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | ≥37.5 | 70 | 1258 | 1 | Reference | 0.02^A^ | A
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | <25 | nd | nd | 1.8 | 1.05, 3.08^*^ | 0.01 | C
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | | | | | | 0.01 | C
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | 25–37.5 | nd | nd | 1.53 | 1.00, 2.36^*^ | 0.01 | C
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | | | | | | 0.01 | C
Wang 2008^67^ Framingham Offspring [18180395] | Mean (SD) 59 (9), Both | CVD event (120/1739; 0.069) | 5.4 y | 25(OH)D | ≥37.5 | 70 | 1258 | 1 | Reference | 0.01 | C
Men
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | ≤37.5 | 63 | 150 | 2.09 | 1.24, 3.54 | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | | | | | | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | 37.5–56.25 | 156 | 463 | 1.43 | 0.96, 2.13 | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | | | | | | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | 56.25–75 | 165 | 464 | 1.6 | 1.10, 2.32 | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | | | | | | 0.02^BC^ | A
Giovannucci 2008^68^ HPFS [18541825] | 40–75 y, Men | Nonfatal MI or fatal CHD (454 cases; 1354 controls) | 10 y | 25(OH)D | >75 | 70 | 277 | 1 | Reference | 0.02^BC^ | A
CVD Death
Both Sexes
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | <44.5 | nd | nd | 1.2 | 0.87, 1.64 | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | 44.5–60.75 | nd | nd | 0.88 | 0.69, 1.14 | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | 60.75–80.25 | nd | nd | 0.83 | 0.65, 1.07 | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III [18695076] | ≥20 y, Both | CVD death (777/13,331; 0.058) | 8.7 y | 25(OH)D | >80.25 | nd | nd | 1 | Reference | nd | C
Myocardial Infarction
Both Sexes
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ∼252 | 1 | Reference | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ∼252 | 0.99 | 0.64, 1.53 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 25(OH)D | nd | nd | ∼252 | 0.77 | 0.47, 1.27 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | | | | | | | | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 1 | Reference | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 1.05 | 0.68, 1.62 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | MI (130/755; 0.172) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 0.82 | 0.52, 1.30 | nd | C
Stroke
Both Sexes
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ∼252 | 1 | Reference | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ∼252 | 1.13 | 0.62, 2.05 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 25(OH)D | nd | nd | ∼252 | 1 | 0.51, 1.94 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | | | | | | | | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 1 | Reference | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 0.63 | 0.37, 1.09 | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | | | | | | nd | C
Marniemi 2005^89^ [15955467] | 65–99 y, Both | Stroke (70/755; 0.093) | 10 y | 1,25(OH)_2_D | nd | nd | ∼252 | 0.41 | 0.22, 0.77^*^ | nd | C
NEW Studies
Bolland 2010^58^ New Zealand | | Primary–MI | 5 y | 25(OH)D | <50 nmol/L | 31 | 736 | 1.20 | 0.7, 2.2 | 0.52 | A
Bolland 2010^58^ New Zealand | | Primary–MI | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–MI | 5 y | 25(OH)D | ≥50 nmol/L | 21 | 735 | 1.00 | Reference | | A
Bolland 2010^58^ New Zealand | | | | | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Stroke | 5 y | 25(OH)D | <50 nmol/L | 37 | 736 | 1.40 | 0.8,2.5 | 0.20 | A
Bolland 2010^58^ New Zealand | | Primary–Stroke | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Stroke | 5 y | 25(OH)D | ≥50 nmol/L | 22 | 735 | 1.00 | Reference | | A
Bolland 2010^58^ New Zealand | | | | | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–MI, Stroke, or sudden death | 5 y | 25(OH)D | <50 nmol/L | 65 | 736 | 1.20 | 0.8, 1.8 | 0.34 | A
Bolland 2010^58^ New Zealand | | Primary–MI, Stroke, or sudden death | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–MI, Stroke, or sudden death | 5 y | 25(OH)D | ≥50 nmol/L | 45 | 735 | 1.00 | Reference | | A
Bolland 2010^58^ New Zealand | | | | | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–TIA | 5 y | 25(OH)D | <50 nmol/L | 24 | 736 | 1.10 | 0.6, 2.0 | 0.76 | A
Bolland 2010^58^ New Zealand | | Primary–TIA | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–TIA | 5 y | 25(OH)D | ≥50 nmol/L | 21 | 735 | 1.00 | Reference | | A
Bolland 2010^58^ New Zealand | | | | | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Congestive heart failure | 5 y | 25(OH)D | <50 nmol/L | 12 | 736 | 1.00 | 0.4, 2.4 | 0.97 | A
Bolland 2010^58^ New Zealand | | Primary–Congestive heart failure | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Congestive heart failure | 5 y | 25(OH)D | ≥50 nmol/L | 10 | 735 | 1.00 | Reference | | A
Bolland 2010^58^ New Zealand | | | | | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Death | 5 y | 25(OH)D | <50 nmol/L | 34 | 736 | 0.90 | 0.5, 1.6 | 0.73 | A
Bolland 2010^58^ New Zealand | | Primary–Death | 5 y | 25(OH)D | | | | | | | A
Bolland 2010^58^ New Zealand | | Primary–Death | 5 y | 25(OH)D | ≥50 nmol/L | 29 | 735 | 1.00 | 1.00 | | A
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | <25.0 nmol/L | 381 | 2,553 | 1.08 | 0.85, 1.37 | 0.1 | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | 25.0–49.9 nmol/L | 648 | 4,068 | 1.01 | 0.81, 1.26 | 0.1 | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | 50.0–74.9 nmol/L | 391 | 2,470 | 0.91 | 0.72, 1.15 | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal ischemic heart disease | 29 y | 25(OH)D | ≥75.0 nmol/L | 158 | 1,079 | 1.00 | Reference | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | | | | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | <25.0 nmol/L | 224 | 2,553 | 1.17 | 0.83, 1.63 | 0.4 | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | 25.0–49.9 nmol/L | 350 | 4,068 | 0.97 | 0.71, 1.34 | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | 50.0–74.9 nmol/L | 228 | 2,470 | 1.02 | 0.74, 1.42 | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Nonfatal MI | 29 y | 25(OH)D | ≥75.0 nmol/L | 89 | 1,079 | 1.00 | Reference | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | | | | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | <25.0 nmol/L | 422 | 2,553 | 1.53 | 1.18, 1.98 | <0.001 | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | 25.0–49.9 nmol/L | 627 | 4,068 | 1.23 | 0.96, 1.58 | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | 50.0–74.9 nmol/L | 367 | 2,470 | 1.18 | 0.91, 1.54 | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | | | | | | | B
Brondum-Jacobsen 2012^69^ | 51–70 years | Primary–Fatal ischemic heart disease/MI | 29 y | 25(OH)D | ≥75.0 nmol/L | 106 | 1,079 | 1.00 | Reference | | B
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | <25.0 nmol/L | 350 | 2,553 | 1.36 | 1.09, 1.70 | <0.001 | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | | | | | | | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | 25.0–49.9 nmol/L | 504 | 4,068 | 1.10 | 0.89, 1.36 | | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | | | | | | | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | 50.0–74.9 nmol/L | 277 | 2,470 | 0.92 | 0.74, 1.16 | | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | | | | | | | A
Brondum-Jacobsen 2013^92^ | 51–70 years | Primary–Ischemic stroke | 29 y | 25(OH)D | ≥75.0 nmol/L | 125 | 1,079 | 1.00 | Reference | | A
deBoer 2012^87^ | | MI | 11 y | 25(OH)D | Normal level | 154 | 1126 | HR 1.00 | Reference | NR | A
deBoer 2012^87^ | | MI | 11 y | 25(OH)D | | | | | | | A
deBoer 2012^87^ | | MI | 11 y | 25(OH)D | Low level (season specific, ranges 43–61 nmol/L) | 67 | 495 | HR 1.24 | 0.91–1.70 | | A
Deo 2011^78^ Cardiovascular Health Study | ≥ 65 years | Primary–Sudden cardiac death | 14 y (median) | 25(OH)D | <50 nmol/L | 31 | 715 | 1.47 | 0.88, 2.46 | Not sig | A
Deo 2011^78^ Cardiovascular Health Study | ≥ 65 years | Primary–Sudden cardiac death | 14 y (median) | 25(OH)D | ≥50 nmol/L | 42 | 1,568 | 1.00 | Reference | Not sig | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | Quartile 1: 3.25–36.50 nmol/L Quartile 2: 36.51–49.95 nmol/L | | 608 | HR 1.27 | 0.81, 1.99 | 0.33 | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | Quartile 1: 3.25–36.50 nmol/L Quartile 2: 36.51–49.95 nmol/L | | | | | | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | Quartile 1: 3.25–36.50 nmol/L Quartile 2: 36.51–49.95 nmol/L | | 606 | HR 1.14 | 0.74, 1.78 | | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | | | | | | | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | Quartile 3: 49.96–65.38 nmol/L | | 608 | HR 1.16 | 0.75, 1.80 | | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | | | | | | | A
Eaton 2011^70^ | Post-menopausal women 50–79 years | Cardiovascular disease mortality | 10 y | 25(OH)D | Quartile 4: 65.39–146.67 nmol/L | | 607 | HR 1.00 | Reference | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | Q1: <45 nmol/L | 933 | 15363 | 1.00 | Reference | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | | 933 | 15363 | | | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | Q2: 45–62.25 nmol/L | 933 | 15363 | 0.71 | 0.54, 0.94 | NR | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | | 933 | 15363 | | | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | Q3: 62.5–79.75 nmol/L | 933 | 15363 | 0.65 | 0.53, 0.79 | NR | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | | 933 | 15363 | | | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | Q4: >80 nmol/L | 933 | 15363 | 0.79 | 0.62, 1.01 | NR | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | | | | | | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | <45 nmol/L ≥45 nmol/L | 933 | 15363 | 1.40 | 1.16, 1.69 | <0.001 | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | | 933 | 15363 | | | | A
Fiscella 2010^71^ NHANES-III | | Primary–Cardiovascular death | 138,549 person years | 25(OH)D | ≥45 nmol/L | 933 | 15363 | 1.00 | Reference | | A
Ginde 2009^72^ | >/= 65 years | Cardiovascular death | 7.3 y | 25(OH)D | <25.0 nmol/L | 767 | 115 | 2.36 | 1.17, 4.75 | <0.05 | B
Ginde 2009^72^ | >/= 65 years | Cardiovascular death | 7.3 y | 25(OH)D | 25.0–49.9 nmol/L | 767 | 904 | 1.54 | 1.01, 2.34 | <0.05 | B
Ginde 2009^72^ | >/= 65 years | Cardiovascular death | 7.3 y | 25(OH)D | 50.0–74.9 nmol/L | 767 | 1296 | 1.26 | 0.85, 1.88 | NS | B
Ginde 2009^72^ | >/= 65 years | Cardiovascular death | 7.3 y | 25(OH)D | 75.0–99.9 nmol/L | 767 | 775 | 1.20 | 0.79, 1.81 | NS | B
Ginde 2009^72^ | >/= 65 years | Cardiovascular death | 7.3 y | 25(OH)D | ≥100.0 nmol/L | 767 | 318 | 1.00 | Reference | | B
Hutchinson 2010^79^ | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 1: mean=33.8 (sd=7.6) | 106 | 1184 | HR 1.08 | 0.79–1.48 | NR | B
Hutchinson 2010^79^ | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
non-smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 2: mean=46.7 (sd=6.0) | 81 | 1187 | HR 0.84 | 0.61–1.15 | | B
non-smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
non-smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 3: mean=56.2 (sd=6.0) | 62 | 1192 | HR 0.71 | 0.51–1.01 | | B
non-smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
non-smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 4: mean=72.3 (sd=13.2) | 76 | 1188 | HR 1.00 | Reference | | B
non-smokers | 25–84 yrs | | | | | | | | | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 1: mean=33.8 (sd=7.6) | 45 | 597 | HR 0.93 | 0.61–1.44 | NR | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 2: mean=46.7 (sd=6.0) | 57 | 606 | HR 1.10 | 0.73–1.67 | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 3: mean=56.2 (sd=6.0) | 46 | 607 | HR 1.04 | 0.67–1.60 | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | | | | | | | B
smokers | 25–84 yrs | CVD mortality | 11.7 y | 25(OH)D | Quartile 4: mean=72.3 (sd=13.2) | 40 | 600 | HR 1.00 | Reference | | B
Jassal 2010^80^ | | Primary–Cardiovascular mortality | 10.4 y | 25(OH)D | per SD increase in serum 25(OH)D | 111 | 1073 | 1.07 | 0.86, 1.33 | NS | A
Jassal 2010^80^ | | Primary–Cardiovascular mortality | 10.4 y | 25(OH)D | | | | | | | A
Jassal 2010^80^ | | Primary–Cardiovascular mortality | 10.4 y | 25(OH)D | per SD increase in log of serum 1,25(OH)2D | 111 | 1073 | 0.98 | 0.80, 1.21 | NS | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Men 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in men | 54.14–153.92 nmol/L | 225 | 964 | 0.84 | 0.52, 1.35 | 0.461 | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Men 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in men | | 225 | 964 | | | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Men 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in men | 35.05–54.13 nmol/L | 225 | 964 | 0.66 | 0.43, 1.02 | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Men 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in men | | 225 | 964 | | | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Men 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in men | 5.08–35.02 nmol/L | 225 | 964 | 1.00 | Reference | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | | Primary–Coronary heart disease | | | | | | | | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Women 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in women | 47.70–127.69 nmol/L | 73 | 819 | 0.42 | 0.19, 0.93 | 0.028 | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Women 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in women | | 73 | 819 | | | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Women 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in women | 33.16–47.69 nmol/L | 73 | 819 | 0.67 | 0.35, 1.29 | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Women 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in women | | 73 | 819 | | | | A
Karakas 2013^61^ MONICA/KORA Augsburg case-cohort study | Women 35–74 years | Primary–Coronary heart disease | 11 y | 25(OH)D in women | 9.87–33.15 nmol/L | 73 | 819 | 1.00 | Reference | | A
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | Continuous per 25nmol/L lower 25(OH)D | 389 | 2312 | 1.06 | 0.94, 1.19 | 0.356 | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | | | | | | | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | <37.5nmol/L | 107 | 681 | 1.17 | 0.83, 1.67 | | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | | | | | | | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | 37.5–75nmol/L | 207 | 1247 | 1.01 | 0.78, 1.30 | | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | | | | | | | B
Kestenbaum 2011^81^ CHS | >65 years | Primary–Cardiovascular mortality | 14 y | 25(OH)D | >75nmol/L | 75 | 384 | 1.00 | Reference | | B
Kestenbaum 2011^81^ CHS | >65 years
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D | Continuous per 25nmol/L lower 25(OH)D | 504 | 2312 | 0.95 | 0.86, 1.05 | 0.303
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D | <37.5nmol/L | 107 | 681 | 1.17 | 0.83, 1.67
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D | 37.5–75nmol/L | 207 | 1247 | 1.01 | 0.78, 1.30
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident heart failure | 14 y | 25(OH)D | >75nmol/L | 75 | 384 | 1.00 | Reference
Kestenbaum 2011^81^ CHS | >65 years
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D | Continuous per 25nmol/L lower 25(OH)D | 299 | 2312 | 1.25 | 1.08, 1.44 | 0.002
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D | <37.5nmol/L | 88 | 681 | 1.40 | 0.93, 2.12
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D | 37.5–75nmol/L | 161 | 1247 | 1.20 | 0.90, 1.59
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D
Kestenbaum 2011^81^ CHS | >65 years | Primary–Incident myocardial infarction | 14 y | 25(OH)D | >75nmol/L | 50 | 384 | 1.00 | Reference
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | M:62–180 nmol/l \|F:56.0–151.0 nmol/l | 150 | 1253 | 0.76 | 0.61, 0.95 | 0.005 | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | M:48.0–61.0 nmol/l \|F:44.0–55.0 nmol/l | 171 | 1222 | 0.86 | 0.70, 1.06 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | M:38.0–47.0 nmol/l \|F:34.0–43.0 nmol/l | 164 | 1284 | 0.81 | 0.66, 1.00 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | M:29.0–37.0 nmol/l \|F:26.0–33.0 nmol/l | 194 | 1202 | 1.04 | 0.86, 1.26 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cardiovascular death | 27.1 y (median) | 25(OH)D | M:5.0–28.0 nmol/l \|F:4.0–25.0 nmol/l | 254 | 1258 | 1.00 | Reference | | A
Kilkkinen 2009^82^ | ≥ 30 years | | | | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | M:62–180 nmol/l \|F:56.0–151.0 nmol/l | 33 | 1253 | 0.48 | 0.31, 0.75 | 0.002 | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | M:48.0–61.0 nmol/l \|F:44.0–55.0 nmol/l | 48 | 1222 | 0.69 | 0.48, 1.00 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | M:38.0–47.0 nmol/l \|F:34.0–43.0 nmol/l | 68 | 1284 | 0.97 | 0.70, 1.35 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | M:29.0–37.0 nmol/l \|F:26.0–33.0 nmol/l | 52 | 1202 | 0.80 | 0.57, 1.14 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Cerebrovascular death | 27.1 y (median) | 25(OH)D | M:5.0–28.0 nmol/l \|F:4.0–25.0 nmol/l | 92 | 1258 | 1.00 | Reference | | A
Kilkkinen 2009^82^ | ≥ 30 years | | | | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | M:62–180 nmol/l \|F:56.0–151.0 nmol/l | 117 | 1253 | 0.91 | 0.70, 1.18 | 0.2 | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | M:48.0–61.0 nmol/l \|F:44.0–55.0 nmol/l | 123 | 1222 | 0.95 | 0.74, 1.22 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | M:38.0–47.0 nmol/l \|F:34.0–43.0 nmol/l | 96 | 1284 | 0.73 | 0.56, 0.95 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | M:29.0–37.0 nmol/l \|F:26.0–33.0 nmol/l | 142 | 1202 | 1.17 | 0.93, 1.48 | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | | | | | | | A
Kilkkinen 2009^82^ | ≥ 30 years | Primary–Coronary disease death | 27.1 y (median) | 25(OH)D | M:5.0–28.0 nmol/l \|F:4.0–25.0 nmol/l | 162 | 1258 | 1.00 | Reference | | A
Lin 2012^83^ | Men 40–69 yrs | Cerebrovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 279 | 1101 | HR 1.05 | 0.98, 1.12 | 0.141 | B
Lin 2012^83^ | Men 40–69 yrs | Cerebrovascular death | 24 y | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ | Men 40–69 yrs | Cerebrovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 157 | 608 | HR 1.04 | 0.96, 1.13 | 0.337 | B
Lin 2012^83^ | | Cerebrovascular death | 24 y | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ | Women 40–69 yrs | Cerebrovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 122 | 493 | HR 1.06 | 0.96, 1.17 | 0.277 | B
Lin 2012^83^ | | | | | | | | | | | B
Lin 2012^83^ | Men 40–69 yrs | cardiovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 200 | 1101 | HR 0.98 | 0.91, 1.06 | 0.678 | B
Lin 2012^83^ | Men 40–69 yrs | cardiovascular death | 24 y | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ | Men 40–69 yrs | cardiovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 119 | 608 | HR 0.94 | 0.85, 1.04 | 0.223 | B
Lin 2012^83^ | | cardiovascular death | 24 y | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ | Women 40–69 yrs | cardiovascular death | 24 y | 25(OH)D | continuous 25(OH)D | 81 | 493 | HR 1.06 | 0.93, 1.20 | 0.399 | B
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | <168.6 IU | 107 | 3094 | 0.76 | 0.56, 1.04 | 0.29 | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | | | 3094 | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | 168.6–437.8 IU | 125 | 3094 | 0.97 | 0.72, 1.30 | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | | | 3094 | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | 437.9–572.3 IU | 108 | 3094 | 0.85 | 0.63, 1.15 | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | | | 3094 | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | Dietary Vit D intake | >572.3 IU | 132 | 3094 | 1.00 | Reference | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | | | | | | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | 12–50.25 nmol/L | 39 | 204 | 1.18 | 0.69, 2.03 | 0.85 | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | | | | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | 50.5–63nmol/L | 33 | 203 | 1.11 | 0.65, 1.91 | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | | | | | | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | 63.25–75 nmol/L | 35 | 202 | 0.97 | 0.57, 1.64 | | A
Messenger 2012^59^ MrOS | ≥ 65 yrs | Primary–Cardiovascular disease(CHD & CVA) | 4.4 y (median) | 25(OH)D | 75.25–138.5 nmol/L | 33 | 204 | 1.00 | Reference | | A
Michaelsson 2010^84^ | birth 1920–1924 | cardiovascular mortality | 12.7 y | 25(OH)D | < 10th percentile (<46 nmol/L) | 24 | 119 | HR 1.53 | 0.97, 2.41 | | B
Michaelsson 2010^84^ | birth 1920–1924 | cardiovascular mortality | 12.7 y | 25(OH)D | | | | | | | B
Michaelsson 2010^84^ | birth 1920–1924 | cardiovascular mortality | 12.7 y | 25(OH)D | 10th–90th percentile (46–93 nmol/L) | 135 | 956 | HR 1.00 | Reference | | B
Michaelsson 2010^84^ | birth 1920–1924 | cardiovascular mortality | 12.7 y | 25(OH)D | | | | | | | B
Michaelsson 2010^84^ | birth 1920–1924 | cardiovascular mortality | 12.7 y | 25(OH)D | >90th percentile (>93 nmol/L) | 18 | 119 | HR 1.16 | 0.69, 1.93 | | B
Prentice 2013^2^ WHI | | Primary–MI | 7.2 y | 25(OH)D | ≥400IU/day | 40 | 1,914 | 1.06 | 0.75, 1.51 | 0.38 | A
Prentice 2013^2^ WHI | | Primary–MI | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–MI | 7.2 y | 25(OH)D | no supplementation | 433 | 23,561 | 1.00 | Reference | | A
Prentice 2013^2^ WHI | | | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Coronary heart disease | 7.2 y | 25(OH)D | ≥400IU/day | 50 | 1,914 | 0.74 | 0.58, 0.95 | 0.53 | A
Prentice 2013^2^ WHI | | Primary–Coronary heart disease | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Coronary heart disease | 7.2 y | 25(OH)D | no supplementation | 545 | 23,561 | 1.00 | Reference | | A
Prentice 2013^2^ WHI | | | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Total heart disease | 7.2 y | 25(OH)D | ≥400IU/day | 132 | 1,914 | 0.96 | 0.79, 1.16 | 0.82 | A
Prentice 2013^2^ WHI | | Primary–Total heart disease | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Total heart disease | 7.2 y | 25(OH)D | no supplementation | 1602 | 23,561 | 1.00 | Reference | | A
Prentice 2013^2^ WHI | | | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Stroke | 7.2 y | 25(OH)D | ≥400IU/day | 38 | 1,914 | 0.84 | 0.66, 1.07 | 0.47 | A
Prentice 2013^2^ WHI | | Primary–Stroke | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Stroke | 7.2 y | 25(OH)D | no supplementation | 471 | 23,561 | 1.00 | Reference | | A
Prentice 2013^2^ WHI | | | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Total cardiovascular disease | 7.2 y | 25(OH)D | ≥400IU/day | 181 | 1,914 | 0.92 | 0.778, 1.09 | 0.81 | A
Prentice 2013^2^ WHI | | Primary–Total cardiovascular disease | 7.2 y | 25(OH)D | | | | | | | A
Prentice 2013^2^ WHI | | Primary–Total cardiovascular disease | 7.2 y | 25(OH)D | no supplementation | 2187 | 23,561 | 1.00 | Reference | | A
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Heart failure | 16 y | 25(OH)D | <50 nmol/l | 10 | 788 | 1.88 | 0.71, 5.01 | 0.206 | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Heart failure | 16 y | 25(OH)D | | | | | | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Heart failure | 16 y | 25(OH)D | ≥50 nmol/l | 8 | 1225 | 1.00 | Reference | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | | 16 y | 25(OH)D | | | | | | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Myocardial Infarction | 16 y | 25(OH)D | <50 nmol/l | 13 | 788 | 0.83 | 0.41, 1.67 | 0.597 | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Myocardial Infarction | 16 y | 25(OH)D | | | | | | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Myocardial Infarction | 16 y | 25(OH)D | ≥50 nmol/l | 22 | 1225 | 1.00 | Reference | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | | 16 y | 25(OH)D | | | | | | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Stroke | 16 y | 25(OH)D | <50 nmol/l | 47 | 788 | 1.68 | 1.10, 2.56 | 0.017 | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Stroke | 16 y | 25(OH)D | | | | | | | B
Schierbeck 2012^88^ Danish Osteoporosis Prevention Study | | Primary–Stroke | 16 y | 25(OH)D | ≥50 nmol/l | 42 | 1225 | 1.00 | Reference | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | 1st quartile: <26.25 nmol/L | NR | 252 | HR 2.11 | 1.22, 3.64 | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | 2nd quartile: 26.25–40.0 nmol/L | NR | 254 | HR 1.41 | 0.83, 2.40 | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | 3rd quartile: 40.25–64 nmol/L | NR | 247 | HR 1.12 | 1.09, 1.15 | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | all-cause mortality | 6.5 yrs | 25(OH)D | 4th quartile: >64 nmol/L | NR | 253 | HR 1.00 | Reference | | B
Semba 2010^93^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | 1st quartile: <26.25 nmol/L | NR | 252 | HR 2.23 | 0.95, 5.25 | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | 2nd quartile: 26.25–40.0 nmol/L | NR | 254 | HR 1.58 | 0.71, 3.53 | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | 3rd quartile: 40.25–64 nmol/L | NR | 247 | HR 2.11 | 1.01, 4.43 | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | | | | | | | B
Semba 2010^93^ | | cardiovascular mortality | 6.5 yrs | 25(OH)D | 4th quartile: >64 nmol/L | NR | 253 | HR 1.00 | Reference | | B
Signorello 2010^74^ | | circulatory disease death | NR | 25(OH)D | Quartile 4: (>54.1 nmol/L) | 41 | 109 | 1.00 | Reference | 0.01 | A
Signorello 2010^74^ | | circulatory disease death | NR | 25(OH)D | | | | | | | A
African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 3: (37.9–54.1 nmol/L) | 76 | 162 | 1.67 | 0.95, 2.93 | | A
African Americans | | circulatory disease death | NR | 25(OH)D | | | | | | | A
African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 2: (25.45–37.88 nmol/L) | 116 | 225 | 1.78 | 1.05, 3.01 | | A
African Americans | | circulatory disease death | NR | 25(OH)D | | | | | | | A
African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 1: <25.45 nmol/L) | 144 | 258 | 2.53 | 1.44, 4.46 | | A
non-African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 4: (>54.1 nmol/L) | 40 | 107 | 1.00 | Reference | 0.01
non-African Americans | | circulatory disease death | NR | 25(OH)D
non-African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 3: (37.9–54.1 nmol/L) | 38 | 84 | 1.09 | 0.51. 2.30
non-African Americans | | circulatory disease death | NR | 25(OH)D
non-African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 2: (25.45–37.87 nmol/L) | 37 | 56 | 3.66 | 1.50, 8.95
non-African Americans | | circulatory disease death | NR | 25(OH)D
non-African Americans | | circulatory disease death | NR | 25(OH)D | Quartile 1: <25.45 nmol/L) | 39 | 61 | 3.25 | 1.33, 7.93
Sun 2012^90^ Nurses' Health Study | | Primary–Ischemic stroke | 17 y | 25(OH)D | 9.2–45.7 nmol/l | 171 | 325 | 1.49 | 1.01, 2.18 | 0.04 | A
Sun 2012^90^ Nurses' Health Study | | Primary–Ischemic stroke | 17 y | 25(OH)D | | | | | | | A
Sun 2012^90^ Nurses' Health Study | | Primary–Ischemic stroke | 17 y | 25(OH)D | 45.8–65.4 nmol/l | 160 | 314 | 1.26 | 0.89, 1.79 | | A
Sun 2012^90^ Nurses' Health Study | | Primary–Ischemic stroke | 17 y | 25(OH)D | | | | | | | A
Sun 2012^90^ Nurses' Health Study | | Primary–Ischemic stroke | 17 y | 25(OH)D | 66.5–264.3 nmol/l | 133 | 289 | 1.00 | Reference | | A
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | Dietary Vit D intake | per 1 SD increase in dietary Vit D intake-log scale | 293 | 1492 | 0.94 | 0.83, 1.08 | NR | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | | | | | | | | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | 25(OH)D | per 1 SD increase in 25(OH)D-log scale | 293 | 1492 | 1.07 | 0.94, 1.23 | NR | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | | | | | | | | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | 25(OH)D | <37.5 nmol/L | 293 | 1492 | 1.00 | 0.77, 1.31 | NR | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | | | 293 | 1492 | | | | B
Welsh 2012^60^ MIDSPAN Family Study | | Primary—Cardiovascular event | 14.4 y (median) | 25(OH)D | ≥37.5 nmol/L | 293 | 1492 | 1.00 | Reference | | B
Tomson 2013^75^ Whitehall study | | Death, ischemic heart disease | 13.1 yrs | 25(OH)D | Doubling Concentration | 659 | 5409 | 0.84 | 0.70, 1.02 | | B
Tomson 2013^75^ Whitehall study | | | 13.1 yrs | 25(OH)D | Doubling Concentration | | | | | | B
Tomson 2013^75^ Whitehall study | | Death, stroke | 13.1 yrs | 25(OH)D | Doubling Concentration | 378 | 5409 | 0.81 | 0.63, 1.03 | | B
Tomson 2013^75^ Whitehall study | | | 13.1 yrs | 25(OH)D | Doubling Concentration | | | | | | B
Tomson 2013^75^ Whitehall study | | Death, other vascular | 13.1 yrs | 25(OH)D | Doubling Concentration | 321 | 5409 | 0.71 | 0.54, 0.93 | | B
Tomson 2013^75^ Whitehall study | | | 13.1 yrs | 25(OH)D | Doubling Concentration | | | | | | B
Tomson 2013^75^ Whitehall study | | Death, all vascular | 13.1 yrs | 25(OH)D | Doubling Concentration | 1358 | 5409 | 0.80 | 0.70, 0.91 | | B
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | <85.92 | 120 | 2131 | 1.32 | 0.95, 1.83 | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | | | | | | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | 85.92–124.58 | 134 | 2224 | 1.20 | 0.91, 1.58 | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | | | | | | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | >=124.58 | 107 | 2081 | 1.00 | Reference | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | | | | | | 0.04 | A
Robinson-Cohen 2013^62^ MESA | | incident coronary heart disease events | 8.5 yrs | 25(OH)D | per 42.96 decrement | 361 | 6436 | 1.15 | 1.01, 1.32 | 0.04 | A
Perna 2013^63^ | | total cvd | 6.5 yrs | 25(OH)D | < 30 | 171 | 1114 | 1.24 | 1.02, 1.50 | | B
Perna 2013^63^ | | total cvd | 6.5 yrs | 25(OH)D | 30–<50 | 448 | 3430 | 1.14 | 0.99, 1.32 | | B
Perna 2013^63^ | | total cvd | 6.5 yrs | 25(OH)D | >=50 | 392 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | total cvd | 6.5 yrs | 25(OH)D | per 25 | 1011 | 7709 | 0.95 | 0.89, 1.01 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | nonfatal cvd | 6.5 yrs | 25(OH)D | < 30 | 136 | 1114 | 1.17 | 0.94, 1.45 | | B
Perna 2013^63^ | | nonfatal cvd | 6.5 yrs | 25(OH)D | 30–<50 | 383 | 3430 | 1.15 | 0.98, 1.35 | | B
Perna 2013^63^ | | nonfatal cvd | 6.5 yrs | 25(OH)D | >=50 | 335 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | nonfatal cvd | 6.5 yrs | 25(OH)D | per 25 | 854 | 7709 | 0.98 | 0.91, 1.05 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | fatal cvd | 6.5 yrs | 25(OH)D | < 30 | 40 | 1114 | 1.55 | 1.01, 2.37 | | B
Perna 2013^63^ | | fatal cvd | 6.5 yrs | 25(OH)D | 30–<50 | 71 | 3430 | 1.05 | 0.73, 1.49 | | B
Perna 2013^63^ | | fatal cvd | 6.5 yrs | 25(OH)D | >=50 | 65 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | fatal cvd | 6.5 yrs | 25(OH)D | per 25 | 176 | 7709 | 0.89 | 0.66, 0.94 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | total chd | 6.5 yrs | 25(OH)D | < 30 | 92 | 1114 | 1.32 | 1.02, 1.72 | | B
Perna 2013^63^ | | total chd | 6.5 yrs | 25(OH)D | 30–<50 | 236 | 3430 | 1.19 | 0.98, 1.45 | | B
Perna 2013^63^ | | total chd | 6.5 yrs | 25(OH)D | >=50 | 208 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | total chd | 6.5 yrs | 25(OH)D | per 25 | 536 | 7709 | 0.92 | 0.84, 1.01 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | nonfatal chd | 6.5 yrs | 25(OH)D | < 30 | 77 | 1114 | 1.28 | 0.97, 1.71 | | B
Perna 2013^63^ | | nonfatal chd | 6.5 yrs | 25(OH)D | 30–<50 | 204 | 3430 | 1.18 | 0.95, 1.46 | | B
Perna 2013^63^ | | nonfatal chd | 6.5 yrs | 25(OH)D | >=50 | 179 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | nonfatal chd | 6.5 yrs | 25(OH)D | per 25 | 460 | 7709 | 0.96 | 0.88, 1.06 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | fatal chd | 6.5 yrs | 25(OH)D | < 30 | 16 | 1114 | 1.53 | 0.80, 2.94 | | B
Perna 2013^63^ | | fatal chd | 6.5 yrs | 25(OH)D | 30–<50 | 32 | 3430 | 1.18 | 0.70, 1.99 | | B
Perna 2013^63^ | | fatal chd | 6.5 yrs | 25(OH)D | >=50 | 31 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | fatal chd | 6.5 yrs | 25(OH)D | per 25 | 79 | 7709 | 0.7 | 0.54, 0.93 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | total stroke | 6.5 yrs | 25(OH)D | < 30 | 64 | 1114 | 1.31 | 0.95, 1.81 | | B
Perna 2013^63^ | | total stroke | 6.5 yrs | 25(OH)D | 30–<50 | 165 | 3430 | 1.2 | 0.94, 1.54 | | B
Perna 2013^63^ | | total stroke | 6.5 yrs | 25(OH)D | >=50 | 124 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | total stroke | 6.5 yrs | 25(OH)D | per 25 | 353 | 7709 | 0.91 | 0.81, 1.02 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | nonfatal stroke | 6.5 yrs | 25(OH)D | < 30 | 55 | 1114 | 1.26 | 0.89, 1.77 | | B
Perna 2013^63^ | | nonfatal stroke | 6.5 yrs | 25(OH)D | 30–<50 | 146 | 3430 | 1.19 | 0.92, 1.55 | | B
Perna 2013^63^ | | nonfatal stroke | 6.5 yrs | 25(OH)D | >=50 | 112 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | nonfatal stroke | 6.5 yrs | 25(OH)D | per 25 | 313 | 7709 | 0.91 | 0.81, 1.02 | | B
Perna 2013^63^ | | | 6.5 yrs | 25(OH)D | | | | | | | B
Perna 2013^63^ | | fatal stroke | 6.5 yrs | 25(OH)D | < 30 | 9 | 1114 | 1.86 | 0.74, 4.66 | | B
Perna 2013^63^ | | fatal stroke | 6.5 yrs | 25(OH)D | 30–<50 | 20 | 3430 | 1.44 | 0.68, 3.03 | | B
Perna 2013^63^ | | fatal stroke | 6.5 yrs | 25(OH)D | >=50 | 12 | 3165 | 1.00 | Reference | | B
Perna 2013^63^ | | fatal stroke | 6.5 yrs | 25(OH)D | per 25 | 41 | 7709 | 0.86 | 0.61, 1.23 | | B
Schottker 2013^76^ ESTHER | | CVD mortality | 9.5 yrs | 25(OH)D | <30 | 71 | 1439 | 1.29 | 0.94, 1.76 | | B
Schottker 2013^76^ ESTHER | | CVD mortality | 9.5 yrs | 25(OH)D | 30–50 | 137 | 4188 | 0.94 | 0.73, 1.21 | | B
Schottker 2013^76^ ESTHER | | CVD mortality | 9.5 yrs | 25(OH)D | >50 | 142 | 3927 | 1.00 | Reference | | B
Skaaby 2013^86^ Monica10 and Inter99 | | ischemic heart disease | 10 yrs | 25(OH)D | per 10nmol/L | 478 | 8131 | 1.01 | 0.98, 1.05 | 0.44 | B
Skaaby 2013^86^ Monica10 and Inter99 | | ischemic heart disease | 10 yrs | 25(OH)D | Q1 | 478 | 8131 | 1.00 | Reference | 0.25 | B
Skaaby 2013^86^ Monica10 and Inter99 | | ischemic heart disease | 10 yrs | 25(OH)D | Q2 | 478 | 8131 | 1.17 | 0.91, 1.51 | 0.25 | B
Skaaby 2013^86^ Monica10 and Inter99 | | ischemic heart disease | 10 yrs | 25(OH)D | Q3 | 478 | 8131 | 1.00 | 0.76, 1.31 | 0.25 | B
Skaaby 2013^86^ Monica10 and Inter99 | | ischemic heart disease | 10 yrs | 25(OH)D | Q4 | 478 | 8131 | 1.24 | 0.95, 1.62 | 0.25 | B
Skaaby 2013^86^ Monica10 and Inter99 | | | 10 yrs | 25(OH)D | | | | | | | B
Skaaby 2013^86^ Monica10 and Inter99 | | stroke | 10 yrs | 25(OH)D | per 10nmol/L | 316 | 8131 | 1.00 | 0.96, 1.05 | 0.92 | B
Skaaby 2013^86^ Monica10 and Inter99 | | stroke | 10 yrs | 25(OH)D | Q1 | 316 | 8131 | 1.00 | Reference | 0.78 | B
Skaaby 2013^86^ Monica10 and Inter99 | | stroke | 10 yrs | 25(OH)D | Q2 | 316 | 8131 | 1.08 | 0.79, 1.49 | 0.78 | B
Skaaby 2013^86^ Monica10 and Inter99 | | stroke | 10 yrs | 25(OH)D | Q3 | 316 | 8131 | 1.18 | 0.86, 1.63 | 0.78 | B
Skaaby 2013^86^ Monica10 and Inter99 | | stroke | 10 yrs | 25(OH)D | Q4 | 316 | 8131 | 1.13 | 0.80, 1.59 | 0.78 | B
Kuhn 2013^65^ EPIC-Germany | | Myocardial Infarction | 7.6 yrs | 25(OH)D | Q4: median 66.5 | 118 | 533 | 1.00 | Reference | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | Myocardial Infarction | 7.6 yrs | 25(OH)D | Q3: median 50.5 | 117 | 533 | 0.95 | 0.70, 1.28 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | Myocardial Infarction | 7.6 yrs | 25(OH)D | Q2: median 40.4 | 158 | 533 | 1.24 | 0.93, 1.66 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | Myocardial Infarction | 7.6 yrs | 25(OH)D | Q1: median 28.9 | 166 | 533 | 1.43 | 1.07, 1.92 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | | 7.6 yrs | 25(OH)D | | | | | | | A
Kuhn 2013^65^ EPIC-Germany | | stroke | 7.6 yrs | 25(OH)D | Q4: median 66.6 | 111 | 533 | 1.00 | Reference | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | stroke | 7.6 yrs | 25(OH)D | Q3: median 50.5 | 101 | 533 | 0.86 | 0.63, 1.17 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | stroke | 7.6 yrs | 25(OH)D | Q2: median 40.4 | 102 | 533 | 0.83 | 0.61, 1.12 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | stroke | 7.6 yrs | 25(OH)D | Q1: median 28.9 | 157 | 533 | 1.37 | 1.02, 1.84 | 0.19 | A
Kuhn 2013^65^ EPIC-Germany | | | 7.6 yrs | 25(OH)D | | | | | | | A
Kuhn 2013^65^ EPIC-Germany | | CVD as composite endpoint | 7.6 yrs | 25(OH)D | Q4: median 66.5 | 229 | 533 | 1.00 | Reference | 0.12 | A
Kuhn 2013^65^ EPIC-Germany | | CVD as composite endpoint | 7.6 yrs | 25(OH)D | Q3: median 50.5 | 218 | 533 | 0.89 | 0.70, 1.14 | 0.12 | A
Kuhn 2013^65^ EPIC-Germany | | CVD as composite endpoint | 7.6 yrs | 25(OH)D | Q2: median 40.4 | 260 | 533 | 1.06 | 0.83, 1.35 | 0.12 | A
Kuhn 2013^65^ EPIC-Germany | | CVD as composite endpoint | 7.6 yrs | 25(OH)D | Q1: median 28.9 | 323 | 533 | 1.41 | 1.11, 1.79 | 0.12 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | <=44 | 50 | 1474 | 1.00 | Reference | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | | | | | | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | 45–56 | 58 | 1470 | 0.72 | 0.41, 1.30 | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | | | | | | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | 57–69 | 46 | 1481 | 0.93 | 0.55, 1.50 | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | | | | | | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | >=70 | 47 | 1480 | 0.76 | 0.45, 1.28 | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | | | | | | 0.89 | A
Brodin 2013^91^ Tromso study | | total venous thromboembolism | 10.7 yrs | 25(OH)D | per 1 sd decrease in serum 25ohd | 201 | 5905 | 1.02 | 0.91, 1.22 | 0.89 | A
Formiga 2014^77^ Octabaix | | Cardiovascular mortality | 2.8 yrs | 25(OH)D | Q1: <34.94 | 6 | 71 | 1.04 | 0.33, 3.24 | 0.86 | B
Formiga 2014^77^ Octabaix | | Cardiovascular mortality | 2.8 yrs | 25(OH)D | Q2: 34.94–61.65 | 6 | 77 | 0.89 | 0.28, 2.80 | 0.86 | B
Formiga 2014^77^ Octabaix | | Cardiovascular mortality | 2.8 yrs | 25(OH)D | Q3: 61.66–83.37 | 6 | 84 | 1.47 | 0.45, 4.58 | 0.86 | B
Formiga 2014^77^ Octabaix | | Cardiovascular mortality | 2.8 yrs | 25(OH)D | Q4:>83.37 | 7 | 80 | 1.00 | Reference | 0.86 | B

* Statistically significant (P<0.05)

Table 11b Vitamin D and cardiovascular outcomes: Results of nested case-control studies (new table)

Author Year Study Name [PMID] | Age Range, Sex | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Hosseinpanah 2011^64^ Tehran Lipid and Glucose Study (TLGS) | 19–70 years | Primary–Cardiovascular disease | 5.7 y | 25(OH)D | <25.0 nmol/L | 85 | 133 | 2.90 | 1.76, 4.67 | <0.001 | B
Hosseinpanah 2011^64^ Tehran Lipid and Glucose Study (TLGS) | 19–70 years | Primary–Cardiovascular disease | 5.7 y | 25(OH)D | 25–37.48 nmol/L | 86 | 173 | 1.46 | 0.83, 2.56 | 0.18 | B
Hosseinpanah 2011^64^ Tehran Lipid and Glucose Study (TLGS) | 19–70 years | Primary–Cardiovascular disease | 5.7 y | 25(OH)D | ≥37.5 nmol/L | 80 | 196 | 1.00 | Reference | | B
Pilz 2009^73^ | | cardiovascular mortality | 6.2 y | 25(OH)D | 1st quartile (mean 25(OH)D 30.6 nmol/L) | 12 | 152 | 5.38 | 2.02, 14.34 | 0.001 | B
Pilz 2009^73^ | | cardiovascular mortality | 6.2 y | 25(OH)D | 2nd–4th quartiles (mean 25(OH)D 45.6–78.9) | 8 | 462 | 1.00 | Reference | 0.001 | B

A Multivariable Cox regression with continuous 25(OH)D and regression splines with nonlinear relationships suggests an increased hazard of CVD events at serum 25(OH)D concentrations below approximately 50–55 nmol/L. See Figure 2 on page 508 of article.

B Adjusted regression analyses found OR=0.98 (0.96, 0.998) per 2.5 nmol/L increase in 25(OH)D and risk reduction of -2.1% (-0.2%, -4.0%) per 2.5 nmol/L increase in serum 25(OH)D concentration.

C In a subgroup analysis of participants on no cholesterol lowering drugs at baseline, comparing the highest serum 25(OH)D concentration category (>75 nmol/L) to the lowest (≤37.5 nmol/L), adjusted RR=2.30 (1.33, 3.97).

Figure 6a Cardiovascular outcomes risk stratified by vitamin D concentration for combined and general CV outcomes

Abbreviations: CVD = cardiovascular disease; EPIC = European Prospective Investigation into Cancer; ESTHER = EStrogen and THromboEmbolism Risk Study; MESA = Multi-ethnic Study of Atherosclerosis; NHANES = National Health and Nutrition Examination Study

This figure, known as a forest plot, displays the risk for combined and general cardiovascular outcomes stratified by vitamin D concentration. The first column shows the 13 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 13 studies. Results for each study are in Table 11a.

Figure 6b Cardiovascular outcomes risk stratified by vitamin D concentration for combined and general CV outcomes by gender

Abbreviations: MONICA = Multinational MONItoring of trends and determinants in CArdiovascular disease Study; KORA = Cooperative Health Research in the Region Augsburg; HPFS = Health Professionals Follow-Up Study

This figure, known as a forest plot, displays the risk for combined and general cardiovascular outcomes stratified by vitamin D concentration by gender. The first column shows the 5 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 5 studies. Results for each study are in Table 11a.

Figure 6c Cardiovascular outcomes risk stratified by vitamin D concentration for CV mortality

Abbreviations: InChianti = Invecchiare nel Chianti; CHS = Cardiovascular Health Study; NHANES = National Health and Nutrition Examination Study; ESTHER = EStrogen and THromboEmbolism Risk Study

This figure, known as a forest plot, displays the risk for cardiovascular mortality outcomes stratified by vitamin D concentration. The first column shows the 17 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 17 studies. Results for each study are in Table 11a.

Figure 6d Cardiovascular outcomes risk stratified by vitamin D concentration for CV mortality by gender

Abbreviation: WHI = Women's Health Initiative

This figure, known as a forest plot, displays the risk for cardiovascular mortality outcomes stratified by vitamin D concentration by gender. The first column shows the 6 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 6 studies. Results for each study are in Table 11a.

Figure 6e Cardiovascular outcomes risk stratified by vitamin D concentration for myocardial infarction

Abbreviations: CHS = Cardiovascular Health Study; EPIC = European Prospective Investigation into Cancer

This figure, known as a forest plot, displays the risk for myocardial infarction stratified by vitamin D concentration. The first column shows the 7 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 7 studies. Results for each study are in Table 11a.

Figure 6f Cardiovascular outcomes risk stratified by vitamin D concentration for Stroke/TIA]

Abbreviations: EPIC = European Prospective Investigation into Cancer; ESTHER = EStrogen and THromboEmbolism Risk Study

This figure, known as a forest plot, displays the risk for transient ischemic attack stratified by vitamin D concentration. The first column shows the 10 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 10 studies. Results for each study are in Table 11a.

Figure 6g Cardiovascular outcomes risk stratified by vitamin D concentration for fatal stroke

Abbreviation: ESTHER = EStrogen and THromboEmbolism Risk Study

This figure, known as a forest plot, displays the risk for fatal stroke stratified by vitamin D concentration. The first column shows the seven studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the seven studies. Results for each study are in Table 11a.

Figure 6h Cardiovascular outcomes risk stratified by vitamin D concentration for congestive heart failure

Abbreviation: CHS = Cardiovascular Health study

This figure, known as a forest plot, displays the risk for congestive heart failure stratified by vitamin D concentration. The first column shows the three studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the three studies. Results for each study are in Table 11a.

##### Total Cardiovascular Events

(Figure 6a, b, e, and h)

One high-quality systematic review57 that included 17 studies, 16 of which were included in the original report or the current report (the remaining study was excluded from the current report) found a significant association between lower serum 25(OH)D concentrations and increased risk for total cardiovascular disease and coronary heart disease risks.

Six prospective cohort studies evaluated the association between serum 25(OH)D concentrations and the incidence of total cardiovascular events, ranging from 4.4 years to 14.4 years followup. Three of these studies found no significant association between levels of serum 25(OH)D and risk for a cardiovascular event (two rated A, one rated B).58-60 One study, the German MONICA/KORA cohort study, with a mean followup of 11 years, found significantly decreased risks of total cardiovascular events for both men and women, with a larger effect in women (rated A).61 Another study, the U.S. MESA study, found an association of serum 25(OH)D with decreased risk of CHD among Caucasians and Chinese participants but not among Black or Hispanic participants (rated A).62 The German ESTHER cohort study found that serum 25(OH)D concentrations of less than 75nmol/L were associated with an increased risk for all cardiovascular events (rated B).63

Two nested case-control studies were identified. One nested case-control study within the Tehran Lipid and Glucose Study with 5.7 years followup found a significantly increased risk for total cardiovascular events for individuals in the lowest tertile of 25(OH)D concentrations compared with the two higher tertiles (rated B).64 A study nested within the multi-country EPIC study found no association of serum 25(OH)D with total CV events in the fully adjusted model (rated A).65

In the original report, total cardiovascular events were evaluated by an RCT,66 the Framingham Offspring Study (FOS),67 and a nested case-control study derived from the Health Professionals Followup Study (HPFS).68 The RCT found no significant effect of vitamin D; both cohort studies found significant associations between lower serum 25(OH)D concentrations and increased rates of outcomes.

The RCT randomized almost 2700 elderly participants (65–85 years) from the general population in Ipswich, UK (52° N) to vitamin D_3_ 100,000 IU every 4 months or placebo.66 After 5 years, 36 percent of the participants had a cardiac or cerebrovascular event, but there was no statistically significant difference between those taking vitamin D and those taking placebo. Similar results were found in subgroups of men and women. The RCT was rated quality B primarily due to inadequate verification of outcomes.

The FOS cohort evaluated 1739 men and women with no history of cardiovascular disease and a mean age of 59 years (based on the standard deviation, with an approximate rage of 41 to 77 years).67 After 5.4 years, 6.9 percent had a cardiovascular event (including myocardial infarction, coronary insufficiency, angina, stroke, transient ischemic attack, claudication, and heart failure). Overall, the methodological quality of the study was A; though their secondary analysis of three categories of serum 25(OH)D concentrations (as opposed to two categories) was rated C due to incomplete reporting and lack of adjustment for important variables including season of blood draw. In their primary analysis, people with serum 25(OH)D concentrations less than 37.5 nmol/L were 70 percent more likely (P=0.02) to have a cardiovascular event. In their secondary analysis, those with 25(OH)D concentrations between 25 and 37.5 nmol/L were about 50 percent more likely (P=0.01) to have an event than those with higher concentrations. Furthermore, a multivariable analysis of continuous 25(OH)D concentrations suggested increased likelihoods of cardiovascular events in those with 25(OH)D concentrations below approximately 50 to 55 nmol/L.

In a nested case-control study of the HPFS, 454 men 40 to 75 years old with no cardiovascular history who had a nonfatal myocardial infarction or coronary heart disease death over a 10 year period were matched with 1354 controls.68 The methodological quality of the analysis was A, although due to limitations on analyzable serum, the investigators had to use a case-control analysis instead of a complete analysis of all eligible men in the HPFS. Across four categories of men based on their serum 25(OH)D concentrations, lower concentrations were significantly associated with increased cardiovascular events (trend across categories P=0.02). Compared with men who had 25(OH)D concentrations above 75 nmol/L, those with 25(OH)D concentrations 56 to 75 nmol/L had an adjusted relative risk (RR) of 1.6 (95% CI 1.1, 2.3), those with 25(OH)D 37.5 to 56 nmol/L had an RR of 1.4 (95% CI 0.96, 2.1), and those with 25(OH)D below 37.5 nmol/L had an RR of 2.1 (95% CI 1.2, 3.5).

##### Cardiovascular Death

(Figures 6c and 6d)

Sixteen prospective studies and one nested case control study that examined the association between serum 25(OH)D and risk for cardiovascular death (including fatal myocardial infarction, sudden cardiac death, and coronary disease death) were identified for the current report. Seven prospective cohort studies (reported in eight articles) and the nested case control studies, with followups ranging from 7.3 to 29 years (one study did not report length of followup and one, an analysis of NHANES data, reported follow up in person years), observed an increased risk for cardiovascular death for those with the lowest serum 25(OH)D concentrations compared with the highest (three rated A, six rated B).63,69-76

The study by Eaton, which followed a subsample of the Women's Health Initiative participants, found an association among women with normal waist to hip ratios but not among women with abdominal obesity (rated A). 70

The study by Signorello observed the association among both African American and non-African American participants (rated A).74 A study by Fiscella of 15,363 adult participants in NHANES assessed differences between African Americans and whites and found a higher risk for cardiovascular death among blacks than whites that disappeared when adjusted for the lower serum 25(OH)D levels in blacks (rated A).71

The Whitehall study, reported by Tomson, observed a strong inverse association among elderly men between serum 25(OH)D and risk for cardiovascular death, at a median of 13 years' followup (rated B).75 The ESTHER study reported a strong inverse association among men and women at two followup times (4.5 and 9.2 years)(both rated B).63,76

The remaining 9 cohort studies, including the Octabaix 3-Year Followup study of the oldest old,77 found no association between serum 25(OH)D concentrations and risk for cardiovascular death four A, five B).58,78-84

In the original report, the British RCT of vitamin D_3_100,000 IU every 4 months versus placebo analyzed cardiovascular death as a primary outcome; 8 percent of the participants had cardiovascular deaths within 5 years.66 Fewer people taking vitamin D_3_ supplements had cardiovascular deaths (RR = 0.84), but this finding was not statistically significant (95% CI 0.65, 1.10). Similar results were found in subgroups of men and women.

An analysis of NHANES III (methodological quality C) evaluated cardiovascular death (due to hypertensive disease, ischemic heart disease, arrhythmia, heart failure, cerebrovascular disease, atherosclerosis or other disease of the arteries) in over 13,000 men and women regardless of baseline medical history.85 During almost 9 years of follow up, 5.8 percent had a cardiovascular death. The analysis compared four categories of serum 25(OH)D concentrations ranging from less than 44.5 nmol/L to more than 80 nmol/L. No significant association was found between serum 25(OH)D concentration and cardiovascular death.

##### Ischemic Heart Disease

(Figure 6a and b)

Three prospective cohort studies (reported in two articles) identified for the current report assessed the association between serum 25(OH)D concentrations and incident ischemic heart disease. These studies, one with a 10-year follow up and one with a 29-year follow up, found no significant difference in risk for nonfatal ischemic heart disease across four quartiles of serum 25(OH)D concentrations (both rated B).69,86

The RCT evaluated total ischemic heart disease.66 In this elderly British population, 17% had an ischemic heart disease event; no effect of vitamin D_3_ supplementation was found. Similar results were found in subgroups of men and women.

##### Ischemic Heart Disease Death

(Figure 6c and d)

The pooled results of two population-based studies reported in an article identified for the current report observed an association of serum 25(OH)D with death from ischemic heart disease(rated B). 86

An RCT identified for the original report evaluated total ischemic heart disease death as a primary outcome.66 In the trial, 3.4% had an ischemic heart disease event; no effect of vitamin D_3_ supplementation was found (RR = 0.84 [95% CI 0.56, 1.27]). Similar results were found in subgroups of men and women.

##### Myocardial Infarction

(Figure 6e)

Five prospective cohort studies identified for the current report assessed the association between serum 25(OH)D concentration and risk for myocardial infarction. Four of the studies found no association (two rated A, two rated B).58,69,87,88 A nested case control study within the EPIC study with a mean follow up time of 7.6 years found an association between serum 25(OH)D and myocardial infarction when the outcomes were adjusted only for sex and BMI but no association with a model that adjusted for various lifestyle factors as well (rated A).65 One cohort study that followed 2,312 older adults with no history of disease at baseline for 14 years found, after adjustment, that each 25nmol/L decrease in 25-OHD concentration was associated with a 25 percent greater (95% CI: 8% to 44% greater) relative hazard of myocardial infarction.81

In one small analysis, 755 elderly (age 65 to 99 years) Finnish men and women, regardless of cardiovascular history, were evaluated on the basis of myocardial infarction (methodological quality C due to lack of reporting of relevant data including information on the serum 25(OH)D or 1,25(OH)_2_D concentrations within the tertiles).89 During 10 years of follow up, 17 percent of the participants had a myocardial infarction. Both analyses of serum 25(OH)D and 1,25(OH)_2_D concentrations found no significant association with risk of myocardial infarction.

##### Stroke

(Figure 6f)

Seven prospective cohort studies identified for the current report assessed the association between serum 25(OH)D concentration and risk for stroke or transient ischemic attack. Three of the studies (followup ranging from 17 to 29 years) found a significantly increased risk for stroke or TIA for those with the lowest or lower serum 25(OH)D concentrations compared with those with the highest or higher concentrations, respectively (two rated B, one rated A),69,88,90 although for the women in the Nurses' Health Study,90 the difference was relatively small. The remaining four studies, with followup of 5 to 13 years, found no difference (two rated A, two rated B).58,63,86,91

One nested case control study within the EPIC population study, which had a followup of 7.6 years, reported a small j-shaped association of serum 25(OH)D with risk for stroke (rated A). 65

The RCT identified for the original report evaluated total cerebrovascular disease.66 In this elderly British population, 7.7% had a cerebrovascular event; no effect of vitamin D_3_ supplementation was found. Similar results were found in subgroups of men and women.

Stroke was evaluated in the same small Finnish study. During 10 years of follow up, 9.3 percent of the participants had a stroke. Both analyses of serum 25(OH)D and 1,25(OH)_2_D concentrations found no significant association with risk of stroke.

##### Cerebrovascular Death

(Figure 6g)

Three prospective cohort studies identified for the current report assessed the association between serum 25(OH)D concentrations and risk for fatal stroke or cerebrovascular death.63,82,83 One study, with a median followup of 27 years, found an increased risk for the lowest quintile of 25(OH)D concentration compared with the highest (rated A).82 The other two studies, with mean followup of 9 and 24 years, found no significant association between serum 25(OH)D concentration and risk for fatal stroke or cerebrovascular death for either men or women both rated B).63,83

The RCT identified for the original report evaluated cerebrovascular disease death as a primary outcome.66 In the trial, 2.0% had a fatal stroke; no effect of vitamin D_3_ supplementation was found. Similar results were found in subgroups of men and women.

##### Findings per Vitamin D Concentration

The RCT identified in the original study compared vitamin D_3_ supplementation 100,000 IU every 4 months with placebo, but found no effect on cardiovascular outcomes. Two cohort studies found a significant association between higher serum 25(OH)D concentrations and lower risk of combined cardiovascular events. Both found that those people in the highest 25(OH)D category analyzed within each study had the lowest risk. The FOS used a maximum threshold of 37.5 nmol/L; the HPFS used a maximum threshold of 75 nmol/L. The FOS provided a graphic representation of a multivariable regression of continuous 25(OH)D concentrations (Figure 2 in the study).67 The risk of cardiovascular events rose below 37 to 50 nmol/L serum 25(OH)D concentration. The Finnish cohort did not report the range of serum 25(OH)D and 1,25(OH)_2_D concentrations.89

##### Findings per Age and Sex

For the observational studies identified for the current report, differences were similar among men and women.

The single RCT identified for the original report included elderly people from the general population. No effects on various cardiovascular events were found. Subgroup analyses of men and women yielded similar findings. The four cohort studies included adults across the full age range. Three of the cohorts included about half men and women; one included only men. None evaluated potential differences in associations based on age or sex, but no differences were evident across studies.

#### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  For cardiovascular events, only a minority of evaluated participants were within this life stage (almost all above 40 years). The NHANES III study, which found no association between serum 25(OH)D concentration and cardiovascular death, included largely people within this life stage.
- 51–70 y
  The majority of people investigated for the association between serum 25(OH)D concentration and cardiovascular events were within this life stage. Significant associations were found between lower serum 25(OH)D concentrations and increased rates of cardiovascular events, across a range of 25(OH)D concentrations. The NHANES III study likely included many people within this life stage; no association was found with cardiovascular death in the original report; an analysis of a larger population identified for the current report found an association, as did a European population-based study.
- ≥71 y
  A number of new studies identified for the current report included a predominance of participants within this age group. Vitamin D supplementation and exposure were not consistently associated with cardiovascular outcomes in these studies. The majority of participants in the British RCT identified for the original report included men and women within this age group. Vitamin D supplementation was not found to have an effect on cardiovascular outcomes. Among the cohort studies, only the small Finnish study adequately evaluated people within this life stage. No significant associations were found between serum 25(OH)D or 1,25(OH)_2_D concentrations and either myocardial infarction or stroke, however, the absolute concentrations were not reported.
- Postmenopause
  In the original report, only the RCT provided data on a subgroup that included only postmenopausal women: No effect of vitamin D_3_ supplementation was found. For the current report, a post hoc assessment of a sample of WHI participants found an increased risk for cardiovascular death with decreasing serum 25(OH)D among normal weight postmenopausal women but not women with abdominal obesity.70
- Pregnant & lactating women
  Not reviewed

### Vitamin D and Body Weight

The current report did not assess the association between serum 25(OH)D concentrations and body weight. The original report searched for systematic reviews and primary studies that evaluated associations between vitamin D intake or body stores and incidence of overweight or obesity; no such studies were found. For the outcome weight change (in kilograms or body mass index units), only randomized controlled trials were included. The EPC and the TEP agreed that the limited resources would not be expended on reviewing observational studies for the surrogate outcome body weight (where overweight or obesity is considered to be the clinical outcomes). Only studies of adults were included. Studies of weight gain in children are included in the “Growth” section.

#### Synopsis

No qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and body weight in adults. Three RCTs from Finland, Norway, and India compared different doses of vitamin D (300 IU daily, 20,000 or 40,000 IU weekly, or 120,000 IU every 2 weeks) to placebo, with or without supplemental calcium in both groups. The study participants also varied: they were postmenopausal women, obese men and women, or only obese men. In the Finnish and Norwegian studies, the participants on average, gained weight in all groups over 1 or 3 years; in the Indian study weight remained mostly stable over 6 weeks. All studies found no difference in weight change with or without vitamin D supplementation.

#### Detailed Presentation

(Tables 12 and 13)

Table 12 Vitamin D and weight: Characteristics of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Heikkinen 1997^94^ Kuopio ORFPS Kuopio, Finland (63°N) [9405029] | - Health status | All, post-menopause | nd | Vit D_3_ & Ca lactate vs. Placebo & Ca lactate | nd
Heikkinen 1997^94^ Kuopio ORFPS Kuopio, Finland (63°N) [9405029] | - Mean age (range), y | 53 (47-56) | nd | Vit D_3_ & Ca lactate vs. Placebo & Ca lactate | nd
Heikkinen 1997^94^ Kuopio ORFPS Kuopio, Finland (63°N) [9405029] | - Male (%) | 0 | nd | Vit D_3_ & Ca lactate vs. Placebo & Ca lactate | nd
Sneve 2008^95^ Tromsø, Norway (70°N) [19056900] | - Health status | Healthy overweight and obese | 25(OH)D 53.1±16.9 nmol/L Ca intake 940±398 mg/d | Vit D_3_ 40,000 IU per week vs. Vit D_3_ 20,000 IU per week vs. Placebo All: Ca carbonate 500 mg/d | The compliance rate for cholecalciferol/placebo capsules were 95% in all 3 groups, and for the calcium tablets 81–85% across all 3 groups.
Sneve 2008^95^ Tromsø, Norway (70°N) [19056900] | - Mean age (range), y | 48 (21–70) | 25(OH)D 53.1±16.9 nmol/L Ca intake 940±398 mg/d | Vit D_3_ 40,000 IU per week vs. Vit D_3_ 20,000 IU per week vs. Placebo All: Ca carbonate 500 mg/d | The compliance rate for cholecalciferol/placebo capsules were 95% in all 3 groups, and for the calcium tablets 81–85% across all 3 groups.
Sneve 2008^95^ Tromsø, Norway (70°N) [19056900] | - Male (%) | 36 | 25(OH)D 53.1±16.9 nmol/L Ca intake 940±398 mg/d | Vit D_3_ 40,000 IU per week vs. Vit D_3_ 20,000 IU per week vs. Placebo All: Ca carbonate 500 mg/d | The compliance rate for cholecalciferol/placebo capsules were 95% in all 3 groups, and for the calcium tablets 81–85% across all 3 groups.
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Health status | Healthy, obese | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Mean age (SD), y | 44 (8) | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Male (%) | 100% | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws

Table 13 Vitamin D and weight: Results of RCTs [no new studies in the current report]

Author Year Study Name [PMID] | Age Range, Sex (Subgroup) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Isocaloric Diet
Heikkinen 1997^94^ Kuopio ORFPS [9405029] | 47–56 y, Women | Weight | 2° | 3 y | Vit D_3_ 300 IU + Ca lactate 93 mg | 83 | kg | 71.5 | +1.84% | +0.43%, +3.25% | -1.5% | -3.6%, +0.6%^A^ | NS^B^ | C
Heikkinen 1997^94^ Kuopio ORFPS [9405029] | 47–56 y, Women | Weight | 2° | 3 y | Ca lactate 93 mg | 95 | | 67.6 | +3.32% | +1.73%, 4.91% | | | | C
Sneve 2008^95^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Vit D_3_ 40,000 IU weekly + Ca carbonate 500 mg | 116 | kg | 101.0 | +0.1 | -0.6, +0.8 | -0.4 | -1.3, +0.5^A^ | NS | B
Sneve 2008^95^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Vit D_3 _20,000 IU weekly + Ca carbonate 500 mg | 106 | | 98.6 | +0.3 | -0.3, +0.9 | -0.2 | -1.1, +0.7^A^ | NS | B
Sneve 2008^95^ [19056900] | 21–70 y, Both | Weight | 1° | 1 y | Ca carbonate 500 mg | 112 | | 100.6 | +0.5 | -0.2, +1.2 | | | | B
Sneve 2008^95^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Vit D_3 _40,000 IU weekly + Ca carbonate 500 mg | 116 | BMI | 35.0 | 0.0 | -0.2, +0.2 | -0.2 | -0.6, +0.2^A^ | NS | B
Sneve 2008^95^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Vit D_3 _20,000 IU weekly + Ca carbonate 500 mg | 106 | | 34.4 | +0.1 | -0.1, +0.3 | -0.1 | -0.4, +0.2^A^ | NS | B
Sneve 2008^95^ [19056900] | 21–70 y, Both | BMI | 1° | 1 y | Ca carbonate 500 mg | 112 | | 35.1 | +0.2 | -0.1, +0.5 | | | | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | Weight | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | kg | nd | +0.03 | -0.6, +0.6 | +0.42 | -0.4, +1.2 | NS | C
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | Weight | 2° | 6 wk | Placebo | 36 | | nd | -0.38 | -0.9, +0.2 | | | | C
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | BMI | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | BMI | 26.7 | -0.02 | -0.2, +0.2 | +0.02 | -0.3, +0.3 | NS | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | BMI | 2° | 6 wk | Placebo | 36 | | 26.0 | -0.04 | -0.3, +0.2 | | | | B

A Estimated from reported data

B Per estimated 95% confidence interval, P=0.17

Note: Outcomes cells are shaded for the Control rows.

Three RCTs of vitamin D reported body weight (or body mass index [BMI]) as an outcome. The Kuopio (Finland) Osteoporosis Risk Factor and Prevention Study (Kuopio ORFPS) included postmenopausal women in a four-arm study.94 Two of the study arms included hormone replacement treatment and are not further discussed here. The remaining two arms compared vitamin D_3_ 300 IU (83 women) versus placebo (95 women), where all women were taking low dose calcium lactate 500 mg/d (equivalent to 93 mg Ca^++^/d). Women on cholesterol-lowering medication at any point during the trial were excluded. The primary outcome of the trial was the serum lipid profile. The women ranged in age from 47 to 56 years. After 3 years, women, on average, gained weight in both study arms (about 1–2 kg). Those in the placebo arm gained an absolute 1.5 percent more weight than those in the vitamin D arm, but the difference was not statistically significant. The study had a methodological quality of C due to an uneven distribution of body weights between study arms at baseline (means 71.5 and 67.6 kg) and an overall withdrawal rate of over 30 percent.

The second trial was conducted in Norway among healthy overweight and obese women and men.95 The participants' mean baseline serum 25(OH)D concentration was 53 nmol/L. The trial compared vitamin D_2_ 40,000 IU weekly (116 participants completed), 20,000 IU weekly (106 participants), and placebo (112 participants). All study participants also took calcium carbonate 500 mg daily. Almost all participants complied with the vitamin D (or placebo). Changes in weight and BMI were primary outcomes. The participants ranged in age from 21 to 70 years. After 1 year, changes in weight were small (increases of 0.1–0.5 kg) in each trial group. Compared to the placebo group, those taking the larger dose of vitamin D had less weight gain than those taking the smaller dose, but none of the differences among study groups were statistically significant. The study was rated methodological quality B, primarily due to the high dropout rate (25 percent), which was not explained.

The third trial was conducted in New Delhi, India among healthy obese men.96 The participants' mean baseline serum 25(OH)D concentration was about 33 nmol/L. The trial compared vitamin D_3_ 120,000 given under supervised conditions every 2 weeks and placebo in 100 men, of whom 71 were analyzed; most dropouts occurred because of refusals for subsequent blood draws (to assess the primary outcome). After 6 weeks, weight in kg and BMI were essentially stable, with no difference in weight change between the interventions. The study was rated methodological quality B because of the high dropout rate; for weight (in kg), the study was of quality C because baseline weights were not reported.

##### Findings per Vitamin D Dose

There was a lack of effect found across a range of doses from 300 IU to 8570 IU (prorated) daily.

##### Findings per Age and Sex

There was a lack of effect found in studies both of men mostly in their 40s, somewhat older people of both sexes, and postmenopausal women.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  No effect was found in one trial of men mostly within this life stage after 6 weeks.
- 51–70 y
  The majority of people in the trials were within this life stage. No significant effect was found on weight from vitamin D supplementation for 1 or 3 years.
- ≥71 y
  No data
- Postmenopause
  All the women in the Finnish trial were postmenopausal.
- Pregnant & lactating women
  Not reviewed

### Vitamin D and Cancer

This section explores cancer from all causes and total cancer mortality.

#### Synopsis

No qualified systematic reviews have evaluated relationships between vitamin D and total cancer incidence or mortality. No new RCTs were identified for the current report that addressed the effect of vitamin D or vitamin D combined with calcium on the risk for total cancer or cancer mortality. One cohort study found no association between total (all-cause) cancer and 25(OH)D concentrations (rated A), whereas a second cohort study observed an association in men but not in women (rated B). Ten cohort studies and one nested case control study addressed the association of serum 25(OH)D concentrations and cancer mortality. Five of the cohort studies (1 rated A, 4 rated B) observed no association of serum 25(OH)D concentration with total cancer mortality. Three cohort studies and the nested case control study observed a trend toward increased risk with decreased serum 25(OH)D (all rated B). One analysis using updated NHANES III data (rated B) observed a trend toward increasing risk for death with increasing serum 25(OH)D among men at higher latitudes whose blood was drawn in summer but the reverse in women. One cohort study observed a U-shaped association of increasing mortality with both low and high serum 25(OH)D.

One RCT in the original report showed no effect of combined vitamin D_3_ (1000 IU/d) and calcium (∼1500 mg/d) supplementation versus calcium supplementation (∼1500 mg/d) alone on the risk of total cancer in healthy postmenopausal women (>55 years old) living in Nebraska (latitude 41°N). Another RCT also found no difference in total cancer mortality or incidence between supplemental vitamin D_3_ (100,000 IU every 4 months) and placebo in elderly (71+ years old) men and women living in the United Kingdom (latitude 52° N). Both RCTs were rated B quality.

Analyses using NHANES III data (general adult populations living in the United States) showed no significant association between baseline 25(OH)D concentrations and total cancer mortality.

#### Detailed Presentation

(Tables 14, 15, 16, & 17)

Table 14 Vitamin D and total cancer and total cancer mortality: Characteristics of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | - Health status | Mentally and physically fit; post-menopause | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | - Mean age (SD), y | 67 (7.3) | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | - Male (%) | 0 | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Health status | General population | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/d (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Mean age (range), y | 75 (65–85) | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/d (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Male (%) | 76% | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/d (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%

A No difference between the vitamin D and the placebo arm.

Table 15 Vitamin D and total cancer and total cancer mortality: Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Cohort
Freedman 2007^103^ NHANES III US (various) [16481636] | - Health status | Any | - Assay method | RIA (DiaSorin) | Cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | Final model includes sex, race/ethnicity, and smoking pattern. Other potential confounders were examined but not chosen.
Freedman 2007^103^ NHANES III US (various) [16481636] | - Mean age (range), y | 44 (≥17) | - Assay method | RIA (DiaSorin) | Cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | Final model includes sex, race/ethnicity, and smoking pattern. Other potential confounders were examined but not chosen.
Freedman 2007^103^ NHANES III US (various) [16481636] | - Male (%) | 45 | - Season blood drawn | All | Cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | Final model includes sex, race/ethnicity, and smoking pattern. Other potential confounders were examined but not chosen.
Melamed 2008^85^ NHANES III US (various) [18695076] | - Health status | DM 7.4%, history of CVD 7.9%, HTN 25% | - Assay method | RIA (DiaSorin) | Cancer mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Mean age (range), y | 45 (≥20) | - Assay method | RIA (DiaSorin) | Cancer mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Male (%) | 46 | - Season blood drawn | All | Cancer mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
New Studies:
Cawthon, 2010^98^ MrOS | - Health status | >80% excellent/good health status | | | Cancer mortality stratified by baseline 25(OH)D quartiles and tertiles | X | X | X | X | X | X | MrOS study
Cawthon, 2010^98^ MrOS | - Mean age (range), y | 74 (≥65) | | | Cancer mortality stratified by baseline 25(OH)D quartiles and tertiles | X | X | X | X | X | X | MrOS study
Cawthon, 2010^98^ MrOS | - Male (%) | 100% | | | Cancer mortality stratified by baseline 25(OH)D quartiles and tertiles | X | X | X | X | X | X | MrOS study
de Boer, 2012^87^ US (various) | - Health status | nd | | | Cancer stratified by baseline 25(OH)D median | | X | X | X | | X
de Boer, 2012^87^ US (various) | - Mean age (SD), y | 74 (SD 4.6) | | | Cancer stratified by baseline 25(OH)D median | | X | X | X | | X
de Boer, 2012^87^ US (various) | - Male (%) | 30% | | | Cancer stratified by baseline 25(OH)D median | | X | X | X | | X
Eaton, 2011^70^ US (various) | - Health status | nd | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | | X | X | X | X
Eaton, 2011^70^ US (various) | - Mean age (SD), y | 65.1 (7.6) | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | | X | X | X | X
Eaton, 2011^70^ US (various) | - Male (%) | 0% | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | | X | X | X | X
Freedman, 2010^100^ US (various) | - Health status | nd | | | Total cancer mortality stratified by baseline 25(OH)D sextiles | | X | X | | X | X
Freedman, 2010^100^ US (various) | - Mean age (SD), y | 44.5 | | | Total cancer mortality stratified by baseline 25(OH)D sextiles | | X | X | | X | X
Freedman, 2010^100^ US (various) | - Male (%) | 87.8% | | | Total cancer mortality stratified by baseline 25(OH)D sextiles | | X | X | | X | X
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Health status | nd | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | X | X | X | | X
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Mean age (SD), y | nd | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | X | X | X | | X
Hutchinson, 2010^79^ Tromso Tromso, Norway | - Male (%) | nd | | | Cancer mortality stratified by baseline 25(OH)D quartiles | | X | X | X | | X
Lin, 2012^83^ Linxian, China | - Health status | Healthy, Hypertension | | | Cancer mortality stratified by baseline 25(OH)D tertiles | | X | X | X | | X
Lin, 2012^83^ Linxian, China | - Mean age (SD), y | 56.5 (SD 7.9) | | | Cancer mortality stratified by baseline 25(OH)D tertiles | | X | X | X | | X
Lin, 2012^83^ Linxian, China | - Male (%) | 55% | | | Cancer mortality stratified by baseline 25(OH)D tertiles | | X | X | X | | X
Michaelsson, 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Health status | More than 1/3 being treated for hypertension | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | X | X | X
Michaelsson, 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Mean age (SD), y | 71 (SD 0.6) | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | X | X | X
Michaelsson, 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Male (%) | 100% | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | X | X | X
Signorello, 2013^74^ Southern Community Cohort Study US | - Health status | nd | | | | | | X | | | X
Signorello, 2013^74^ Southern Community Cohort Study US | - Mean age (SD), y | nd | | | | | | X | | | X
Signorello, 2013^74^ Southern Community Cohort Study US | - Male (%) | nd | | | | | | X | | | X
Schottker 2013^76^ ESTHER Germany | - Health status | NR | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Mean age | 62 (SD 6.5) | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Male (%) | 43.8% | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | | X | X | X
Ordonez-Mena97 Saarland. Germany | - Health status | nd | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | | | X
Ordonez-Mena97 Saarland. Germany | - Mean age | NR (50–74) | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | | | X
Ordonez-Mena97 Saarland. Germany | - Male (%) | 54% | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | X | X | | | X
Afzal 2013^99^ Denmark | - Health status | NR | | | Cancer mortality stratified by baseline 25(OH)D category | | X | X | | | X
Afzal 2013^99^ Denmark | - Mean age | 58 (47–65) | | | Cancer mortality stratified by baseline 25(OH)D category | | X | X | | | X
Afzal 2013^99^ Denmark | - Male (%) | NR | | | Cancer mortality stratified by baseline 25(OH)D category | | X | X | | | X
New nested case-control studies:
Fedirko, 2012^101^ EPIC Multiple Countries | - Health status | nd | | | | | X | X | X | X | X
Fedirko, 2012^101^ EPIC Multiple Countries | - Mean age (SD), y | 62.1 (SD 7.2) | | | | | X | X | X | X | X
Fedirko, 2012^101^ EPIC Multiple Countries | - Male (%) | 40.5% | | | | | X | X | X | X | X

Table 16 Vitamin D and total cancer and total cancer mortality: Results of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 13 | 446 | RR (Vit D+Ca vs. Ca) | 0.76 | 0.38, 1.55 | NS | B
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | Post-menopausal women | Incident cancer (all causes) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 17 | 445 | | | | | B
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | Post-menopausal women | Incident cancer (restricted to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 8 | 403 | RR (Vit D+Ca vs. Ca) | 0.55 | 0.24,1.28 | NS | B
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | Post-menopausal women | Incident cancer (restricted to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Ca (citrate 1400 mg or carbonate 1500 mg) | 15 | 416 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | Incident cancer (all causes) | 2° | 5 | Vit D_3_ 100,000 IU every 4 mo (∼833 IU/d) | 188 | 1345 | HR (Vit D vs. placebo) | 1.09 | 0.86, 1.36 | NS | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | Incident cancer (all causes) | 2° | 5 | Placebo | 173 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | | Total cancer mortality | 2° | 5 | Vit D_3_ 100,000 IU every 4 mo (∼833 IU/d) | 63 | 1345 | HR (Vit D vs. placebo) | 0.86 | 0.61, 1.2 | NS
Trivedi 2003^66^ [12609940] | | Total cancer mortality | 2° | 5 | Placebo | 72 | 1341

Note: Outcomes cells are shaded for the Control rows.

Table 17 Vitamin D and total cancer and total cancer mortality: Results of cohort studies (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D, nmol/L | No. of Cases | No. in Category | Adjusted HR | 95% CI | P for Trend | Study Quality
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | <50 | 175 | 5744 | 1 | Reference | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | | | | | | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 50 to <62.5 | 103 | 3143 | 1.22 | 0.91, 1.64 | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | | | | | | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 62.5 to <80 | 117 | 3713 | 1.02 | 0.69, 1.50 | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | | | | | | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 80 to <100 | 80 | 4218 (total, ≥80 nmol/L) | 1 | 0.71, 1.40 | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | | | | | | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | 100 to <120 | 41 | | 0.92 | 0.58, 1.46 | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | | | | | | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (536/16818; 0.032) | 105 mo | ≥120 | 20 | | 1.49 | 0.85, 2.64 | 0.65 | B
Freedman 2007^103^ NHANES III US [16481636] | | | | | | | | | | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | <50 | 88 | 1993 | 1 | Reference | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | | | | | | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 50 to <62.5 | 57 | 1461 | 1.03 | 0.73, 1.44 | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | | | | | | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 62.5 to <80 | 71 | 1845 | 0.99 | 0.57, 1.74 | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | | | | | | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | 80 to <100 | 58 | 2333 (total, ≥80 nmol/L) | 1.21 | 0.83, 1.78 | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | | | | | | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, males | Cancer mortality (318/7632; 0.042) | 105 mo | ≥100 | 44 | | 1.35 | 0.78, 2.31 | 0.08 | B
Freedman 2007^103^ NHANES III US [16481636] | | | | | | | | | | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | <50 | 87 | 3751 | 1 | Reference | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | | | | | | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 50 to <62.5 | 46 | 1682 | 1.4 | 0.94, 2.08 | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | | | | | | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 62.5 to <80 | 46 | 1845 | 1.02 | 0.62, 1.67 | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | | | | | | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | 80 to <100 | 22 | 1885 (total, ≥80 nmol/L) | 0.72 | 0.40, 1.26 | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | | | | | | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636] | Adults, females | Cancer mortality (218/9163; 0.024) | 105 mo | ≥100 | 17 | | 0.78 | 0.40, 1.53 | 0.12 | B
Freedman 2007^103^ NHANES III US [16481636]
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | >80 | nd | nd | 1 | Reference | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | | | | | | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | 61–80 | nd | nd | 0.8 | 0.54, 1.19 | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | | | | | | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | 44–60 | nd | nd | 1.08 | 0.8, 1.46 | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | | | | | | nd | C
Freedman 2007^103^ NHANES III US [16481636] | Adults, both sexes | Cancer mortality (N=13331) | Median 8.7 (IQR 7.1–10.2) y | <44 | nd | nd | 0.91 | 0.63, 1.31 | nd | C
NEW Cohort Studies
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Q 1: <49.8 nmol/L | NR | 372 | 0.52 | 0.27, 1.00 | 0.086 | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Q 2: 49.8≥ to <63 nmol/L | NR | 370 | 0.90 | 0.51, 1.60 | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Q 3: ≥63to <75 nmol/L | NR | 372 | 0.80 | 0.45, 1.41 | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Q 4: ≥75 nmol/L | NR | 376 | 1.00 | reference | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Deficient, <50 nmol/L | NR | 376 | 0.51 | 0.27, 0.98 | 0.044 | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Insufficient, 50 to <75 nmol/L | NR | 737 | 0.85 | 0.52, 1.40 | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | Sufficient, ≥75 nmol/L | NR | 377 | 1.00 | reference | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | | | | | | | B
Cawthon 2010^98^ MrOS US (6 sites) | Men 65 and over | cancer mortality | 7.3 yrs | per SD decrease | NR | 1490 | 0.80 | 0.64, 0.99 | NR | B
de Boer 2012^87^ Cardiovascular Health Study US (4 sites) | Adults 65 and over | cancer | 11 yrs | Normal level | 259 | 1126 | 1.00 | Reference | NR | A
de Boer 2012^87^ Cardiovascular Health Study US (4 sites) | Adults 65 and over | cancer | 11 yrs | | | | | | | A
de Boer 2012^87^ Cardiovascular Health Study US (4 sites) | Adults 65 and over | cancer | 11 yrs | Low level (season specific, ranges 43–61 nmol/L) | 111 | 495 | 1.13 | 0.90, 1.42 | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | Q 1: 3.25–36.50 nmol/L | nd | 608 | 1.39 | 0.88, 2.19 | 0.11 | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | | | | | | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | Q 2: 36.51–49.95 nmol/L | nd | 606 | 1.22 | 0.79, 1.89 | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | | | | | | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | Q 3: 49.96–65.38 nmol/L | nd | 608 | 1.12 | 0.72, 1.72 | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | | | | | | | A
Eaton 2011^70^ WHI US (multisite) | Postmenopausal women | cancer mortality | 10 yrs | Q 4: 65.39–146.67 nmol/L | nd | 607 | 1.00 | Reference | | A
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | < 37.5 nmol/L | 116 | 2689 | RR = 1 | Reference | 0.43 | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | 37.5–<50 nmol/L | 174 | 3056 | 1.04 | 0.77, 1.41 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | 50–<62.5 nmol/L | 165 | 3143 | 1.23 | 0.89, 1.69 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | 62.5–80 nmol/L | 200 | 3713 | 1.19 | 0.86, 1.65 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | 80–<100 nmol/L | 139 | 2521 | 1.12 | 0.80, 1.57 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, all seasons | total cancer mortality | 13.4 yrs | ≥100 nmol/L | 90 | 1697 | 1.15 | 0.79, 1.68 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | < 37.5 nmol/L | 55 | 2689 | 1.00 | Reference | 0.23 | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | 37.5–<50 nmol/L | 79 | 3056 | 1.3 | 0.77, 2.19 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | 50–<62.5 nmol/L | 57 | 3143 | 1.2 | 0.64, 2.26 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | 62.5–80 nmol/L | 78 | 3713 | 1.67 | 0.98, 2.86 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | 80–<100 nmol/L | 54 | 2521 | 1.31 | 0.77, 2.23 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, winter/lower latitude | total cancer mortality | | ≥100 nmol/L | 32 | 1697 | 1.5 | 0.74, 3.02 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | < 37.5 nmol/L | 61 | 2689 | 1.00 | Reference | 0.67 | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | 37.5–<50 nmol/L | 95 | 3056 | 0.91 | 0.63, 1.32 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | 50–<62.5 nmol/L | 108 | 3143 | 1.19 | 0.78, 1.82 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | 62.5–80 nmol/L | 122 | 3713 | 1.02 | 0.67, 1.54 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | 80–<100 nmol/L | 85 | 2521 | 1.03 | 0.66, 1.63 | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men & women, summer/higher latitude | | | ≥100 nmol/L | 58 | 1697 | 1.02 | 0.63, 1.45 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | < 37.5 nmol/L | 47 | 2689 | 1.00 | Reference | 0.09 | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | 37.5–<50 nmol/L | 95 | 3056 | 1.66 | 0.98, 2.80 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | 50–<62.5 nmol/L | 90 | 3143 | 1.43 | 0.90, 2.26 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | 62.5–80 nmol/L | 122 | 3713 | 1.52 | 0.82, 2.80 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | 80–<100 nmol/L | 90 | 2521 | 1.66 | 1.06, 2.61 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, all seasons | | | ≥100 nmol/L | 69 | 1697 | 1.85 | 1.02, 3.35 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | < 37.5 nmol/L | 25 | 2689 | 1.00 | Reference | 0.55 | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | 37.5–<50 nmol/L | 51 | 3056 | 2.58 | 1.37, 4.87 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | 50–<62.5 nmol/L | 31 | 3143 | 1.14 | 0.48, 2.70 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | 62.5–80 nmol/L | 52 | 3713 | 1.99 | 0.86, 4.13 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | 80–<100 nmol/L | 33 | 2521 | 1.42 | 0.74, 2.72 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, winter/lower latitude | | | ≥100 nmol/L | 23 | 1697 | 1.94 | 0.69, 5.45 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | < 37.5 nmol/L | 22 | 2689 | 1.00 | Reference | 0.045 | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | 37.5–<50 nmol/L | 44 | 3056 | 1.28 | 0.51, 3.23 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | 50–<62.5 nmol/L | 59 | 3143 | 1.55 | 0.81, 2.99 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | 62.5–80 nmol/L | 70 | 3713 | 1.33 | 0.53, 3.53 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | 80–<100 nmol/L | 57 | 2521 | 1.76 | 0.87, 3.57 | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | men, summer/higher latitude | | | ≥100 nmol/L | 46 | 1697 | 1.84 | 0.85, 3.98 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | < 37.5 nmol/L | 69 | 2689 | 1.00 | Reference | 0.29 | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | 37.5–<50 nmol/L | 79 | 3056 | 0.85 | 0.59, 1.22 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | 50–<62.5 nmol/L | 75 | 3143 | 1.25 | 0.82, 1.90 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | 62.5–80 nmol/L | 78 | 3713 | 1.11 | 0.69, 1.79 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | 80–<100 nmol/L | 49 | 2521 | 0.86 | 0.50, 1.46 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, all seasons | | | ≥100 nmol/L | 21 | 1697 | 0.64 | 0.35, 1.18 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | < 37.5 nmol/L | 30 | 2689 | 1.00 | Reference | 0.42 | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | 37.5–<50 nmol/L | 28 | 3056 | 0.74 | 0.36, 1.51 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | 50–<62.5 nmol/L | 26 | 3143 | 1.27 | 0.51, 3.18 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | 62.5–80 nmol/L | 26 | 3713 | 1.44 | 0.61, 3.38 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | 80–<100 nmol/L | 21 | 2521 | 1.28 | 0.50, 3.24 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, winter/lower latitude | | | ≥100 nmol/L | 9 | 1697 | 1.01 | 0.26, 3.90 | | B
Freedman 2010^100^ NHANES III US (multisite) | | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | < 37.5 nmol/L | 39 | 2689 | 1.00 | Reference | 0.03 | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | 37.5–<50 nmol/L | 51 | 3056 | 0.88 | 0.54, 1.43 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | 50–<62.5 nmol/L | 49 | 3143 | 1.18 | 0.65, 2.12 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | 62.5–80 nmol/L | 52 | 3713 | 0.99 | 0.52, 1.87 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | 80–<100 nmol/L | 28 | 2521 | 0.7 | 0.34, 1.44 | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | | | | | | | B
Freedman 2010^100^ NHANES III US (multisite) | women, summer/higher latitude | | | ≥100 nmol/L | 12 | 1697 | 0.52 | 0.25, 1.10 | | B
Hutchinson 2010^79^ Tromsø Study Norway | Men (55–74 years) Women (50–74 years) | cancer mortality | 11.7 yrs | Quartile 1: mean=33.8 (sd=7.6) | 72 | 1184 | 1.14 | 0.80–1.63 | NR | B
| | cancer mortality | 11.7 yrs | | | | | | | B
non-smokers | | cancer mortality | 11.7 yrs | Quartile 2: mean=46.7 (sd=6.0) | 69 | 1187 | 1.13 | 0.80–1.61 | | B
non-smokers | | cancer mortality | 11.7 yrs | | | | | | | B
non-smokers | | cancer mortality | 11.7 yrs | Quartile 3: mean=56.2 (sd=6.0) | 74 | 1192 | 1.23 | 0.87–1.75 | | B
| | cancer mortality | 11.7 yrs | | | | | | | B
smokers | | cancer mortality | 11.7 yrs | Quartile 4: mean=72.3 (sd=13.2) | 58 | 1188 | 1.00 | Reference | | B
smokers | | cancer mortality | 11.7 yrs | | | | | | | B
smokers | | cancer mortality | 11.7 yrs | Quartile 1: mean=33.8 (sd=7.6) | 55 | 597 | 0.82 | 0.56–1.21 | NR | B
smokers | | cancer mortality | 11.7 yrs | | | | | | | B
smokers | | cancer mortality | 11.7 yrs | Quartile 2: mean=46.7 (sd=6.0) | 54 | 606 | 0.86 | 0.59–1.26 | | B
smokers | | cancer mortality | 11.7 yrs | | | | | | | B
smokers | | cancer mortality | 11.7 yrs | Quartile 3: mean=56.2 (sd=6.0) | 60 | 607 | 1.02 | 0.70–1.48 | | B
smokers | | cancer mortality | 11.7 yrs | | | | | | | B
smokers | | cancer mortality | 11.7 yrs | Quartile 4: mean=72.3 (sd=13.2) | 56 | 600 | 1.00 | Reference | | B
Lin 2012^83^ General Population Trial of Linxian China | | cancer deaths | 24 yrs | continuous 25(OH)D | 217 | 1101 | 0.97 | 0.89, 1.05 | 0.406 | B
Lin 2012^83^ General Population Trial of Linxian China | | cancer deaths | 24 yrs | | | | | | | B
Lin 2012^83^ General Population Trial of Linxian China | Men (40–69 years) | cancer deaths | 24 yrs | continuous 25(OH)D | 141 | 608 | 1.00 | 0.91, 1.10 | 0.967 | B
Lin 2012^83^ General Population Trial of Linxian China | | cancer deaths | 24 yrs | | | | | | | B
Lin 2012^83^ General Population Trial of Linxian China | women | cancer deaths | 24 yrs | continuous 25(OH)D | 76 | 493 | 0.88 | 0.75, 1.03 | 0.115 | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Sweden | Elderly men (mean age 71) | cancer mortality | 12.7 yrs | < 10th percentile (<46 nmol/L) | 27 | 119 | 1.99 | 1.29, 3.08 | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Sweden | Elderly men (mean age 71) | cancer mortality | 12.7 yrs | | | | | | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Sweden | Elderly men (mean age 71) | cancer mortality | 12.7 yrs | 10th–90th percentile (46–93 nmol/L) | 118 | 956 | 1.00 | Reference | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Sweden | Elderly men (mean age 71) | cancer mortality | 12.7 yrs | | | | | | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Sweden | Elderly men (mean age 71) | cancer mortality | 12.7 yrs | >90th percentile (>93 nmol/L) | 19 | 119 | 1.56 | 0.95, 2.56 | | B
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | Quartile 4: (>54.1 nmol/L) | 115 | 228 | OR = 1 | Reference | 0.53 | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | | | | | | | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | Quartile 3: 37.9–>54.1 nmol/L) | 102 | 228 | OR = 0.79 | 0.52, 1.21 | | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | | | | | | | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | Quartile 2: (25.45– 37.9 nmol/L) | 127 | 255 | OR = 1.03 | 0.66, 1.59 | | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | | | | | | | A
Signorello 2013^74^ Southern Community Cohort Study | Men and women (40–79 years, 2/3 African American) | cancer death | NR | Quartile 1: <25.45 nmol/L) | 133 | 243 | OR = 1.28 | 0.78, 2.11 | | A
Tomson 2013^75^ Whitehall study | | Death, cancer | 13.1 yrs | Doubling Concentration | 809 | 5409 | 0.84 | 0.71, 1.00 | | B
Schottker 2013^76^ ESTHER | | cancer mortality | 9.5 yrs | <30 | 90 | 1439 | 1.42 | 1.08, 1.87 | | B
Schottker 2013^76^ ESTHER | | cancer mortality | 9.5 yrs | 30–50 | 172 | 4188 | 1.04 | 0.83, 1.29 | | B
Schottker 2013^76^ ESTHER | | cancer mortality | 9.5 yrs | >50 | 171 | 3927 | 1.00 | Reference | | B
Afzal 2013^99^ | | all cancer | 28 yrs | 50% reduction in plasma levels | 2488 | 9791 | 1.06 | 1.02, 1.11 | | B
Ordonez-Mena97 | | total cancer | 8 yrs | Q1 | 235 | 2253 | 1.10 | 0.93, 1.30 | | B
Ordonez-Mena97 | | total cancer | 8 yrs | Q2+Q3 | 396 | 4500 | 1.00 | Reference | | B
Ordonez-Mena97 | | total cancer | 8 yrs | Q4 | 242 | 2254 | 1.12 | 0.95, 1.32 | | B
NEW Nested case-control study
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | <36.3 | 104 | 242 | 1.00 | Reference | 0.04 | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | | | | | | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | 36.4–48.6 | 85 | 239 | 0.76 | 0.56, 1.02 | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | | | | | | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | 48.7–60.5 | 95 | 241 | 0.93 | 0.69, 1.24 | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | | | | | | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | 60.6–76.8 | 78 | 240 | 0.78 | 0.58, 1.06 | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | | | | | | | B
Fedirko 2012^101^ EPIC Europe (multinational) | Men and women (age at diagnosis approximately 62) | colorectal cancer specific mortality | 73 mos | >76.8 | 82 | 240 | 0.69 | 0.50, 0.93 | | B

* Statistically significant (P<0.05)

Two cohort studies were identified for the current report that assessed the association between serum 25(OH)D and all-cause cancer. The Cardiovascular Health Study, conducted in four U.S. cities, tracked white adults 65 and over for a median of 11 years and found no association of cancer with seasonally adjusted serum 25(OH)D concentrations (rated A).87 The ESTHER Study, conducted in Germany, tracked 9,580 men and women ages 50 to 74 for more than 8 years: this study found an association between decreased serum 25(OH)D and increased risk for any cancer in men but not in women (rated B).97

Eight observational studies were identified for the current report that assessed the association of serum 25(OH)D with cancer mortality.

The MrOS study, which followed men 65 and over in six U.S. cities for a 7.3-year followup, found an association of cancer mortality with serum 25(OH)D concentrations within the range clinically defined as vitamin D deficient but not with the lowest quartile of serum 25(OH)D (rated B). 98

The Whitehall Study, a British study of 5,409 men with a followup of 13 years, observed a trend toward increasing risk for total cancer mortality with decreasing serum 25(OH)D (rated B). 75

A substudy in 2,429 postmenopausal women within the Women's Health Initiative with measured baseline 25(OH)D concentrations were followed for 10 years. No association was seen between cancer mortality and serum 25(OH)D concentrations (rated A). 70

The ESTHER Study observed a significant association between serum 25(OH)D in the lowest quartile and increased risk for total cancer mortality (rated B). 76

The Copenhagen City Heart Study, which followed 9,791 adults for 28 years, observed no association between serum 25(OH)D and total cancer mortality (rated B). 99

The General Population Trial of Linxian followed 29,584 men and women (40–69 years of age), of whom 217 died of cancer. No association was seen between serum 25(OH)D and risk for cancer death (rated B). 83

The Southern Community Cohort Study, which followed some 85,000 men and women, ages 40 to 79 (about two-thirds of whom were African American), also observed no significant association between serum 25(OH)D concentrations and cancer death. No differences were seen between African Americans and whites or between men and women (rated A) 74

An assessment of NHANES III data that stratified men and women by latitude and season of blood draw and followed them for an average of 13.4 years found a trend toward increased risk for cancer death with increasing serum 25(OH)D among men in higher latitudes with summer blood sampling but a decreased risk among women in this category; cancer deaths were not independently verified in this study(B). 100

The Uppsala Longitudinal Study of Adult Men followed a population of elderly men (average age 71 years) for an average 12.7 years. This study observed a U-shaped association: both lower and higher serum 25(OH)D were associated with higher cancer mortality (<10th percentile: adjusted HR 1.99 [1.29, 3.08]; >90th percentile: adjusted HR 1.56 [0.95, 2.56]) (rated B). 84

The Tromsø Study followed 7,161 men (age 55 to 74) and women (age 50 to 74), of whom 498 died of cancer over 11.7 years. A non-significant trend was observed between decreasing serum 25(OH)D and increasing cancer mortality (rated B). 79

A nested case-control study conducted within the EPIC study that matched 541 individuals who died of colorectal cancer (CRC) with 661 controls (half were men; average age at diagnosis was 62) observed a small but significant trend toward increasing risk for CRC death and lower serum 25(OH)D however it was noted that a high proportion of the women in the cohort were taking bisphosphonates to prevent osteoporosis, which could have affected risk for cancer and mortality (rated B). 101

From the original report, a 4-year population-based RCT,102 sampled from a 9 county, largely rural area in eastern Nebraska (latitude 41°N), aimed to determine the efficacy of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) or calcium alone (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d) compared to placebo in reducing fracture incident. Only the comparison between the combined vitamin D and calcium versus the calcium alone groups is discussed here. The other comparisons are described in the calcium and combined vitamin D and calcium sections. This study was rated methodological quality B. Incidence of cancer was a secondary outcome of this trial. A total of 1179 postmenopausal women, aged more than 55 years old, were randomized. The mean 25(OH)D concentration at baseline was 72 nmol/L. The relative risk of developing cancer at the end of study was 0.76 (95% CI: 0.38, 1.55). On the hypothesis that cancers diagnosed early in the study would have been present, although unrecognized on entry, the analyses were restricted to women who were free of cancer at 1 year intervention. The relative risk of developing cancer at the end of study for the vitamin D_3_ plus calcium group changed to 0.55 (95% CI 0.24, 1.28).

Another 5-year RCT compared the effects of supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo on total cancer mortality and incidence in 2686 elderly participants with a mean age of 75 years in the United Kingdom (latitude 52° N).66 Total cancer mortality and incidence were evaluated as two of multiple secondary endpoints. The primary endpoint was the prevention of fracture. At 5 years vitamin D_3_ supplementation had no significant effect on the prevention of total cancer mortality (HR 0.86; 95% CI 0.61, 1.20) or incidence (HR 1.09; 95% CI 0.86, 1.36). This trial was rated B because it did not report in sufficient detail the randomization method, and the outcome ascertainment was based on death certificates or self-reported data, not verified with another objective documents (e.g., medical records or pathology reports).

Reported in two publications (one was rated B and one was rated C), there was no association between baseline 25(OH)D concentrations and total cancer mortality in the total NHANES III study population85,103 or in subgroup analyses by either season or latitude after a median 9 years of follow up.103

#### Findings by Age, Sex and/or Ethnicity

Of the studies identified for the current report, only one assessed differences in the association of serum 25(OH)D with total cancer mortality by ethnicity and saw no differences.74 The analysis of NHANES III data observed apparently opposite associations between serum 25(OH)D concentrations between men and women of northern latitudes, as described above.100

Among studies identified for the original report, there were no differences in the total cancer mortality and incidence between men and women, reported in a 5-year RCT compared the effects of supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo. In the NHANES III analysis, there was a suggestion of increased risk of total cancer mortality in men whose baseline 25(OH)D were in the two highest categories (80 to <100 nmol/L; ≥100 nmol/L) compared to the reference category (<50 nmol/L) [80 to <100 nmol/L: RR = 1.21, 95% CI 0.83 to 1.78; ≥100 nmol/L: RR = 1.35; 95% CI 0.78 to 2.31; P for trend=0.08]. However, this relationship was not seen in women (P for trend=0.12).103 When racial/ethnic groups were considered separately, there was also no association between baseline 25(OH)D concentrations and total cancer mortality in non-Hispanic whites (P for trend=0.80), non-Hispanic blacks (P for trend=0.14), or Mexican Americans (P for trend=0.37).

#### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  No data
- 3–8 y
  No data
- 9–18 y
  No data
- 19–50 y
  No studies identified for the current report assessed the association between serum 25(OH)D and total cancer mortality by age. Analyses using NHANES III data showed no significant association between baseline 25(OH)D concentrations and total cancer mortality. NHANES III included participants mostly within this life stage.
- 51–70 y
  A proportion of participants in NHANES III were in this life stage, but no unique conclusions are possible for this life stage separate from those for people 19 to 50 years.
- ≥71 y
  One RCT included elderly men and women mostly in this life stage. The trial found no difference in total cancer mortality or incidence between supplemental vitamin D_3_ (100,000 IU every 4 months) and placebo.
- Postmenopause
  One assessment of postmenopausal women identified for the current study observed no association of serum 25(OH)D concentrations with total cancer death. One RCT with healthy postmenopausal women showed no effect of vitamin D_3_ supplementation (1000 IU/d) on the risk of total cancer.
- Pregnant & lactating women
  No Data

#### Prostate Cancer

##### Synopsis

No qualified systematic reviews have evaluated the association between serum 25(OH)D concentrations and incidence of prostate cancer. In the current report, one prospective cohort study and four nested case control studies (2 rated A, 3 rated B) found no association between baseline serum 25(OH)D concentrations and risk for prostate cancer. Two nested case-control studies (2B) observed a trend between higher serum 25(OH)D concentrations and increasing risk for prostate cancer. In one study this increase was seen only among men whose sera were sampled in Summer or Autumn; in the other study, this trend was observed only when participants were divided by quartiles of serum 25(OH)D concentration, but not when they were divided by categories of vitamin D sufficiency (concentrations less than 50nmol/L being considered deficient, 50–75nmol/L insufficient, and 75–125nmol/L considered sufficient). In the original report, eight nested case-control studies (2 rated B, 6 C) found no association between baseline serum 25(OH)D concentrations and the risk of prostate cancer. One study rated C found a significant association between lower baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and higher risk of prostate cancer (adjusted OR 1.8, lowest compared to highest quartile). The same study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and who had serum 25(OH)D concentration less than 40 nmol/L (adjusted OR 3.5). However, there was no difference in risk between low and high serum 25(OH)D concentration for those older than 51 years at study entry. A C-rated study suggested a U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer.

##### Detailed Presentation

(Tables 18 & 19; Figure 7)

Table 18 Vitamin D and prostate cancer: Characteristics of observational studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Nutrients | Demographic | Anthrop | Medical | UV Exposure | Lifestyles | Comments
Ahn 2008^110^ PLCO US (21ºN to 44ºN) [18505967] | Health status | 8% current smoker | Assay | RIA (Heartland) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | X | | X | X | | X
Ahn 2008^110^ PLCO US (21ºN to 44ºN) [18505967] | Mean age (range/SD), y | 67.8 (5.3) | Assay | RIA (Heartland) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | X | | X | X | | X
Ahn 2008^110^ PLCO US (21ºN to 44ºN) [18505967] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D quintiles | X | | X | X | | X
Platz 2004^119^ Mikhak 2007^117^ HPFS US (multiple latitudes) [15090720] [17440943] | Health status | Smoked 18%; DM 3.6% | Assay | RIA | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | 6% nonwhite
Platz 2004^119^ Mikhak 2007^117^ HPFS US (multiple latitudes) [15090720] [17440943] | Mean age (range/SD), y | 66 (7) | Assay | RIA | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | 6% nonwhite
Platz 2004^119^ Mikhak 2007^117^ HPFS US (multiple latitudes) [15090720] [17440943] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | 6% nonwhite
Freedman 2007^103^ NHANES III US (multiple latitudes) [17971526] | Health status | 28% current smoker | Assay | RIA | Prostate cancer mortality stratified by 2 baseline 25(OH)D categories | X | X | X | X | X | X | 71% white; 14% black; 6% Hispanics
Freedman 2007^103^ NHANES III US (multiple latitudes) [17971526] | Mean age (range/SD), y | 44 | Assay | RIA | Prostate cancer mortality stratified by 2 baseline 25(OH)D categories | X | X | X | X | X | X | 71% white; 14% black; 6% Hispanics
Freedman 2007^103^ NHANES III US (multiple latitudes) [17971526] | Male (%) | 100 | Season blood drawn | South: Nov to Mar; North: Apr to Oct | Prostate cancer mortality stratified by 2 baseline 25(OH)D categories | X | X | X | X | X | X | 71% white; 14% black; 6% Hispanics
Tuohimaa 2004^120^ Helsinki Heart Vasterbotten; Janus Project; Finland (60°N) [14618623] | Health status | Gemfibrozil vs. placebo subjects | Assay | RIA (Incstar) | Prostate cancer risk stratified by 5 baseline 25(OH)D categories | | X | | | X
Tuohimaa 2004^120^ Helsinki Heart Vasterbotten; Janus Project; Finland (60°N) [14618623] | Mean age (range/SD), y | <40 to >60 | Assay | RIA (Incstar) | Prostate cancer risk stratified by 5 baseline 25(OH)D categories | | X | | | X
Tuohimaa 2004^120^ Helsinki Heart Vasterbotten; Janus Project; Finland (60°N) [14618623] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by 5 baseline 25(OH)D categories | | X | | | X
Li 2007^116^ Gann 1996^122^ PHS US (multiple latitudes) [17388667] [8850273] | Health status | on ASA, β-carotene, placebo trial; 9% current smoker | Assay | RIA (Bruce Hollis) | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | | X | 94% white
Li 2007^116^ Gann 1996^122^ PHS US (multiple latitudes) [17388667] [8850273] | Mean age (range/SD), y | 58.9 (8.3) | Assay | RIA (Bruce Hollis) | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | | X | 94% white
Li 2007^116^ Gann 1996^122^ PHS US (multiple latitudes) [17388667] [8850273] | Male (%) | 100 | Season blood drawn | 24% spring or winter | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | | X | 94% white
Corder 1993^114^ San Francisco US (37ºN) [8220092] | Health status | nd | Assay | Competitive protein-binding (Haddad, 1971) | Prostate cancer risk compared by baseline 25(OH)D | | X | | | X | | 50% black; 50% white
Corder 1993^114^ San Francisco US (37ºN) [8220092] | Mean age (range/SD), y | 57 (38–81) | Assay | Competitive protein-binding (Haddad, 1971) | Prostate cancer risk compared by baseline 25(OH)D | | X | | | X | | 50% black; 50% white
Corder 1993^114^ San Francisco US (37ºN) [8220092] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk compared by baseline 25(OH)D | | X | | | X | | 50% black; 50% white
Ahonen 2000^111^ Helsinki Heart Finland (60°N) [11075874] | Health status | Gemfibrozil vs. placebo subjects | Assay | RIA (Incstar) | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | X | X
Ahonen 2000^111^ Helsinki Heart Finland (60°N) [11075874] | Mean age (range/SD), y | 40–57 | Assay | RIA (Incstar) | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | X | X
Ahonen 2000^111^ Helsinki Heart Finland (60°N) [11075874] | Male (%) | 100 | Season blood drawn | Jan-Feb; Mar-May; Sep | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | X | X
Nomura 1998^118^ Honolulu Heart US (21ºN) [9794175] | Health status | 64% smoked | Assay | Protein-binding | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | 100% Japanese Americans
Nomura 1998^118^ Honolulu Heart US (21ºN) [9794175] | Mean age (range/SD), y | 58 (49–70) | Assay | Protein-binding | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | 100% Japanese Americans
Nomura 1998^118^ Honolulu Heart US (21ºN) [9794175] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | 100% Japanese Americans
Tuohimaa 2007^121^ Helsinki Heart Finland (60°N) 17301263 | Health status | Gemfibrozil vs. placebo subjects | Assay | RIA (Incstar) | Prostate cancer risk stratified by 3 baseline 25(OH)D categories | | X | X | X
Tuohimaa 2007^121^ Helsinki Heart Finland (60°N) 17301263 | Mean age (range/SD), y | 51 (3.7) | Assay | RIA (Incstar) | Prostate cancer risk stratified by 3 baseline 25(OH)D categories | | X | X | X
Tuohimaa 2007^121^ Helsinki Heart Finland (60°N) 17301263 | Male (%) | 100 | Season blood drawn | Most in winter | Prostate cancer risk stratified by 3 baseline 25(OH)D categories | | X | X | X
Jacobs 2004^115^ NPC Eastern US (25º46'N to 41ºN) [15225833] | Health status | Selenium vs. placebo subjects^A^ | Assay | RIA | Prostate cancer risk stratified by baseline 25(OH)D tertiles | | X | X | X | X | X
Jacobs 2004^115^ NPC Eastern US (25º46'N to 41ºN) [15225833] | Mean age (range/SD), y | 68 (nd) | Assay | RIA | Prostate cancer risk stratified by baseline 25(OH)D tertiles | | X | X | X | X | X
Jacobs 2004^115^ NPC Eastern US (25º46'N to 41ºN) [15225833] | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | | X | X | X | X | X
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Health status | nd | Assay | RIA (Bruce Hollis, 1993) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Mean age (range/SD), y | <45–75+ | Assay | RIA (Bruce Hollis, 1993) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Male (%) | 100 | Season blood drawn | Aug through Nov | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Health status | had >1 colon adenoma removal | Assay | Competitive protein-binding (Quest) | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Mean age (range/SD), y | 62 (8.7) | Assay | Competitive protein-binding (Quest) | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Health status | nd | Assay | RIA (Bruce Hollis, 1993) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Mean age (range/SD), y | <45–75+ | Assay | RIA (Bruce Hollis, 1993) | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Braun 1995^113^ WCC, MD US (39°N) [7612803] | Male (%) | 100 | Season blood drawn | Aug through Nov | Prostate cancer risk stratified by baseline 25(OH)D quintiles | | X | | | | | 100% white
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Health status | had >1 colon adenoma removal | Assay | Competitive protein-binding (Quest) | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Mean age (range/SD), y | 62 (8.7) | Assay | Competitive protein-binding (Quest) | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
Baron 2005^112^ CPP US (multiple latitudes) [15767334]^B^ | Male (%) | 100 | Season blood drawn | nd | Prostate cancer risk stratified by baseline 25(OH)D tertiles | X | X | | | X | | 5% black
New nested case-control studies
Barnett, 2010^104^ MrOS US (various) | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | probably need to check another article from this study to get funding info
Barnett, 2010^104^ MrOS US (various) | Mean age (range/SD), y | 73.6 (5.9) | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | probably need to check another article from this study to get funding info
Barnett, 2010^104^ MrOS US (various) | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | | | X | X | probably need to check another article from this study to get funding info
Brandstedt, 2012^105^ Malmo, Sweden | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | | | X | Malmo Diet and Cancer Study (MDCS)
Brandstedt, 2012^105^ Malmo, Sweden | Mean age (range), y | 61.7 (NR, SD 6.4) | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | | | X | Malmo Diet and Cancer Study (MDCS)
Brandstedt, 2012^105^ Malmo, Sweden | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | | X | X | | | X | Malmo Diet and Cancer Study (MDCS)
Meyer, 2013^106^ Norway | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D sextiles | | X | | | X
Meyer, 2013^106^ Norway | Mean age (range), y | 48.2 (SD 9.2) | | | Prostate cancer risk stratified by baseline 25(OH)D sextiles | | X | | | X
Meyer, 2013^106^ Norway | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D sextiles | | X | | | X
Park, 2010^107^ Multiethnic Cohort Study | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | | X
Park, 2010^107^ Multiethnic Cohort Study | Mean age (SD), y | 68.7 (SD 7.2) | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | | X
Park, 2010^107^ Multiethnic Cohort Study | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | | X
Shui, 2012^108^ Health Professionals' Followup Study US | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Shui, 2012^108^ Health Professionals' Followup Study US | Mean age (SD), y | 64.4 (SD 7.8) | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Shui, 2012^108^ Health Professionals' Followup Study US | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | Health status | nd | | | Prostate cancer risk stratified by baseline 25(OH)D | | X | X | | | X
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | Mean age (SD), y | 60.5 (SD 6.2) | | | Prostate cancer risk stratified by baseline 25(OH)D | | X | X | | | X
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | Male (%) | 100% | | | Prostate cancer risk stratified by baseline 25(OH)D | | X | X | | | X
NEW Cohort study
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | Health status | NR | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | | X | X | | | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | Mean age | 50–74 | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | | X | X | | | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | Male (%) | 54% | | | Cancer mortality stratified by baseline 25(OH)D tertiles | X | | X | X | | | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer

A For prevention of recurrence of non-melanoma skin cancer.

B This is a cohort study, not a nested case-control study.

Table 19 Vitamin D and prostate cancer: Results of observational studies (updated from original report)

Author Year Study Name PMID | Life Stage (male), y | Outcome (No. of Cases; No. of Controls) | Time To Diagnosis, y | 25(OH)D Concentration, nmol/L | No. of Cases | No. of Control | Adjusted OR | 95% CI | P for Trend | Study Quality
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 12.8–42.5 | 119 | 157 | 1 | Reference | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | | | | | | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 42.5–51. | 125 | 156 | 1.1 | 0.78, 1.56 | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | | | | | | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 51.4–60.5 | 190 | 157 | 1.53 | 1.10, 2.13^*^ | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | | | | | | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 60.6–71.7 | 167 | 156 | 1.33 | 0.95, 1.86 | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | | | | | | 0.2 | B
Ahn 2008^110^ PLCO [8505967] | 51–70 | Prostate cancer (741; 781) | 2–8 | 71.8–129.5 | 148 | 155 | 1.18 | 0.83, 1.68 | 0.2 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 1^A^ | 109 | 114 | 1 | Reference | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | | | | | | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 2 | 115 | 113 | 1 | 0.67, 1.49 | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | | | | | | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 3 | 94 | 120 | 0.77 | 0.51, 1.15 | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | | | | | | 0.59 | B
Platz 2004^119^ Mikhak 2007^117^ HPFS [15090720] [17440943] | 51–70 | Prostate cancer (460; 460) | 2.2 (mean) | Quartile 4 | 142 | 113 | 1.19 | 0.79, 1.79 | 0.59 | B
Freedman 2007^103^ NHANES III [17971526] | 19–50 | Mortality prostate cancer | nd | <62.5 | 22 | nd | 1 | Reference | 0.95 | B
Freedman 2007^103^ NHANES III [17971526] | 19–50 | Mortality prostate cancer | nd | | | | | | 0.95 | B
Freedman 2007^103^ NHANES III [17971526] | 19–50 | Mortality prostate cancer | nd | ≥62.5 | 25 | nd | 0.91 | 0.39, 2.14 | 0.95 | B
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | ≤19 | 19 | nd | 1.5 | 0.8, 2.7 | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | | | | | | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 20–39 | 169 | nd | 1.3 | 0.98, 1.6 | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | | | | | | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 40–59 | 229 | nd | 1 | Reference | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | | | | | | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | 60–79 | 138 | nd | 1.2 | 0.9, 1.5 | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | | | | | | | C
Tuohimaa 2004^120^ Helsinki Heart [14618623] | 19–50 51–70 | Prostate cancer (622; 1451) | ≤9–>14 (range) | ≥80 | 67 | nd | 1.7 | 1.1, 2.4^*^ | | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 1^B^ | nd | nd | 1.01 | 0.71, 1.44 | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | | | | | | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 2 | nd | nd | 1.26 | 0.89, 1.80 | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | | | | | | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 3 | nd | nd | 1 | 0.71, 1.41 | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | | | | | | 0.91 | C
Li 2007^116^ PHS [17388667] | 19–50 51–70 | Prostate cancer (492; 664) | 11 (median) | Quartile 4 | nd | nd | 1 | Reference | 0.91 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 15.7–53.3 | nd | nd | 1 | nd | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | | | | | | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 53.4–70.9 | nd | nd | 1.1 | nd | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | | | | | | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 71–93.5 | nd | nd | 1.16 | nd | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | | | | | | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer (232; 414) | 6 (mean) | 93.6–194 | nd | nd | 0.92 | 0.56, 1.50 | 0.82 | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | | | | | | | | | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 15.7–53.3 | nd | nd | 1 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 53.4–70.9 | nd | nd | 1.19 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 71–93.5 | nd | nd | 1.75 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age ≤61 y | | 93.6–194 | nd | nd | 1.48 | 0.73, 2.98 | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | | | | | | | | | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 15.7–53.3 | nd | nd | 1 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 53.4–70.9 | nd | nd | 1 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 71–93.5 | nd | nd | 0.82 | nd | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | | | | | | nd | C
Gann 1996^122^ PHS [8850273] | 19–50 51–70 | Prostate cancer; age >61 y | | 93.6–194 | nd | nd | 0.76 | 0.39, 1.47 | nd | C
Corder 1993^114^ [8220092] | 19–50 51–70 | Prostate cancer (181; 181) | >5 (mode) | 60.0 (case) vs. 50.5 (control) (est.) | 181 | 181 | - | - | - | C
Corder 1993^114^ [8220092] | 19–50 51–70 | | | | | | | | | C
Corder 1993^114^ [8220092] | 19–50 51–70 | Mortality prostate cancer | | nd | 51 | nd | - | - | - | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | < 30^C^ | 48 | 131 | 1.8 | 1.0, 3.2^*^ | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | | | | | | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | 31–40 | 41 | 143 | 1.4 | 0.8, 2.4 | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | | | | | | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | 41–54 | 26 | 148 | 0.8 | 0.5, 1.5 | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | | | | | | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer (149; 566) | 8–14 (mode) | > 55 | 34 | 144 | 1 | Reference | 0.01 | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | | | | | | | | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those <52 years old at entry | | ≤40 | nd | nd | 3.5 | 1.7, 7.0^*^ | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those <52 years old at entry | | | | | | | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those <52 years old at entry | | >40 | nd | nd | 1 | | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | | | | | | | | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those >51 years old at entry | | ≤40 | nd | nd | 1.2 | 0.7, 2.1 | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those >51 years old at entry | | | | | | | | C
Ahonen 2000^111^ Helsinki Heart [11075874] | 19–50 51–70 | Prostate cancer in those >51 years old at entry | | >40 | nd | nd | 1 | | | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | <85^D^ | 38 | 34 | 1 | Reference | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | | | | | | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | 85–101 | 35 | 36 | 0.8 | 0.4, 1.8 | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | | | | | | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | 102–119 | 30 | 32 | 0.8 | 0.4, 1.7 | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | | | | | | 0.68 | C
Nomura 1998^118^ Honolulu Heart [9794175] | 19–50 51–70 | Prostate cancer (136; 136) | 16 (mean) | ≥120 | 33 | 34 | 0.8 | 0.4, 1.8 | 0.68 | C
Tuohimaa 2007^121^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | <40 | - | - | 1.88 | 1.15, 3.08^*^ | | C
Tuohimaa 2007^121^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | 40–59 | - | - | 1 | Reference | | C
Tuohimaa 2007^121^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | | | | | | | C
Tuohimaa 2007^121^ Helsinki Heart [17301263] | 19–50 51–70 | Prostate cancer (132; 456) | 10.8 (mean) | ≥60 | - | - | 1.25 | 0.64, 2.43 | | C
Jacobs 2004^115^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 20–63.3 | 26 | 58 | 1 | Reference | 0.51 | C
Jacobs 2004^115^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | | | | | | 0.51 | C
Jacobs 2004^115^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 63.4–81.9 | 33 | 49 | 1.71 | 0.68, 4.34 | 0.51 | C
Jacobs 2004^115^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | | | | | | 0.51 | C
Jacobs 2004^115^ NPC [15225833] | 51–70 | Prostate cancer (83; 166) | 5.1 (mean) | 82–149 | 24 | 59 | 0.75 | 0.29, 1.91 | 0.51 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | <60.1 | 7 | 24 | 1 | Reference | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | | | | | | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 60.1–73.8 | 17 | 25 | 2.3 | 0.7, 7.8 | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | | | | | | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 73.9–88.5 | 16 | 24 | 2.3 | 0.7, 7.7 | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | | | | | | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | 88.6–103 | 4 | 25 | 0.6 | 0.1, 2.5 | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | | | | | | 0.6 | C
Braun 1995^113^ WCC [7612803] | 19–50 51–70 | Prostate cancer (61; 122) | 14 (mean) | >103 | 17 | 24 | 2.4^E^ | 0.8, 8.2 | 0.6 | C
Baron 2005^112^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | <62.9 | nd | NA | 1 | Reference | 0.7 | C
Baron 2005^112^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | | | | | | 0.7 | C
Baron 2005^112^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | 62.9–84.9 | nd | NA | 1.22 | 0.66, 2.26 | 0.7 | C
Baron 2005^112^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | | | | | | 0.7 | C
Baron 2005^112^ CPP [15767334]^F^ | 19–50 51–70 | Prostate cancer (70 cases in a total of 672)^F^ | <4 (34%) | 85 | nd | NA | 0.32 | 0.72, 2.43 | 0.7 | C
NEW nested case-control studies
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | Quartile 1(7.75–49.75 nmol/L) | 68 | 411 | HR=1.00 | Reference | | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | | | | | | | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | Quartile 2(50.0–62.3 nmol/L) | 91 | 415 | 1.35 | 0.91, 2.01 | 0.130 | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | | | | | | | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | Quartile 3(62.5–74.8 nmol/L) | 53 | 406 | 0.64 | 0.41, 1.00 | 0.050 | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | | | | | | | B
Barnett 2010^104^ MrOS | men 65 and over | Prostate Cancer (297 cases in a total of 1648) | NR | Quartile 4 (75–189.0 nmol/L) | 85 | 416 | 1.20 | 0.81, 1.78 | 0.370 | B
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | Quartile 1(≤68nmol/L) | 206 | 242 | 1.00 | Reference | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | | | | | | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | Quartile 2(69–84nmol/L) | 237 | 232 | 1.25 | 0.95, 1.65 | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | | | | | | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | Quartile3(85–102nmol/L) | 245 | 226 | 1.37 | 1.03, 1.82 | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | | | | | | | A
Brandstedt 2012^105^ | 51–70 yrs; ≥71 yrs | Prostate Cancer (918; 924) | NR | Quartile 4(≥103nmol/L) | 230 | 224 | 1.34 | 0.99, 1.82 | 0.048 | A
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | <30nmol/L | 72 | 92 | IRR=0.82 | 0.58, 1.15 | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | 30–49nmol/L | 528 | 553 | 1.02 | 0.87, 1.21 | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | 50–69nmol/L | 718 | 771 | 1.00 | Reference | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | 70–89nmol/L | 537 | 466 | 1.24 | 1.05, 1.47 | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | ≥90nmol/L | 251 | 224 | 1.17 | 0.93, 1.48 | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (2106;2106) | NR | 30–nmol/L increase | NR | NR | 1.13 | 1.02, 1.25 | | B
Meyer 2013^106^ | | | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | <30nmol/L | 49 | 63 | 0.80 | 0.52, 1.23 | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | 30–49nmol/L | 304 | 286 | 1.09 | 0.86, 1.40 | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | 50–69nmol/L | 288 | 297 | 1.00 | Reference | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | 70–89nmol/L | 145 | 128 | 1.14 | 0.85, 1.53 | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | ≥90nmol/L | 38 | 50 | 0.74 | 0.46, 1.18 | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Winter/Spring) | NR | 30–nmol/L increase | NR | NR | 0.97 | 0.83, 1.14 | | B
Meyer 2013^106^ | | | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | <30nmol/L | 13 | 14 | 0.97 | 0.45, 2.10 | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | 30–49nmol/L | 132 | 172 | 0.87 | 0.66, 1.16 | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | 50–69nmol/L | 296 | 329 | 1.00 | Reference | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | 70–89nmol/L | 297 | 259 | 1.34 | 1.05, 1.71 | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | ≥90nmol/L | 180 | 144 | 1.46 | 1.07, 2.00 | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | | | | | | | B
Meyer 2013^106^ | | Prostate Cancer (Summer/Autumn) | NR | 30-nmol/L increase | NR | NR | 1.25 | 1.08, 1.45 | | B
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Quartile 1:<57.3 nmol/L | 82 | 163 | 1.00 | Reference | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Quartile 2: 57.3 <77.5 nmol/L | 84 | 166 | 1.05 | 0.70, 1.58 | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Quartile 3: 77.5<99.8 nmol/L | 72 | 172 | 0.81 | 0.52, 1.28 | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Quartile 4: ≥99.8 nmol/L | 91 | 155 | 1.17 | 0.72, 1.89 | 0.600 | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Deficient: <50nmol/LL | 53 | 106 | 1.10 | 0.68, 1.78 | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | Insufficient: 50–75 nmol/L | 98 | 204 | 1.04 | 0.73, 1.48 | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | 75–125 nmol/L | 137 | 287 | 1.00 | Reference | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | | | | | | | A
Park 2010^107^ multiethnic cohort | Men 45–75 yrs | Prostate Cancer (329, 656) | NR | ≥125 nmol/L | 41 | 59 | 1.52 | 0.92, 2.51 | 0.320 | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | Quartile 1 | 41 | 325 | 1.00 | Reference | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | Quartile 2 | 33 | 336 | 0.78 | 0.47, 1.30 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | Quartile 3 | 21 | 334 | 0.50 | 0.28, 0.88 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Lethal Prostate Cancer (209;1324) | 5.2 years | Quartile 4 | 19 | 329 | 0.44 | 0.24, 0.79 | 0.002 | A
Shui 2012^108^ Health Professionals' Followup Study | | | | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | Quartile 1 | 310 | 325 | 1.00 | Reference | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | Quartile 2 | 298 | 336 | 0.93 | 0.74, 1.17 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | Quartile 3 | 319 | 334 | 0.99 | 0.79,1.24 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Overall Prostate Cancer (1260;1324) | 5.2 years | Quartile 4 | 333 | 329 | 1.07 | 0.86, 1.34 | 0.45 | A
Shui 2012^108^ Health Professionals' Followup Study | | | | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | Quartile 1 | 51 | 325 | 1.00 | Reference | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | Quartile 2 | 43 | 336 | 0.96 | 0.61, 52 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | Quartile 3 | 32 | 334 | 0.63 | 0.39, 1.03 | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | Quartile 4 | 40 | 329 | 0.85 | 0.53, 1.35 | 0.22 | A
Shui 2012^108^ Health Professionals' Followup Study | | Advance stage at Diagnosis (166;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | Quartile 1 | 69 | 325 | 1.00 | Reference | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | Quartile 2 | 55 | 336 | 0.81 | 0.54, 1.21 | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | Quartile 3 | 51 | 334 | 0.75 | 0.50, 1.13 | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | | | | | | | A
Shui 2012^108^ Health Professionals' Followup Study | | High Grade Prostate Cancer (239;1324) | 5.2 years | Quartile 4 | 64 | 329 | 0.99 | 0.67, 1.46 | 0.87 | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Quintile 1 (2.5–40.4nmol/L) | 125 | 151 | 1.00 | Reference | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | | | | | | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Quintile 2(40.5–50.4 nmol/L) | 143 | 150 | 1.27 | 0.89, 1.81 | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | | | | | | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Quintile 3(50.5–59.1nmol/L) | 128 | 151 | 1.23 | 0.85, 1.76 | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | | | | | | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Quintile 4 (59.2–70.8nmol/L) | 114 | 150 | 1.06 | 0.73, 1.55 | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | | | | | | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Quintile 5(70.9–163.7nmol/L) | 142 | 150 | 1.28 | 0.88, 1.88 | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | | | | | | | A
Travis 2009^109^ European Prospective Investigation into Cancer and Nutrition (EPIC) | | Prostate Cancer | 4.1 years | Doubling Concentration | 652 | 752 | 1.17 | 0.93, 1.47 | 0.188 | A
Ordonez-Mena 2013^97^ ESTHER | | Prostate Cancer | 8 yrs | Q1 | 38 | 882 | HR 1.16 | 0.78, 1.74 | | B
Ordonez-Mena 2013^97^ ESTHER | | Prostate Cancer | 8 yrs | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | | Prostate Cancer | 8 yrs | Q2+Q3 | 66 | 1737 | HR 1.00 | Reference | | B
Ordonez-Mena 2013^97^ ESTHER | | Prostate Cancer | 8 yrs | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | | Prostate Cancer | 8 yrs | Q4 | 67 | 1505 | HR 1.21 | 0.86, 1.70 | | B

* Statistically significant (P<0.05)

A Cut points separated by analytical run; season, distributions among control (see Table 3 in original study).

B Cut points based on control standardized by season of collection.

C Cut points based on total original cohort.

D Cut points based on control frequency.

E Unadjusted.

F This is a cohort study, not a nested case-control study.

Figure 7 Prostate cancer risk stratified by vitamin D concentration (updated from original report)

This figure, known as a forest plot, displays the risk for prostate cancer stratified by vitamin D concentration. The first column shows the 16 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 16 studies. Results for each study are in Table 19.

For the current report, a total of one prospective cohort and six nested case-control studies reported on the association between baseline serum 25(OH)D concentrations and the risk for prostate cancer.104-109 The cohort study and four of the six nested case-control studies observed no association between serum 25(OH)D and risk for prostate cancer. No studies identified an association between lower serum 25(OH)D and increasing overall risk for prostate cancer. One study, a nested case-control within the Health Professionals' Followup Study, found an association between lower baseline serum 25(OH)D and increasing risk for lethal prostate cancer (adjusted OR 0.44 [0.24, 0.79) (comparing the lowest with the highest quartile of 25(OH)D), with no effect of time to diagnosis (rated A).108 Three nested case-control studies (two rated A and one B) observed a trend between higher serum 25(OH)D concentrations and increasing risk for prostate cancer.105-107 In one study this increase was seen only among men whose sera were sampled in Summer or Autumn;106 in another study, the Multiethnic Cohort, this trend was observed only when participants were divided by quartiles of serum 25(OH)D concentration, but not when they were divided by categories of vitamin D sufficiency.107 The number of cases in the nested case control studies ranged from 297 to 2,106. The methodological quality of two studies was B, and four were rated A.

In the original report, a total of 12 nested case-control studies in 14 publications reported on the association between baseline serum 25(OH)D concentrations and the risk of prostate cancer.103,110-122 The number of cases ranged from 61 to 749. The latitudes of the studies ranged from 21º N to 60º N. The mean age of the subjects ranged from 44 to 68 years. Baseline serum concentrations of 25(OH)D in these studies ranged from 12.8 to 194 nmol/L. The time between blood drawn and the diagnosis of prostate cancer varied from 2 to 16 years. The methodological quality of three studies was rated B and nine studies were rated C.

Ten studies identified for the original report reported data on subjects with a mean age ranged from 51 to 68 years. Eight studies did not find an association by trend analysis between baseline serum 25(OH)D concentrations and the risk of prostate cancer.110,112-119,122 One study found no association between baseline serum 25(OH)D concentrations and mortality from prostate cancer.114 One study found an association between lower baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and the risk of prostate cancer (P for trend = 0.01).111 The adjusted OR of the lowest compared to highest quartile was 1.8. The study also found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95% CI 1.7, 7.0). However, there was no difference in risk (adjusted OR 1.2, P=NS) between low (≤40 nmol/L) and high (>40 nmol/L) serum 25(OH)D concentration for those older than 51 years at study entry. This study did not adjust for factors potentially relevant to prostate cancer. One study reported an U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer: the odds ratio in the group with 25(OH)D concentration of at least 80 nmol/L was 1.7 (95% CI 1.1, 2.4) compared to the group with a 25(OH)D concentration of 40–49 nmol/L; the odds ratio in the group with 25(OH)D concentration of no more than 19 nmol/L was 1.5 (95% CI 0.8, 2.7) compared to the group with a 25(OH)D concentration of 40 to 49 nmol/L.120 Even though this study used a conditional logistic regression in its analysis to maintain matching status, it was unclear if additional factors potentially relevant to prostate cancer were also entered into the regression analysis.

###### 1,25(OH)_2_D

Five studies reported on the association between 1,25(OH)_2_D serum concentrations and the risk of prostate cancer. Four studies did not find an association.115,118,119,122 One study found that the risk of prostate cancer decreased with higher serum concentrations of 1,25(OH)_2_D in men with low serum concentrations of 25(OH)D (unadjusted OR 0.15, comparing 4th quartile of 1,25(OH)_2_D (104–211 pmol/L) to 1st quartile (13–68 pmol/L) in men with serum 25(OH)D concentrations that ranged from 7.5–45 nmol/L).114 When stratified by age and race, this association was only found in men above the median age of 57 years at time of blood drawn but not in younger men; the association was similar in black and white men.

##### Findings by Life Stage

- 0–6 mo
  not applicable
- 7 mo–2 y
  not applicable
- 3–8 y
  not applicable
- 9–18 y
  not reviewed
- 19–50 y
  None of the studies in the update report focused on younger participants. Two studies in the original report provided data on younger subjects. Ahonen et al. analyzed subjects from 40 to 57 years of age.111 The study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95% CI 1.7, 7.0). The corresponding adjusted OR for those older than 51 years at study entry was 1.2 and was not significant. This study adjusted for factors related to insulin resistance syndrome but not those potentially related to prostate cancer. Freedman et al. analyzed data from NHANES III and reported on subjects with a mean age of 44 years and found that the adjusted relative risk of mortality from prostate cancer was 0.91 (95% CI 0.39, 2.14) in the group with baseline serum 25(OH)D concentration of at least 62.5 nmol/L compared to the group with less than 62.5 nmol/L.103 In the original report, one study found that the prostate cancer risk was highest in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95% CI 1.7, 7.0). Another study analyzed data from NHANES III and reported on subjects with a mean age of 44 years and found that the adjusted relative risk of mortality from prostate cancer was 0.91 (95% CI 0.39, 2.14) in the group with baseline serum 25(OH)D concentration of at least 62.5 nmol/L compared to the group with less than 62.5 nmol/L.
- 51–70 y
  All of the studies identified for the update report included men whose average age was 60 or higher. One cohort included only men 65 and older104 Only one study reported on effect of age at diagnosis. No studies identified an association between lower serum 25(OH)D and increasing overall risk for prostate cancer. One study, a nested case-control within the Health Professionals' Followup Study, found an association between lower baseline serum 25(OH)D and increasing risk for lethal prostate cancer (adjusted OR 0.44 [0.24, 0.79) (comparing the highest to the lowest quartile of 25(OH)D), with no effect of time to diagnosis.108 Three nested case-control studies (2B) observed a trend between higher serum 25(OH)D concentrations and increasing risk for prostate cancer.105-107 In one study this increase was seen only among men whose sera were sampled in Summer or Autumn;106 in another study, the Multiethnic Cohort, this trend was observed only when participants were divided by quartiles of serum 25(OH)D concentration, but not when they were divided by categories of vitamin D sufficiency.107 In the original report, eight studies did not find an association by P for trend analysis between baseline serum 25(OH)D concentrations and the risk of prostate cancer. One study found an inverse association of baseline serum 25(OH)D concentrations (<30 compared to >55 nmol/L) and the risk of prostate cancer (adjusted OR 1.8, lowest compared to highest quartile, P for trend = 0.01). This study found that the prostate cancer risk was increased in subjects less than 52 years at study entry and had low serum 25(OH)D concentration (≤40 nmol/L) (adjusted OR 3.5, 95% CI 1.7, 7.0). However, there was no difference in risk (adjusted OR 1.2, P=NS) between low (≤40 nmol/L) and high (>40 nmol/L) serum 25(OH)D concentration for those older than 51 years at study entry. One study reported an U-shaped association between baseline serum 25(OH)D concentrations and the risk of prostate cancer: the odds ratio in the group with 25(OH)D concentration of at least 80 nmol/L was 1.7 (95% CI 1.1, 2.4) compared to the group with a 25(OH)D concentration of 40–49 nmol/L; the odds ratio in the group with 25(OH)D concentration of no more than 19 nmol/L was 1.5 (95% CI 0.8, 2.7) compared to the group with a 25(OH)D concentration of 40 to 49 nmol/L.
- ≥71 y
  No study specifically targeted men older than 70 years.
- Postmenopause
  Not applicable
- Pregnant & lactating women
  Not applicable

#### Colorectal Cancer

##### Synopsis

No qualified systematic reviews have evaluated the association between 25(OH)D concentrations and colorectal cancer mortality or incidence. No new RCTs and cohort studies that addressed the effect of vitamin D or vitamin D and calcium on colorectal cancer mortality or incidence were identified for the current report. Three nested case-control studies (2A, 1B) found trends of increasing colorectal cancer incidence with decreasing 25(OH)D concentrations. One nested case-control study (rated B) found no association between colorectal cancer and 25(OH)D. Two of these nested case-control studies (2B) also examined colon and rectal cancer as separate outcomes. One study reported a significant negative trend between 25(OH)D and colon cancer risk and the other found a non-significant negative trend. For rectal cancer, the same two studies reported either a negative trend or a small but non-significant negative trend with 25(OH)D.

In the original report, one B quality RCT of elderly population reported no significant difference in colorectal cancer mortality or incidence between supplemental vitamin D_3_ and no supplements. One B quality cohort study found an inverse association between higher 25(OH)D concentrations and the risk of colorectal cancer mortality (HR 0.28, highest compared to lowest tertile). Two B quality nested case-control studies of women found a trend between higher 25(OH)D serum concentrations and lower risk of colorectal cancer incidence (trend analysis). Another two B quality nested case-control studies of men, and one B quality and two C quality nested case-control studies of both sexes reported no significant association between 25(OH)D concentrations and risk of colorectal cancer or colon cancer.

##### Detailed Presentation of Supplemental Vitamin D and Colorectal Cancer

(Tables 20 & 21)

Table 20 Vitamin D and colorectal cancer: Characteristics of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Health status | General population | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Mean age (range), y | 75 (65–85) | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%
Trivedi 2003^66^ Oxford, UK (52°N) [12609940] | - Male (%) | 76% | 25(OH)D: 53.4 nmol/L Calcium intake= 742 mg/day (at 4 years, no difference by treatment allocation) | Vit D_3_ 100,000 IU vs. placebo every 4 months | Participants taking ≥80% of study medication: 76%^A^ | Previous CVD: 28%, previous cancer: 6%, steroids user: 5%, and HRT taker: 7%

Abbreviations: CVD = cardiovascular disease; HRT = hormone replacement therapy.

A No difference between the vitamin D and the placebo arm.

Table 21 Vitamin D and colorectal cancer: Results of RCTs [no new studies in the current report]

Author Year Study Name [PMID] | Age Range, Sex (Subgroup) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | CRC, mortality | 2° | 5 y | Vit D_3_ 100,000 IU every 4 mo | 7 | 1345 | Age adj HR (Vit D/Placebo) | 0.62 | 0.24, 1.60 | 0.33 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | CRC, mortality | 2° | 5 y | Placebo | 11 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | CRC, incidence | 2° | 5 y | Vit D_3_ | 28 | 1345 | Age adj HR (Vit D/Placebo) | 1.02 | 0.60, 1.74 | 0.94 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Both sexes | CRC, incidence | 2° | 5 y | Placebo | 27 | 1341 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Men | CRC, mortality | 2° | 5 y | Vit D_3_ | 7 | 1019 | Age adj HR (Vit D/Placebo) | 0.97 | 0.34, 2.78 | 0.96 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Men | CRC, mortality | 2° | 5 y | Placebo | 7 | 1018 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Men | CRC, incidence | 2° | 5 y | Vit D_3_ | 25 | 1019 | Age adj HR (Vit D/Placebo) | 1.18 | 0.65, 2.12 | 0.59 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Men | CRC, incidence | 2° | 5 y | Placebo | 21 | 1018 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Women | CRC, mortality | 2° | 5 y | Vit D_3_ | 0 | 326 | Age adj HR (Vit D/Placebo) | NA | NA | 0.04 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Women | CRC, mortality | 2° | 5 y | Placebo | 4 | 323 | | | | | B
Trivedi 2003^66^ [12609940] | 65–85 y, Women | CRC, incidence | 2° | 5 y | Vit D_3_ | 3 | 326 | Age adj HR (Vit D/Placebo) | 0.49 | 0.12, 1.98 | 0.32 | B
Trivedi 2003^66^ [12609940] | 65–85 y, Women | CRC, incidence | 2° | 5 y | Placebo | 6 | 323 | | | | | B

Note: Outcomes cells are shaded for the Control rows.

In the original report, an RCT compared supplemental vitamin D_3_ (100,000 IU every 4 months) with placebo in 2686 elderly participants with a mean age of 75 years in the United Kingdom (latitude 52° N).66 Colorectal cancer mortality and incidence were evaluated as two of multiple secondary endpoints. The primary endpoint was the prevention of fracture. At 5 years vitamin D_3_ supplementation had no significant effect on the prevention of colorectal cancer mortality (P=0.33) or incidence (P=0.94). This trial was rated B because it did not report in sufficient detail the randomization method, and the outcome ascertainment was based on death certificates or self-reported data, not verified with another objective documents (e.g., medical records or pathology reports).

###### Findings per Age and Sex

The same British trial reported no significant difference in colorectal cancer mortality or incidence between the vitamin D supplements group and the placebo at 5 years in men (P=0.96 and 0.59, respectively). In women, the trial also found no significant difference in colorectal cancer incidence between the two groups (P=0.32), whereas the risk of colorectal cancer mortality in the supplements group was significantly decreased compared to the placebo (0/326 deaths vs. 4/323 deaths; HR, not reported; P=0.04).

###### Findings per Special Populations

No subgroup data were available regarding special populations (e.g., obese participants, smokers, ethnic groups, or users of contraceptives).

##### Detailed Presentation of 25(OH)D Concentrations and Colorectal Cancer

(Tables 22 & 23; Figures 8, 9, & 10)

Table 22 Vitamin D and colorectal cancer: Characteristics of observational studies^A^ (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Cohort
Freedman 2007^103^ NHANES III US (various) [16481636] | - Health status | Any | - Assay method | RIA (DiaSorin) | Colorectal cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | White: 71%; Black: 14%; Hispanic: 6%; Others: 9%
Freedman 2007^103^ NHANES III US (various) [16481636] | - Mean age (range), y | 44 (≥17) | - Assay method | RIA (DiaSorin) | Colorectal cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | White: 71%; Black: 14%; Hispanic: 6%; Others: 9%
Freedman 2007^103^ NHANES III US (various) [16481636] | - Male (%) | 45 | - Season blood drawn | All | Colorectal cancer mortality stratified by prespecified baseline 25(OH)D cut points | X | X | X | X | X | X | White: 71%; Black: 14%; Hispanic: 6%; Others: 9%
Nested case-control
Braun 1995^133^ WCC Maryland, US (38°N) [329893] | - Health status | Any | - Assay method | RIA (Horris 1993) | - 25(OH)D levels between cases and controls | | X | | | X
Braun 1995^133^ WCC Maryland, US (38°N) [329893] | - Mean age (range), y | 55 (nd) | - Assay method | RIA (Horris 1993) | - 25(OH)D levels between cases and controls | | X | | | X
Braun 1995^133^ WCC Maryland, US (38°N) [329893] | - Male (%) | nd | - Season blood drawn | Fall | - Colon cancer risk stratified by baseline 25(OH)D quintiles | | X | | | X
Feskanich 2004^130^ NHS US (various) [15342452] | - Health status | Any | - Assay method | RIA (Horris 1997) | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user (>10 y): 10%; Hormone replacement therapy: 34%
Feskanich 2004^130^ NHS US (various) [15342452] | - Mean age (range), y | 60 (43–70) | - Assay method | RIA (Horris 1997) | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user (>10 y): 10%; Hormone replacement therapy: 34%
Feskanich 2004^130^ NHS US (various) [15342452] | - Male (%) | 0 | - Season blood drawn | All | Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user (>10 y): 10%; Hormone replacement therapy: 34%
Garland 1989^132^ WCC Maryland, US (38°N) [2572900] | - Health status | Any | - Assay method | HPLA (Clemens 1982) | - 25(OH)D levels between cases and controls | | X | | | X | | White: 100%
Garland 1989^132^ WCC Maryland, US (38°N) [2572900] | - Mean age (range), y | 63 (nd) | - Assay method | HPLA (Clemens 1982) | - 25(OH)D levels between cases and controls | | X | | | X | | White: 100%
Garland 1989^132^ WCC Maryland, US (38°N) [2572900] | - Male (%) | 50 | - Season blood drawn | Fall | - Colon cancer risk stratified by baseline 25(OH)D quintiles | | X | | | X | | White: 100%
Cohort
Otani 2007^128^ Japan PHC Japan (various) [17622244] | - Health status | Any | - Assay method | CPBA (Haddad 1971) | - 25(OH)D levels between cases and controls | X | X | X | X | X | X
Otani 2007^128^ Japan PHC Japan (various) [17622244] | - Mean age (range), y | Men: 57 (40–69); Women: 56 (40–69) | - Assay method | CPBA (Haddad 1971) | - 25(OH)D levels between cases and controls | X | X | X | X | X | X
Otani 2007^128^ Japan PHC Japan (various) [17622244] | - Male (%) | | - Season blood drawn | All | - Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Tangrea 1997^127^ ATBC Finland (∼60°N) [9242478] | - Health status | Smoker^B^ | - Assay method | RIA (Horris 1993) | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Tangrea 1997^127^ ATBC Finland (∼60°N) [9242478] | - Mean age (range), y | 60 (50–69) | - Assay method | RIA (Horris 1993) | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Tangrea 1997^127^ ATBC Finland (∼60°N) [9242478] | - Male (%) | 100 | - Season blood drawn | All | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Health status | Post-menopausal women^C^ | - Assay method | RIA (DiaSorin) | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | | X | White: 83%; Black: 9%; Hispanic: 4% Others: 4%
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Mean age (range), y | nd (50–79) | - Assay method | RIA (DiaSorin) | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | | X | White: 83%; Black: 9%; Hispanic: 4% Others: 4%
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Male (%) | 0 | - Season blood drawn | All | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | | X | X | X | | X | White: 83%; Black: 9%; Hispanic: 4% Others: 4%
Wu 2007^129^ HPFS US (various) [17623801] | - Health status | Smoker 5% | - Assay method | RIA (Horris 1997) | - 25(OH)D levels between cases and controls | X | X | X | X | X | X | Aspirin user in 1994: 40%; Current smoker: 5%
Wu 2007^129^ HPFS US (various) [17623801] | - Mean age (range), y | 66 (nd) | - Assay method | RIA (Horris 1997) | - 25(OH)D levels between cases and controls | X | X | X | X | X | X | Aspirin user in 1994: 40%; Current smoker: 5%
Wu 2007^129^ HPFS US (various) [17623801] | - Male (%) | 100 | - Season blood drawn | All | - Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | X | X | X | Aspirin user in 1994: 40%; Current smoker: 5%
NEW Nested case-control studies
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | - Health status | nd | | | - Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | | X | X | age, % female is of controls- colon cancer
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | - Mean age (SD), y | 58.6 (SD 7.2) | | | - Colorectal cancer risk stratified by baseline 25(OH)D quintiles | X | X | X | | X | X | age, % female is of controls- colon cancer
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) Multiple Countries | - Male (%) | 49.7% | | | - Rectum cancer stratified by baseline 25(OH)D quintiles | X | X | X | | X | X | age, % female is of controls- colon cancer
Lee, 2011^126^ Physicians US (various cities) | - Health status | Healthy | | | - Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Lee, 2011^126^ Physicians US (various cities) | - Mean age (SD), y | nd (nd) | | | - Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Lee, 2011^126^ Physicians US (various cities) | - Male (%) | 100 | | | - Colon cancer stratified by baseline 25(OH)D quartiles | X | X | X | | X | X
Neuhouser, 2012^124^ WHI US (various cities) | - Health status | Post-menopausal | | | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | | X | two nested case controls: this one represents the CRC dataset and the one we renumber represents the breast cancer dataset
Neuhouser, 2012^124^ WHI US (various cities) | - Mean age (SD), y | 65.1 (SD 6.8) | | | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | | X | two nested case controls: this one represents the CRC dataset and the one we renumber represents the breast cancer dataset
Neuhouser, 2012^124^ WHI US (various cities) | - Male (%) | 0% | | | Colorectal cancer risk stratified by baseline 25(OH)D quartiles | X | X | X | | | X | two nested case controls: this one represents the CRC dataset and the one we renumber represents the breast cancer dataset
Woolcott, 2010^125^ Multiethnic Cohort Study US, Hawaii/Los Angeles | - Health status | nd | | | Colorectal cancer risk stratified by baseline 25(OH)D sextiles | | X | X
Woolcott, 2010^125^ Multiethnic Cohort Study US, Hawaii/Los Angeles | - Mean age (SD), y | 69.2 (SD 7.9) | | | Colorectal cancer risk stratified by baseline 25(OH)D sextiles | | X | X
Woolcott, 2010^125^ Multiethnic Cohort Study US, Hawaii/Los Angeles | - Male (%) | nd | | | Colorectal cancer risk stratified by baseline 25(OH)D sextiles | | X | X
NEW Cohort study
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Health status | Nd | | | Colorectal cancer stratified by baseline 25(OH)D tertiles | X | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Mean age (SD), y | NR (50–74) | | | Colorectal cancer stratified by baseline 25(OH)D tertiles | X | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Male (%) | 54% | | | Colorectal cancer stratified by baseline 25(OH)D tertiles | X | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer

A This table is ordered alphabetically by study author.

B Participants of a lung cancer prevention 2 by 2 RCT of alpha-tocopherol and beta-carotene.

C Participants of a hip fracture prevention RCT of vitamin D3 and calcium.

Table 23 Vitamin D and colorectal cancer: Results of observational studies (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Cohort study
Colorectal cancer mortality
Women
Freedman 2007^103^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | <50 | 28 | ∼5606 | 1 | Reference | 0.02 | B
Freedman 2007^103^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | | | | | | 0.02 | B
Freedman 2007^103^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | 50–80 | 24 | ∼5606 | 0.44 | 0.20, 0.95^*^ | 0.02 | B
Freedman 2007^103^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | | | | | | 0.02 | B
Freedman 2007^103^ [17971526] | 19–50^A^ 51–70 ≥71 | Colorectal Cancer Mortality (66/16818; 0.004) | nd | ≥80 | 14 | ∼5606 | 0.28 | 0.11, 0.68^*^ | 0.02 | B
Nested case-control study
Colorectal cancer
Men
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | <57.2 | 43 | 74 | 1 | Reference | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | | | | | | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | 57.2–69.0 | 40 | 85 | 0.76 | 0.42, 1.4 | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | | | | | | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | 69.0–80.2 | 36 | 85 | 0.76 | 0.39, 1.5 | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | | | | | | 0.39 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (N=196 cases; 392 controls) | 1–13 | ≥80.2 | 44 | 80 | 0.73 | 0.35, 1.5 | 0.39 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | 46, median | 45 | 71 | 1 | Reference | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | | | | | | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | 62.5 | 44 | 71 | 0.97 | 0.55, 1.70 | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | | | | | | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | 72.8 | 30 | 68 | 0.66 | 0.35, 1.24 | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | | | | | | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | 83.3 | 23 | 74 | 0.51 | 0.27, 0.97^*^ | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | | | | | | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colorectal cancer (179 cases; 356 controls) | 1–9 | 98.5 | 37 | 72 | 0.83 | 0.45, 1.52 | 0.24^B^ | B
Wu 2007^129^ HPFS [17623801] | | | | | | | | | | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 48.2, median | 25 | 34 | 1 | Reference | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | | | | | | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 66.8 | 15 | 28 | 1.03 | 0.36, 2.91 | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | | | | | | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 80 | 9 | 30 | 0.38 | 0.12, 1.26 | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | | | | | | 0.13 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ | Colorectal cancer, age <65 | | 97 | 14 | 36 | 0.45 | 0.15, 1.40 | 0.13 | B
Wu 2007^129^ HPFS [17623801] | | | | | | | | | | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 48.2, median | 34 | 55 | 1 | Reference | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | | | | | | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 66.8 | 36 | 61 | 0.97 | 0.50, 1.87 | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | | | | | | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 80 | 19 | 58 | 0.56 | 0.27, 1.15 | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | | | | | | 0.34 | B
Wu 2007^129^ HPFS [17623801] | 51–70^A^ ≥71 | Colorectal cancer, age ≥65 | | 97 | 27 | 54 | 0.83 | 0.39, 1.75 | 0.34 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | ≤24.5 | 46 | 72 | 1 | Reference
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | 24.5–34.7 | 35 | 73 | 0.7 | 0.4, 1.3 | 0.13 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | | | | | | 0.13 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | 34.7–48.2 | 36 | 73 | 0.8 | 0.4, 1.3 | 0.13 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | | | | | | 0.13 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colorectal cancer (146 cases; 292 controls) | 1–8 | >48.2 | 29 | 72 | 0.6 | 0.3, 1.1 | 0.13 | B
Women
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | <31.0 | 88 | 67 | 2.53 | 1.49, 4.32
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | 31.0–42.3 | 80 | 73 | 1.96 | 1.18, 3.24^*^ | 0.02 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | | | | | | 0.02 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | 42.4–58.3 | 78 | 73 | 1.95 | 1.18, 3.24^*^ | 0.02 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | | | | | | 0.02 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Post-menopausal women | Colorectal cancer (306 cases; 306 controls) | 1–12 | ≥58.4 | 60 | 93 | 1 | Reference | 0.02 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 40.2, median | 53 | 77 | 1 | Reference
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 55.1 | 47 | 79 | 0.93 | 0.53, 1.63 | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | | | | | | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 66.7 | 35 | 75 | 0.79 | 0.44, 1.40 | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | | | | | | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 77.5 | 29 | 77 | 0.58 | 0.31, 1.07 | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | | | | | | 0.02^C^ | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colorectal cancer (192 cases; 384 controls) | 1–11 | 99.1 | 29 | 75 | 0.53 | 0.27, 1.04 | 0.02^C^ | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | <57.2 | 41 | 77 | 1 | Reference
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | 57.2–69.0 | 34 | 73 | 1 | 0.55, 1.9 | 0.74 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | | | | | | 0.74 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | 69.0–80.2 | 44 | 71 | 1.2 | 0.65, 2.3 | 0.74 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | | | | | | 0.74 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colorectal cancer (179 cases; 358 controls) | 1–13 | ≥80.2 | 41 | 76 | 1.1 | 0.50, 2.3 | 0.74 | B
Colon cancer
Both sexes
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | <43 | nd | nd | 1 | Reference
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 43.0–51.5 | nd | nd | 0.3 | 0.1, 1.0 | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | | | | | | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 51.5–61.8 | nd | nd | 0.5 | 0.2, 1.5 | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | | | | | | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | 61.8–75.3 | nd | nd | 0.7 | 0.2, 2.0 | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | | | | | | 0.57 | C
Braun 1995^133^ WCC [329893] | 19–50 51–70^A^ ≥71 | Colon cancer (57 cases; 114 controls) | 1–17 | ≥75.3 | nd | nd | 0.4 | 0.1, 1.4 | 0.57 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | 10 to <50 | 9 | 8 | 1 | Reference
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | 50.0–67.5 | 7 | 13 | 0.48 | 0.13, 1.80 | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | | | | | | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | 67.5–82.5 | 5 | 18 | 0.25 | 0.06, 0.98^*^ | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | | | | | | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | 82.5–105 | 4 | 17 | 0.21 | 0.05, 0.89^*^ | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | | | | | | 0.41 | C
Garland 1989^132^ WCC [2572900] | 19–50 51–70^A^ ≥71 | Colon cancer (34 cases; 67 controls) | 1–9 | 105–227.5 | 9 | 11 | 0.73 | 0.20, 2.66 | 0.41 | C
Men
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | <57.2 | 25 | 54 | 1 | Reference
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | 57.2–69.0 | 27 | 55 | 0.98 | 0.48, 2.0 | 0.7 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | | | | | | 0.7 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | 69.0–80.2 | 29 | 66 | 1 | 0.48, 2.3 | 0.7 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | | | | | | 0.7 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (141 cases; 282 controls) | 1–13 | ≥80.2 | 38 | 62 | 1.2 | 0.51, 2.7 | 0.7 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 48.3, median | 49 | 66 | 1 | Reference
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 66.8 | 44 | 68 | 0.74 | 0.42, 1.33 | 0.005^D^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | | | | | | 0.005^D^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 80 | 17 | 68 | 0.29 | 0.14, 0.59^*^ | 0.005^D^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | | | | | | 0.005^D^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Colon cancer (139 cases; 276 controls) | 1–9 | 97 | 29 | 74 | 0.46 | 0.24, 0.89^*^ | 0.005^D^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | ≤24.5 | 30 | 47 | 1 | Reference
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | 24.5–34.7 | 18 | 47 | 0.6 | 0.3, 1.2 | 0.69^E^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | | | | | | 0.69^E^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | 34.7–48.2 | 22 | 45 | 0.8 | 0.4, 1.6 | 0.69^E^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | | | | | | 0.69^E^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Colon cancer (91 cases; 182 controls) | 1–8 | >48.2 | 21 | 42 | 0.8 | 0.4, 1.6 | 0.69^E^ | B
Women
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 41.2, median | 41.2 | 75 | 1 | Reference
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 59.7 | 59.7 | 71 | 1.03 | 0.56, 1.89 | 0.17 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | | | | | | 0.17 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 73.3 | 73.3 | 77 | 0.54 | 0.28, 1.03 | 0.17 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | | | | | | 0.17 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Colon cancer (148 cases; 296 controls) | 1–11 | 98.1 | 98.1 | 72 | 0.7 | 0.35, 1.38 | 0.17 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | <57.2 | 21 | 53 | 1 | Reference
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | 57.2–69.0 | 27 | 48 | 1.7 | 0.78, 3.6 | 0.12 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | | | | | | 0.12 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | 69.0–80.2 | 27 | 41 | 2.1 | 0.90, 4.7 | 0.12 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | | | | | | 0.12 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Colon cancer (115 cases; 230 controls) | 1–13 | ≥80.2 | 31 | 53 | 2.1 | 0.78, 5.6 | 0.12 | B
Rectal cancer
Men
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | <57.2 | 18 | 20 | 1 | Reference
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | 57.2–69.0 | 13 | 30 | 0.17 | 0.02, 1.2 | 0.06 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | | | | | | 0.06 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | 69.0–80.2 | 7 | 19 | 0.25 | 0.05, 1.3 | 0.06 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | | | | | | 0.06 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–13 | ≥80.2 | 6 | 18 | 0.075 | 0.005, 0.99 | 0.06 | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | ≤24.5 | 16 | 25 | 1 | Reference
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | 24.5–34.7 | 17 | 26 | 0.9 | 0.4, 2.4 | 0.06^F^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | | | | | | 0.06^F^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | 34.7–48.2 | 14 | 28 | 0.8 | 0.3, 2.0 | 0.06^F^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | | | | | | 0.06^F^ | B
Tangrea 1997^127^ ATBC [9242478] | 19–50 51–70^A^ | Rectal cancer (55 cases; 110 controls) | 1–8 | >48.2 | 8 | 30 | 0.4 | 0.1, 1.1 | 0.06^F^ | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 53.0, median | 11 | 30 | 1 | Reference
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 73.3 | 15 | 28 | 1.74 | 0.61, 5.00 | 0.08 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | | | | | | 0.08 | B
Wu 2007^129^ HPFS [17623801] | 19–50 51–70^A^ ≥71 | Rectal cancer (40 cases; 80 controls) | 1–9 | 93.5 | 14 | 22 | 3.32 | 0.87, 12.69 | 0.08 | B
Women
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | <57.2 | 20 | 24 | 1 | Reference
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | 57.2–69.0 | 7 | 25 | 0.26 | 0.07, 1.0 | 0.17 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | | | | | | 0.17 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | 69.0–80.2 | 17 | 30 | 0.46 | 0.15, 14 | 0.17 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | | | | | | 0.17 | B
Otani 2007^128^ Japan PHC [17622244] | 19–50 51–70^A^ | Rectal cancer (64 cases; 128 controls) | 1–13 | ≥80.2 | 10 | 23 | 0.33 | 0.08, 1.3 | 0.17 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Rectal cancer (44 cases; 88 controls) | 1–11 | 44.4, median | 24 | 31 | 1 | Reference | 0.03 | B
Feskanich 2004^130^ NHS [15342452] | 19–50 51–70^A^ | Rectal cancer (44 cases; 88 controls) | 1–11 | 66.2 | 10 | 26 | 92.4 | 10 0.8, 1.31 | 0.03 | B
NEW Nested case-control studies
Colorectal cancer
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | Quintile 1:<25 | 64 | 116 | RR=1.32 | 0.87, 2.01 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | | | | | | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | Quintile 2:25–50 | 473 | 873 | 1.28 | 1.05, 1.56 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | | | | | | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | Quintile 3:50–75 | 448 | 909 | 1 | Reference | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | | | | | | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | Quintile 4:75–100 | 173 | 382 | 0.88 | 0.68, 1.13 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colorectal Cancer (1248 cases;1248 controls) | NR | Quintile 5:>100 | 90 | 216 | 0.77 | 0.56, 1.06 | <0.001 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | Quartile 1 (median39.3 nmol/L) | 57 | 153 | 1.00 | Reference | 0.67 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | | | | | | 0.67 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | Quartile 2 (median 55.8 nmol/L) | 41 | 138 | 0.71 | 0.42, 1.21 | 0.67 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | | | | | | 0.67 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | Quartile 3(median 66.8 nmol/L) | 74 | 173 | 1.24 | 0.76, 2.04 | 0.67 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colorectal Cancer (229 cases;389 controls) | NR | Quartile 4(median 94.75 nmol/L | 57 | 154 | 1.08 | 0.62, 1.87 | 0.67 | B
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | <32.7 | 293 | 562 | 4.45 | 1.96, 10.10 | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | | | | | | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | 32.7–43.6 | 306 | 578 | 2.76 | 0.72, 3.14 | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | | | | | | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | 43.6–64.5 | 250 | 520 | 1.51 | 1.30, 5.89 | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | | | | | | 0.003 | A
Neuhouser 2012^124^ WHI | 50–79 years | Colorectal Cancer (1080 cases;1080 controls) | NR | >64.5 | 231 | 500 | 1.00 | Reference | 0.003 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | <42 nmol/L | 67 | 154 | 1.00 | Reference | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | | | | | | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | 42.0–55.5 nmol/L | 42 | 128 | 0.63 | 0.37, 1.08 | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | | | | | | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | 55.5–65.8 nmol/L | 38 | 126 | 0.54 | 0.32, 0.93 | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | | | | | | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | 65.8–82.0 nmol/L | 43 | 130 | 0.62 | 0.36, 1.07 | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | | | | | | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | ≥82.0 nmol/L | 39 | 125 | 0.60 | 0.33, 1.07 | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | | | | | | 0.010 | A
Woolcott 2010^125^ multiethnic cohort | 45–75 years | Colorectal Cancer (229 casea;434 controls) | NR | Per doubling | NR | NR | 0.68 | 0.51, 0.92 | 0.010 | A
Colon cancer
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | Quartile 1 (median 39.25 nmol/L) | 36 | 106 | 1.00 | Reference | 0.350 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | | | | | | 0.350 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | Quartile 2 (median 55.75 nmol/L) | 37 | 109 | 0.95 | 0.52, 1.74 | 0.350 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | | | | | | 0.350 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | Quartile 3 (median 66.8 nmol/L) | 52 | 126 | 1.34 | 0.75, 2.39 | 0.350 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Colon Cancer (136 casesa;287 controls) | NR | Quartile 4 (median 94.75 nmol/L) | 47 | 118 | 1.38 | 0.73, 2.64 | 0.350 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | <25nmol/l | 45 | 72 | 1.90 | 1.10, 3.29 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | | | | | | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | ≥25<50nmol/l | 300 | 549 | 1.36 | 1.05,1.76 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | | | | | | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | ≥50<75nmol/l | 286 | 581 | 1 | Reference | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | ≥75<100nmol/l | 104 | 242 | 0.86 | 0.62, 1.17 | <0.001 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Colon Cancer (785 cases;785 controls) | NR | ≥100nmol/l | 50 | 126 | 0.71 | 0.46, 1.08 | <0.001 | B
Rectal cancer
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | <25nmol/l | NR | NR | 0.77 | 0.37, 1.59 | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | | | | | | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | ≥25<50nmol/l | NR | NR | 1.17 | 0.84, 1.65 | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | | | | | | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | ≥50<75nmol/l | NR | NR | 1.00 | Reference | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | | | | | | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | ≥75<100nmol/l | NR | NR | 0.93 | 0.60, 1.45 | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | | | | | | 0.320 | B
Jenab 2010^123^ European Prospective Investigation into Cancer and Nutrition (EPIC) | 30–77 years | Rectal Cancer (463 cases, 463 controls) | NR | ≥100nmol/l | NR | NR | 0.82 | 0.48, 1.40 | 0.320 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | Quartile 1 (median 39.3 nmol/L) | 20 | 44 | 1.00 | Reference | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | | | | | | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | Quartile 2 (median 55.8 nmol/L) | 15 | 41 | 0.53 | 0.18, 1.60 | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | | | | | | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | Quartile 3 (median 66.8 nmol/L) | 9 | 37 | 0.42 | 0.13, 1.40 | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | | | | | | 0.050 | B
Lee 2011^126^ Physicians Health Study | 40–84 years | Rectal Cancer (57 cases, 102 controls) | NR | Quartile 4 (median 94.8 nmol/L) | 13 | 37 | 0.45 | 0.14, 1.46 | 0.050 | B
Colon cancer
NEW Cohort study
Ordonez-Mena 2013^97^ ESTHER | | Colorectal Cancer | 8 yrs | Q1 | 37 | 2373 | HR 1.02 | 0.68, 1.53 | | B
Ordonez-Mena 2013^97^ ESTHER | | Colorectal Cancer | 8 yrs | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | | Colorectal Cancer | 8 yrs | Q2+Q3 | 69 | 4741 | HR 1.00 | Reference | | B
Ordonez-Mena 2013^97^ ESTHER | | Colorectal Cancer | 8 yrs | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | | Colorectal Cancer | 8 yrs | Q4 | 30 | 2368 | HR 0.77 | 0.50, 1.20 | | B

* Statistically significant (P<0.05).

A Most representative life stage.

B P for trend = 0.31 when cases diagnosed within 2 years of blood collection were excluded.

C Results were not notably changed when cases diagnosed within the first year after blood collection were excluded (P for trend not reported). Subgroup analyses per age were also reported as follows: Age ≥ 60, OR = 0.35 (95% CI 0.14, 0.87) between the lowest and highest quintiles; P for trend = 0.006. Age < 60, OR = 1.36 (95% CI 0.48, 3.92) between the lowest and highest quintiles; P for trend = 0.70.

D P for trend = 0.008 when cases diagnosed within 2 years of blood collection were excluded.

E P for trend = 0.58 when cases diagnosed within 2 years of blood collection were excluded.

F P for trend = 0.04 when cases diagnosed within 2 years of blood collection were excluded.

Figure 8 Colorectal cancer risk stratified by vitamin D concentration

This figure, known as a forest plot, displays the risk for colorectal cancer stratified by vitamin D concentration. The first column shows the 11 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 11 studies. Results for each study are in Table 23.

Figure 9 Colon cancer risk stratified by vitamin D concentration

This figure, known as a forest plot, displays the risk for colon cancer stratified by vitamin D concentration. The first column shows the nine studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the nine studies. Results for each study are in Table 23.

Figure 10 Rectal cancer risk stratified by vitamin D concentration

This figure, known as a forest plot, displays the risk for rectal cancer stratified by vitamin D concentration. The first column shows the 7 studies that reported this outcome. The second column shows how the range of vitamin D concentrations is broken down (e.g., by tertile, quartile, or by predefined categories). The third column shows the levels of 25-hydroxyvitamin D corresponding to those categories. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the p value given for each study. The sixth column is the quality grade that was given to each of the 7 studies. Results for each study are in Table 23.

Four nested case-control studies that assessed the association of serum 25(OH)D with colorectal cancer were identified for the current report. A nested case-control study conducted within the EPIC study that matched 1220 cases of colorectal cancer with 1222 controls found increasing risk for colorectal cancer with lower serum 25(OH)D.123 This study was rated B for quality because cases were ascertained from cancer registries and were not verified independently. Two additional nested case-control studies, one nested in the Women's Health Initiative (WHI) and the other in the Multiethnic Cohort (both rated A), found increasing risk for colorectal cancer with lower 25(OH)D (the WHI is described further later in the section on vitamin D plus calcium).124,125 Another case-control study, nested in the Physicians' Health Study, found no association between colorectal cancer incidence and levels of 25(OH)D and 1,25(OH)2D in U.S. male physicians aged 40–84 years (rated B).126

The studies nested in the EPIC and Physicians' Health cohorts also assessed colon and rectal cancer as separate outcomes. The nested case-control study within EPIC found a trend toward increasing risk for colon cancer incidence with lower 25(OH)D;123 the study within the Physicians' Health cohort found a similar but non-significant trend.126 For rectal cancer incidence, the Physicians' Health nested case-control study found a negative trend between 25(OH)D and rectal cancer, while the EPIC nested case-control found a small but non-significant negative trend.

From the original report, a total of seven nested case-control studies evaluated the associations between 25(OH)D concentrations and risk of colorectal cancer127-131 or colon cancer.132,133 The number of pairs of cases and controls in these studies ranged from 101 to 588. Another cohort study comprising 16,818 adult community volunteers from the NHANES III103 assessed the association between 25(OH)D concentrations and colorectal cancer mortality. The mean age of the subjects ranged from 44 to 66 years. Locations of the studies ranged from 20°N to 60°N. Baseline 25(OH)D concentrations ranged from 10 nmol/L to 227.5 nmol/L. No studies reported follow up 25(OH)D concentrations. Time between blood drawn and the diagnosis of colorectal cancer incidence or mortality ranged from less than 1 year to 17 years. None of the studies reported power calculations. Methodological quality of five nested case-control studies127-131 were rated B and two were rated C.132,133 Common reasons for downgrading the quality ratings included exclusion of participants without available blood samples, no verification of cancer diagnosis, and lack of adequate statistical adjustments. The cohort study103 was rated B because it was unclear whether cases were verified and there was no statistical adjustment for family history.

##### Findings per Age and Sex

The NHANES III103 analyzed data for both sexes combined. An adjusted analysis found an inverse association between 25(OH)D concentrations and the risk of colorectal cancer mortality (HR: 0.28, highest [≥80 nmol/L] compared to lowest tertile [<50 nmol/L]; P for trend = 0.02). Two studies from WCC reported colon cancer incidence for both sexes combined.132,133 One study reported a significantly lower 25(OH)D concentrations in colon cancer cases than controls (58.9 nmol/L vs. 86.6 nmol/L; P<0.001).133 Both studies reported no significant association between 25(OH)D concentrations and colon cancer risk by trend analysis.

In the original report, three studies, from the Japan PHC, HPFS, and ATBC respectively, provided data on adult men.127-129 None of the studies found an association between 25(OH)D concentrations and colorectal cancer risk. Although all three studies provided data on colon cancer and rectal cancer as subgroup analysis, only HPFS reported a significant trend between higher 25(OH)D concentrations and lower risk of colon cancer (OR 0.46, highest [median 97.0 nmol/L] compared to lowest quartile [median 48.3 nmol/L]; P for trend = 0.005).129 The HPFS also reported a subgroup analysis on men aged 65 years or older.129 No significant association was reported between 25(OH)D concentrations and colorectal cancer risk by trend analysis.

The Japan PHC and HPFS compared 25(OH)D concentrations between colorectal cancer cases and controls.128,129 Neither reported a significant difference. One study explored subgroup analyses. Only the rectal cancer cases had significantly lower 25(OH)D concentrations compared to the controls (55 nmol/L for cases vs. 110 nmol/L for controls; P = 0.005).128

Two nested case-control studies from the NHS and Japan PHC provided data on adult women.128,130 The NHS reported a trend between higher 25(OH)D concentrations and lower colorectal cancer risk (OR 0.53, highest [median 99.1 nmol/L] compared to lowest quintile [median 40.2 nmol/L]; P for trend = 0.02).130 This trend remained significant in a subgroup analysis of women age 60 years or older (OR 0.35 between the highest quintiles [median 99.1 nmol/L] and lowest [median 40.2 nmol/L]; P for trend = 0.006) or in rectal cancer alone (OR 0.31, highest [median 92.4 nmol/L] compared to lowest tertile [median 44.4 nmol/L]; P for trend = 0.03).130 The WHI focused on postmenopausal women.131 A significant trend was reported between higher 25(OH)D concentrations and lower colorectal cancer risk (OR 2.53, between highest [≥58.4 nmol/L] and lowest quintiles [<31.0 nmol/L]; P for Trend = 0.02).

The Japan PHC compared 25(OH)D concentrations between cases and controls; no significant difference was reported.128

##### Findings per Special Populations

No subgroup data were available regarding the association between 25(OH)D concentrations and colorectal cancer risk in obese persons. In the original report, one study exclusively included male smokers aged between 50 and 69 years,127 and reported no significant association between 25(OH)D concentrations and colorectal cancer risk by trend analysis. Another study that exclusively included white population also found no association.132 In addition, another study that focused on women who were taking hormone replacement therapy reported no significant association between 25(OH)D and colorectal cancer.130

##### Findings Excluding Early Cases

In the original report, three studies performed sensitivity analyses on the association between 25(OH)D concentrations and colorectal cancer risk by excluding cases diagnosed within the first 1 to 2 years after blood draw.127,129,130 One study found a significant association between higher 25(OH)D concentrations and lower colon cancer risk (OR 0.3, between highest [>48.2 nmol/L] and lowest quartiles [≤ 24.5 nmol/L]; P for Trend = 0.04), which was not significant in main analysis.127 Otherwise, the results were not materially different from the main analysis.

##### Findings on 1,25-Dihydroxyvitamin D

The nested case-control study within the Physicians' Health cohort found no significant associations between 1,25(OH)_2_D and colorectal, colon, and rectal cancer risk. 126

In the original report, a total of three studies evaluated the associations between 1,25(OH)_2_D concentrations and colorectal cancer risk127,130 or colon cancer.133 None of the studies found a significant association by trend analysis. One study reported no significant association between 1,25(OH)_2_D concentrations and rectal cancer risk.127

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  The analysis of the NHANES III with a mean age of 44 years included participants mostly within this life stage. The study found an inverse association between 25(OH)D and colorectal cancer mortality.
- 51–70 y
  Three of the nested case-control studies identified for the update report included people with mean age ranged from 59 to 69 years; a fourth study included individuals aged 40–84 (mean age was not reported). A trend between higher 25(OH)D levels and lower risk of colorectal cancer was found in three studies and one study found no association. Of the two studies that also assessed colon and rectal cancer outcomes separately, one study found significant negative trends between 25(OH)D and colon or rectal cancer and one study reported no association.
- ≥71 y
  In the original report, one RCT with a mean age of 75 included participants mostly within this life stage. The trial found no difference in colorectal cancer mortality or incidence between supplemental vitamin D and no supplements.
- Postmenopause
  In the original report, one study and a subgroup analysis in another study focused on postmenopausal women. A trend between higher 25(OH)D concentrations and lower colorectal cancer risk was found in these two studies.
- Pregnant & lactating women
  Not reviewed

#### Colorectal Adenoma

##### Synopsis

No qualified systematic reviews have evaluated the association between 25(OH)D concentrations and the risk of colorectal adenoma. No new studies were identified for the update report. In the original report, one B quality nested case-control study in women found no significant association between 25(OH)D concentrations and the risk of colorectal adenoma.

##### Detailed Presentation

(Tables 24 & 25)

Table 24 Vitamin D and colorectal adenoma: Characteristics of observational studies [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Nested Case-Control
Platz 2000^134^ NHS US (various) [11045788] | - Health status | Any | - Assay method | RIA (Horris 1993) | - Colorectal adenoma risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | Aspirin user: 26%; Hormone replacement therapy: 36%
Platz 2000^134^ NHS US (various) [11045788] | - Mean age (SD), y | 59 (7) | - Assay method | RIA (Horris 1993) | - Colorectal adenoma risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | Aspirin user: 26%; Hormone replacement therapy: 36%
Platz 2000^134^ NHS US (various) [11045788] | - Male (%) | 0 | - Season blood drawn | All | - Colorectal adenoma risk stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X | Aspirin user: 26%; Hormone replacement therapy: 36%

Table 25 Vitamin D and colorectal adenoma: Results of observational studies [no new studies in the current report]

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | 25(OH)D Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for Trend | Study Quality
Nested case-control study
Colorectal adenoma
Women
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326 controls) | 5 | 16.3, median | 103 | 82 | 1 | Reference | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326 controls) | 5 | 22.6 | 62 | 80 | 0.64 | 0.41, 1.00 | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326 controls) | 5 | 28.3 | 61 | 82 | 0.58 | 0.36, 0.95 | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colorectal adenoma (326 cases; 326 controls) | 5 | 38.0 | 100 | 82 | 1.04 | 0.66, 1.66 | 1.0 | B
Colon adenoma
Women
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 16.3, median | 79 | 64 | 1 | Reference | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 22.6 | 55 | 64 | 0.71 | 0.43, 1.18 | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 28.3 | 51 | 69 | 0.60 | 0.35, 1.02 | 1.0 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Colon adenoma (261 cases; 261 controls) | 5 | 38.0 | 76 | 64 | 1.02 | 0.60, 1.73 | 1.0 | B
Rectal adenoma
Women
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 16.3, median | 24 | 18 | 1 | Reference | 0.9 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 22.6 | 7 | 16 | 0.38 | 0.12, 0.19 | 0.9 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 28.3 | 10 | 13 | 0.34 | 0.08, 1.42 | 0.9 | B
Platz 2000^134^ NHS [11045788] | 19–50 51–70^A^ ≥71 | Rectal adenoma (65 cases; 65 controls) | 5 | 38.0 | 24 | 18 | 1.59 | 0.50, 5.03 | 0.9 | B

* Statistically significant (P<0.05)

A Most representative life stage

In the original report, one nested case-control study within the NHS evaluated the relationship between 25(OH)D concentrations and the risk of colorectal adenoma in women.134 At 5 years, an adjusted analysis found no significant association between 25(OH)D concentrations and the incidence of colorectal adenoma by trend analysis. Subgroup analyses also found no significant association between 25(OH)D concentrations and the incidence of colon or rectal adenoma. No subgroup data were available regarding age or other special populations (e.g., obese, smokers, ethnic groups, or users of contraceptives). This study was rated B because it excluded more than 50 percent of participants of the original cohort because their blood samples were not available.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  A proportion of participants in the NHS was in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- 51–70 y
  The analysis of the NHS included female participants mostly within this life stage. The study found no association between 25(OH)D and the incidence of colorectal adenoma.
- ≥71 y
  A proportion of participants in the NHS was in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Postmenopause
  The analysis of NHS partially included postmenopausal women. However, no unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Pregnant & lactating women
  Not reviewed

#### Breast Cancer

##### Synopsis

No qualified systematic reviews evaluated the association between vitamin D and calcium intake or serum 25(OH)D concentration and risk of breast cancer. One cohort study compared serum 25(OH)D and the risk of breast cancer-specific mortality and found no association. Eight observational studies that assessed the association between 25(OH)D and breast cancer were identified for the current report. Two cohort and four nested case-control studies found no association.124,135-137 Two nested case-control studies found increasing risk of breast cancer with decreasing 25(OH) concentrations.138,139

Two studies that examined the relationship between vitamin D and calcium intake or 25(OH)D and breast density were identified. A RCT found a decrease in percent mammographic density among women who had ≥400 IU/d total vitamin D intake.140 A nested case-control found lower risk of increased mammographic density with 25(OH) concentrations above the first quartile.141

In the original report, one cohort study compared serum 25(OH)D concentrations and the risk of breast cancer-specific mortality,103 and two nested case-control studies compared 25(OH)D concentrations and the risk of breast cancer.142,143 The cohort study utilizing NHANES III data found significant decrease in breast cancer-specific mortality during 9 years of follow up in those with serum concentration of 25(OH)D greater than 62 nmol/L. The Nurses' Health Study and Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial, however, found no significant relationship between serum concentration of 25(OH) D and risk of breast cancer diagnosis in either pre- or postmenopausal women during 7 to 12 years of follow up.142,143 All three studies were rated B quality.

##### Detailed Presentation

(Tables 26a-d & 27a-d)

Table 26a Vitamin D and breast cancer: Characteristics of nested case-control studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Nested Case-Control
Bertone-Johnson 2005^142^ NHS US (38° N) [16103450] | - Health status | No Cancer | - Assay method | RIA | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Bertone-Johnson 2005^142^ NHS US (38° N) [16103450] | - Mean age (range/SD), y | 57 (7.0) | - Assay method | RIA | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Bertone-Johnson 2005^142^ NHS US (38° N) [16103450] | | | - Season blood drawn | All year | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Freedman 2008^143^ PLCO Trial US (38° N) [18381472] | - Health status | No Cancer | - Assay method | RIA | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Freedman 2008^143^ PLCO Trial US (38° N) [18381472] | - Mean age (range/SD), y | 67 (ND) | - Assay method | RIA | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
Freedman 2008^143^ PLCO Trial US (38° N) [18381472] | | | - Season blood drawn | Dec-Sep | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | X | X | X | X | | X
NEW Studies
Nested Case-Control
Neuhouser 2012^124^ WHI US (various) | - Health status | Post-menopausal | | | | X | X | X | | | X | two nested case controls: this one represents the CRC dataset and the one we renumber represents the breast cancer dataset
Neuhouser 2012^124^ WHI US (various) | - Mean age (SD), y | 65.1 (SD 6.8) | | | | X | X | X | | | X | two nested case controls: this one represents the CRC dataset and the one we renumber represents the breast cancer dataset
Nested Case-Control
Almquist, 2010^137^ Malmo Diet and Cancer Study | - Health outcome | Healthy | | | Breast cancer risks: Quartile 1 vs. Quartile 2, 3, 4
Almquist, 2010^137^ Malmo Diet and Cancer Study | - Mean age (SD), y | 57 (SD 7.3) | | | Breast cancer risks: Quartile 1 vs. Quartile 2, 3, 4
Engel, 2010^138^ French E3N France | - Health outcome | nd | | | Breast cancer risks: Quintile 1 vs. Quintile 2, 3 | | X | X
Engel, 2010^138^ French E3N France | - Mean age (SD), y | 56.9 (6.4) | | | Breast cancer risks: Quintile 1 vs. Quintile 2, 3 | | X | X
McCullough, 2009^136^ Cancer Prevention Study-II (CPS-II) | - Health outcome | nd | | | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | | X | X | | X
McCullough, 2009^136^ Cancer Prevention Study-II (CPS-II) | - Mean age (SD), y | 69.6 (5.8) | | | Breast cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | | X | X | | X
Rejnmark, 2009^139^ Denmark | - Health outcome | nd | | | Breast cancer risks: Tertile 1 vs. Tertile 2, 3
Rejnmark, 2009^139^ Denmark | - Mean age (SD), y | 58 (29–87) | | | Breast cancer risks: Tertile 1 vs. Tertile 2, 3
NEW Cohort study
Kuhn 2013^145^ EPIC Multiple Countries | - Health outcome | Nd | | | Breast Cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | | X | X | | X | X | This analysis does not include data from the Malmo site, as these data were analyzed and published separately as Almquist, 2010, reference 126 in the original report.
Kuhn 2013^145^ EPIC Multiple Countries | - Mean age (SD), y | 50.7 (SD 8.8) | | | Breast Cancer risks: Quintile 1 vs. Quintile 2, 3, 4, 5 | | X | X | | X | X | This analysis does not include data from the Malmo site, as these data were analyzed and published separately as Almquist, 2010, reference 126 in the original report.

Table 26b Vitamin D and breast cancer: Characteristics of prospective cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Freedman 2007^103^ NHANES III US (38° N) [17971526] | - Health status | Non-institutionalized | | Breast cancer risks: Quintile 1 vs. Quintile 2 | X | X | X | | X | X
Freedman 2007^103^ NHANES III US (38° N) [17971526] | - Mean age (range/SD), y | 44 (ND) | | Breast cancer risks: Quintile 1 vs. Quintile 2 | X | X | X | | X | X
NEW Studies
Jacobs, 2011^144^ Women's Healthy Eating and Living (WHEL) US (various) | - Health outcome | Cancer in remission | | Breast cancer risks: Quartile 4 vs. Quartile 1, 2, 3 | | | | | | | This article contains both prospective cohort and case-control data. Case-control data given here
Jacobs, 2011^144^ Women's Healthy Eating and Living (WHEL) US (various) | - Mean age (SD), y | 51.9 (SD 9) | | Breast cancer risks: Quartile 4 vs. Quartile 1, 2, 3 | | | | | | | This article contains both prospective cohort and case-control data. Case-control data given here
Jacobs, 2011^144^ Women's Healthy Eating and Living (WHEL) US (various) | - Male (%) | 0% | | Breast cancer risks: Quartile 4 vs. Quartile 1, 2, 3 | | | | | | | This article contains both prospective cohort and case-control data. Case-control data given here
Eliassen, 2011^135^ NHSIII | - Health outcome | nd | | Breast cancer risks: Quartile 1 vs. Quartile 2, 3, 4
Eliassen, 2011^135^ NHSIII | - Mean age (SD), y | 44.9 (SD 4.4) | | Breast cancer risks: Quartile 1 vs. Quartile 2, 3, 4
Eliassen, 2011^135^ NHSIII | - Male (%) | 0% | | Breast cancer risks: Quartile 1 vs. Quartile 2, 3, 4
NEW Cohort study
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Health status | nd | | Breast cancer risk: Tertile 2 vs. Tertile 1 and 3 | | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Mean age (range/SD), y | NR (50–74) | | Breast cancer risk: Tertile 2 vs. Tertile 1 and 3 | | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer
Ordonez-Mena 2013^97^ ESTHER Saarland, Germany | - Male (%) | 54% | | Breast cancer risk: Tertile 2 vs. Tertile 1 and 3 | | X | X | | | X | confounders- add multivitamin use, fish consumption, red meat consumption, daily fruit intake, daily vegetable intake, scholarly education, physical activity, family history of cancer

Table 26c Vitamin D and breast density: Characteristics of RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
New Studies
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study US | - Health outcome | Post-menopausal | | Percent mammographic density stratified by 25(OH)D_3_ medians
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study US | - Mean age (SD), y | 62 (SD 8) | | Percent mammographic density stratified by 25(OH)D_3_ medians
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study US | - Male (%) | 0% | | Percent mammographic density stratified by 25(OH)D_3_ medians

Table 26d Vitamin D and breast density: Characteristics of nested case-control studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
New Studies
Green 2010^141^ Nurses' Health Study US (various) | - Health outcome | Post-menopausal | | Percent mammographic density stratified by 25(OH)D_3_ quartiles
Green 2010^141^ Nurses' Health Study US (various) | - Mean age (SD), y | 61 (nd) | | Percent mammographic density stratified by 25(OH)D_3_ quartiles
Green 2010^141^ Nurses' Health Study US (various) | - Male (%) | 0% | | Percent mammographic density stratified by 25(OH)D_3_ quartiles

Table 27a Vitamin D and breast cancer: Results of nested case-control studies (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≤50 (1^st^ batch) | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≤70 (2^nd^ batch) | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≤45 (3^rd^ batch) | 159 | 297 | 1 | Reference | nd | B
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 51–70 | 149 | 278 | 0.95 | 0.66, 1.36
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 149 | 278 | 0.95 | 0.66, 1.36
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 72–85 | 149 | 278 | 0.95 | 0.66, 1.36
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 149 | 278 | 0.95 | 0.66, 1.36
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 47 to 60 | 149 | 278 | 0.95 | 0.66, 1.36
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 72–82 | 125 | 266 | 0.74 | 0.51, 1.06
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 125 | 266 | 0.74 | 0.51, 1.06
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 87–97 | 125 | 266 | 0.74 | 0.51, 1.06
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 125 | 266 | 0.74 | 0.51, 1.06
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 62–72 | 125 | 266 | 0.74 | 0.51, 1.06
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 85–97 | 144 | 296 | 0.8 | 0.58, 1.11
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 144 | 296 | 0.8 | 0.58, 1.11
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 100–117 | 144 | 296 | 0.8 | 0.58, 1.11
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 144 | 296 | 0.8 | 0.58, 1.11
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | 75–90 | 144 | 296 | 0.8 | 0.58, 1.11
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≥100 | 124 | 265 | 0.73 | 0.49, 1.07
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 124 | 265 | 0.73 | 0.49, 1.07
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≥120 | 124 | 265 | 0.73 | 0.49, 1.07
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | | 124 | 265 | 0.73 | 0.49, 1.07
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer (701/1425) | <1–82 mo | 25(OH)D | ≥92 | 124 | 265 | 0.73 | 0.49, 1.07
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | 97 | 191 | 1 | Reference | NS
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | | | | | NS
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | 84 | 170 | 0.96 | 0.62, 1.49 | NS
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | 77 | 164 | 0.8 | 0.51, 1.26
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | 90 | 192 | 0.85 | 0.55, 1.32
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer <60 y (701/1425) | | | | 70 | 146 | 0.92 | 0.57, 1.48
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | 62 | 109 | 1 | Reference | 0.03
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | | | | | 0.03
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | 65 | 114 | 1.07 | 0.60, 1.92 | 0.03
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | 48 | 105 | 0.64 | 0.35, 1.16
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | 54 | 99 | 0.68 | 0.38, 1.24
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425)
Bertone-Johnson 2005^142^ NHS [16103450] | Pre- and Post-menopausal | Breast cancer ≥60 y (701/1425) | | | | 54 | 125 | 0.57 | 0.31, 1.04
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | <46 | 172 | 2010 | 1 | Reference | NS | B
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 46–58 | 188 | 2010 | 1.02 | 0.75, 1.41 | NS | B
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 59–71 | 244 | 2010 | 1.36 | 0.99, 1.87
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | 72–83 | 205 | 2010 | 1.13 | 0.82, 1.55
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D
Freedman 2008^143^ PLCO Cancer Screening Trial [18381472] | Pre- and Post-menopausal | Breast cancer (1005/2010) | 12 y | 25(OH)D | ≥84 | 196 | 2010 | 1.04 | 0.75, 1.45
NEW Studies
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | <36.7 | 105 | 181 | 1.06 | 0.78, 1.43 | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | | | | | | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | 36.7 to <50.9 | 68 | 147 | 1.11 | 0.83, 1.49 | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | | | | | | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | 50.9 to <64.9 | 84 | 162 | 0.99 | 0.75, 1.31 | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | | | | | | 0.60 | A
Neuhouser 2012^124^ WHI | 50–79 years | Breast Cancer (1080 cases, 1080 controls) | NR | 25(OH)D | >64.9 | 53 | 130 | 1.00 | Reference | 0.60 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | Quartile 1(<70l) | NR | 213 | OR=1.00 | Reference | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | | | | | | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | Quartile 2 (71–86) | NR | 164 | 0.84 | 0.60,1.15 | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | | | | | | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | Quartile 3(87–105) | NR | 176 | 0.84 | 0.60, 1.17 | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | | | | | | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D3 | Quartile 4(>105) | NR | 192 | 0.93 | 0.66,1.33 | 0.71 | A
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls)
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | Quartile 1(72) | NR | 191 | 1.00 | Reference | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | | | | | | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | Quartile 2 (72–87) | NR | 170 | 0.95 | 0.68, 1.31 | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | | | | | | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | Quartile 3(88–106) | NR | 183 | 0.94 | 0.68, 1.32 | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | | | | | | 0.78
Almquist 2010^137^ Malmo Diet and Cancer Study | Born 1923–1950 | Breast Cancer (213 cases, 213 controls) | 7.0 years | 25(OH)D2+D3 | Quartile 4(>106) | NR | 191 | 0.96 | 0.68, 1.37 | 0.78
Engel 2010^138^ French E3N | born between 1925 and 1950 | Breast Cancer (636 cases, 1272 controls) | ≤10 years | 25(OH)D | <49.5 nmol/L | 226 | 630 | OR=1.00 | Reference | 0.02 | A
Engel 2010^138^ French E3N | born between 1925 and 1950 | Breast Cancer (636 cases, 1272 controls) | ≤10 years | 25(OH)D | | | | | | 0.02 | A
Engel 2010^138^ French E3N | born between 1925 and 1950 | Breast Cancer (636 cases, 1272 controls) | ≤10 years | 25(OH)D | 49.5–67.5 nmol/L | 198 | 600 | 0.81 | 0.63, 1.04 | 0.02 | A
Engel 2010^138^ French E3N | born between 1925 and 1950 | Breast Cancer (636 cases, 1272 controls) | ≤10 years | 25(OH)D | | | | | | 0.02 | A
Engel 2010^138^ French E3N | born between 1925 and 1950 | Breast Cancer (636 cases, 1272 controls) | ≤10 years | 25(OH)D | >67.5 nmol/L | 191 | 603 | 0.73 | 0.55, 0.96 | 0.02 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | <36.7 | 89 | 193 | OR=1.00 | Reference | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | | | | | | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | 36.7–49.7 | 115 | 217 | 1.29 | 0.86, 1.94 | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | | | | | | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | 49.8–60.7 | 99 | 204 | 1.14 | 0.75, 1.72 | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | | | | | | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | 60.8–73.1 | 118 | 220 | 1.44 | 0.96, 2.18 | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | | | | | | 0.60 | A
McCullough 2009^136^ Cancer Prevention Study-II (CPS-II) | 47–85 years | Breast Cancer(516 cases, 516 controls) | 1month–6.9 years | 25(OH)D | >73.1 | 95 | 198 | 1.09 | 0.70, 1,68 | 0.60 | A
Rejnmark 2009^139^ | Pre- and Post- menopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | <60nmo/L | NR | NR | 1.00 | Reference | <0.05 | B
Rejnmark 2009^139^ | Pre- and Post- menopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | | | | | | <0.05 | B
Rejnmark 2009^139^ | Pre- and Post- menopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | 60–84nmol/L | NR | NR | 0.94 | 0.59, 1.47 | <0.05 | B
Rejnmark 2009^139^ | Pre- and Post- menopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | >84nmol/L | NR | NR | 0.52 | 0.32, 0.85 | <0.05
Rejnmark 2009^139^ | | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D
Rejnmark 2009^139^ | Premenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | <60nmo/L | NR | NR | 1.00 | Reference | <0.05
Rejnmark 2009^139^ | Premenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | | | | | | <0.05
Rejnmark 2009^139^ | Premenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | 60–84nmol/L | NR | NR | 0.59 | 0.26, 1.33 | <0.05
Rejnmark 2009^139^ | Premenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | >84nmol/L | NR | NR | 0.38 | 0.15, 0.97 | <0.05
Rejnmark 2009^139^ | | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D
Rejnmark 2009^139^ | Postmenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | <60nmo/L | NR | NR | 1.00 | Reference | >0.05
Rejnmark 2009^139^ | Postmenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | | | | | | >0.05
Rejnmark 2009^139^ | Postmenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | 60–84nmol/L | NR | NR | 1.20 | 0.67, 2.16 | >0.05
Rejnmark 2009^139^ | Postmenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | | | | | | >0.05
Rejnmark 2009^139^ | Postmenopausal | Breast Cancer(142 cases, 420 controls) | NR | 25(OH)D | >84nmol/L | NR | NR | 0.71 | 0.38, 1.30 | >0.05
Kuhn 2013^145^ EPIC | 40–65 years | Breast Cancer | 4.1 yrs | 25(OH)D | Q1: <=39.3 | 342 | 688 | 1.00 | Reference | 0.67
Kuhn 2013^145^ EPIC | 40–65 years | Breast Cancer | 4.1 yrs | 25(OH)D | Q2: 39.4–50.9 | 357 | 707 | 1.03 | 0.83, 1.29
Kuhn 2013^145^ EPIC | 40–65 years | Breast Cancer | 4.1 yrs | 25(OH)D | Q3: 51.0–63.0 | 324 | 670 | 0.94 | 0.74, 1.19 | | A
Kuhn 2013^145^ EPIC | 40–65 years | Breast Cancer | 4.1 yrs | 25(OH)D | Q4: >63.0 | 368 | 717 | 1.07 | 0.85, 1.36
Kuhn 2013^145^ EPIC | 40–65 years | Breast Cancer | 4.1 yrs | 25(OH)D | log2 (continuous) | 1391 | 2782 | 1.01 | 0.86, 1.19 | 0.86

* Statistically significant (P<0.05)

A Total number of women not reported

Table 27b Vitamin D and breast cancer: Results of prospective cohort studies (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted RR | 95% CI | P for Trend | Study Quality
Freedman 2007^103^ NHANES III [17971526] | All Adults | Breast cancer mortality (28/ND)^A^ | 105 mo | 25(OH)D | <63 | 20 | ND | 1 | Reference | NS | B
Freedman 2007^103^ NHANES III [17971526] | All Adults | Breast cancer mortality (28/ND)^A^ | 105 mo | 25(OH)D | | | | | | NS | B
Freedman 2007^103^ NHANES III [17971526] | All Adults | Breast cancer mortality (28/ND)^A^ | 105 mo | 25(OH)D | ≥63 | 8 | ND | HR 0.28 | 0.08, 0.93* | NS | B
NEW Studies
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | <25 nmol/L(deficient) | nr | 51 | OR=1.14 | 0.57, 2.31 | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | | | | | | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | ≥25and <50 nmol/L(insufficient) | nr | 282 | 1.00 | 0.68, 1.48 | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | | | | | | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | ≥50 and <75 nmol/L(suboptimal) | nr | 410 | 1.05 | 0.76, 1.47 | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | | | | | | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D | ≥75 nmol/L(optimal) | nr | 281 | 1.00 | Reference | 0.85
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Breast Cancer (512/3085) | NR | 25(OH)D
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | <25 nmol/L(deficient) | nr | 6 | 0.17 | 0.01, 4.56 | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | | | | | | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | ≥25and <50 nmol/L(insufficient) | nr | 31 | 1.02 | 0.33, 3.16 | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | | | | | | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | ≥50 and <75 nmol/L(suboptimal) | nr | 45 | 1.76 | 0.64, 4.87 | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | | | | | | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D | ≥75 nmol/L(optimal) | nr | 36 | 1.00 | Reference | 0.61 | B
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Premenopausal | NR | 25(OH)D
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | <25 nmol/L(deficient) | nr | 37 | 1.45 | 0.62,3.37 | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | | | | | | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | ≥25and <50 nmol/L(insufficient) | nr | 202 | 1.09 | 0.68, 1.76 | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | | | | | | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | ≥50 and <75 nmol/L(suboptimal) | nr | 266 | 0.90 | 0.60, 1.36 | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | | | | | | 0.49
Jacobs 2011^144^ Women's Healthy Eating and Living (WHEL) | | Postmenopausal | NR | 25(OH)D | ≥75 nmol/L(optimal) | nr | 187 | 1.00 | Reference | 0.49
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | Quartile 1(<46 nmol/L) | 141 | 441 | 1.00 | Reference | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | | | | | | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | Quartile 2(46.0 to 61.5 nmol/L) | 151 | 456 | 1.05 | 0.79, 1.39 | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | | | | | | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | Quartile 3(61.5 to <76.5 nmol/L) | 145 | 452 | 0.95 | 0.71, 1.29 | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | | | | | | 0.320 | A
Eliassen 2011 135 NHSIII | | Breast Cancer (613 cases, 1218 controls) | NR | 25(OH)D | Quartile 4 (≥76.5 nmol/L) | 176 | 482 | 1.20 | 0.88, 1.63 | 0.320 | A
Ordonez-Mena 2013^97^ ESTHER | 50–74 years | Breast Cancer | 8 yrs | 25(OH)D | Q1 | 38 | 1464 | 1.08 | 0.72, 1.60 | | B
Ordonez-Mena 2013^97^ ESTHER | 50–74 years | Breast Cancer | 8 yrs | 25(OH)D | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | 50–74 years | Breast Cancer | 8 yrs | 25(OH)D | Q2+Q3 | 71 | 2951 | 1.00 | Reference | | B
Ordonez-Mena 2013^97^ ESTHER | 50–74 years | Breast Cancer | 8 yrs | 25(OH)D | | | | | | | B
Ordonez-Mena 2013^97^ ESTHER | 50–74 years | Breast Cancer | 8 yrs | 25(OH)D | Q4 | 26 | 846 | 1.39 | 0.89, 2.18 | | B

A Total number of women not reported

Table 27c Vitamin D and breast density: Results of RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | 50–79 years | percent mammographic density | 1° | 1 yr | (Vit D₃ 400 IU+1,000 mg calcium)/day | 179 | % | 3.7 | final=3.6 | 2.9, 4.6 | +0.8 | -0.2, 1.8 | 0.1 | A
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | 50–79 years | percent mammographic density | 1° | 1 yr | | | | | | | | | | A
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | 50–79 years | percent mammographic density | 1° | 1 yr | placebo | 151 | % | 2.8 | final=2.8 | 2.2, 3.7 | | | | A
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | 50–79 years | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake <200 | percent mammographic density | 1° | 1 yr | (Vit D₃ 400 IU+1,000 mg calcium)/day | 87 | % | 3.6 | final=3.5 | 2.5, 4.9 | +0.5 | -0.9, 1.9 | 0.47
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake <200 | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake <200 | percent mammographic density | 1° | 1 yr | placebo | 77 | % | 3 | final=3 | 2.1, 4.3
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake <200 | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake >400 | percent mammographic density | 1° | 1 yr | (Vit D₃ 400 IU+1,000 mg calcium)/day | 53 | % | 4.3 | final=4 | 2.6, 6.0 | +1.7 | -0.1, 3.5 | 0.07
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake >400 | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake >400 | percent mammographic density | 1° | 1 yr | placebo | 44 | % | 2.7 | final=2.3 | 1.3, 4.2
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake >400 | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake 200–<400 | percent mammographic density | 1° | 1 yr | (Vit D₃ 400 IU+1,000 mg calcium)/day | 29 | % | 2.4 | final=2.8 | 1.4, 5.6 | -0.4 | -2.5, 1.7 | 0.70
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake 200–<400 | percent mammographic density | 1° | 1 yr
Bertone-Johnson, 2012^140^ WHI Mammogram Density/Ancillary Study | Total vitamin D intake 200–<400 | percent mammographic density | 1° | 1 yr | placebo | 24 | % | 2.5 | final=3.2 | 1.7, 6.1

Note: Outcomes cells are shaded for the Control rows.

Table 27d Vitamin D and breast density: Results of nested case-control studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 1,25(OH)₂D: 1st quartile (32.5– 72.8 nmol/l) | 110 | % | nr | Final=25.2 | | | | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 1,25(OH)₂D: 2nd quartile (72.8–82.8 nmol/) | 108 | % | nr | 27.6 | | +2.1 | nc | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 1,25(OH)₂D: 3rd quartile (82.8–93.3 nmol/l) | 110 | % | nr | 23.3 | | -2.2 | nc | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 1,25(OH)₂D: 4th quartile (93.5-140.5 nmol/l) | 114 | % | nr | 25.8 | | +0.3 | nc | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 25(OH)D: 1st quartile (cut points vary by batches) | 118 | % | nr | 26.3 | | | | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 25(OH)D: 2nd quartile | 115 | % | nr | 25.6 | | -0.7 | nc | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 25(OH)D: 3rd quartile | 124 | % | nr | 24.8 | | -1.5 | nc | | B
Green 2010^141^ Nurses' Health Study | | percent mammogram-phic density | 1° | within one year of blood collection | 25(OH)D: 4th quartile | 112 | % | nr | 25.7 | | -0.6 | nc | | B

Nine observational studies that assessed the association between 25(OH)D and breast cancer incidence were identified for the current report. One observational study that assessed the association between 25(OH)D and breast cancer-specific mortality was also identified.

Two cohort studies, within the Women's Healthy Eating and Living (WHEL) Study and the Nurses' Health Study II (NHSII) and the ESTHER study, found no association between 25(OH)D and breast cancer (all rated B).97,144The study in the WHEL cohort also found no association after stratifying by pre- and post-menopause. The Health, Eating, Activity, and Lifestyle (HEAL) cohort study found no association between 25(OH)D and breast cancer-specific mortality (rated B).

Six nested case-control studies were identified. Four of the nested case-control studies found no association between 25(OH)D concentrations and breast cancer incidence (rated 3A, 1B).124,136,137 The other two nested case-control studies found increasing risk of breast cancer with decreasing 25(OH) concentrations (both rated B).138,139 In one of these, a stratified analysis by menopause status found the negative trend remained for premenopausal women but not for postmenopausal women.139

Two studies with breast density outcomes were identified. The Women's Health Initiative (WHI) Mammogram Density Ancillary Study found a decrease in percent mammographic density among women who had ≥400 IU/d total vitamin D intake and were enrolled in the vitamin D_3_ 400 IU + 1,000 mg calcium per day arm of the trial.140 A nested case-control study within the Nurses' Health Study found lower percent mammographic density in women who had 25(OH)D levels above the first quartile; statistical significance was not assessed.141

From the original report, the NHANES III study followed 16,818 adults with a mean age of 44 years with a background calcium intake on average of about 812 mg/day (from diet and supplements).103 The study included 71% non-Hispanic white, 14% non-Hispanic black, 6% Mexican American, and 9% from other races. During 9 years of follow up, women with serum concentration of 25(OH) D greater than 62 nmol/L had a hazard ratio of 0.28 for breast cancer-specific mortality compared to those with 62 nmol/L or lower (95% CI 0.08–0.93). The breast cancer-specific mortality was one of many cancer-specific mortality outcomes reported in this study.

In the original report, two nested case-control studies of women with a mean age of 57 years and 67 years, respectively, found no relationship between serum 25(OH)D concentrations and risk of breast cancer.142,143 However, in the second study, when compared with the lowest quintile, quintiles 3 to 5 were associated with nonsignificantly elevated risks. In multivariable adjusted analyses, the risk associated with 25(OH)D levels below 37.5 nmol/L compared with higher levels was 0.81 (95% CI 0.59, 1.12).143

###### Findings by Age and Sex

In the original report, in the one nested case-control study (methodological quality B) including both premenopausal and postmenopausal women, no relationship was found between serum 25(OH)D levels and risk of breast cancer. However, in this study, there was a statistically significant trend towards decreased risk of breast cancer among women older than 60 years of age with serum concentration of 25(OH)D greater than 62 nmol/L.

##### Findings by Life Stage

- 0–6 mo
  Not applicable
- 7 mo–2 y
  Not applicable
- 3–8 y
  Not applicable
- 9–18 y
  Not applicable
- 19–50 y
  In the NHSII cohort study, 25(OH)D concentration from women aged 32–54 years was not associated with breast cancer incidence. In the original report, a follow up study of NHANES III including women with a mean age of 44 years found a decreased mortality (hazard ratio 0.28) due to breast cancer among those with serum concentration of 25(OH)D greater than 62 nmol/L.
- 51–70 y
  The ESTHER study found no association between serum 25(OH)D concentration and breast cancer incidence in women aged 50–74 years. The WHI Mammogram Density Ancillary Study found an association between vitamin D intake and percent mammographic density in women aged 50 to 79 who had ≥400 IU/d total vitamin D intake.140 The nested case-control studies identified for the update report included individuals with mean age ranged from 57 to 65 years. A trend between higher 25(OH)D levels and lower risk of breast cancer was found in two studies; the other two studies found no association. In the original report, two nested case-control studies of women with a mean age of 57 years and 67 years, respectively, found no relationship between vitamin D levels and risk of breast cancer. However, in one of these studies, there was a statistically significant trend towards decreased risk of breast cancer among women older than 60 years of age with serum concentration of 25(OH)D greater than 62 nmol/L.
- ≥71 y
  Not reviewed
- Postmenopause
  In the WHEL cohort study, no significant trends were found between 25(OH)D and breast cancer in pre- and post-menopausal women.144 In a nested case-control study, no association was found between breast cancer risk and 25(OH)D in postmenopausal women.139
- Pregnant & lactating women
  Not reviewed

#### Pancreatic Cancer

##### Synopsis

No qualified systematic reviews evaluated associations between serum 25(OH)D concentrations and the incidence of pancreatic cancer. A pooled nested case-control study within eight cohorts found an association between 25(OH)D concentration and pancreatic cancer (rated A).146 Individuals with 25(OH)D concentration ≥100 nmol/L had greater risk of pancreatic cancer incidence compared to those with 25(OH)D <25 nmol/L (OR=2.24, 95% CI 1.22, 4.12).

In the original report, two nested case-control studies, rated A in methodological quality, evaluated the association between serum 25(OH) concentration and the risk of developing pancreatic cancer in two different populations. One study found that older adult male smokers living in Finland with higher baseline serum 25(OH)D concentration had an increased risk of exocrine pancreatic cancer compared with those with lower concentration (>65.5 vs. <32 nmol/L; OR=2.92; P for trend=0.001). The other study found that baseline 25(OH)D concentrations were not associated with the risk of overall pancreatic cancer (>82.3 vs. <45.9 nmol/L; OR=1.45; P for trend=0.49) among older adults living in the United States. However, there was an increased risk of pancreatic cancer among the study participants with higher compared to lower 25(OH)D concentrations (>78.4 vs. <49.3 nmol/L; OR=4.03) only in those living in low residential UVB exposure areas but not among those living in moderate or high residential UVB exposure areas.

##### Detailed Presentation

(Tables 28 & 29)

Table 28 Vitamin D and pancreatic cancer: Characteristics of observational studies (updated from original report)

Author Year Trial/Cohort Country (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Trial/Cohort Country (Latitude) [PMID] | Population | | 25(OH)D | | Comparisons | Nutrients | Demographic | Anthrop | Medical | UV Exposure | Lifestyles | Comments
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | Health status | All smokers | Assay | RIA (DiaSorin) | Exocrine pancreatic risk stratified by baseline 25(OH)D quintiles | X | X | | | X | X
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | Mean age (range/SD), y | 58 | Assay | RIA (DiaSorin) | Exocrine pancreatic risk stratified by baseline 25(OH)D quintiles | X | X | | | X | X
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | Male (%) | 100 | Season blood drawn | nd; but result adjusted for this variable | Exocrine pancreatic risk stratified by baseline 25(OH)D quintiles | X | X | | | X | X
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | Health status | DM: 10.5% | Assay | RIA (Heartland Assays lab) | Pancreatic risk stratified by baseline 25(OH)D quintiles Pancreatic risk stratified by residential sun exposure levels and baseline 25(OH)D quartiles | | X | X | | X | X
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | Mean age (range), y | 66 (55–74) | Assay | RIA (Heartland Assays lab) | Pancreatic risk stratified by baseline 25(OH)D quintiles Pancreatic risk stratified by residential sun exposure levels and baseline 25(OH)D quartiles | | X | X | | X | X
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | Male (%) | 65.2 | Season blood drawn | All seasons | Pancreatic risk stratified by baseline 25(OH)D quintiles Pancreatic risk stratified by residential sun exposure levels and baseline 25(OH)D quartiles | | X | X | | X | X
NEW Studies
Stolzenberg-Solomon, 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | Health status | nd | | | Pancreatic risk stratified by baseline 25(OH)D sextiles
Stolzenberg-Solomon, 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | Mean age (SD), y | nd (nd) | | | Pancreatic risk stratified by baseline 25(OH)D sextiles
Stolzenberg-Solomon, 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | Male (%) | 66.5% | | | Pancreatic risk stratified by baseline 25(OH)D sextiles
Afzal 2013^99^ Denmark | Health status | NR | | | Pancreatic risk stratified by baseline 25(OH)D category | | X | X | | | X | HR (95%CI) for pancreatic cancer are shown in Figure 1
Afzal 2013^99^ Denmark | Mean age (SD), y | 58 (47–65) | | | Pancreatic risk stratified by baseline 25(OH)D category | | X | X | | | X | HR (95%CI) for pancreatic cancer are shown in Figure 1
Afzal 2013^99^ Denmark | Male (%) | 45% | | | Pancreatic risk stratified by baseline 25(OH)D category | | X | X | | | X | HR (95%CI) for pancreatic cancer are shown in Figure 1

Table 29 Vitamin D and pancreatic cancer: Results of observational studies (updated from original report)

Author Year Study Name [PMID] | Life Stage, y | Outcome (No. of Cases; No. of Control) | Time to Diagnosis, y | 25(OH)D Concentration, nmol/L | No. of Cases | No. of Control | Adjusted OR | 95% CI | P for Trend | Study Quality
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | <32 | 27 | 80 | 1 | Reference | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 32–41.1 | 34 | 80 | 1.3 | 0.70, 2.40 | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | | | | | | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 41.1–51.1 | 47 | 80 | 2.12 | 1.15, 3.90^*^ | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | | | | | | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | 51.1–65.5 | 35 | 81 | 1.5 | 0.81, 2.76 | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | | | | | | 0.001 | A
Stolzenberg-Solomon 2006^147^ ATBC Finland (60°N) [17047087] | 51–70, male only | Exocrine pancreatic cancer (200; 400) | 11.8 (median) | >65.5 | 57 | 79 | 2.92 | 1.56, 5.48^*^ | 0.001 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | ≤45.9 | 44 | 74 | 1 | Reference | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | | | | | | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >45.9 to ≤60.3 | 40 | 74 | 0.97 | 0.47, 1.98 | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | | | | | | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >60.3 to ≤69.5 | 27 | 73 | 0.86 | 0.40, 1.84 | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | | | | | | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >69.5 to ≤82.3 | 31 | 74 | 0.84 | 0.39, 1.80 | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | | | | | | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer (184; 368) | 5.4 (median), up to 11 y | >82.3 | 42 | 73 | 1.45 | 0.66, 3.15 | 0.49 | A
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | <49.3 | 22 | 44 | 1 | Reference | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | >49.3 to <65.2 | 22 | 42 | 2.52 | 0.92, 6.90 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | >65.2 to <78.4 | 21 | 43 | 2.33 | 0.83, 6.48 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Low residential sun exposure area (91; 167) | nd | >78.4 | 26 | 38 | 4.03 | 1.38, 11.79^*^ | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | | | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | <49.3 | 33 | 48 | 1.97 | 0.80, 4.82 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | >49.3 to <65.2 | 15 | 50 | 0.66 | 0.22, 2.01 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | >65.2 to <78.4 | 18 | 49 | 0.91 | 0.31, 2.71 | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | | | | | | P for interaction between low and moderate/high residential sun exposure = 0.015
Stolzenberg-Solomon 2009^148^ PLCO US (various) [19208842] | 51–70, both sexes | Pancreatic cancer: Moderate residential sun exposure area (91; 167) | nd | >78.4 | 24 | 54 | 1.45 | 0.53, 3.96 | P for interaction between low and moderate/high residential sun exposure = 0.015
NEW Studies
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | <25 | 115 | 256 | 1.00 | Reference | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | | | | | | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | 25 to <37.5 | 164 | 389 | 1.04 | 0.74, 1.44 | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | | | | | | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | 37.5 to <50.0 | 208 | 494 | 1.10 | 0.79, 1.55 | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | | | | | | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | 50.0 to <75.0 | 306 | 764 | 1.06 | 0.76, 1.48 | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | | | | | | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | 75.0 to <100.0 | 120 | 310 | 1.08 | 0.73, 1.59 | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | | | | | | 0.14 | A
Stolzenberg–Solomon 2010^146^ Cohort Consortium Vitamin D Pooling Project or Rarer Cancers | | Pancreatic Cancer (952 cases, 1333 controls) | nd | >100 | 39 | 69 | 2.24 | 1.22, 4.12 | 0.14 | A
Afzal 2013^99^ | | Pancreatic Cancer | 28 yrs | 25(OH)D, 50% reduction in plasma levels | 109 | 9791 | HR 1.05 | 0.84, 1.30 | | B

* Statistically significant (P<0.05)

###### 51–74 years

The pooled nested case-control study is based on 8 cohorts: the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study (ATBC), CLUE, the Cancer Prevention Study II Nutrition Cohort (CPSII), the New York University Women's Health Study (NYU-WHS), the Multiethnic Cohort Study (MEC), the PLCO, and the Shanghai Women's and Men's Health Studies (SWHS and SMHS) 146 . The pooled sample contains 952 cases (median age 62, IQR 56–68) and 1,333 controls (median age 52, IQR 57–67). Serum 25(OH)D concentration was stratified into sextiles. The odds ratio for pancreatic cancer was 2.24 (95% CI 1.22, 4.12) comparing the 6th sextile (≥100 nmol/L) to the 1st sextile (<25 nmol/L). The result was adjusted for age, race/ethnicity, sex, cohort, date of blood draw, BMI, smoking status, and diabetes status.

In the original report, one nested case-control study based on the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study (ATBC) in older adult male smokers aged 54 to 62 years in Finland identified 200 cases of incident exocrine pancreatic cancer.147 These cases were matched to 400 controls. Baseline serum 25(OH)D concentration was stratified into quintiles. The odds ratio for exocrine pancreatic cancer was 2.92 (95% CI 1.56, 5.48) comparing 5th quintile (>65.5 nmol/L) to 1st quintile (<32 nmol/L). The result was adjusted for age, month of blood drawn, years smoked, number of cigarettes smoked per day, reporting to have quit smoking more than three consecutive visits (>1 y) during the trial (1985–1993), occupational physical activity, education, and serum retinol. The study authors excluded islet cell carcinomas from analysis because the etiology for their pathogenesis might be different from that of exocrine tumors.

In the original report, another nested case-control study based on the Prostate, Lung, Colorectal, and Ovarian Screening (PLCO) trial in older men and women aged 55 to 74 years in the United States identified 184 cases of incident pancreatic cancer.148 These cases were matched to 368 controls. Baseline serum 25(OH)D concentration was stratified into quintiles. The odds ratio for exocrine pancreatic cancer was 1.45 (95% CI 0.66, 3.15) comparing 5th quintile (>82.3 nmol/L) to 1st quintile (<45.9 nmol/L). The result was adjusted for age, race, sex, date of blood draw based on 2-month blocks, BMI and smoking. The association was not significantly modified by season of blood collection (P for interaction > 0.14); but estimated residential annual solar UVB exposure significantly modified the 25(OH)D concentration and pancreatic cancer association (P for interaction = 0.015). In the joint effects models, among subjects with low estimated annual UVB residential exposure, higher compared with lower 25(OH)D concentrations were associated with increased risk of pancreatic cancer (compared with the lowest quartile, the ORs for each respective quartile were 2.52, 2.33, and 4.03; 95% CI 1.38, 11.79), whereas among subjects with moderate to high residential UVB exposure, 25(OH)D concentrations were not associated with pancreatic cancer. There was no significant interaction of 25(OH)D concentration and pancreatic cancer by smoker status, sex, physical activity, or total vitamin A intake.

##### Findings by Life Stage

- 0–6 mo
  not reviewed
- 7 mo–2 y
  not reviewed
- 3–8 y
  not reviewed
- 9–18 y
  not reviewed
- 19–50 y
  No study specifically targeted this age group.
- 51–70 y
  One pooled nested case-control study within eight cohorts found that individuals with 25(OH)D concentration ≥100 nmol/L had greater risk of pancreatic cancer incidence compared to those with 25(OH)D <25 nmol/L (OR=2.24, 95% CI 1.22, 4.12). In the original report, one nested case-control study found that male smokers living in Finland with higher baseline serum 25(OH)D concentration had an increased risk of pancreatic cancer compared with those with lower concentration (5^th^ vs. 1^st^ quintile, >65.5 vs. <32 nmol/L: OR 2.92, 95% CI 1.56, 5.48, P for trend = 0.001). Another study found that baseline 25(OH)D concentrations were not associated with overall risk of pancreatic cancer among older adults living in the United States (5^th^ vs. 1^st^ quintile, >82.3 vs. <45.9 nmol/L: OR 1.45, 95% CI 0.66, 3.15; P for trend=0.49). However, there was an increased risk of pancreatic cancer among the study participants living in low residential UVB exposure areas (4^th^ vs. 1^st^ quartile >78.4 vs. <49.3 nmol/L: OR=4.03; 95% CI 1.38, 11.79).
- ≥71 y
  No study specifically targeted this age group.
- Postmenopause
  not reviewed
- Pregnant & lactating women
  not reviewed

### Vitamin D and Immunologic Outcomes

We reviewed primary studies that evaluated relationships between vitamin D and any immune function related outcomes.

#### Synopsis

The current report identified five RCTs that assessed the effect of supplemental vitamin D on infectious illnesses and three cohort studies that assessed the association between vitamin D concentrations and risk for infectious illnesses. RCTs of infants and adults reported no significant effect of supplementation on the risk for upper respiratory infections; whereas one RCT conducted among 4-year-old Japanese children reported a positive effect of supplementation. Three prospective cohort studies observed an association between low cord blood 25(OH)D concentrations and increased risk for respiratory infections at 3 to 6 months of age, in New Zealand, South Korea, and the Netherlands. A Norwegian prospective study found an association between lower midpregnancy serum 25(OH)D and lower respiratory tract infections in the first 36 months of life. Two studies of school-age children, one in Colombia and one in Canada, observed associations between low serum 25A(OH)D and gastrointestinal tract infections and ear infections, and viral respiratory tract infections, respectively. A study of healthy U.S. adults found an association between serum concentrations of 25(OH)D levels of 95nmol/L or higher and reduced risk for acute respiratory viral infections. Studies of German and Finnish adults observed associations between lower serum 25(OH)D and respiratory disease mortality and pneumonia, respectively.

The current report identified one RCT that found no effect of prenatal vitamin D supplementation on the risk for wheeze, atopy, or eczema at 3 years of age. The report also identified five prospective cohort/nested case control studies that reported mixed associations of serum concentrations of 25(OH)D and risk for asthma, atopy, and/or eczema. An Australian study observed a significant association of cord blood 25(OH)D and risk for eczema but not allergies at 12 months of age. A prospective cohort study conducted in the UK found no association between maternal serum 25(OH)D at 34 weeks gestation and asthma, wheeze, and atopy in their children at 6 years of age. A prospective cohort study conducted in the Netherlands found that serum 25(OH)D concentrations at 4 years of age significantly predicted asthma and severe asthma at 8 years of age. Another UK longitudinal study found a small but significant association of wheeze and antecubital dermatitis in 10-year old children with serum levels of 25(OH)D2 but a negative association with 25(OH)D3. Finally, the HUNT study, a large population health survey in Norway, found no association of 25(OH)D with asthma in women and only a weak association in men that disappeared when adjusted for confounders.

The current report identified one RCT and four prospective cohort studies on the risk for autoimmune disease. A substudy of the WHI CaD trial found no effect of supplementation on women's risk for rheumatoid arthritis. Two nested case control studies and one cohort study assessed the association between maternal serum 25(OH)D concentrations or subsequent childhood or adult status with risk for type 1 diabetes mellitus and reported mixed findings. One study assessed the effects of maternal 25(OH)D concentrations on the risk for multiple sclerosis (MS) in the offspring and also assessed the effect of 25(OH)D concentrations across the adult population on the risk for subsequent MS and found mixed effects.

In the original report, analyses using NHANES III data (general adult populations living in the United States) showed no significant association between baseline 25(OH)D concentrations and infectious disease mortality.

One cohort study from UK suggested a relationship between maternal 25(OH)D concentration and the risk of eczema in their children, but the analysis did not control for important potential confounders, and the 25(OH)D concentrations in children were not measured.

#### Detailed Presentation

(Tables 30a-d & 31a-d)

Table 30a Vitamin D (mother) and immunologic outcomes (offspring): Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Melamed 2008^85^ NHANES III US (various) [18695076] | - Health status | DM 7.4%, history of CVD 7.9%, HTN 25% | - Assay method | RIA (DiaSorin) | Infectious disease mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Mean age (range), y | 45 (≥20) | - Assay method | RIA (DiaSorin) | Infectious disease mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Male (%) | 46 | - Season blood drawn | All | Infectious disease mortality stratified by baseline 25(OH)D quartiles | X | X | X | X | X | X
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Health status | singleton pregnancy <17 wk | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | | X | | | X | | White only
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Mean age (range/SD), y | 26.3 | - Assay method | RIA | Length and weight in offspring stratified by mother's 25(OH)D | | X | | | X | | White only
Gale 2008^55^ PAHSG UK (50°N) [17311057] | - Male (%) | 0 | - Season blood drawn | nd | Length and weight in offspring stratified by mother's 25(OH)D | | X | | | X | | White only
NEW Studies
Jones 2012^162^ Perth, Australia | - Health status | Healthy | | | Eczema stratified by baseline 25(OH)D levels | | X | | | X | | Age, race= of mothers
Jones 2012^162^ Perth, Australia | - Mean age (SD), y | 33.4 (SD 4.5) | | | Eczema stratified by baseline 25(OH)D levels | | X | | | X | | Age, race= of mothers
Jones 2012^162^ Perth, Australia | - Male (%) | 51.5% | | | Eczema stratified by baseline 25(OH)D levels | | X | | | X | | Age, race= of mothers
Mai, 2012^166^ HUNT Study Nord-Trondelag, Norway | - Health status | nd | | | Asthma stratified by baseline 25(OH)D quartiles | | X | X | | X | X | Age= women controls
Mai, 2012^166^ HUNT Study Nord-Trondelag, Norway | - Mean age (SD), y | 39.7 (8.5) | | | Asthma stratified by baseline 25(OH)D quartiles | | X | X | | X | X | Age= women controls
Mai, 2012^166^ HUNT Study Nord-Trondelag, Norway | - Male (%) | 43% | | | Asthma stratified by baseline 25(OH)D quartiles | | X | X | | X | X | Age= women controls
Pike, 2012^163^ UK | - Health status | nd | | | Asthma stratified by baseline 25(OH)D levels | X | X | X | | X
Pike, 2012^163^ UK | - Mean age (SD), y | 30.37 (3.81), y | | | Asthma stratified by baseline 25(OH)D levels | X | X | X | | X
Pike, 2012^163^ UK | - Male (%) | 51.74% | | | Asthma stratified by baseline 25(OH)D levels | X | X | X | | X
Tolppanen, 2013^165^ UK, Southwest England | - Health status | nd | | | Asthma stratified by baseline 25(OH)D_2_ and 25(OH)D_3_ tertiles
Tolppanen, 2013^165^ UK, Southwest England | - Mean age (SD), y | 9.84 (SD 0.02) | | | Asthma stratified by baseline 25(OH)D_2_ and 25(OH)D_3_ tertiles
Tolppanen, 2013^165^ UK, Southwest England | - Male (%) | 52.1 | | | Asthma stratified by baseline 25(OH)D_2_ and 25(OH)D_3_ tertiles
van Oeffelen, 2011^164^ Netherlands | - Health status | nd | | | Asthma stratified by baseline 25(OH)D tertiles | | X | | | | X
van Oeffelen, 2011^164^ Netherlands | - Mean age (SD), y | nd (nd) | | | Asthma stratified by baseline 25(OH)D tertiles | | X | | | | X
van Oeffelen, 2011^164^ Netherlands | - Male (%) | 51.9% | | | Asthma stratified by baseline 25(OH)D tertiles | | X | | | | X
NEW Nested case-control studies—Immune Function—Autoimmune Disease
Munger, 2013^168^ US | - Health status | Presumed healthy | | | Type 1 Diabetes Mellitus stratified by baseline 25(OH)D tertiles
Munger, 2013^168^ US | - Mean age (SD), y | 20.6 (4.0) | | | Type 1 Diabetes Mellitus stratified by baseline 25(OH)D tertiles
Munger, 2013^168^ US | - Male (%) | 95.1% | | | Type 1 Diabetes Mellitus stratified by baseline 25(OH)D tertiles
Salzer 2012^170^ Risk of Multiple Sclerosis Gestational Risk factors of Multiple Sclerosis (GRoMS) Sweden | - Health status | nd | | | Multiple Sclerosis stratified by baseline 25(OH)D medians
Salzer 2012^170^ Risk of Multiple Sclerosis Gestational Risk factors of Multiple Sclerosis (GRoMS) Sweden | - Mean age (Range), y | 26 (16–60) | | | Multiple Sclerosis stratified by baseline 25(OH)D medians
Salzer 2012^170^ Risk of Multiple Sclerosis Gestational Risk factors of Multiple Sclerosis (GRoMS) Sweden | - Male (%) | 7.8% | | | Multiple Sclerosis stratified by baseline 25(OH)D medians
Sorensen, 2012^169^ Norway | - Health status | nd | | | Type 1 Diabetes stratified by baseline 25(OH)D quartiles | | X | | | X
Sorensen, 2012^169^ Norway | - Mean age (SD), y | 9 (SD 3.6) | | | Type 1 Diabetes stratified by baseline 25(OH)D quartiles | | X | | | X
Sorensen, 2012^169^ Norway | - Male (%) | 51% | | | Type 1 Diabetes stratified by baseline 25(OH)D quartiles | | X | | | X
NEW Cohort study—Immune Function—Autoimmune Disease
Simpson, 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) US Denver, CO | - Health status | At increased risk for Type 1 Diabetes | | | Islet Autoimmune stratified by baseline 25(OH)D levels | | X
Simpson, 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) US Denver, CO | - Mean age (SD), y | 11.9 (4.4) | | | Islet Autoimmune stratified by baseline 25(OH)D levels | | X
Simpson, 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) US Denver, CO | - Male (%) | 49% | | | Islet Autoimmune stratified by baseline 25(OH)D levels | | X
NEW Cohort study—Immune Function—Infectious Diseases
Belderbos, 2011^153^ Utrecht, Netherland | - Health status | Healthy | | | Respiratory Syncytial Virus Bronchiolitis stratified by 25(OH)D tertiles | | | X
Belderbos, 2011^153^ Utrecht, Netherland | - Mean age (SD), y | 0.77 (0.13) | | | Respiratory Syncytial Virus Bronchiolitis stratified by 25(OH)D tertiles | | | X
Belderbos, 2011^153^ Utrecht, Netherland | - Male (%) | 56% | | | Respiratory Syncytial Virus Bronchiolitis stratified by 25(OH)D tertiles | | | X
Camargo, 2011^154^ Wellington (41°S latitude) and Christchurch (43°S latitude), New Zealand | - Health status | nd | | | Infection and Asthma stratified by 25(OH)D tertiles | | X | | X | X | X
Camargo, 2011^154^ Wellington (41°S latitude) and Christchurch (43°S latitude), New Zealand | - Mean age (SD), y | 0.77 (nd) | | | Infection and Asthma stratified by 25(OH)D tertiles | | X | | X | X | X
Camargo, 2011^154^ Wellington (41°S latitude) and Christchurch (43°S latitude), New Zealand | - Male (%) | 51% | | | Infection and Asthma stratified by 25(OH)D tertiles | | X | | X | X | X
Sabetta, 2010^159^ US Greenwich, CT | - Health status | Healthy | | | Acute Viral Respiratory Tract Infections stratified by 25(OH)D medians | X | X | X
Sabetta, 2010^159^ US Greenwich, CT | - Mean age (range), y | nd (20–88) | | | Acute Viral Respiratory Tract Infections stratified by 25(OH)D medians | X | X | X
Sabetta, 2010^159^ US Greenwich, CT | - Male (%) | 43% | | | Acute Viral Respiratory Tract Infections stratified by 25(OH)D medians | X | X | X
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) Korea | - Health status | NR | | | Respiratory tract infections, Acute nasopharyngitis, otitis media, and bronchiolitis stratified by 25(OH)D tertiles | X | | | | X | X
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) Korea | - Mean age (SD), y | Maternal age: 32.2 (SD 3.4) Newborns Range: (0–6) months | | | Respiratory tract infections, Acute nasopharyngitis, otitis media, and bronchiolitis stratified by 25(OH)D tertiles | X | | | | X | X
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) Korea | - Male (%) | Mothers: 0% Newborns: 53.1% | | | Respiratory tract infections, Acute nasopharyngitis, otitis media, and bronchiolitis stratified by 25(OH)D tertiles | X | | | | X | X
Science 2013^158^ Canada | - Health status | NR | | | Respiratory tract infections stratified by 25(OH)D medians | | X
Science 2013^158^ Canada | - Mean age (SD), y | 9.3 (SD 3.4) | | | Respiratory tract infections stratified by 25(OH)D medians | | X
Science 2013^158^ Canada | - Male (%) | 47.5% | | | Respiratory tract infections stratified by 25(OH)D medians | | X
Schottker 2013^76^ ESTHER Germany | - Health status | NR | | | Respiratory disease mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Mean age (SD), y | 62 (SD 6.5) | | | Respiratory disease mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Male (%) | 43.8% | | | Respiratory disease mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Thornton 2013^157^ Bogotá School Children Cohort Bogota, Columbia | - Health status | ∼7–12.5% stunted | | | Earache/discharge with fever and Cough with fever stratified by 25(OH)D tertiles | | X
Thornton 2013^157^ Bogotá School Children Cohort Bogota, Columbia | - Mean age (SD), y | 8.9 (SD 1.6) | | | Earache/discharge with fever and Cough with fever stratified by 25(OH)D tertiles | | X
Thornton 2013^157^ Bogotá School Children Cohort Bogota, Columbia | - Male (%) | 48% | | | Earache/discharge with fever and Cough with fever stratified by 25(OH)D tertiles | | X
Magnus 2013^156^ Norwegian Mother and Child Cohort Study Norway | - Health status | NR | | | Asthma stratified by 25(OH)D quartiles | X | X | X | X | X | X
Magnus 2013^156^ Norwegian Mother and Child Cohort Study Norway | - Mean age (SD), y | NR | | | Asthma stratified by 25(OH)D quartiles | X | X | X | X | X | X
Magnus 2013^156^ Norwegian Mother and Child Cohort Study Norway | - Male (%) | 0% | | | Asthma stratified by 25(OH)D quartiles | X | X | X | X | X | X
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study Kuopio, Finland | - Health status | NR | | | Pneumonia stratified by 25(OH)D tertiles | X | X | X | | X | X
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study Kuopio, Finland | - Mean age (SD), y | 62.5 (SD 6.5) | | | Pneumonia stratified by 25(OH)D tertiles | X | X | X | | X | X
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study Kuopio, Finland | - Male (%) | 50.9% | | | Pneumonia stratified by 25(OH)D tertiles | X | X | X | | X | X

Table 30b Vitamin D and immunologic outcomes: Characteristics of autoimmune disease RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Racovan, 2012^167^ WHI US | - Health status | Post-menopausal | | | Rheumatoid Arthritis (RA) stratified by mother's 25(OH)D medians
Racovan, 2012^167^ WHI US | - Mean age (range/SD), y | 62.34 (SD 6.91) | | | Rheumatoid Arthritis (RA) stratified by mother's 25(OH)D medians
Racovan, 2012^167^ WHI US | - Male (%) | 0% | | | Rheumatoid Arthritis (RA) stratified by mother's 25(OH)D medians

Table 30c Vitamin D and immunologic outcomes: Characteristics of infectious disease continuous RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Li-Ng, 2009^150^ US Long Island, NY | - Health status | nd | | | Duration of Upper Respiratory Tract stratified by 25(OH)D levels
Li-Ng, 2009^150^ US Long Island, NY | - Mean age (range/SD), y | 58.1 (SD 13.4) | | | Duration of Upper Respiratory Tract stratified by 25(OH)D levels
Li-Ng, 2009^150^ US Long Island, NY | - Male (%) | 20.3% | | | Duration of Upper Respiratory Tract stratified by 25(OH)D levels
Laaksi, 2010^151^ Pori Brigade, Finland | - Health status | Healthy | | | Days absent from duty stratified by 25(OH)D_3_ levels | | X
Laaksi, 2010^151^ Pori Brigade, Finland | - Mean age (SD), y | Nd (nd) | | | Days absent from duty stratified by 25(OH)D_3_ levels | | X
Laaksi, 2010^151^ Pori Brigade, Finland | - Male (%) | 100% | | | Days absent from duty stratified by 25(OH)D_3_ levels | | X

Table 30d Vitamin D and immunologic outcomes: Characteristics of infectious disease dichotomous RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Laaksi, 2010^151^ Pori Brigade, Finland | - Health status | Healthy | | | Days absent from duty and self-reported cold symptoms stratified by 25(OH)D_3_ levels | | X
Laaksi, 2010^151^ Pori Brigade, Finland | - Mean age (range/SD), y | Nd (nd) | | | Days absent from duty and self-reported cold symptoms stratified by 25(OH)D_3_ levels | | X
Laaksi, 2010^151^ Pori Brigade, Finland | - Male (%) | 100% | | | Days absent from duty and self-reported cold symptoms stratified by 25(OH)D_3_ levels | | X
Li-Ng, 2009^150^ | - Health status | nd | | | Upper respiratory tract stratified by 25(OH)D medians
Li-Ng, 2009^150^ | - Mean age (SD), y | 58.1 (SD 13.4) | | | Upper respiratory tract stratified by 25(OH)D medians
Li-Ng, 2009^150^ | - Male (%) | 20.3% | | | Upper respiratory tract stratified by 25(OH)D medians
Manaseki-Holland, 2012^149^ Kabul, Afghanistan | - Health status | nd | | | Pneumonia stratified by 25(OH)D_3_ medians | | | | | | | Age groups reported but not mean age, only father's ethnicity reported
Manaseki-Holland, 2012^149^ Kabul, Afghanistan | - Mean age (SD), y | nd (nd) | | | Pneumonia stratified by 25(OH)D_3_ medians | | | | | | | Age groups reported but not mean age, only father's ethnicity reported
Manaseki-Holland, 2012^149^ Kabul, Afghanistan | - Male (%) | 52% | | | Pneumonia stratified by 25(OH)D_3_ medians | | | | | | | Age groups reported but not mean age, only father's ethnicity reported
Murdoch, 2012^152^ VIDARIS New Zealand | - Health status | nd | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
Murdoch, 2012^152^ VIDARIS New Zealand | - Mean age (SD), y | 48 (10) | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
Murdoch, 2012^152^ VIDARIS New Zealand | - Male (%) | 25% | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
Murdoch, 2012^152^ VIDARIS New Zealand | | | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
Murdoch, 2012^152^ VIDARIS New Zealand | - Mean age (SD), y | 10.4 (2.4) | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
Murdoch, 2012^152^ VIDARIS New Zealand | - Male (%) | 55% | | | Days of missed work per episode stratified by 25(OH)D_3_ and Placebo medians
NEW Studies
Goldring 2013^161^ UK | - Health status | NR | | | Wheeze ever and lower respiratory tract infection stratified by 25(OH)D medians | X | X | | | | X | Children of mothers enrolled in a 3-arm RCT of vitamin D administration were prospectively followed
Goldring 2013^161^ UK | - Mean age (SD), y | 3 | | | Wheeze ever and lower respiratory tract infection stratified by 25(OH)D medians | X | X | | | | X | Children of mothers enrolled in a 3-arm RCT of vitamin D administration were prospectively followed
Goldring 2013^161^ UK | - Male (%) | 44% | | | Wheeze ever and lower respiratory tract infection stratified by 25(OH)D medians | X | X | | | | X | Children of mothers enrolled in a 3-arm RCT of vitamin D administration were prospectively followed

Table 31a Vitamin D (mother) and immunologic outcomes (offspring): Results of observational studies (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted HR, OR, RR | 95% CI | P for Trend | Study Quality
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | <44 | nd | 13331 (Total) | 0.84 | 0.38, 1.86 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | 44–60 | nd | nd | 0.87 | 0.43, 1.74 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | 61–80 | nd | nd | 1.01 | 0.53, 1.93 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | Adults, both sexes | Infectious disease mortality (N=13,331) | Median 8.7 (IRQ 7.1–10.2) y | 25(OH)D | >80 | nd | nd | 1 | Reference | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | <30 (Quartile) | 9 | 440 (total) | 1 | Reference | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | 30–50 | 10 | | 1.11^A^ | 0.43, 2.84 | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | | | | | | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | 50–75 | 15 | | 1.75^A^ | 0.73, 4.17 | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | | | | | | nd | C
Gale 2008^55^ PAHSG UK (54°N) [17311057] | Pregnant women; infant at 9 mo | Atopic eczema at 9 mo (48/440; 0.11) | 9 mo | Maternal 25(OH)D at late pregnancy | >75 | 14 | | 1.62^A^ | 0.67, 3.89 | nd | C
NEW Studies—Allergy/Asthma
Jones 2012^162^ | Pregnant or lactating women, non-smoking | eczema | NR | 25(OH)D_3_ | per 10 nmol/L rise in CB 25(OH)D_3_ | 78 | 231 | OR=0.857 | 0.739, 0.995 | 0.042 | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | ≥75.0 | 81 | 328 | OR=1.00 | Reference | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | 50.0–74.9 | 125 | 555 | 0.8 | 0.57, 1.13 | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | <50.0 | 170 | 566 | 0.94 | 0.67, 1.32 | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Female 19–65 yrs | asthma | 11 yrs | 25(OH)D | each 25-nmol/L reduction | 376 | 1449 | 0.97 | 0.85, 1.12 | | A
Mai 2012^166^ | | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | ≥75.0 | 33 | 247 | 1.00 | Reference | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | 50.0–74.9 | 77 | 384 | 1.5 | 0.95, 2.38 | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | <50.0 | 98 | 462 | 1.47 | 0.93, 2.32 | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | | | | | | | A
Mai 2012^166^ | Male 19–65 yrs | asthma | 11 yrs | 25(OH)D | each 25-nmol/L reduction | 208 | 1093 | 1.14 | 0.94, 1.37 | | A
Pike 2012^163^ | | current doctor-diagnosed asthma | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 87 | 836 | RR=0.98 | 0.92, 1.04 | 0.56 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | current wheeze in last 12 months | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 117 | 833 | 0.99 | 0.94, 1.05 | 0.76 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | any wheeze at or before 6 years | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 504 | 823 | 1.00 | 0.98, 1.02 | 0.95 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | transient wheeze | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 367 | 707 | 1.00 | 0.98, 1.02 | 0.89 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | persistent late wheeze | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 137 | 475 | 0.98 | 0.94, 1.03 | 0.49 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | persistent late wheeze with atopy | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 46 | 251 | 0.91 | 0.84, 0.99 | 0.04 | B
Pike 2012^163^ | | | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | | | | | | B
Pike 2012^163^ | | persistent late wheeze without atopy | 6 yrs | 25(OH)D | per 10 nmol/l rise in CB 25(OH)D3 | 48 | 253 | 1.01 | 0.94, 1.09 | 0.73 | B
Tolppanen 2013^165^ | | wheezing | 1 yrs | 25(OH)D_2_ | per doubling of exposure | 141 | 3323 | OR=0.83 | 0.68, 1.00 | | B
Tolppanen 2013^165^ | | | 1 yrs | 25(OH)D_2_ | per doubling of exposure | | | | | | B
Tolppanen 2013^165^ | | asthma | 1 yrs | 25(OH)D_2_ | per doubling of exposure | 464 | 3323 | 0.89 | 0.78, 1.02 | | B
Tolppanen 2013^165^ | | | 1 yrs | 25(OH)D_2_ | per doubling of exposure | | | | | | B
Tolppanen 2013^165^ | | flexural dermatitis | 1 yrs | 25(OH)D_2_ | per doubling of exposure | 300 | 3748 | 0.83 | 0.72, 0.94 | | B
Tolppanen 2013^165^ | | | | | | | | | | | B
Tolppanen 2013^165^ | | wheezing | 1 yrs | 25(OH)D_3_ | per doubling of exposure | 141 | 3323 | 1.14 | 1.03, 1.28 | | B
Tolppanen 2013^165^ | | | 1 yrs | 25(OH)D_3_ | per doubling of exposure | | | | | | B
Tolppanen 2013^165^ | | asthma | 1 yrs | 25(OH)D_3_ | per doubling of exposure | 464 | 3323 | 1.02 | 0.93, 1.12 | | B
Tolppanen 2013^165^ | | | 1 yrs | 25(OH)D_3_ | per doubling of exposure | | | | | | B
Tolppanen 2013^165^ | | flexural dermatitis | 1 yrs | 25(OH)D_3_ | per doubling of exposure | 300 | 3748 | 1.09 | 1.00, 1.18 | | B
van Oeffelen 2011^164^ | | bronchial hyperresponsiveness | 8 yrs | 25(OH)D | Tertile 1: range 23.1–60.2 nmol/L | 80 | 204 | OR=1.00 | Reference | | A
van Oeffelen 2011^164^ | | bronchial hyperresponsiveness | 8 yrs | 25(OH)D | | | | | | | A
van Oeffelen 2011^164^ | | bronchial hyperresponsiveness | 8 yrs | 25(OH)D | Tertile 2: range 60.7–78.8 nmol/L | 88 | 209 | 1.16 | 0.62, 2.18 | | A
van Oeffelen 2011^164^ | | bronchial hyperresponsiveness | 8 yrs | 25(OH)D | | | | | | | A
van Oeffelen 2011^164^ | | bronchial hyperresponsiveness | 8 yrs | 25(OH)D | Tertile 3: range 79.0–303.8 nmol/L | 87 | 194 | 1.19 | 0.63, 2.23 | | A
van Oeffelen 2011^164^ | | | 8 yrs | 25(OH)D | | | | | | | A
van Oeffelen 2011^164^ | | atopy | 8 yrs | 25(OH)D | Tertile 1: range 23.1–60.2 nmol/L | 93 | 346 | 1.00 | Reference
van Oeffelen 2011^164^ | | atopy | 8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | atopy | 8 yrs | 25(OH)D | Tertile 2: range 60.7–78.8 nmol/L | 101 | 237 | 2.19 | 1.17, 4.12
van Oeffelen 2011^164^ | | atopy | 8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | atopy | 8 yrs | 25(OH)D | Tertile 3: range 79.0–303.8 nmol/L | 93 | 279 | 1.23 | 0.64, 2.39
van Oeffelen 2011^164^
van Oeffelen 2011^164^ | | asthma | 5–8 yrs | 25(OH)D | Tertile 1: range 23.1–60.2 nmol/L | NR | NR | 1.00 | Reference
van Oeffelen 2011^164^ | | asthma | 5–8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | asthma | 5–8 yrs | 25(OH)D | Tertile 2: range 60.7–78.8 nmol/L | NR | NR | 0.97 | 0.57, 1.65
van Oeffelen 2011^164^ | | asthma | 5–8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | asthma | 5–8 yrs | 25(OH)D | Tertile 3: range 79.0–303.8 nmol/L | NR | NR | 0.68 | 0.39, 1.19
van Oeffelen 2011^164^ | | | 5–8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | severe asthma | 5–8 yrs | 25(OH)D | Tertile 1: range 23.1–60.2 nmol/L | NR | NR | 1.00 | Reference
van Oeffelen 2011^164^ | | severe asthma | 5–8 yrs | 25(OH)D
van Oeffelen 2011^164^ | | severe asthma | 5–8 yrs | 25(OH)D | Tertile 2: range 60.7–78.8 nmol/L | NR | NR | 1.06 | 0.59, 1.90
van Oeffelen 2011^164^ | | severe asthma | 5–8 yrs | 25(OH)D | Tertile 3: range 79.0–303.8 nmol/L | NR | NR | 0.61 | 0.32, 1.15
NEW Nested case-control studies—Immune Function—Autoimmune Disease
Munger 2013^168^ | US Navy, MC active duty | Type 1 Diabetes Mellitus | 5.4 yrs | 25(OH)D | <75nmol/L | 45 | 102 | RR =1 | Reference | 0.03 | B
Munger 2013^168^ | US Navy, MC active duty | Type 1 Diabetes Mellitus | 5.4 yrs | 25(OH)D | | | | | | 0.03 | B
Munger 2013^168^ | US Navy, MC active duty | Type 1 Diabetes Mellitus | 5.4 yrs | 25(OH)D | 75–<100nmol/L | 76 | 236 | 0.6 | 0.38, 0.97 | 0.03 | B
Munger 2013^168^ | US Navy, MC active duty | Type 1 Diabetes Mellitus | 5.4 yrs | 25(OH)D | | | | | | 0.03 | B
Munger 2013^168^ | US Navy, MC active duty | Type 1 Diabetes Mellitus | 5.4 yrs | 25(OH)D | ≥100nmol/L | 65 | 220 | 0.56 | 0.35, 0.90 | 0.03 | B
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 0–6 mos | Multiple Sclerosis | NR | 25(OH)D | ≥75nmol/l | 192 | 576 | OR =0.39 | 0.16, 0.98 | NR | A
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 0–6 mos | Multiple Sclerosis | NR | 25(OH)D | | | | | | NR | A
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 0–6 mos | Multiple Sclerosis | NR | 25(OH)D | <75nmol/l | | | 1 | Reference | NR | A
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 0–6 mos | Multiple Sclerosis | NR | 25(OH)D
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 19–50 yrs | Multiple Sclerosis | NR | 25(OH)D | ≥75nmol/l | 37 | 222 | 1.8 | 0.53, 5.8 | NR | A
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 19–50 yrs | Multiple Sclerosis | NR | 25(OH)D | | | | | | NR | A
Salzer 2012 Risk of Multiple Sclerosis170 Gestational Risk factors of Multiple Sclerosis (GRoMS)170 | 19–50 yrs | Multiple Sclerosis | NR | 25(OH)D | <75nmol/l | | | 1 | Reference | NR | A
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | <55nmol/L | 39 | 94 | OR= 2.38 | 1.12, 5.07 | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | | | | | | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | >54 to 59nmol/L | 31 | 88 | 1.78 | 0.85, 3.74 | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | | | | | | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | >69nmol/L to 89nmol/L | 22 | 75 | 1.35 | 0.63, 2.89 | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | | | | | | 0.031 | B
Sorensen 2012^169^ | Pregnant | Type 1 Diabetes | NR | 25(OH)D | >89nmol/L | 17 | 71 | 1 | Reference | 0.031 | B
NEW Cohort study—Immune Function—Autoimmune Disease
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Islet Autoimmune (IA) | 9 mos | 25(OH)D | Inadequate (≤50) | 30 | 128 | HR=0.72 | 0.24,2.71 | 0.56 | A
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Islet Autoimmune (IA) | 9 mos | 25(OH)D | | 30 | 128 | | | 0.56 | A
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Islet Autoimmune (IA) | 9 mos | 25(OH)D | Adequate (>50 ) | 30 | 128 | 1.00 | Reference | 0.56 | A
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Type 1 Diabetes | NR | 25(OH)D | Inadequate (≤50) | 55 | 185 | HR=0.44 | 0.14, 1.45 | 0.18 | A
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Type 1 Diabetes | NR | 25(OH)D | | 55 | 185 | | | | A
Simpson 2011^171^ Diabetes Autoimmunity Study in the Young (DAISY) | 3–8 yrs | Type 1 Diabetes | NR | 25(OH)D | Adequate (>50 ) | 55 | 185 | 1.00 | Reference | | A
NEW Cohort studies—Immune function—Infectious Diseases
Belderbos 2011^153^ | 0–6 months | Respiratory Syncytial Virus Bronchiolitis | NR | 25(OH)D | <50nmol/L | 36 | | RR= 6.2 | 1.6, 24.9 | 0.13 | A
Belderbos 2011^153^ | 0–6 months | Respiratory Syncytial Virus Bronchiolitis | NR | 25(OH)D | | | | | | 0.13 | A
Belderbos 2011^153^ | 0–6 months | Respiratory Syncytial Virus Bronchiolitis | NR | 25(OH)D | 50–74nmol/L | 48 | | 1.3 | NR | 0.13 | A
Belderbos 2011^153^ | 0–6 months | Respiratory Syncytial Virus Bronchiolitis | NR | 25(OH)D | | | | | | 0.13 | A
Belderbos 2011^153^ | 0–6 months | Respiratory Syncytial Virus Bronchiolitis | NR | 25(OH)D | ≥75nmol/l | 72 | | 1 | Reference | 0.13 | A
Camargo 2011^154^ | 0–6 months | Respiratory Infection | NR | 25(OH)D | ≥75nmol/L | NR | NR | OR= 1 | Reference | | B
Camargo 2011^154^ | 0–6 months | Respiratory Infection | NR | 25(OH)D | | | | | | | B
Camargo 2011^154^ | 0–6 months | Respiratory Infection | NR | 25(OH)D | 25–74nmol/L | NR | NR | 1.35 | 0.88, 2.08 | | B
Camargo 2011^154^ | 0–6 months | Respiratory Infection | NR | 25(OH)D | | | | | | | B
Camargo 2011^154^ | 0–6 months | Respiratory Infection | NR | 25(OH)D | <25nmol/L | NR | NR | 2.04 | 1.13, 3.67 | 0.03 | B
Camargo 2011^154^ | 0–6 months | | | | | | | | | | B
Camargo 2011^154^ | 0–6 months | Any Infection | | | ≥75nmol/L | NR | NR | OR= 1 | Reference | | B
Camargo 2011^154^ | 0–6 months | Any Infection | | | | | | | | | B
Camargo 2011^154^ | 0–6 months | Any Infection | | | 25–74nmol/L | NR | NR | 1.49 | 0.92, 2.43 | | B
Camargo 2011^154^ | 0–6 months | Any Infection | | | | | | | | | B
Camargo 2011^154^ | 0–6 months | Any Infection | | | <25nmol/L | NR | NR | 2.36 | 1.17, 4.73 | 0.02 | B
Camargo 2011^154^ | 0–6 months | | | | | | | | | | B
Camargo 2011^154^ | 15 mos | Wheeze | | | per 10nmol/L | 331 | NR | OR=0.98 | 0.93, 1.02 | 0.3 | B
Camargo 2011^154^ | 15 mos | Wheeze | | | | | | | | | B
Camargo 2011^154^ | 3 yrs | Wheeze | | | per 10nmol/L | 472 | NR | 0.96 | 0.91, 1.00 | 0.04 | B
Camargo 2011^154^ | 3 yrs | Wheeze | | | | | | | | | B
Camargo 2011^154^ | 5 yrs | Wheeze | | | per 10nmol/L | 533 | NR | 0.95 | 0.91, 0.99 | 0.04 | B
Camargo 2011^154^ | 5 yrs | | | | | | | | | | B
Camargo 2011^154^ | 5 yrs | Incident asthma | | | per 10nmol/L | 181 | | OR =1.03 | 0.97, 1.10 | 0.02 | B
Sabetta 2010^159^ | 19–50 yrs | Acute Viral Respiratory Tract Infections | 4 months | 25(OH)D | ≥95 nmol/L | 3 | 18 | OR= 0.24 | 0.07, 0.87 | | A
Sabetta 2010^159^ | 19–50 yrs | Acute Viral Respiratory Tract Infections | 4 months | 25(OH)D | | | | | | | A
Sabetta 2010^159^ | 19–50 yrs | Acute Viral Respiratory Tract Infections | 4 months | 25(OH)D | <95 nmol/L | 81 | 180 | 1 | Reference | 0.015 | A
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | respiratory tract infections | 6 months | 25(OH)D | <25.0 | 74 | 180 | 3.41 | 1.57, 7.42 | 0.0008 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | respiratory tract infections | 6 months | 25(OH)D | 25.0–74.9 | 89 | 292 | 2.14 | 1.00, 4.58 | 0.0008 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | respiratory tract infections | 6 months | 25(OH)D | >=75.0 | 9 | 53 | 1.00 | Reference | 0.0008 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | | 6 months | 25(OH)D | | | | | | | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | acute nasopharyngitis | 6 months | 25(OH)D | <25.0 | 67 | 180 | 4.64 | 1.88, 11.44 | 0.0002 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | acute nasopharyngitis | 6 months | 25(OH)D | 25.0–74.9 | 75 | 292 | 2.71 | 1.11, 6.59 | 0.0002 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | acute nasopharyngitis | 6 months | 25(OH)D | >=75.0 | 6 | 53 | 1.00 | Reference | 0.0002 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | | 6 months | 25(OH)D | | | | | | | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | otitis media | 6 months | 25(OH)D | <25.0 | 10 | 180 | 3.06 | 0.38, 24.46 | 0.3625 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | otitis media | 6 months | 25(OH)D | 25.0–74.9 | 18 | 292 | 3.42 | 0.45, 26.15 | 0.3625 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | otitis media | 6 months | 25(OH)D | >=75.0 | 1 | 53 | 1.00 | Reference | 0.3625 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | | 6 months | 25(OH)D | | | | | | | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | bronchiolitis | 6 months | 25(OH)D | <25.0 | 9 | 180 | 2.74 | 0.34, 22.11 | 0.4819 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | bronchiolitis | 6 months | 25(OH)D | 25.0–74.9 | 19 | 292 | 3.62 | 0.47, 27.63 | 0.4819 | B
Shin 2013^155^ Cohort for Childhood Origin of Asthma and allergic diseases (COCOA) | | bronchiolitis | 6 months | 25(OH)D | >=75.0 | 1 | 53 | 1.00 | Reference | 0.4819 | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | per 1-unit change in log levels | 229 | 743 | 0.52 | 0.35, 0.79 | 0.002 | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | <25 | | 4 | 0.72 | 0.13, 3.94 | 0.7 | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | >=25 | | 739 | 1.00 | Reference | | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | <50 | | 152 | 1.54 | 1.07, 2.21 | 0.021 | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | >=50 | | 591 | 1.00 | Reference | | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | <75 | | 565 | 1.35 | 1.01, 1.82 | 0.043 | B
Science 2013^158^ | | respiratory tract infections | 156 days | 25(OH)D | >=75 | | 178 | 1.00 | Reference | | B
Schottker 2013^76^ ESTHER | | respiratory disease mortality | 9.5 yrs | 25(OH)D | <30 | 13 | 1439 | NR | NR | | B
Schottker 2013^76^ ESTHER | | respiratory disease mortality | 9.5 yrs | 25(OH)D | 30–50 | 26 | 4188 | NR | NR | | B
Schottker 2013^76^ ESTHER | | respiratory disease mortality | 9.5 yrs | 25(OH)D | >50 | 16 | 3927 | 1.00 | reference | | B
Thornton 2013^157^ Bogotá School Children Cohort | | earache/discharge with fever | 140 days | 25(OH)D | Deficient: <50 | nr | 48 | 2.36 | 1.26, 4.44 | | B
Thornton 2013^157^ Bogotá School Children Cohort | | earache/discharge with fever | 140 days | 25(OH)D | Insufficient: 50–<75 | nr | 222 | 0.35 | 0.19, 0.65 | | B
Thornton 2013^157^ Bogotá School Children Cohort | | earache/discharge with fever | 140 days | 25(OH)D | Sufficient: >=75 | nr | 205 | 1.00 | Reference | | B
Thornton 2013^157^ Bogotá School Children Cohort | | | 140 days | 25(OH)D | | | | | | | B
Thornton 2013^157^ Bogotá School Children Cohort | | cough with fever | 140 days | 25(OH)D | Deficient: <50 | nr | 48 | 0.77 | 0.57, 1.04 | | B
Thornton 2013^157^ Bogotá School Children Cohort | | cough with fever | 140 days | 25(OH)D | Insufficient: 50–<75 | nr | 222 | 0.53 | 0.44, 0.65 | | B
Thornton 2013^157^ Bogotá School Children Cohort | | cough with fever | 140 days | 25(OH)D | Sufficient: >=75 | nr | 205 | 1.00 | Reference | | B
Magnus 2013^156^ Norwegian Mother and Child Cohort Study | | asthma | 36 mos | 25(OH)D | 20 nmol/L increase in 25(OH)D | 489 | 1672 | 0.91 | 0.81, 1.02 | | B
Magnus 2013^156^ Norwegian Mother and Child Cohort Study | | asthma | 36 mos | 25(OH)D | <51 | 114 | 316 | 1.00 | Reference | | B
Magnus 2013^156^ Norwegian Mother and Child Cohort Study | | asthma | 36 mos | 25(OH)D | 51–75 | 187 | 584 | 0.84 | 0.61, 1.17 | | B
Magnus 2013^156^ Norwegian Mother and Child Cohort Study | | asthma | 36 mos | 25(OH)D | >75 | 188 | 771 | 0.67 | 0.48, 0.95 | | B
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study | | pneumonia | 9.8 yrs | 25(OH)D3 | Tertile 1: 8.9–33.8 Tertile 2: 33.9–50.7 Tertile 3: 50.8–112.8 | | | | | | B
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study | | pneumonia | 9.8 yrs | 25(OH)D3 | | 38 | 925 | 2.4 | 1.2, 4.9 | | B
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study | | pneumonia | 9.8 yrs | 25(OH)D3 | | 22 | 426 | 1.4 | 0.7, 2.8 | | B
Aregbesola 2013^160^ Kuopio Ischemic Heart Disease Risk Factor (KIHD) study | | pneumonia | 9.8 yrs | 25(OH)D3 | | 13 | 70 | 1.0 | Reference | | B

A Crude OR

Table 31b Vitamin D and immunologic outcomes: Results of autoimmune disease RCTs (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted HR, OR, RR | 95% CI | P for Trend | Study Quality
Racovan 2012^167^ WHI | Postmenopause | Rheumatoid Arthritis | 5.1 yrs | Vit D | 400IU + Ca 1000ng | 45 | 16283 | HR 1.15 | 0.75, 1.75 | 0.53 | A
Racovan 2012^167^ WHI | Postmenopause | Rheumatoid Arthritis | 5.1 yrs | Vit D | Placebo | 41 | 16238 | HR 1 | Reference | | A

Table 31c Vitamin D and immunologic outcomes: Results of infectious disease RCTs (continuous outcomes) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | Followup Duration | Intervention | No. Analyzed | Final mean | Final SD | Net Diff | Net Diff 95% CI | Study Quality
Li-Ng 2009^150^ | 18–80 years | Duration of Upper Respiratory Tract | 12 wks | Vit D 2000IU/day | 78 | 5.4 | 4.8 | +1.0 | -1,2, 1.4 | B
Li-Ng 2009^150^ | 18–80 years | Duration of Upper Respiratory Tract | 12 wks | Placebo | 70 | 5.3 | 3.1 | Reference | | B
Laaksi 2010^151^ | 18–28 years | Days absent from duty | 6 mos | Vit D3 400 IU | 80 | 2.2 | 3.2 | -0.8 | -1.9, 0.3 | B
Laaksi 2010^151^ | 18–28 years | Days absent from duty | 6 mos | Placebo | 84 | 3.0 | 4.0 | Reference | | B

Table 31d Vitamin D and immunologic outcomes: Results of infectious disease RCTs (dichotomous outcomes) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | Followup Duration (Time to Dx) | Vit D Measure | Intervention | No. of Events | No. in Category | Adjusted HR, OR, RR | 95% CI | P for Trend | Study Quality
Laaksi 2010^151^ | 18–28 years | Self-reported common cold symptoms | 6 months | Vit D3 | 400 IU | 45 | 80 | OR 1.17 | 0.63, 2.16 | 0.619 | B
Laaksi 2010^151^ | 18–28 years | Self-reported common cold symptoms | 6 months | Placebo | Placebo | 44 | 84 | 1 | Reference | | B
Laaksi 2010^151^ | 18–28 years | No days absent from duty | 6 months | Vit D3 | 400 IU | 41 | 80 | 1.89 | 1.01, 3.54 | 0.045 | B
Laaksi 2010^151^ | 18–28 years | No days absent from duty | 6 months | Placebo | Placebo | 30 | 84 | 1 | Reference | | B
Li-Ng 2009^150^ | 18–80 years | Upper Respiratory Tract | 12 weeks | Vit D | 2000IU/day | 28 | 78 | OR 0.79 | 0.41, 1.54 | 0.61 | B
Li-Ng 2009^150^ | 18–80 years | Upper Respiratory Tract | 12 weeks | | Placebo | 29 | 70 | 1 | Reference | | B
Manaseki-Holland 2012^149^ | infants aged 1–11 months | All Pneumonia First episode | NR | Vit D3 | 100,000IU | 260 | 1782 person years | IRR =1.065 | 0.895, 1.268 | 0.476 | A
Manaseki-Holland 2012^149^ | infants aged 1–11 months | All Pneumonia First episode | NR | Vit D3 | Placebo | 2445 | 1782 person years | 1 | Reference | | A
Manaseki-Holland 2012^149^ | infants aged 1–11 months | All Pneumonia repeat episode | | | 100,000IU | 138 | 2031 person years | IRR =1.685 | 1.282, 2.212 | <0.0001 | A
Manaseki-Holland 2012^149^ | infants aged 1–11 months | All Pneumonia repeat episode | | | Placebo | 82 | 2027 person years | 1 | Reference | | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | No of URTs per person | 18 months | Vit D3 & Placebo | 100,000IU | 3.7 | 161 | RR =0.97 | 0.85,1.11 | 0.65 | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | No of URTs per person | 18 months | Vit D3 & Placebo | Placebo | 3.7 | 161 | 1 | Reference | | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | No. of days if missed work per episode^*^ | 18 months | Vit D3 & Placebo | 100,000IU | 0.76 | 161 | RR 1.03 | 0.81, 1.30 | 0.82 | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | No. of days if missed work per episode^*^ | 18 months | Vit D3 & Placebo | Placebo | 0.76 | 161 | RR 1 | Reference | | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | Duration of symptoms | 18 months | Vit D3 & Placebo | 100,000IU | 12 | 161 | RR 0.96 | 0.73, 1.25 | 0.76 | A
Murdoch 2012^152^ VIDARIS | 18 yrs & older | Duration of symptoms | 18 months | Vit D3 & Placebo | Placebo | 12 | 161 | RR 1 | Reference | | A
Goldring 2013^161^ | | wheeze ever | 3 yrs | Vit D | either 800 IU ergocalciferol daily or 200,000 IU calciferol (single dose) | 11 | 56 | OR 0.56 | 0.20, 1.57 | 0.27 | A
Goldring 2013^161^ | | wheeze ever | 3 yrs | Vit D | control | 14 | 50 | OR 1.00 | Reference | | A
Goldring 2013^161^ | | lower respiratory tract infection | 3 yrs | Vit D | either 800 IU ergocalciferol daily or 200,000 IU calciferol (single dose) | 14 | 54 | OR 1.00 | 0.35, 2.91 | 1 | A
Goldring 2013^161^ | | lower respiratory tract infection | 3 yrs | Vit D | control | 11 | 50 | OR 1.00 | Reference | | A

* Included in Table 31d (dichotomous outcomes) because differences reported as relative risks.

[underlined: Infection]. The current report identified five RCTs that assessed the effect of supplemental vitamin D on infectious illnesses and nine cohort studies that assessed the association between 25(OH)D concentrations and risk for infectious illnesses.

A RCT in Afghanistan that randomized infants to 100,000IU every 3 months for 18 months or to placebo found no effect of supplementation on the incidence of pneumonia or subsequent episodes of pneumonia (rated A).149 A U.S. RCT that randomized healthy adults 18 to 80 years of age to 2000IU vitamin D per day or placebo for 3 months reported no effect of supplementation on the incidence or duration of upper respiratory infections (rated B).150 A Finnish study that randomized male soldiers, 18 to 28 years of age, to 400IU vitamin D per day or placebo for 6 months reported no effect on the acute prevalence of respiratory infection or self-reported cold symptoms but a small significant effect on the number of soldiers who had no days absent from duty (adjusted OR 1.89 [1.01, 3.54](rated B).151 The VIDARIS Study, a New Zealand RCT of 322 adults 18 years of age and older (mean age 47, 25% men) that randomized individuals to an initial 200,000 IU oral dose of vitamin D_3_, then 200,000 IU 1 month later, then 100,000 IU monthly or placebo for 18 months found no effect on the number of upper respiratory infections, days of work missed, or duration of symptoms (rated A).152

Nine prospective cohort studies were also identified for the current report that assessed the association of prenatal or baseline 25(OH)D concentrations with risk for infectious illness incidence or mortality.

A prospective cohort study in the Netherlands followed 156 infants from birth to 6 months of age and observed an association between low cord blood 25(OH)D concentrations and increased risk for respiratory syncytial virus bronchiolitis infections (rated B).153 A prospective cohort study in New Zealand followed a group of infants from birth and found an association of low cord blood serum 25(OH)D status with increased risk for respiratory infection at 3 months of age(rated B).154 A study in South Korea (the COCOA study) followed 525 newborns from birth to 6 months of age and found an association between low maternal cord blood 25(OH)D concentrations and increased risk for viral respiratory tract infections (p=0.0004) (rated B).155 A Norwegian prospective cohort study (MoBa) followed 1248 infants from birth to 36 months and observed an association between increasing midpregnancy maternal 25(OH)D concentrations and decreasing frequency and number of lower respiratory tract infections (rated B).156

A prospective cohort study of 475 school-age children, the Bogota School Children Cohort, observed an association between lower baseline serum 25(OH)D and increased risk for gastrointestinal tract infections (RR 2.05) and ear infections (RR 2.36) (rated B).157 A prospective cohort study in Canadian Hutterite communities followed 743 children 3 to 15 years of age for 6 months and found that younger age and lower serum 25(OH)D levels were associated with increased risk for viral RTI: Serum 25(OH)D levels <75 nmol/L increased the risk of viral RTI by 50% (hazard ratio [HR], 1.51; 95% confidence interval [CI], 1.10–2.07, P=.011) and levels <50 nmol/L increased the risk by 70% (HR, 1.67; 95% CI, 1.16–2.40, P=.006).158

A study of healthy U.S. adults followed for 4 months found an association between serum concentrations of 25(OH)D levels of 95nmol/L or higher and reduced risk for acute respiratory viral infections (rated A).159 The ESTHER Study of 9,578 German adults observed an association between vitamin D deficiency (defined by the authors as less than 30nmol/L) and an increased risk for respiratory disease mortality (HR2.50, 1.12, 5.56) (rated B).76 The Kuipio IHD Risk Factor Study, which followed 1,421 Finnish adults 53 to 73 years of age for 10 years, found a 2.6-fold increased risk for pneumonia in the lowest compared with the highest tertile of serum 25(OH)D (rated B).160

[underlined: Asthma, Atopy, and Eczema]. The current report identified one RCT and five prospective studies on the association between serum 25(OH)D and risk for asthma, atopy, and/or eczema. A UK RCT randomized 180 pregnant women at 27 weeks gestation to receive 0 or 800IU vitamin D daily for the remainder of pregnancy or one oral bolus of 20,000IU; at 3 years of age, no significant differences were seen among 158 offspring in their risk for ever having experienced wheeze, atopy, or eczema (rated A). 161

An Australian cohort study measured maternal and cord blood and found a significant association between cord blood 25(OH)D and decreased risk for eczema at 12 months of age. No association was seen with the results of skin prick tests for environmental and food allergies and IgE testing for food allergy. 162

A UK prospective study that followed 860 mother-infant pairs found no association between maternal serum 25(OH)D at 34 weeks gestation and the incidence of asthma, wheeze, or atopy at 6 years of age. 163

A longitudinal study in the Netherlands (PIAMA) is assessing associations of nutritional indicators with the risk for asthma in a large birth cohort. The most recent data suggest that rates of asthma and severe asthma at 8 years of age are higher among those whose serum 25(OH)D concentrations were in the lowest or middle tertile at 4 years of age. 164

The Avon Longitudinal Study of Parents and Children, a UK study, measured serum 25(OH)D2 and D3 (using HPLC/ tandem mass spectrometry) in some 14,500 children and found an association between lower levels of 25(OH)D2 at a mean age of 9.8 years and higher levels of wheeze, poor lung function, and flexural (antecubital) dermatitis at a mean age of 15.5 years; higher levels of 25(OH)D3 were associated with increased incidence of flexural dermatitis and wheezing but were not associated with lung function. Although the authors adjusted for confounders, they cautioned about interpreting the results without conducting trials. 165

The HUNT study analyzed the association of baseline vitamin D (and other nutrient) status in adults with the risk for asthma 11 years later using data from a large-scale longitudinal survey of health in Norway. They found no association of 25(OH)D concentrations with subsequent risk for asthma among women and a small association in men that disappeared after adjustment for confounders. 166

[underlined: Autoimmune.] The current report identified one RCT, three nested case control studies, and one prospective cohort study on the risk for autoimmune disease. A substudy of the WHI CaD trial that assessed participants at 5.1 years found no effect of supplementation with 400IU vitamin D and 1000mg calcium on women's risk for rheumatoid arthritis (rated A).167 A nested case control study among U.S. Navy and Marine Corps military personnel observed an association of Type 1 diabetes mellitus (DM) with serum 25(OH)D status at enlistment (310 cases and 310 matched controls) among white soldiers but not among black or Hispanic soldiers (rated B).168 A nested case control study conducted in Norway observed a trend toward an increasing association of type 1 DM in the first 15 years of life and decreased maternal 25(OH)D concentrations (rated C).169 A U.S. prospective cohort study of children at increased risk for developing Type 1 DM based on an Islet Autoimmune genetic marker, found no association of 25(OH)D concentrations at 9 months of age and subsequent risk for progression to DM(rated B). GRoMS, a nested case control study among individuals in Sweden who developed multiple sclerosis, found no association with maternal serum 25(OH)D concentrations but a possible association of adult levels with subsequent risk for the disease (rated B).170

In the original report, one study analyzed NHANES III data and showed no association between baseline 25(OH)D concentrations and infectious disease.85 NHANES III cohort represents general adult populations living in the United States. This study was rated quality C.

One cohort study from UK analyzed the serum 25(OH)D concentration in 440 white women in late pregnancy (˜33 wk) and found their infants' risk of eczema at age 9 months was higher in those mothers in the top quartile of the distribution of serum 25(OH)D (>50 nmol/L) compared with those at the bottom quartile (<30 nmol/L), although the results were not statistically significant.55 However, this analysis did not control for important potential confounders, and the 25(OH)D concentrations in children were not measured. This study was rated quality C.

#### Findings by Life Stage

- 0–6 mo
  No data in original study. A RCT in Afghanistan that randomized infants to 100,000IU every 3 months for 18 months or to placebo found no effect of supplementation on the incidence of pneumonia or subsequent episodes of pneumonia. A prospective cohort study in South Korea that followed 525 infants from birth to 6 months of age observed a significant association of low cord blood 25(OH)D and increased risk for respiratory tract infection. A prospective cohort study in the Netherlands followed 156 infants from birth to 6 months of age and observed an association between low cord blood 25(OH)D concentrations and increased risk for respiratory syncytial virus bronchiolitis infections. A prospective cohort study in New Zealand followed a group of infants from birth and found an association of low cord blood serum 25(OH)D concentrations with increased risk for respiratory infection at 3 months of age.
- 7 mo–2 y
  No data in original study. A RCT in the UK that randomized pregnant women at 27 weeks gestation to receive 0 or 800IU vitamin D daily for the remainder of pregnancy or one oral bolus of 20,000IU; at 3 years of age, no significant differences were seen among 158 offspring in their risk for ever having experienced wheeze, atopy, or eczema. A prospective cohort study in Norway that followed 1,248 children from birth to 36 months of age observed a significant association between maternal serum 25(OH)D at midpregnancy and the number and frequency of lower respiratory tract infections. An Australian cohort study measured maternal and cord blood and found a significant association between cord blood 25(OH)D and decreased risk for eczema at 12 months of age. No association was seen with the results of skin prick tests for environmental and food allergies and IgE testing for food allergy.162
- 3–8 y
  No data in original study. A RCT in Japan that randomized 344 3-year-old nursery school children to 1200IU vitamin D per day or placebo found a significant decrease in the incidence of Influenza A among supplemented children after 4 months; the effect was greater in children receiving no other vitamin supplementation at baseline. A prospective study that followed 475 Colombian school-age children for 1 year found an association between baseline serum 25(OH)D and risk for gastrointestinal and ear infections.157 A prospective study that followed 743 children (3 to 15 years of age) in Canadian Hutterite communities for 6 months observed an association between vitamin D deficiency and insufficiency and risk for viral respiratory tract infections.158 A UK prospective study that followed 860 mother-infant pairs found no association between maternal serum 25(OH)D at 34 weeks gestation and the incidence of asthma, wheeze, or atopy at 6 years of age.163 A longitudinal study in the Netherlands (PIAMA) is assessing associations of nutritional indicators with the risk for asthma in a large birth cohort. The most recent data suggest that rates of asthma and severe asthma at 8 years of age are higher among those whose serum 25(OH)D concentrations were in the lowest or middle tertile at 4 years of age.164
- 9–18 y
  No data in original study. The Avon Longitudinal Study of Parents and Children, a UK study, measured serum 25(OH)D2 and D3 (using HPLC/ tandem mass spectrometry) in some 14,500 children and found an association between lower levels of 25(OH)D2 at a mean age of 9.8 years and higher levels of wheeze, poor lung function, and flexural (antecubital) dermatitis at a mean age of 15.5 years; higher serum concentration of 25(OH)D3 were associated with higher incidence of flexural dermatitis and wheezing but were not associated with lung function. A nested case control study conducted in Norway observed a trend toward an increasing association of type 1 DM in the first 15 years of life and decreased maternal 25(OH)D concentrations. A U.S. prospective cohort study of children at increased risk for developing Type 1 DM based on an Islet Autoimmune genetic marker, found no association of 25(OH)D concentrations at 9 months of age and subsequent risk for progression to DM.
- 19–50 y
  Three RCTs found no effect of supplemental vitamin D on the risk for respiratory infections among adults. The HUNT study analyzed the association of baseline vitamin D (and other nutrient) status in adults with the risk for asthma 11 years later using data from a large-scale longitudinal survey of health in Norway; they found no association of 25(OH)D concentrations with subsequent risk for asthma among women and a small association in men that disappeared after adjustment for confounders. A nested case control study among U.S. Navy and Marine Corps military personnel observed an association of Type 1 diabetes mellitus (DM) with serum 25(OH)D concentrations at enlistment (310 cases and 310 matched controls) among white soldiers but not among black or Hispanic soldier. The original report identified NHANES III data that include people in this life stage. Analyses using NHANES III data (general adult populations living in the United States) showed no significant association between baseline 25(OH)D concentrations and infectious disease mortality.
- 51–70 y
  NHANES III data also include people in this life stage. The German prospective ESTHER study identified for the current report observed a significant inverse association between serum 25(OH)D concentrations and risk for respiratory disease mortality among adults 50 to 74 years of age. The Finnish Kuipio IHD Risk Factor Study observed an increased risk for pneumonia among the adults, 53 to 73 years of age in the lowest tertile of serum 25(OH)D.
- ≥71 y
  NHANES III data also include people in this life stage
- Postmenopause
  No data found in the original report. The current report identified a substudy of the WHI CaD trial that assessed participants at 5.1 years and found no effect of supplementation with 400IU vitamin D and 1000mg calcium on women's risk for rheumatoid arthritis
- Pregnant & lactating women
  Studies identified for the current report are described above for 0–6 months. One cohort study from UK identified in the original report analyzed the serum 25(OH)D concentration in white women in late pregnancy (˜33 wk) and showed a relationship between maternal 25(OH)D concentration and the risk of eczema in their children. However, this analysis did not control for important confounders, and the 25(OH)D concentrations in children were not measured.

### Vitamin D and Pregnancy-Related Outcomes

This section includes preeclampsia, small-for-gestational age, and preterm birth.

#### Preeclampsia

##### Synopsis

For the current report, two RCTs, two prospective studies, and five nested case control studies were identified that assessed the outcome of risk for preeclampsia. The RCTs, whose results were combined and reported in one article, found that supplementation with 2000IU or 4000IU vitamin D per day decreased the risk for preeclampsia. Both prospective studies observed an association between second-trimester serum 25(OH)D concentrations and decreased risk for preeclampsia. Three of the five nested case control studies observed an association between low 25(OH)D concentrations (<50nmol/L) and preeclampsia or severe preeclampsia.

In the original report, a single nested case-control study found an association between low 25(OH)D concentration (<37.5 nmol/L) early in pregnancy and preeclampsia. The study was rated B for methodological quality.

##### Detailed Presentation

(Tables 32a-c & 33a-c)

Table 32a Vitamin D and preeclampsia: Characteristics of observational studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle
Bodnar 2007^179^ PEPPS^A^ US (41°N) [17535985] | - Health status | Healthy | - Assay method | ELISA | Comparison of mean 25(OH)D levels in cases and controls | | x | x
Bodnar 2007^179^ PEPPS^A^ US (41°N) [17535985] | - Age range, y | 20–29 | - Assay method | ELISA | Comparison of mean 25(OH)D levels in cases and controls | | x | x
Bodnar 2007^179^ PEPPS^A^ US (41°N) [17535985] | - Male (%) | 0% | - Season blood drawn | ND | Comparison of mean 25(OH)D levels in cases and controls | | x | x
NEW Studies
Wei, 2012^174^ International Trial of Antioxidants in the Prevention of Preeclampsia (INTAPP) Canada | - Health status | 31.3% in high-risk group including chronic hypertension, prepregnancy diabetes, multiple pregnancy, or a history of preeclampsia | | | Preeclampsia stratified by 25(OH)D tertiles | | X | X | X | X | X
Wei, 2012^174^ International Trial of Antioxidants in the Prevention of Preeclampsia (INTAPP) Canada | - Mean age (SD), y | 30.3 (4.8) | | | Preeclampsia stratified by 25(OH)D tertiles | | X | X | X | X | X
Wei, 2012^174^ International Trial of Antioxidants in the Prevention of Preeclampsia (INTAPP) Canada | - Male (%) | 0% | | | Preeclampsia stratified by 25(OH)D tertiles | | X | X | X | X | X
Shand, 2010^177^ EMMA Vancouver, Canada | - Health status | nd | | | Preeclampsia stratified by 25(OH)D medians | X | X | X | | X | X
Shand, 2010^177^ EMMA Vancouver, Canada | - Mean age (SD), y | nd | | | Preeclampsia stratified by 25(OH)D medians | X | X | X | | X | X
Shand, 2010^177^ EMMA Vancouver, Canada | - Male (%) | 0% | | | Preeclampsia stratified by 25(OH)D medians | X | X | X | | X | X
Baker, 2010^175^ US Chapel Hill, NC | - Health status | Healthy | | | Severe preeclampsia stratified by 25(OH)D tertiles | | X | X | | X
Baker, 2010^175^ US Chapel Hill, NC | - Mean age (range), y | 28 (23–34) | | | Severe preeclampsia stratified by 25(OH)D tertiles | | X | X | | X
Baker, 2010^175^ US Chapel Hill, NC | - Male (%) | 0% | | | Severe preeclampsia stratified by 25(OH)D tertiles | | X | X | | X
Powe, 2010^178^ US Boston, MA | - Health status | nd | | | Severe preeclampsia stratified by 25(OH)D quartiles | | X | | | X
Powe, 2010^178^ US Boston, MA | - Mean age (SD), y | 30.4 (SD 6) | | | Severe preeclampsia stratified by 25(OH)D quartiles | | X | | | X
Powe, 2010^178^ US Boston, MA | - Male (%) | 0% | | | Severe preeclampsia stratified by 25(OH)D quartiles | | X | | | X
Woodham 2011^176^ Chapel Hill, UK | - Health status | nd | | | Severe preeclampsia stratified by 25(OH)D | | X | X | | X
Woodham 2011^176^ Chapel Hill, UK | - Mean age (range), y | 29 (25–33) | | | Severe preeclampsia stratified by 25(OH)D | | X | X | | X
Woodham 2011^176^ Chapel Hill, UK | - Male (%) | 0% | | | Severe preeclampsia stratified by 25(OH)D | | X | X | | X
Scholl 2013^173^ Camden Study Camden, New Jersey US | - Health status | Healthy/NR | | | Preeclampsia stratified by 25(OH)D quartiles | X | X | X | | | X
Scholl 2013^173^ Camden Study Camden, New Jersey US | - Mean age (SD), y | 22.8 (SD 5.4) | | | Preeclampsia stratified by 25(OH)D quartiles | X | X | X | | | X
Scholl 2013^173^ Camden Study Camden, New Jersey US | - Male (%) | 0% | | | Preeclampsia stratified by 25(OH)D quartiles | X | X | X | | | X
Wei 2013^172^ INTAPP Canada | - Health status | nd | | | Preeclampsia stratified by 25(OH)D medians | | X | X | | X | X
Wei 2013^172^ INTAPP Canada | - Mean age (SD), y | 28.68 (SD 5.44) | | | Preeclampsia stratified by 25(OH)D medians | | X | X | | X | X
Wei 2013^172^ INTAPP Canada | - Male (%) | 0% | | | Preeclampsia stratified by 25(OH)D medians | | X | X | | X | X

A Pregnancy Exposures and Preeclampsia Prevention Study

Table 32b Vitamin D and other pregnancy outcomes: Characteristics of observational studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle
NEW Studies
Baker 2011^182^ | Health status | Healthy | | Preterm birth 25(OH)D tertiles | | X | X | | X
Baker 2011^182^ | | Healthy | | Preterm birth 25(OH)D tertiles | | X | X | | X
Baker 2011^182^ | Mean age (Range), y | 33 (30–37) | | Preterm birth 25(OH)D tertiles | | X | X | | X
Baker 2011^182^ | | 33 (30–37) | | Preterm birth 25(OH)D tertiles | | X | X | | X
Baker 2011^182^ | Male (%) | 0 | | Preterm birth 25(OH)D tertiles | | X | X | | X
Bodnar, 2010^180^ US Pittsburgh, PA (latitude 40 degree N) | - Health status | Healthy | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | | X
Bodnar, 2010^180^ US Pittsburgh, PA (latitude 40 degree N) | - Mean age (Range), y | 21 (14–35) | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | | X
Bodnar, 2010^180^ US Pittsburgh, PA (latitude 40 degree N) | - Male (%) | 0% | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | | X
Burris 2012^45^ US, Massachusetts | - Health status | nd | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | X
Burris 2012^45^ US, Massachusetts | - Mean age (SD), y | 33 (SD 4.5) | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | X
Burris 2012^45^ US, Massachusetts | - Male (%) | 0% | | Small-for-gestational age births stratified by 25(OH)D tertiles | | X | X | | X
2013^181^ US | - Health status | nd | | Preterm birth at less than 35 wk and Preterm birth at less than 32 wk stratified by 25(OH)D sextiles | | X | X | | X | X
2013^181^ US | - Mean age (SD), y | NR | | Preterm birth at less than 35 wk and Preterm birth at less than 32 wk stratified by 25(OH)D sextiles | | X | X | | X | X
2013^181^ US | - Male (%) | 0% | | Preterm birth at less than 35 wk and Preterm birth at less than 32 wk stratified by 25(OH)D sextiles | | X | X | | X | X

Table 32c Vitamin D and preeclampsia: Characteristics of RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle
NEW Studies
Wagner 2013^42^ US | - Health status | nd | | Preeclampsia stratified by 25(OH)D tertiles | | X
Wagner 2013^42^ US | - Mean age (Range), y | 27 (18–41) | | Preeclampsia stratified by 25(OH)D tertiles | | X
Wagner 2013^42^ US | - Male (%) | 0% | | Preeclampsia stratified by 25(OH)D tertiles | | X

Table 33a Vitamin D and preeclampsia: Results of observational studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | Study Quality
Bodnar 2007^179,A^ PEPPS^B^ US (41°N) [17535985] | Pregnancy | Preeclampsia (55/1198; 4%)^C^ | ND | 25(OH)D^D^ | <37.5 (vs. >37.5) | 49 | 265 | 5 | 1.7, 14.1 | B
NEW Studies
Wei 2012^174^ | | preeclampsia | 12–18 weeks gestation | 25(OH)D | per SD increase | 32 | 697 | 0.79 | 0.52, 1.20 | A
Wei 2012^174^ | | preeclampsia | 12–18 weeks gestation | 25(OH)D | <50 | 15 | 272 | 1.24 | 0.58, 2.67 | A
Wei 2012^174^ | | preeclampsia | 12–18 weeks gestation | 25(OH)D | >50 | 17 | 425 | 1.00 | Reference | A
Wei 2012^174^ | | preeclampsia | 24–26 weeks gestation | 25(OH)D | per SD increase | 28 | 604 | 0.68 | 0.44, 1.05 | A
Wei 2012^174^ | | preeclampsia | 24–26 weeks gestation | 25(OH)D | <50 | 19 | 236 | 3.24 | 1.37, 7.69 | A
Wei 2012^174^ | | preeclampsia | 24–26 weeks gestation | 25(OH)D | >50 | 9 | 368 | 1.00 | Reference | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | <37.5 | 10 | NR | 0.91 | 0.31, 2.62 | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | ≥37.5 | 18 | NR | 1.00 | Reference | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | <50 | 17 | NR | 1.39 | 0.54, 3.53 | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | ≥50 | 11 | NR | 1.00 | Reference | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | <75 | 21 | NR | 0.57 | 0.19, 1.66 | A
Shand 2010^177^ | | preeclampsia | 10–20 weeks gestation | 25(OH)D | ≥75 | 6 | NR | 1.00 | Reference | A
Baker 2010^175^ | Pregnant or lactating women | severe preeclampsia | NR | 25(OH)D | < 50 | 22 | 160 | 5.41 | 2.02, 14.52 | B
Baker 2010^175^ | Pregnant or lactating women | severe preeclampsia | NR | 25(OH)D | 50–74.9 | 10 | 51 | 2.16 | 0.85, 5.40 | B
Baker 2010^175^ | Pregnant or lactating women | severe preeclampsia | NR | 25(OH)D | ≥75 | 11 | 30 | 1.00 | Reference | B
Powe 2010^178^ | | severe preeclampsia | NR | 25(OH)D | Quartile 1 (ND) | 39 (overall) | 170 (overall) | 1.50 | 0.57, 3.96 | B
Powe 2010^178^ | | severe preeclampsia | NR | 25(OH)D | Quartile 2 (ND) | | | 1.04 | 0.39, 2.76 | B
Powe 2010^178^ | | severe preeclampsia | NR | 25(OH)D | Quartile 3 (ND) | | | 0.67 | 0.23, 1.91 | B
Powe 2010^178^ | | severe preeclampsia | NR | 25(OH)D | Quartile 4 (ND) | | | 1.00 | Reference | B
Scholl 2013^173^ Camden Study | | preeclampsia | 20 weeks gestation | 25(OH)D | <30 | 12 | 121 | 2.13 | 1.07, 4.26 | B
Scholl 2013^173^ Camden Study | | preeclampsia | 20 weeks gestation | 25(OH)D | 30–40 | 12 | 116 | 2.09 | 1.04, 4.22 | B
Scholl 2013^173^ Camden Study | | preeclampsia | 20 weeks gestation | 25(OH)D | 40–50 | 7 | 154 | 0.94 | 0.41, 2.17 | B
Scholl 2013^173^ Camden Study | | preeclampsia | 20 weeks gestation | 25(OH)D | >=50 | 38 | 750 | 1.00 | Reference | B
Wei 2013^172^ INTAPP | | preeclampsia | 24–26 weeks gestation | 25(OH)D | <50 nmol/L | NR | NR | 2.97 | 1.23, 7.20 | B
Wei 2013^172^ INTAPP | | preeclampsia | 24–26 weeks gestation | 25(OH)D | >=50 nmol/L | NR | NR | 1.00 | Reference | B
Woodham 2011^176^ | | severe preeclampsia | NR | 25(OH)D | | 41 | 164 | 0.95 | 0.94, 0.97 | B

A This is a nested case-control study.

B Pregnancy Exposures and Preeclampsia Prevention Study.

C Incidence obtained from the “parent” cohort study in which this case control study is nested.

D Early in pregnancy, approximately 30 wk. before outcome assessment.

Table 33b Vitamin D and other pregnancy outcomes: Results of observational studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome (n/N; Incidence) | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | Study Quality
Baker 2011^182^ | | preterm birth | NR | 25(OH)D | <50 nmol/L | 3 | 11 | 0.82 | 0.19, 3.57 | A
Baker 2011^182^ | | preterm birth | NR | 25(OH)D | | | | | | A
Baker 2011^182^ | | preterm birth | NR | 25(OH)D | 50–74.9 nmol/L | 8 | 32 | 0.87 | 0.34, 2.25 | A
Baker 2011^182^ | | preterm birth | NR | 25(OH)D | | | | | | A
Baker 2011^182^ | | preterm birth | NR | 25(OH)D | ≥75 nmol/L | 29 | 117 | 1.00 | Reference | A
Bodnar 2010^180^
white women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | <37.5 nmol/L | 8 | 11 | 7.5 | 1.8, 31.9 | A
white women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | | | | | | A
white women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | 37.5–75 nmol/L | 27 | 134 | 1.0 | Reference | A
white women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | | | | | | A
white women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | >75 nmol/L | 42 | 128 | 2.1 | 1.2, 3.8 | A
white women | Pregnant or lactating women
black women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | <37.5 nmol/L | 17 | 65 | 1.5 | 0.6, 3.5
black women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D
black women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | 37.5–75 nmol/L | 13 | 63 | 1.0 | Reference
black women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D
black women | Pregnant or lactating women | Small-for-gestational age births | NR | 25(OH)D | >75 nmol/L | 4 | 11 | 2.2 | 0.5, 9.0
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | < 75 | 42 | 85 | 1.0 | Reference | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | >=75 | 33 | 126 | 0.4 | 0.2, 0.8 | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | per 1-SD increase | 75 | 211 | 0.5 | 0.3, 0.8 | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | Q1 (median 43.6) | 27 | 52 | 1.0 | Reference | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | Q2 (median 72.7) | 24 | 53 | 1.0 | 0.4, 2.5 | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | Q3 (median 95.4) | 15 | 53 | 0.4 | 0.2, 1.1 | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 35 wk | 24–28 weeks gestation | 25(OH)D | Q4 (median 116) | 9 | 53 | 0.2 | 0.1, 0.7 | A
Bodnar 2013^181^ | | | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | < 75 | 16 | 85 | 1.0 | Reference | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | >=75 | 9 | 126 | 0.2 | 0.1, 0.6 | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | per 1-SD increase | 25 | 211 | 0.4 | 0.2, 0.8 | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | Q1 (median 43.6) | 10 | 52 | 1.0 | Reference | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | Q2 (median 72.7) | 7 | 53 | 0.5 | 0.1, 1.7 | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | Q3 (median 95.4) | 6 | 53 | 0.4 | 0.1, 1.5 | A
Bodnar 2013^181^ | | preterm birth at less than 32 wk | | | | | | | | A
Bodnar 2013^181^ | | Q4 (median 116) | | | 2 | 53 | 0.1 | 0.02, 0.7 | | A

Table 33c Vitamin D and preeclampsia: results of RCTs (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | Followup Duration | Intervention | No. of Events | No. in Category | Adjusted HR, OR, RR | 95% CI | P for Trend | Study Quality
Wagner 2013^42^ | | Preeclampsia | NR | 2000 IU | 9 | 201 | RR 0.55 | 0.22, 1.34 | 0.43 | B
Wagner 2013^42^ | | Preeclampsia | NR | | | | | | | B
Wagner 2013^42^ | | Preeclampsia | NR | 4000 IU | 4 | 193 | RR 0.25 | 0.08, 0.80 | 0.05 | B
Wagner 2013^42^ | | Preeclampsia | NR | | | | | | | B
Wagner 2013^42^ | | Preeclampsia | NR | control | 9 | 110 | RR 1.00 | Reference | | B

In the current report, two RCTs, whose results were combined and reported in one article, found that supplementation with 2000IU or 4000IU vitamin D per day decreased the risk for preeclampsia.

The U.S. NICHD and Thrasher trials randomized 504 women to receive 0, 2000, or 4000IU vitamin D per day in addition to their prenatal vitamins. Supplementation with 4000IU increased serum 25(OH)D concentrations and resulted in a trend toward lower rates of preeclampsia; increasing maternal serum 25(OH)D concentrations were strongly associated with decreased risk for preeclampsia (OR 0.77, 95% CI 0.57, 1.06) (rated B). 42

Two prospective cohort studies observed an inverse association between second-trimester serum 25(OH)D concentrations and risk for preeclampsia. One Chinese study that followed 697 women found that low serum 25(OH)D at 12 to 18 weeks gestation and 24 to 26 weeks gestation was associated with a higher risk for preeclampsia (p<0.05) (rated B).172 A U.S. study that followed a cohort of 1,141 pregnant women in Camden NJ found that serum 25(OH)D less than 50nmol/L at study entry (13.7±5.7 weeks gestation) was associated with an increased risk for preeclampsia (OR 2.86, 95% CI 1.28, 6.41) (rated B).173

Five nested case control studies assessed the association between maternal serum 25(OH)D concentrations during early or mid-gestation and the risk for subsequent preeclampsia. Three of these studies observed an association between maternal 25(OH)D concentrations and subsequent risk for preeclampsia. One Canadian study of 1,301 women (cases and controls) found that the risk for preeclampsia was increased for women with low 25(OH)D concentrations (<50nmol/L vs. ≥50nmol/L) during the second trimester but not during the first trimester.174 A U.S. study of 51 women diagnosed with preeclampsia and 204 matched controls (in a cohort of 3,992 women) that divided midgestational 25(OH)D status into tertiles found that low serum 25(OH)D concentrations (<37.5 nmol/L) was associated with severe preeclampsia.175 A U.S. study aimed at identifying placental growth factors that, combined with 25(OH)D concentrations, would predict the risk for preeclampsia found that low maternal 25(OH)D concentrations, by itself, had some predictive power regarding the risk for preeclampsia.176 Two additional nested case control studies, the Canadian EMMA study and a U.S. study found that low first trimester maternal 25(OH)D levels were not associated with risk for preeclampsia.177,178

In the original report, a nested case-control study evaluated the association between 25(OH)D concentration and risk of preeclampsia.179 The study found an association between 25(OH)D concentrations less than 37.5 nmol/L (measured approximately 30 wk before outcome assessment) and increased risk of preeclampsia. The study was rated B for methodological quality.

##### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  Not applicable
- 3–8 y
  Not applicable
- 9–18 y
  Not applicable
- 19–50 y
  See pregnant and lactating women.
- 51–70 y
  Not applicable
- ≥71 y
  Not applicable
- Postmenopause
  Not applicable
- Pregnant & lactating women
  For the current report, one RCT reported that higher dose vitamin D supplementation decreased the risk for preeclampsia. Two prospective cohort studies and three nested case control studies found an association between low 25(OH)D concentrations at mid-gestation and the risk for preeclampsia, and two nested case control studies found no association with first trimester 25(OH)D concentrations and risk for preeclampsia. In the original report, a single nested case-control study found an association between low 25(OH)D concentration (<37.5 nmol/L) early in pregnancy and preeclampsia.

#### Other Outcomes

##### Synopsis

In the current report, we identified two cohort studies that assessed the association between maternal serum 25(OH)D concentrations and the risk for giving birth to a small-for-gestational-age (SGA) infant and one cohort study and one nested case control study that assessed the association with preterm birth. One of the two cohort studies found an increase in the risk for SGA at the lowest concentration range of maternal serum 25(OH)D compared with higher serum vitamin D concentrations among both white and black women; the other study observed a U-shaped association between serum 25(OH)D and the risk for risk for SGA among white women. The prospective study observed an increase in the risk for preterm birth among women carrying twins whose serum 25(OH)D was less than 75nmol/L. The nested case control study that assessed the association with preterm birth found no significant association.

We found no studies for the current report on the relationship of maternal serum 25(OH)D and pregnancy hypertension.

The original report did not identify any eligible studies on the relationship of vitamin D with or without calcium and high blood pressure, preterm birth, or small-for-gestational-age infants.

##### Detailed Presentation

(Tables 32a-c & 33a-c)

In the current report, two cohort studies assessed the association between maternal serum 25(OH)D concentrations and the risk for giving birth to a SGA infant and one nested case control study that assessed the association with preterm birth.

One U.S. cohort study of 1,067 white and 236 black mother-infant pairs found an association of serum 25(OH)D less than 25nmol/L with an increased risk for SGA, compared with serum 25(OH)D of 25nmol/L or greater (adjusted OR 3.94 [1,51, 10.29]). When the data were further adjusted for race, the adjusted odds ratio fell slightly (3.17 [1.16, 8.63]). 45

The other cohort study, which assessed 412 mother-infant pairs, found a U-shaped association between serum 25(OH)D and risk for SGA among white mothers. The lowest risk was observed from 60 to 80 nmol/L; compared with serum 25(OH)D 37.5–75 nmol/L, SGA odds ratios (95% CI) for levels,37.5 and.75 nmol/L were 7.5 (1.8, 31.9) and 2.1 (1.2, 3.8), respectively. This association was not seen among black mothers (study rated A). 180

A multisite U.S. prospective study of 211 twin pregnancies found that late second trimester serum 25(OH)D concentrations of 75nmol/L or greater were associated with a decreased risk for preterm birth (aOR 0.40, 95%CI 0.2, 0.8) (rated A).181 One Canadian nested case control study of 227 mother infant pairs, the EMMA study, found no association of low maternal serum 25(OH)D (<37.5nmol/L) at 10 to 21 weeks gestation with the risk for preterm birth.177

##### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  Not applicable
- 3–8 y
  Not applicable
- 9–18 y
  Not applicable
- 19–50 y
  See pregnant and lactating women.
- 51–70 y
  Not applicable
- ≥71 y
  Not applicable
- Postmenopause
  Not applicable
- Pregnant & lactating women
  In the current report, we identified two cohort studies that assessed the association between maternal serum 25(OH)D concentrations and the risk for giving birth to a small-for-gestational-age (SGA) infant and one nested case control study that assessed the association with preterm birth. The two cohort studies found an increase in the risk for SGA at the lowest concentration range of maternal serum 25(OH)D compared with higher serum vitamin D concentrations. One study found this increase in risk for both white and black mothers, whereas the other study found that the risk increased only for white mothers. A prospective study observed an increase in the risk for preterm birth among women carrying twins whose serum 25(OH)D was less than 75nmol/L at mid-gestation. A nested case control study that assessed the association of serum 25(OH)D with preterm birth found no significant association. We found no studies for the current report on the relationship of maternal serum 25(OH)D and pregnancy hypertension.

### Vitamin D and Clinical Outcomes of Bone Health

The current report sought RCTs and observational studies reporting on the association between vitamin D intervention or exposure and clinical outcomes related to bone health, including rickets, fractures, muscle strength, and falls, published since the original report.

For bone health outcomes, the original report (e.g., bone mineral density, fracture, fall or muscle strength) relied on a recent comprehensive systematic review (Effectiveness and Safety of Vitamin D in Relation to Bone Health) performed by the Ottawa EPC (Table 28).8 Because the Ottawa's EPC report did not report separate analyses for the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation were presented in the “Combined Vitamin D and Calcium” section. The Ottawa EPC report also did not report separate analyses by study designs (i.e., RCTs, prospective cohorts, before and after study, and case-control studies), although the report primarily included RCTs.

The Ottawa EPC report was updated with literature published between January 2006 and September 2008, selected according to our eligibility criteria. Only RCTs qualified for inclusion.

#### Rickets

##### Synopsis

No new studies assessing the association between vitamin D intervention or exposure and the risk for rickets met the inclusion criteria for the current report.

The Ottawa EPC report concluded that there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). According to the report, there is inconsistent evidence to determine whether there is a threshold concentration of serum 25(OH)D above which rickets do not occur.

Our updated search did not identify new RCTs examining the effect of vitamin D supplementation on rickets.

##### Detailed Presentation

(Table 34)

Table 34 Summary of systematic review of the effect of vitamin D on bone health (not updated from original report)

Author Year [PMID] | Cranney 2007^8^ [18088161]
Design | Systematic review of RCTs and observational studies
Population | - Include all ages; - Exclude secondary causes of osteoporosis (e.g., glucocorticoid-induced, renal or liver disease); - Exclude studies on the treatment of vitamin D-dependent rickets (to minimize clinical heterogeneity as treatments is often nondietary sources of vitamin D)
Intervention (Exposure) and Comparator | Intervention (Exposure):; - Include vitamin D_2_ or D_3_ with or without calcium.; - Exclude vitamin D preparations, calcitriol, α-calcidol (because they are not nutritional supplements, and have different safety profile); Comparator:; - No vitamin D or lower doses/levels of vitamin D
Results | See text for summary results for the following outcomes in both vitamin D and combined vitamin D and calcium sections of the report:; - Rickets; - Fractures, falls, or performance measures; - Bone mineral density or bone mineral contents; - How does dietary intake of vitamin D from fortified foods and vitamin D supplementation affect serum 25(OH)D Concentrations; - Adverse events
Comments | Case-control studies were included but always summarized separately from cohort studies and RCTs. Meta-analyses were performed to pool results from RCTs only.
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | No | Publication bias assessed? | No
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

###### Ottawa EPC Report: Rickets—infants (0 through 12 months) and young children (1 through 5 years)

Overall, there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). There is inconsistent evidence to determine whether there is a threshold concentration of serum 25(OH)D above which rickets do not occur.

Six studies (one RCT, three before-after and two case-control studies) reported mean or median serum 25(OH)D concentrations < 30 nmol/L in children with rickets whereas the other studies reports the mean or median 25(OH)D concentrations were above 30 nmol/L (and up to 50 nmol/L). In seven of eight case-control studies, serum 25(OH)D concentrations were lower in the children with rickets compared with controls.

##### Findings by Life Stage

- 0–6 mo
  The Ottawa EPC report included infants and young children and concluded that there is fair evidence for an association between low serum 25(OH)D concentrations and confirmed rickets, regardless of the types of assay measures of 25(OH)D concentrations (RIA, CPBA, HPLC). There were no new data since the Ottawa EPC report.
- 7 mo–2 y
  The Ottawa EPC report included infants and young children. There were no new data since the Ottawa EPC report.
- 3–8 y
  The Ottawa EPC report included young children. There were no new data since the Ottawa EPC report.
- 9–18 y
  Not reviewed
- 19–50 y
  Not reviewed
- 51–70 y
  Not reviewed
- ≥71 y
  Not reviewed
- Postmenopause
  Not reviewed
- Pregnant & lactating women
  Not reviewed

#### Fractures, Falls, or Performance Measures

##### Synopsis

The current report did not identify any new trials that assessed the effect of interventions of vitamin D alone on fracture risk; eight observational studies assessed the association between serum 25(OH)D and fracture risk; (interventions that assessed the effect of vitamin D and calcium are described in Table 59 and the accompanying text). We identified two RCTs that examined the effect of supplementation with vitamin D on the risk for falls, and two RCTs on muscle strength; four prospective cohort studies assessed the association between serum(OH)D concentrations and muscle strength, and one prospective cohort study assessed the association between serum 2(OH)D and falls. The RCTs reported significant effects of vitamin D supplementation on decreasing risk for falls and increasing muscle strength. Three of the four prospective cohort studies reported associations between lower serum 25(OH)D and decreased or decreasing muscle strength and performance; the fourth saw no association. An association was seen between lower 25(OH)D concentrations and increased risk for falls. The studies are described in detail below.

Table 59 Combined vitamin D and calcium and bone health: Results of RCTs published after the Ottawa EPC report (stress fracture) (formerly Table 98) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (ITT) | 1° | 2 mo | Vit D 800 IU + Ca 200 mg | 139 | 2626 | RR (Vit D+Ca)/ placebo | 0.8 | 0.64, 0.99 | 0.026 | B
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (ITT) | 1° | 2 mo | | | | | | | | B
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (ITT) | 1° | 2 mo | Placebo | 170 | 2575 | | | | | B
Lappe 2008^259^ [18433305] | 17–35 y women | | | | | | | | | | | B
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (per protocol) | 1° | 2 mo | Vit D 800 IU + Ca 200 mg | 126 | 1852 | Adjusted OR (Vit D+Ca)/ placebo | 0.79 | 0.62, 1.01 | 0.059 | B
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (per protocol) | 1° | 2 mo | | | | | | | | B
Lappe 2008^259^ [18433305] | 17–35 y women | Stress fracture from Navy training (per protocol) | 1° | 2 mo | Placebo | 160 | 1848 | | | | | B
NEW Studies
Prentice 2013^2^ WHI US (various) | | Total fractures | 1° | 7.2 yrs | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate | 872 | 7718 | HR | 0.97 | 0.88, 1.07 | NR | A
Prentice 2013^2^ WHI US (various) | | Total fractures | 1° | 7.2 yrs | placebo | 870 | 7584 | | 1.00 | Reference | | A
Prentice 2013^2^ WHI US (various) | | | | | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Hip fracture | | | 1000mg/day of Ca & 400IU/day of Vit D3 | 68 | 7718 | HR | 0.86 | 0.62, 1.20 | NR | A
Prentice 2013^2^ WHI US (various) | | Hip fracture | | | Placebo | 80 | 7584 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | any fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 78 | 1586 | HR | 0.83 | 0.61, 1.12 | | A
Salovaara 2010^260^ OSTPRE Study nd | | any fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | any fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 94 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | any nonvertebral fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 71 | 1586 | HR | 0.87 | 0.63, 1.19 | | A
Salovaara 2010^260^ OSTPRE Study nd | | any nonvertebral fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | any nonvertebral fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 82 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | any osteoporotic fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 42 | 1586 | HR | 0.81 | 0.54, 1.22 | | A
Salovaara 2010^260^ OSTPRE Study nd | | any osteoporotic fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | any osteoporotic fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 52 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | distal forearm fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 23 | 1586 | HR | 0.70 | 0.41, 1.20 | | A
Salovaara 2010^260^ OSTPRE Study nd | | distal forearm fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | distal forearm fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 32 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | proximal humerus fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 6 | 1586 | HR | 1.01 | 0.32, 3.14 | | A
Salovaara 2010^260^ OSTPRE Study nd | | proximal humerus fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | proximal humerus fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 6 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | hip fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 4 | 1586 | HR | 2.23 | 0.41, 12.29 | | A
Salovaara 2010^260^ OSTPRE Study nd | | hip fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | hip fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 2 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | vertebral fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 9 | 1586 | HR | 0.67 | 0.29, 1.58 | | A
Salovaara 2010^260^ OSTPRE Study nd | | vertebral fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | vertebral fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 13 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | upper extremity fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 41 | 1586 | HR | 0.75 | 0.49, 1.16 | | A
Salovaara 2010^260^ OSTPRE Study nd | | upper extremity fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | upper extremity fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 50 | 1609 | | 1.00 | Reference | | A
Salovaara 2010^260^ OSTPRE Study nd | | | | | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | lower extremity fracture | 1° | 3.01 yrs | 400 IU cholecalciferol + 500 mg calcium carbonate | 22 | 1586 | | 1.02 | 0.58, 1.80 | | A
Salovaara 2010^260^ OSTPRE Study nd | | lower extremity fracture | 1° | 3.01 yrs | | | | | | | | A
Salovaara 2010^260^ OSTPRE Study nd | | lower extremity fracture | 1° | 3.01 yrs | control (no intervention or placebo) | 20 | 1609 | | 1.00 | Reference | | A
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No falls | 1° | 3 y | 1g/daily & 800 IU/daily | 754 | 1566 | OR | 1.05 | 0.91, 1.20 | >0.05 | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No falls | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No falls | 1° | 3 y | Placebo | 740 | 1573 | OR | 1.00 | Reference | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls (≤1) | 1° | 3 y | 1g/daily & 800 IU/daily | 1109 | 1566 | OR | 1.13 | 0.97, 1.32 | >0.05 | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls (≤1) | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls (≤1) | 1° | 3 y | Placebo | 1073 | 1573 | OR | 1.00 | Reference | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No fall requiring medical attention (FRMA) | 1° | 3 y | 1g/daily & 800 IU/daily | 1308 | 1566 | OR | 0.84 | 0.70, 1.01 | >0.05 | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No fall requiring medical attention (FRMA) | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—No fall requiring medical attention (FRMA) | 1° | 3 y | Placebo | 1274 | 1573 | OR | 1.00 | Reference | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls requiring medical attention (FRMA) (≤1) | 1° | 3 y | 1g/daily & 800 IU/daily | 1488 | 1566 | OR | 0.72 | 0.53, 0.97 | 0.03 | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls requiring medical attention (FRMA) (≤1) | 1° | 3 y | | | | | | | | C
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | | Primary—Falls requiring medical attention (FRMA) (≤1) | 1° | 3 y | Placebo | 1466 | 1573 | OR | 1.00 | Reference | | C

Note: Outcomes cells are shaded for the Control rows.

Overall, the Ottawa EPC report, summarized in the original report, concluded that the associations between serum 25(OH)D concentrations and the risk of fractures, falls, and performance measures among postmenopausal women or elderly men are inconsistent.8

Findings from three additional RCTs (published after the Ottawa EPC report)183-185 also did not show significant effects of either vitamin D_2_ or D_3_ supplementation (daily doses ranged from 400 IU to 822 IU) in reducing the risk of total fractures or falls in elderly populations (≥71 years old).

##### Detailed Presentation

(Tables 35a-d & 36a-d)

Table 35a Vitamin D and bone health: Characteristics of RCTs published after the Ottawa EPC report (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lyons 2007^185^ South Wales, UK (52°N) [17473911] | - Health status | Living in care facilities including some elderly with mobility, cognitive, visual, hearing or communication impairments | nd | Vit D_2_ 100,000 IU 4-monthly vs. placebo | 80% (percentage of occasions observed to take tablets)
Lyons 2007^185^ South Wales, UK (52°N) [17473911] | - Mean age (range), y | 84 (62–107) | nd | Vit D_2_ 100,000 IU 4-monthly vs. placebo | 80% (percentage of occasions observed to take tablets)
Lyons 2007^185^ South Wales, UK (52°N) [17473911] | - Male (%) | 23.7 | nd | Vit D_2_ 100,000 IU 4-monthly vs. placebo | 80% (percentage of occasions observed to take tablets)
Burleigh 2007^184^ Scotland (55° 57'N) [17656420] | - Health status | Inpatient with high levels of comorbidity, mortality and polypharmacy | 25(OH)D: 22.0 nmol/L | Vit D_3_ 800 IU/d + Ca carbonate 1200 mg/d vs. Ca carbonate 1200 mg | Ca group=87%, Vit D+Ca group=89% (total study drug taken/total study drug prescribed, as recorded in drug prescription charts)
Burleigh 2007^184^ Scotland (55° 57'N) [17656420] | - Mean age (SD), y | 83 (7.6) | 25(OH)D: 22.0 nmol/L | Vit D_3_ 800 IU/d + Ca carbonate 1200 mg/d vs. Ca carbonate 1200 mg | Ca group=87%, Vit D+Ca group=89% (total study drug taken/total study drug prescribed, as recorded in drug prescription charts)
Burleigh 2007^184^ Scotland (55° 57'N) [17656420] | - Male (%) | 40 | 25(OH)D: 22.0 nmol/L | Vit D_3_ 800 IU/d + Ca carbonate 1200 mg/d vs. Ca carbonate 1200 mg | Ca group=87%, Vit D+Ca group=89% (total study drug taken/total study drug prescribed, as recorded in drug prescription charts)
Bunout 2006^183^ Chile (32°S) [16797903] | - Health status | Healthy | 25(OH)D: ≤40 nmol/L | Ca 800 mg/d vs. Ca 800 mg/d + Vit D 400 IU/d (with and without exercise training) | 92% (tablet counting)
Bunout 2006^183^ Chile (32°S) [16797903] | - Mean age (SD), y | 76 (4) | 25(OH)D: ≤40 nmol/L | Ca 800 mg/d vs. Ca 800 mg/d + Vit D 400 IU/d (with and without exercise training) | 92% (tablet counting)
Bunout 2006^183^ Chile (32°S) [16797903] | - Male (%) | 11.6 | 25(OH)D: ≤40 nmol/L | Ca 800 mg/d vs. Ca 800 mg/d + Vit D 400 IU/d (with and without exercise training) | 92% (tablet counting)
NEW Studies
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Health status | Healthy | 25(OH)D: 22.0 nmol/L | 1000mg and 800 IU daily vs. 1000mg daily | >80% (noncompliant participants excluded)
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Mean age (SD), y | 77 (SD 4) | 25(OH)D: 22.0 nmol/L | 1000mg and 800 IU daily vs. 1000mg daily | >80% (noncompliant participants excluded)
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Male (%) | 26% | 25(OH)D: 22.0 nmol/L | 1000mg and 800 IU daily vs. 1000mg daily | >80% (noncompliant participants excluded)
Prince, 2008^187^ Perth, Australia | - Health status | Vitamin d deficient/depleted | 25(OH)D: ≤40 nmol/L | 1000mg of Ca & 1000 IU of Vit D2 daily vs. 1000mg of Ca & placebo daily | 92% (tablet counting)
Prince, 2008^187^ Perth, Australia | - Mean age (SD), y | 77.4 (5) Range: 0–90 | 25(OH)D: ≤40 nmol/L | 1000mg of Ca & 1000 IU of Vit D2 daily vs. 1000mg of Ca & placebo daily | 92% (tablet counting)
Prince, 2008^187^ Perth, Australia | - Male (%) | 0% | 25(OH)D: ≤40 nmol/L | 1000mg of Ca & 1000 IU of Vit D2 daily vs. 1000mg of Ca & placebo daily | 92% (tablet counting)

Table 35b Vitamin D and muscle strength: Characteristics of RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
NEW Studies
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | - Health status | nd | serum vitamin D- placebo- 35.3+/-13.8 nmol/l, D3-34.25+/-11.0 nmol/l serum calcium-placebo- 9.4+/-0.4mg/dl, D3- 9.4+/-0.4mg/dl | Double placebo vs. 60,000 IU/week Vs. 500mg/twice daily & 60,000 IU/week | All completes were adherent
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | - Mean age (SD), y | 77.6 (SD 6.6) | serum vitamin D- placebo- 35.3+/-13.8 nmol/l, D3-34.25+/-11.0 nmol/l serum calcium-placebo- 9.4+/-0.4mg/dl, D3- 9.4+/-0.4mg/dl | Double placebo vs. 60,000 IU/week Vs. 500mg/twice daily & 60,000 IU/week | All completes were adherent
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | - Male (%) | nd | serum vitamin D- placebo- 35.3+/-13.8 nmol/l, D3-34.25+/-11.0 nmol/l serum calcium-placebo- 9.4+/-0.4mg/dl, D3- 9.4+/-0.4mg/dl | Double placebo vs. 60,000 IU/week Vs. 500mg/twice daily & 60,000 IU/week | All completes were adherent
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Health status | Healthy | Serum vitamin D level:55±18 nmol/L Calcium intake: 608±38 mg/d | 1000 mg & 800 IU daily Vs. 1000 mg daily | >80% (noncompliant participants excluded)
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Mean age (SD), y | 77 (SD 4) | Serum vitamin D level:55±18 nmol/L Calcium intake: 608±38 mg/d | 1000 mg & 800 IU daily Vs. 1000 mg daily | >80% (noncompliant participants excluded)
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | - Male (%) | 26% | Serum vitamin D level:55±18 nmol/L Calcium intake: 608±38 mg/d | 1000 mg & 800 IU daily Vs. 1000 mg daily | >80% (noncompliant participants excluded)
Ward, 2010^202^ Manchester, UK | - Health status | Healthy | total serum 25OHD placebo: 17.9 ± 7.4 nmol/l vit D group: 18.1 ± 8.0 nmol/l | 150,000 IU/ quarterly Vs. Placebo | 100%
Ward, 2010^202^ Manchester, UK | - Mean age (SD), y | 13.8 (SD 0.7) Range: 12–14 | total serum 25OHD placebo: 17.9 ± 7.4 nmol/l vit D group: 18.1 ± 8.0 nmol/l | 150,000 IU/ quarterly Vs. Placebo | 100%
Ward, 2010^202^ Manchester, UK | - Male (%) | 11.6 | total serum 25OHD placebo: 17.9 ± 7.4 nmol/l vit D group: 18.1 ± 8.0 nmol/l | 150,000 IU/ quarterly Vs. Placebo | 100%
Zhu, 2010^188^ Perth, Australia | - Health status | plasma 25(OH)D concentration less than 60 nmol/L | Serum 25(OH)D 17.7 ±10.5 nmol/L | 1,000 mg/d Ca +1,00 IU vit D2 Vs. 1,000 mg/d Ca | vitamin D group: 86.7% control group: 86.8%
Zhu, 2010^188^ Perth, Australia | - Mean age (SD), y | 77 (SD 4.8) | Serum 25(OH)D 17.7 ±10.5 nmol/L | 1,000 mg/d Ca +1,00 IU vit D2 Vs. 1,000 mg/d Ca | vitamin D group: 86.7% control group: 86.8%
Zhu, 2010^188^ Perth, Australia | - Male (%) | 0% | Serum 25(OH)D 17.7 ±10.5 nmol/L | 1,000 mg/d Ca +1,00 IU vit D2 Vs. 1,000 mg/d Ca | vitamin D group: 86.7% control group: 86.8%

Table 35c Vitamin D and muscle strength: Characteristics of prospective cohorts (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
NEW Studies
Dam, 2009^190^ Rancho Bernardo study California, US | - Health status | nd | serum vitamin D: men- 107.6±29.2 nmol/L, women- 100.8±33.1 nmol/L | 10–80 nmol/l 82.5–97.5 nmol/l 100–112.5 nmol/l 115–337.5 nmol/l Vs. 10–90 nmol/l 92.5–102.5 nmol/l 105–120 nmol/l 122.5–262.5 nmol/l | nd
Dam, 2009^190^ Rancho Bernardo study California, US | - Mean age (SD), y | 74.6 (SD 10.3) | serum vitamin D: men- 107.6±29.2 nmol/L, women- 100.8±33.1 nmol/L | 10–80 nmol/l 82.5–97.5 nmol/l 100–112.5 nmol/l 115–337.5 nmol/l Vs. 10–90 nmol/l 92.5–102.5 nmol/l 105–120 nmol/l 122.5–262.5 nmol/l | nd
Dam, 2009^190^ Rancho Bernardo study California, US | - Male (%) | 38% | serum vitamin D: men- 107.6±29.2 nmol/L, women- 100.8±33.1 nmol/L | 10–80 nmol/l 82.5–97.5 nmol/l 100–112.5 nmol/l 115–337.5 nmol/l Vs. 10–90 nmol/l 92.5–102.5 nmol/l 105–120 nmol/l 122.5–262.5 nmol/l | nd
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | - Health status | diabetes, cvd, copd, knee pain | 1/3– 25(OH)D <50nmol/L, 2/3– <75nmol/L | <50 nmol/L Vs. 50–<75 nmol/L Vs. ≥75 nmol/L | nd
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | - Mean age (SD), y | 74.7 (SD 2.9) | 1/3– 25(OH)D <50nmol/L, 2/3– <75nmol/L | <50 nmol/L Vs. 50–<75 nmol/L Vs. ≥75 nmol/L | nd
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | - Male (%) | 49% | 1/3– 25(OH)D <50nmol/L, 2/3– <75nmol/L | <50 nmol/L Vs. 50–<75 nmol/L Vs. ≥75 nmol/L | nd
Menant, 2012^193^ Sydney, Australia | - Health status | Healthy | Serum vitamin D– 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Menant, 2012^193^ Sydney, Australia | - Mean age (SD), y | 78 (SD 4.6) Range: 70–90 | Serum vitamin D– 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Menant, 2012^193^ Sydney, Australia | - Male (%) | 46% | Serum vitamin D– 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | - Health status | plasma 25(OH)D concentration less than 60 nmol/L | Serum 25OH(D) Low vitamin D: 37.1±8.4 High vitamin D: 67.8±13.4 | > 50nmol/l Vs. ≤ 50nmol/l | nd
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | - Mean age (SD), y | 62 (SD 7) Range: 50–79 | Serum 25OH(D) Low vitamin D: 37.1±8.4 High vitamin D: 67.8±13.4 | > 50nmol/l Vs. ≤ 50nmol/l | nd
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | - Male (%) | 51% | Serum 25OH(D) Low vitamin D: 37.1±8.4 High vitamin D: 67.8±13.4 | > 50nmol/l Vs. ≤ 50nmol/l | nd

Table 35d Vitamin D and bone health: Characteristics of observational studies published after the Ottawa EPC report (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
NEW Studies
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Health status | nd | Serum vitamin D: 66.2+/-25.8 nmol/L | Normal level Vs. Low level (season specific, ranges 43–61 nmol/L) | nd
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Mean age (SD), y | 74.6 (SD 4.6) | Serum vitamin D: 66.2+/-25.8 nmol/L | Normal level Vs. Low level (season specific, ranges 43–61 nmol/L) | nd
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Male (%) | 30% | Serum vitamin D: 66.2+/-25.8 nmol/L | Normal level Vs. Low level (season specific, ranges 43–61 nmol/L) | nd
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | - Health status | nd | Dietary calcium intake, median (IQR) (mg/d) 717 (515–973) 736 (532–995) 719 (517–978) 716 (501–940) Supplemental calcium intake (% yes) 18.3 25.0 17.4 28.7 Supplemental vitamin D intake (% yes) 8.3 13.1 8.1 12.2 in order of groups: hip fracture no/yes, any non-spine fracture no/yes | Quartile 1: ≤44.5 nmol/l vs. Quartile 2: 44.5–60.9 nmol/L vs. Quartile 3: 60.9–79.9 nmol/L vs. Quartile 4: >79.9 nmol/L | nd
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | - Mean age (SD), y | nd | | Quartile 1: ≤44.5 nmol/l vs. Quartile 2: 44.5–60.9 nmol/L vs. Quartile 3: 60.9–79.9 nmol/L vs. Quartile 4: >79.9 nmol/L | nd
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | - Male (%) | nd | | Quartile 1: ≤44.5 nmol/l vs. Quartile 2: 44.5–60.9 nmol/L vs. Quartile 3: 60.9–79.9 nmol/L vs. Quartile 4: >79.9 nmol/L | nd
Barrett-Connor, 2012^198^ US (various) | - Health status | Healthy, Overweight/Obese, and diabetes = 10%; mild CKD (GFR<60 mL/min/1.73m3) =12% | nd | Normal level Vs. Low vit D | nd
Barrett-Connor, 2012^198^ US (various) | - Mean age (SD), y | 74 (SD 6) | nd | Normal level Vs. Low vit D | nd
Barrett-Connor, 2012^198^ US (various) | - Male (%) | 100% | nd | Normal level Vs. Low vit D | nd
Burgi 2011^203^ US | - Health status | nd | nd | 3.8–49.3 nmol/L vs. 49.3–66.5 nmol/L vs. 66.5–82.0 nmol/L vs. 82.0–99.5 nmol/L vs. 99.5–281.3 nmol/L | Nd
Burgi 2011^203^ US | - Mean age (SD), y | 19.5 (SD 1.8) | nd | 3.8–49.3 nmol/L vs. 49.3–66.5 nmol/L vs. 66.5–82.0 nmol/L vs. 82.0–99.5 nmol/L vs. 99.5–281.3 nmol/L | Nd
Burgi 2011^203^ US | - Male (%) | 0% | nd | 3.8–49.3 nmol/L vs. 49.3–66.5 nmol/L vs. 66.5–82.0 nmol/L vs. 82.0–99.5 nmol/L vs. 99.5–281.3 nmol/L | Nd
Cauley 2011^199^ WHI OS US | - Health status | nd | nd | <50 nmol/L vs. 50–<75 nmol/Ll vs. ≥75 nmol/L | nd
Cauley 2011^199^ WHI OS US | - Mean age (Range), y | 64 (50–70) | nd | <50 nmol/L vs. 50–<75 nmol/Ll vs. ≥75 nmol/L | nd
Cauley 2011^199^ WHI OS US | - Male (%) | nd | nd | <50 nmol/L vs. 50–<75 nmol/Ll vs. ≥75 nmol/L | nd
Michael, 2011^189^ US (various) | - Health status | nd | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Michael, 2011^189^ US (various) | - Mean age (SD), y | 70.3 (SD 3.7) Range: 50–79 | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Michael, 2011^189^ US (various) | - Male (%) | 0% | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Rouzi 2012^200^ Jeddah, Saudi Arabia | - Health status | Healthy | Serum 25(OH)D: 34.27±22.80 nmol/L | <17.90 nmol/L vs. >45.1 nmol/L | nd
Rouzi 2012^200^ Jeddah, Saudi Arabia | - Mean age (SD), y | 61.3 (SD 7.2) | Serum 25(OH)D: 34.27±22.80 nmol/L | <17.90 nmol/L vs. >45.1 nmol/L | nd
Rouzi 2012^200^ Jeddah, Saudi Arabia | - Male (%) | nd | Serum 25(OH)D: 34.27±22.80 nmol/L | <17.90 nmol/L vs. >45.1 nmol/L | nd
Cauley, 2008^195^ WHI-OS nd | - Health status | Post-menopausal | Serum 25(OH)D controls: 59.60 ± 18.05 nmol/l cases: 55.95 ± 20.28 nmol/l | Quartile 1: 9.2–47.5 nmol/L vs. Quartile 2: 47.6–70.6 nmol/L vs. Quartile 3: 60.2–70.6 nmol/L vs. Quartile 4: 70.7–121.5 nmol/L vs. per 2.5 nmol/L decrease vs. per 25 nmol/L decrease | nd
Cauley, 2008^195^ WHI-OS nd | - Mean age (Range), y | Nd (50–79) | Serum 25(OH)D controls: 59.60 ± 18.05 nmol/l cases: 55.95 ± 20.28 nmol/l | Quartile 1: 9.2–47.5 nmol/L vs. Quartile 2: 47.6–70.6 nmol/L vs. Quartile 3: 60.2–70.6 nmol/L vs. Quartile 4: 70.7–121.5 nmol/L vs. per 2.5 nmol/L decrease vs. per 25 nmol/L decrease | nd
Cauley, 2008^195^ WHI-OS nd | - Male (%) | 0% | Serum 25(OH)D controls: 59.60 ± 18.05 nmol/l cases: 55.95 ± 20.28 nmol/l | Quartile 1: 9.2–47.5 nmol/L vs. Quartile 2: 47.6–70.6 nmol/L vs. Quartile 3: 60.2–70.6 nmol/L vs. Quartile 4: 70.7–121.5 nmol/L vs. per 2.5 nmol/L decrease vs. per 25 nmol/L decrease | nd
Looker 2013^196^ NHANES III US (multiple cities) | - Health status | NR | osteoporotic fracture- yes: 57.5 nmol/L, no: 60.1 nmol/L hip fracture- yes: 57.6 nmol/L, 60.0 nmol/L | 3 categories per 1 SD unit decline in serum 25OHD | nd
Looker 2013^196^ NHANES III US (multiple cities) | - Mean age (SD), y | 75.2 | osteoporotic fracture- yes: 57.5 nmol/L, no: 60.1 nmol/L hip fracture- yes: 57.6 nmol/L, 60.0 nmol/L | 3 categories per 1 SD unit decline in serum 25OHD | nd
Looker 2013^196^ NHANES III US (multiple cities) | - Male (%) | 25.7% | osteoporotic fracture- yes: 57.5 nmol/L, no: 60.1 nmol/L hip fracture- yes: 57.6 nmol/L, 60.0 nmol/L | 3 categories per 1 SD unit decline in serum 25OHD | nd
Menant, 2012^193^ Sydney, Australia | - Health status | nd | serum vitamin D- 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Menant, 2012^193^ Sydney, Australia | - Mean age (SD), y | 78 (SD 4.6) Range: 70–90 | serum vitamin D- 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Menant, 2012^193^ Sydney, Australia | - Male (%) | 46% | serum vitamin D- 62.2±24.6 nmol/L | ≤ 50nmol/l Vs. > 50nmol/l | nd
Michael, 2011^189^ US (various) | - Health status | nd | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Michael, 2011^189^ US (various) | - Mean age (SD), y | 70.3 (SD 3.7) Range: 50–79 | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Michael, 2011^189^ US (various) | - Male (%) | 0% | Serum vitamin D- 48.2+/-21.4 nmol/L | ≥ 75 nmol/l Vs. 50–74nmol/l Vs. 25–49 nmol/l Vs. ≤ 25 nmol/l | nd
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) Norway | - Health status | 46.1–59.2% good or very good health | median (25th and 75th percentiles) s-25(OH)D in the randomly sampled subcohort was 53.5 (42.2, 67.8) nmol/L | Quartile 1: 4.5–42.1 vs. Quartile 2: 42.2–53.5 vs. Quartile 3: 53.5–67.8 vs. Quartile 4: 67.9–250.0 | nd
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) Norway | - Mean age (SD), y | 71.9 (SD 3.9) | median (25th and 75th percentiles) s-25(OH)D in the randomly sampled subcohort was 53.5 (42.2, 67.8) nmol/L | Quartile 1: 4.5–42.1 vs. Quartile 2: 42.2–53.5 vs. Quartile 3: 53.5–67.8 vs. Quartile 4: 67.9–250.0 | nd
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) Norway | - Male (%) | 28% | median (25th and 75th percentiles) s-25(OH)D in the randomly sampled subcohort was 53.5 (42.2, 67.8) nmol/L | Quartile 1: 4.5–42.1 vs. Quartile 2: 42.2–53.5 vs. Quartile 3: 53.5–67.8 vs. Quartile 4: 67.9–250.0 | nd

Table 36a Vitamin D and bone health: Results of RCTs published after the Ottawa EPC report (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Lyons 2007^185^ [17473911] | ≥71 both sexes | First fracture | 1° | Median time to first fracture = 387 (IQR: 220–582) d in Vit D_2_ group; 367 (IQR:139–618) d in placebo group | Vit D_2_ ∼822 IU^A^ | 205 | 1670 | HR Vit D/placebo | 0.95 | 0.79, 1.15 | NS | C
Lyons 2007^185^ [17473911] | ≥71 both sexes | First fracture | 1° | Median time to first fracture = 387 (IQR: 220–582) d in Vit D_2_ group; 367 (IQR:139–618) d in placebo group | | | | | | | | C
Lyons 2007^185^ [17473911] | ≥71 both sexes | First fracture | 1° | Median time to first fracture = 387 (IQR: 220–582) d in Vit D_2_ group; 367 (IQR:139–618) d in placebo group | Placebo | 218 | 1673 | | | | | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fall | 1° | Median 1 (IQR 15–71 d) | Vit D_3_ 800 IU + Ca carbonate 1200 mg | 36 | 100 | RR (Vit D+Ca)/Ca | 0.82 | 0.59, 1.16 | NS | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fall | 1° | Median 1 (IQR 15–71 d) | | | | | | | | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fall | 1° | Median 1 (IQR 15–71 d) | Ca carbonate 1200 mg | 45 | 103 | | | | | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | | | | | | | | | | | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fracture | 1° | Median 1 (IQR | Vit D_3_ 800 IU + Ca carbonate 1200 mg | 1 | 100 | nd | nd | | NS | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fracture | 1° | | | | | | | | | C
Burleigh 2007^184^ [17656420] | ≥71 both sexes | Fracture | 1° | 15–71 d) | Ca carbonate 1200 mg | 3 | 103 | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Ca 800 mg | 13^B^ | 24 | Fall free survival curve | nd | | NS | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | | | | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Ca 800 mg + exercise training | 6^B^ | 22 | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | | | | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Vit D 400 IU + Ca 800 mg | 9^B^ | 24 | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | | | | | | | | C
Bunout 2006^183^ [16797903] | ≥71 both sexes | Fall | 2° | 9 mo | Vit D 400 IU + Ca 800 mg + Exercise training | 8^B^ | 22 | | | | | C
NEW Studies
Pfeifer, 2009^186^ Multiple Countries | | Primary–Falls (≥1) | 1° | 12 mo | 1000 mg & 800 IU daily | NR | 122 | RR | 0.73 | 0.54, 0.96 | <0.01 | A
Pfeifer, 2009^186^ Multiple Countries | | Primary–Falls (≥1) | 1° | 12 mo | | | | | | | | A
Pfeifer, 2009^186^ Multiple Countries | | Primary–Falls (≥1) | 1° | 12 mo | 1000 mg daily | NR | 120 | RR | 1.00 | Reference | | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥1) | 1° | 1 y | 1000mg of Ca & 1000 IU of Vit D2 daily | 80 | 151 | OR | 0.66 0.61 | 0.41, 1.06 0.37, 0.99 adjusted for height | NS < 0.05 | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥1) | 1° | 1 y | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥1) | 1° | 1 y | 1000mg of Ca & placebo daily | 95 | 151 | OR | 1.00 | Reference | | A
Prince, 2008^187^ Perth, Australia | | | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–1 fall | | | 1000mg of Ca & 1000 IU of Vit D2 daily | 32 | 151 | OR | 0.50 | 0.28, 0.88 | < 0.05 | A
Prince, 2008^187^ Perth, Australia | | Primary–1 fall | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–1 fall | | | 1000mg of Ca & placebo daily | 51 | 151 | OR | 1.00 | Reference | | A
Prince, 2008^187^ Perth, Australia | | | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥2) | | | 1000mg of Ca & 1000 IU of Vit D2 daily | NR | 151 | OR | 0.86 | 0.50, 1.49 | > 0.05 | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥2) | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–Falls (≥2) | | | 1000mg of Ca & placebo daily | NR | 151 | OR | 1.00 | Reference | | A
Prince, 2008^187^ Perth, Australia | | | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in winter/spring | | | 1000mg of Ca & 1000 IU of Vit D2 daily | 38 | 151 | OR | 0.55 | 0.32, 0.96 | < 0.05 | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in winter/spring | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in winter/spring | | | 1000mg of Ca & placebo daily | 54 | 151 | OR | 1.00 | Reference | | A
Prince, 2008^187^ Perth, Australia | | | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in summer/autumn | | | 1000mg of Ca & 1000 IU of Vit D2 daily | 42 | 151 | OR | 0.81 | 0.46, 1.42 | > 0.05 | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in summer/autumn | | | | | | | | | | A
Prince, 2008^187^ Perth, Australia | | Primary–First fall in summer/autumn | | | 1000mg of Ca & placebo daily | 41 | 151 | OR | 1.00 | Reference | | A

Note: Outcomes cells are shaded for the Control rows.

A Daily dose was calculated from the intermittent doses that were used in the study (i.e., 100,000 IU tablets every 4 months)

B Estimated from figure

Table 36b Vitamin D and muscle strength: Results of RCTs (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change/ Final | Change SD | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | 71+ | Short physical performance battery (SPPB) summary score | 2° | 16 wk | 8,400 IU/weekly | 109 | | 9.00 | change= 0.355 | 0.108, 0.601 | -0.25 | -0.60, -0.10 | 0.17 | A
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | 71+ | Short physical performance battery (SPPB) summary score | 2° | 16 wk | Placebo | 104 | | 9.07 | change= 0.601 | 0.351, 0.852 | Reference | NR | | A
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | 71+ | Short physical performance battery (SPPB) gait speed | 2° | 16 wk | 8,400 IU/weekly | 109 | cm/s | 93.70 | change= 3.10 | -0.252, 6.458 | -0.84 | -5.63, 3.95 | 0.73 | A
Lips, 2010^201^ Multiple countries; North America(9 centers); Europe (3 centers) | 71+ | Short physical performance battery (SPPB) gait speed | 2° | 16 wk | Placebo | 104 | cm/s | 88.70 | change= 3.94 | 0.567, 7.38 | Reference | NR | | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Quadriceps strength left leg | 2° | 12 mo | 1000 mg & 800 IU daily | 114 | Newton | 211.00 | final= 236 | SD=75 | +12 | -8.6, 32.6 | 0.25 | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Quadriceps strength left leg | 2° | 12 mo | 1000 mg daily | 114 | Newton | 217.00 | final= 224 | SD=83 | Reference | | | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Body sway total length | 2° | 12 mo | 1000 mg & 800 IU daily | 114 | mm | 86.00 | final= 81 | SD=32 | -5 | -13, 3 | 0.22 | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Body sway total length | 2° | 12 mo | 1000 mg daily | 114 | mm | 90.00 | final= 86 | SD=30 | Reference | | | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Timed up and go (TUG) | 2° | 12 mo | 1000 mg & 800 IU daily | 114 | secs | 9.00 | final= 7.5 | SD=3.4 | -0.8 | -1.9, 0.3 | 0.16 | A
Pfeifer, 2009^186^ Bad Pyrmont, Germany Graz, Austria | 71+ | Secondary-Timed up and go (TUG) | 2° | 12 mo | 1000 mg daily | 114 | secs | 8.50 | final= 8.3 | SD=5.1 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Maximum force | 1° | 1 yr | 150,000 IU/ quarterly | 33 | kN/kg | 2.80 | change= -0.08 | SD=0.22 | -0.04 | -0.12, 0.04 | 0.32 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Maximum force | 1° | 1 yr | Placebo | 32 | kN/kg | 2.71 | change= -0.04 | SD=0.04 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Eslinger fitness index | 1° | 1 yr | 150,000 IU/ quarterly | 33 | Percent | 89.44 | change= -4.31 | SD=9.32 | +0.17 | -3.8, 4.2 | 0.93 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Eslinger fitness index | 1° | 1 yr | Placebo | 32 | percent | 85.41 | change= -4.48 | SD=6.68 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Efficiency | 1° | 1 yr | 150,000 IU/ quarterly | 33 | Percent | 87.76 | change= 2.72 | SD=8.57 | +1.10 | -0.91, 3.12 | 0.10 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Efficiency | 1° | 1 yr | Placebo | 32 | Percent | 84.36 | change= -0.56 | SD=7.42 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Velocity | 1° | 1 yr | 150,000 IU/ quarterly | 33 | m/sec | 2.19 | change= 0.02 | SD=0.13 | +0.03 | -0.03, 0.09 | 0.28 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Velocity | 1° | 1 yr | Placebo | 32 | m/sec | 2.12 | change= -0.01 | SD=0.09 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Jump height | 1° | 1 yr | 150,000 IU/ quarterly | 33 | m | 0.34 | change= 0.01 | SD=0.04 | +0.01 | -0.01, 0.03 | 0.32 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Jump height | 1° | 1 yr | Placebo | 32 | m | 0.33 | change= 0.00 | SD=0.04 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Maximum power relative to body weight | 1° | 1 yr | 150,000 IU/ quarterly | 33 | kW/kg | 39.52 | change= -1.06 | SD=4.18 | +0.18 | -1.6, 2.0 | 0.84 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Maximum power relative to body weight | 1° | 1 yr | Placebo | 32 | kW/kg | 37.81 | change= -1.24 | SD=2.91 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Spine bone mineral content (BMC) | 1° | 1 yr | 150,000 IU/ quarterly | 35 | g | 11.73 | change= 0.52 | SD=0.39 | -0.05 | -0.24, 0.15 | 0.62 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Spine bone mineral content (BMC) | 1° | 1 yr | Placebo | 33 | g | 11.97 | change= 0.57 | SD=0.43 | Reference | | | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Tibia 66% cortical bone mineral content (Ct BMC) | 1° | 1 yr | 150,000 IU/ quarterly | 33 | mg/ mm | 268.38 | change= 7.68 | SD=12.26 | -1.98 | -8.4, 4.4 | 0.54 | A
Ward, 2010^202^ Manchester, UK | 9–18 yrs | Tibia 66% cortical bone mineral content (Ct BMC) | 1° | 1 yr | Placebo | 31 | mg/ mm | 261.23 | change= 9.66 | SD=13.38 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | Timed up and go (TUAG) | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | secs | 11.0 | Final=8.1 | SD=3.9 | -0.9 | -2.2, 0.5 | 0.2 | A
Zhu, 2010^188^ Perth, Australia | 71+ | Timed up and go (TUAG) | 1° | 1y | 1,000 mg/d Ca | 132 | secs | 10.8 | Final=9 | SD=7 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: ankle dorsiflexion | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 11.6 | Final=10.9 | SD=3.7 | 0 | -0.9, 0.9 | 1 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: ankle dorsiflexion | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 11.8 | Final=10.9 | SD=4 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: knee flexor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 11.8 | Final=12.9 | SD=3.5 | -0.1 | -1.0, 0.8 | 0.83 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: knee flexor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 11.9 | Final=13 | SD=3.9 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: knee extensor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 18.3 | Final=18 | SD=5 | -0.3 | -1.6, 1.0 | 0.65 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: knee extensor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 18.8 | Final=18.3 | SD=5.5 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip extensor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 14.6 | Final=17.2 | SD=5.2 | +0.3 | -1.1, 1.7 | 0.67 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip extensor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 14.4 | Final=16.9 | SD=6.2 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip abductor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 12.3 | Final=14.5 | SD=4.1 | +0.4 | -0.7, 1.5 | 0.48 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip abductor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 12.2 | Final=14.1 | SD=4.9 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip flexor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 14.5 | Final=15.4 | SD=4.2 | 0 | -1.1, 1.1 | 1 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip flexor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 14.5 | Final=15.4 | SD=4.8 | Reference | | | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip adductor | 1° | 1y | 1,000 mg/d Ca +1,00 IU vit D2 | 129 | kg | 14.4 | Final=16.4 | SD=4.2 | +0.1 | -1.1, 1.3 | 0.86 | A
Zhu, 2010^188^ Perth, Australia | 71+ | lower limb muscle strength: hip adductor | 1° | 1y | 1,000 mg/d Ca | 132 | kg | 14.7 | Final=16.3 | SD=5.2 | Reference | | | A

Table 36c Vitamin D and muscle strength: Results of prospective cohorts (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Concentration, nmol/L | No. Analyzed | Unit | Baseline | Change/ Final | Change SD | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (women) | 2° | 2.5 y (median) | 10–80 nmol/l | 159 | kg (%) | NR | Change= -0.78 | -4.76, 6.32 | +1.55 | NC | 0.22 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (women) | 2° | 2.5 y (median) | 82.5–97.5 nmol/l | 181 | kg (%) | NR | Change= -3.30 | -1.34, 7.95 | +5.63 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (women) | 2° | 2.5 y (median) | 100–112.5 nmol/l | 153 | kg (%) | NR | Change= -2.01 | -6.85, 2.83 | +0.32 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (women) | 2° | 2.5 y (median) | 115–337.5 nmol/l | 163 | kg (%) | NR | Change= -2.33 | -7.10, 2.45 | Reference | Reference | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (men) | 2° | 2.5 y (median) | 10–90 nmol/l | 114 | kg (%) | NR | Change= -0.71 | -2.12, 3.54 | +1.63 | NC | 0.22 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (men) | 2° | 2.5 y (median) | 92.5–102.5 nmol/l | 86 | kg (%) | NR | Change= -0.64 | -3.91, 2.63 | +1.7 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (men) | 2° | 2.5 y (median) | 105–120 nmol/l | 110 | kg (%) | NR | Change= -0.37 | -2.34, 3.07 | +1.97 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in grip strength (men) | 2° | 2.5 y (median) | 122.5–262.5 nmol/l | 99 | kg (%) | NR | Change= -2.34 | -5.15, 0.48 | Reference | Reference | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG)(women) | 2° | 2.5 y (median) | 10–80 nmol/l | 159 | kg (%) | NR | Change= 21.92 | 16.22, 27.62** | +13.79 | NC | 0.002 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG)(women) | 2° | 2.5 y (median) | 82.5–97.5 nmol/l | 181 | kg (%) | NR | Change= 7.37 | 2.69, 12.04 | -0.76 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG)(women) | 2° | 2.5 y (median) | 100–112.5 nmol/l | 153 | kg (%) | NR | Change= 8.48 | 3.48, 13.48 | +0.35 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG)(women) | 2° | 2.5 y (median) | 115–337.5 nmol/l | 163 | kg (%) | NR | Change= 8.13 | 3.16, 13.10 | Reference | Reference | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG) (men) | 2° | 2.5 y (median) | 10–90 nmol/l | 114 | kg (%) | NR | Change= 3.36 | -1.11, 7.82 | +1.94 | NC | 0.99 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG) (men) | 2° | 2.5 y (median) | 92.5–102.5 nmol/l | 86 | kg (%) | NR | Change= 3.52 | -1.75, 8.79 | +2.1 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG) (men) | 2° | 2.5 y (median) | 105–120 nmol/l | 110 | kg (%) | NR | Change= 4.95 | 0.69, 9.21 | +3.53 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed up and go (TUG) (men) | 2° | 2.5 y (median) | 122.5–262.5 nmol/l | 99 | kg (%) | NR | Change= 1.42 | -3.05, 5.09 | Reference | Reference | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(women) | 2° | 2.5 y (median) | 10–80 nmol/l | 159 | kg (%) | NR | Change= 21.98 | 16.28, 27.67** | +14.28 | NC | 0.002 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(women) | 2° | 2.5 y (median) | 82.5–97.5 nmol/l | 181 | kg (%) | NR | Change= 7.38 | 2.70, 12.06 | -0.32 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(women) | 2° | 2.5 y (median) | 100–112.5 nmol/l 115–337.5 nmol/l | 153 163 | kg (%) | NR | Change= 8.51 Change= 7.70 | 3.51, 13.51 2.58, 12.62 | +0.81 Reference | NC Reference | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(men) | 2° | 2.5 y (median) | 10–90 nmol/l | 114 | kg (%) | NR | Change= 3.36 | -1.11, 7.82 | +1.94 | NC | 0.99 | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(men) | 2° | 2.5 y (median) | 92.5–102.5 nmol/l | 86 | kg (%) | NR | Change= 3.52 | -1.75, 8.79 | +2.1 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(men) | 2° | 2.5 y (median) | 105–120 nmol/l | 110 | kg (%) | NR | Change= 4.95 | 0.69, 9.21 | +3.53 | NC | | C
Dam, 2009^190^ Rancho Bernardo study California, US | | Change in Timed chair stands (TCS)(men) | 2° | 2.5 y (median) | 122.5–262.5 nmol/l | 99 | kg (%) | NR | Change= 1.42 | -3.05, 5.09 | Reference | Reference | | C
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | knee extensor strength | 1° | 4y | <50 nmol/L | 1818 | nm/ kg | 12.83 | Final=11.9 | SE=0.2 | NC | NC | 0.76 | B
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | knee extensor strength | 1° | 4y | 50–<75 nmol/L | 1818 | nm/ kg | 13.01 | Final=11.9 | SE=0.2 | | | | B
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | knee extensor strength | 1° | 4y | ≥75 nmol/L | 1818 | nm/ kg | 12.91 | Final=11.8 | SE=0.2 | | | | B
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | grip strength | 1° | 4y | <50 nmol/L | 1971 | kg | 28.87 | Final=29.2 | SE=0.4 | NC | NC | 0.09 | B
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | grip strength | 1° | 4y | 50–<75 nmol/L | 1971 | kg | 29.71 | Final=29.8 | SE=0.4 | | | | B
Houston, 2012^192^ Healthy, Aging and Body Composition US Pittsburgh, Memphis | | grip strength | 1° | 4y | ≥75 nmol/L | 1971 | kg | 29.81 | Final=30.0 | SE=0.4 | | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Grip strength | 1° | 1 y | > 50 nmol/l | 309 | kg | NR | final=28.7 | SD=11.7 | +4.7 | 3.3, 6.1 | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Grip strength | 1° | 1 y | ≤ 50nmol/l | 154 | kg | NR | final=24.0 | SD=10.3 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Quadriceps strength | 1° | 1 y | > 50 nmol/l | 309 | kg | NR | final=28.9 | SD=11.9 | +6 | 5, 7 | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Quadriceps strength | 1° | 1 y | ≤ 50nmol/l | 154 | kg | NR | final=22.9 | SD=10.4 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Finger press reaction time | 1° | 1 y | > 50 nmol/l | 309 | ms | NR | final=235.4 | SD=45.2 | -11.7 | NR | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Finger press reaction time | 1° | 1 y | ≤ 50nmol/l | 154 | ms | NR | final=247.1 | SD=50.0 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Sway, eyes open-floor | 1° | 1 y | > 50 nmol/l | 309 | mm2 | NR | final=76.5 | SD=40.1 | -5.4 | -11.0, 0.2 | 0.06 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Sway, eyes open-floor | 1° | 1 y | ≤ 50nmol/l | 154 | mm2 | NR | final=81.9 | SD=46.0 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Sway, eyes open-foam | 1° | 1 y | > 50 nmol/l | 309 | mm2 | NR | final=182.2 | SD=97.5 | -5.6 | -17.7, 6.5 | 0.37 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Sway, eyes open-foam | 1° | 1 y | ≤ 50nmol/l | 154 | mm2 | NR | final=187.8 | SD=89.9 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Physiological Profile assessment (PPA) fall risk score | 1° | 1 y | > 50 nmol/l | 309 | | NR | final=0.8 | SD=0.9 | -0.2 | -0.3, -0.1 | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Physiological Profile assessment (PPA) fall risk score | 1° | 1 y | ≤ 50nmol/l | 154 | | NR | final=1.0 | SD=0.9 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Maximal balance range | 1° | 1 y | > 50 nmol/l | 309 | mm | NR | final=155.7 | SD=56.8 | +21.1 | 14.2, 28.0 | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Maximal balance range | 1° | 1 y | ≤ 50nmol/l | 154 | mm | NR | final=134.6 | SD=49.7 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Coordinated stability score | 1° | 1 y | > 50 nmol/l | 309 | | NR | final=13.6 | SD=12.4 | -5.0 | -7, -3 | <0.001 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Coordinated stability score | 1° | 1 y | ≤ 50nmol/l | 154 | | NR | final=18.6 | SD=13.3 | Reference | | | B
Menant, 2012^193^ Sydney, Australia | | Primary-Choice stepping reaction time | | | > 50 nmol/l | 309 | secs | | final=987.4 | SD=215.1 | -73.4 | -101.7, -45.1 | <0.001
Menant, 2012^193^ Sydney, Australia | | Primary-Choice stepping reaction time | | | ≤ 50nmol/l | 154 | secs | | final=1060.8 | SD=223.0 | Reference
Menant, 2012^193^ Sydney, Australia | | Primary-6 m walk speed | | | > 50 nmol/l | 309 | m/s | | final=0.73 | SD=0.16 | +0.06 | 0.04, 0.08 | <0.001
Menant, 2012^193^ Sydney, Australia | | Primary-6 m walk speed | | | ≤ 50nmol/l | 154 | m/s | | final=0.67 | SD=0.17 | Reference
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Appendicular lean mass | 1° | 2.6 y | > 50nmol/l | 389 | percent | 62.20 | NR | NR | +0.01 | -0.52, 0.54 | 0.963 | B
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Appendicular lean mass | 1° | 2.6 y | ≤ 50nmol/l | 297 | percent | 59.30 | NR | NR | Reference | | | B
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Leg strength | 1° | 2.6 y | > 50nmol/l | 389 | kg | 100.80 | NR | NR | +5.74 | 0.65, 10.82 | 0.027 | B
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Leg strength | 1° | 2.6 y | ≤ 50nmol/l | 297 | kg | 91.50 | NR | NR | Reference | | | B
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Leg muscle quality | 1° | 2.6 y | > 50nmol/l | 389 | kg/kg | 5.90 | NR | NR | +0.49 | 0.17, 0.82 | 0.003 | B
Scott, 2010^191^ Tasmanian Older Adult Cohort Study (TASOAC) Tasmania, Australia | | Leg muscle quality | 1° | 2.6 y | ≤ 50nmol/l | 297 | kg/kg | 5.50 | NR | NR | Reference | | | B

Table 36d Vitamin D and bone health: Results of observational studies published after the Ottawa EPC report (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup | Concentration, nmol/L | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
de Boer 2012^87^ Cardiovascular Health Study US (various) | | Hip fracture | 1° | 11 yrs | Normal level | 118 | 1126 | HR | 1.00 | Reference | NR | A
de Boer 2012^87^ Cardiovascular Health Study US (various) | | Hip fracture | 1° | 11 yrs | Low level (season specific, ranges 43–61 nmol/L) | 72 | 495 | HR | 1.34 | 0.97, 1.84 | | A
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | Quartile 1: ≤44.5 nmol/L | 84 | 2501 | HR | 1.92 | 0.97, 3.83 | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | | | | HR | | | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | Quartile 2: 44.5–60.9 nmol/L | | | HR | 0.75 | 0.32, 1.72 | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | | | | HR | | | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | Quartile 3: 60.9–79.9 nmol/l | | | HR | 1.86 | 1.00, 3.45 | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | | | | HR | | | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | Hip fracture | 1° | 2 yrs | Quartile 4: >79.9 nmol/l | | | HR | 1.00 | Reference | 0.217 | B
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | Quartile 1: ≤44.5 nmol/L | 247 | 2494 | HR | 1.21 | 0.83, 1.75 | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | | | | HR | | | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | Quartile 2: 44.5–60.9 nmol/L | | | HR | 1.01 | 0.68, 1.49 | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | | | | HR | | | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | Quartile 3: 60.9–79.9 nmol/l | | | HR | 1.12 | 0.78, 1.60 | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | | | | HR | | | 0.752
Barbour, 2012^194^ US Pittsburgh, PA and Memphis, TN | age 70–79 | nonspine fracture | 1° | 2 yrs | Quartile 4: >79.9 nmol/l | | | HR | 1.00 | Reference | 0.752
Barrett-Connor, 2012^198^ US (various) | 51–70 yrs; ≥71 yrs | nonspine fracture | 1° | 4.6 yrs | Normal level | 100 | 594 | HR | 1.2 | 0.8, 1.8 | | A
Barrett-Connor, 2012^198^ US (various) | 51–70 yrs; ≥71 yrs | nonspine fracture | 1° | 4.6 yrs | | | | HR | | | | A
Barrett-Connor, 2012^198^ US (various) | 51–70 yrs; ≥71 yrs | nonspine fracture | 1° | 4.6 yrs | Low vit D | 34 | 183 | HR | 1.00 | Reference | | A
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | 3.75–49.25 nmol/L | 600 | 1200 | OR | 1.00 | Reference | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | | | | OR | | | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | 49.5–66.5 nmol/L | | | OR | 0.77 | 0.54, 1.11 | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | | | | OR | | | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | 66.8–82 nmol/L | | | OR | 0.76 | 0.52, 1.10 | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | | | | OR | | | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | 82.3–99.5 nmol/L | | | OR | 0.61 | 0.42, 0.91 | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | | | | OR | | | 0.02 | B
Burgi 2011^203^ US | 9–50 yrs | stress fracture | 1° | NR | 99.75–281.25 nmol/L | | | OR | 0.51 | 0.34, 0.78 | 0.02 | B
Cauley 2011^199^ WHI OS US | Postmenopausal women | fractures | 1° | 8.6 yrs | <50 nmol/L | 150 | 270 | OR | 1.00 | Reference | 0.02 | A
Cauley 2011^199^ WHI OS US | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.02 | A
whites | Postmenopausal women | fractures | 1° | 8.6 yrs | 50– <75 nmol/L | 156 | 321 | OR | 0.82 | 0.58, 1.16 | 0.02 | A
whites | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.02 | A
whites | Postmenopausal women | fractures | 1° | 8.6 yrs | ≥75 nmol/L | 84 | 189 | OR | 0.56 | 0.35, 0.90 | 0.02 | A
| Postmenopausal women | fractures | 1° | 8.6 yrs
blacks | Postmenopausal women | fractures | 1° | 8.6 yrs | <50 nmol/L | 241 | 508 | OR | 1.00 | Reference | 0.043
blacks | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.043
blacks | Postmenopausal women | fractures | 1° | 8.6 yrs | 50– <75 nmol/L | 108 | 193 | OR | 1.48 | 1.05, 2.10 | 0.043
blacks | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.043
blacks | Postmenopausal women | fractures | 1° | 8.6 yrs | ≥75 nmol/L | 30 | 57 | OR | 1.33 | 0.73, 2.43 | 0.043
| Postmenopausal women | fractures | 1° | 8.6 yrs
Hispanics | Postmenopausal women | fractures | 1° | 8.6 yrs | <50 nmol/L | 89 | 182 | OR | 1.00 | Reference | 0.72
Hispanics | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.72
Hispanics | Postmenopausal women | fractures | 1° | 8.6 yrs | 50– <75 nmol/L | 71 | 140 | OR | 1.02 | 0.69, 1.79 | 0.72
Hispanics | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.72
Hispanics | Postmenopausal women | fractures | 1° | 8.6 yrs | ≥75 nmol/L | 31 | 60 | OR | 1.09 | 0.50, 2.37 | 0.72
| Postmenopausal women | fractures | 1° | 8.6 yrs
Asians | Postmenopausal women | fractures | 1° | 8.6 yrs | <50 nmol/L | 37 | 80 | OR | 1.00 | Reference | 0.22
Asians | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.22
Asians | Postmenopausal women | fractures | 1° | 8.6 yrs | 50– <75 nmol/L | 45 | 85 | OR | 1.49 | 0.76, 2.93 | 0.22
Asians | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.22
Asians | Postmenopausal women | fractures | 1° | 8.6 yrs | ≥75 nmol/L | 30 | 59 | OR | 1.66 | 0.68, 4.02 | 0.22
| Postmenopausal women | fractures | 1° | 8.6 yrs
native Americans | Postmenopausal women | fractures | 1° | 8.6 yrs | <50 nmol/L | 29 | 55 | OR | 1.00 | Reference | 0.29
native Americans | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.29
native Americans | Postmenopausal women | fractures | 1° | 8.6 yrs | 50– <75 nmol/L | 9 | 18 | OR | 0.64 | 0.15, 2.79 | 0.29
native Americans | Postmenopausal women | fractures | 1° | 8.6 yrs | | | | OR | | | 0.29
native Americans | Postmenopausal women | fractures | 1° | 8.6 yrs | ≥75 nmol/L | 6 | 15 | OR | 0.43 | 0.09, 2.08 | 0.29
Rouzi, 2012^200^ Jeddah, Saudi Arabia | | fragility fractures | 1° | 5.2 yrs | <17.90 nmol/L | 138 | 707 | OR | 1.25 | 0.91, 1.70 | | A
Rouzi, 2012^200^ Jeddah, Saudi Arabia | | fragility fractures | 1° | 5.2 yrs | | | | OR | | | | A
Rouzi, 2012^200^ Jeddah, Saudi Arabia | | fragility fractures | 1° | 5.2 yrs | >45.1 nmol/L | | | OR | 1.00 | Reference | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | Quartile 1: 9.2–47.5 nmol/L | NR | 244 | OR | 1.71 | 1.05, 2.79 | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | | | | OR | | | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | Quartile 2: 47.6–70.6 nmol/L | NR | 195 | OR | 1.09 | 0.70, 1.71 | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | | | | OR | | | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | Quartile 3: 60.2–70.6 nmol/L | NR | 167 | OR | 0.82 | 0.51, 1.31 | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | | | | OR | | | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | Quartile 4: 70.7–121.5 nmol/L | NR | 193 | OR | 1.00 | Reference | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | | | | OR | | | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | per 2.5 nmol/L decrease | NR | 799 | OR | 1.03 | 1.01, 1.05 | 0.015 | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | | | | OR | | | | A
Cauley, 2008^195^ WHI-OS nd | | hip fractures | 1° | 7.1 yrs | per 25 nmol/L decrease | NR | 799 | OR | 1.33 | 1.06, 1.68 | | A
Looker 2013^196^ NHANES III | | major osteoporotic fracture | 1° | 7 yrs | per 1 SD unit decline in serum 25OHD | 400 | 4749 | RR | 1.27 | 1.12, 1.44 | | A
Looker 2013^196^ NHANES III | | major osteoporotic fracture | 1° | 7 yrs | per 1 SD unit decline in serum 25OHD | | | RR | | | | A
Looker 2013^196^ NHANES III | | major osteoporotic fracture | 1° | 7 yrs | per 1 SD unit decline in serum 25OHD | 212 | NR | RR | 1.14 | 0.97, 1.34 | | A
Looker 2013^196^ NHANES III | | major osteoporotic fracture | 1° | 7 yrs | per 1 SD unit decline in serum 25OHD | | | RR | | | | A
Looker 2013^196^ NHANES III | | major osteoporotic fracture | 1° | 7 yrs | per 1 SD unit decline in serum 25OHD | 188 | NR | RR | 1.40 | 1.13, 1.74 | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | Q1: 4.5–42.1 | 317 | 256 | HR | 1.34 | 1.05, 1.70 | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | | | | HR | | | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | Q2: 42.2–53.5 | 294 | 255 | HR | 1.13 | 0.90, 1.44 | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | | | | HR | | | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | Q3: 53.5–67.8 | 272 | 255 | HR | 1.10 | 0.87, 1.39 | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | | | | HR | | | | A
Holvik 2013^197^ Norwegian Epidemiologic Osteoporosis Studies (NOREPOS) | | hip fracture | 1° | 10.7 yrs | Q4: 67.9–250.0 | 279 | 256 | HR | 1.00 | Reference | | A
Menant, 2012^193^ Sydney, Australia | | Primary-Falls in men | 1° | 1 y | ≤ 50nmol/l | 94 | 215 | IRR | 1.93 | 1.19, 3.15 | 0.008 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Falls in men | 1° | 1 y | | 94 | 215 | | | | 0.008 | B
Menant, 2012^193^ Sydney, Australia | | Primary-Falls in men | 1° | 1 y | > 50nmol/l | 94 | 215 | IRR | 1.00 | Reference | 0.008 | B
Menant, 2012^193^ Sydney, Australia | | | 1° | 1 y | | | | | | | | B
Menant, 2012^193^ Sydney, Australia | | Primary- Falls in women | 1° | 1 y | ≤ 50nmol/l | 115 | 248 | IRR | 0.83 | 0.56, 1.23 | 0.362 | B
Menant, 2012^193^ Sydney, Australia | | Primary- Falls in women | 1° | 1 y | | 115 | 248 | | | | 0.362 | B
Menant, 2012^193^ Sydney, Australia | | Primary- Falls in women | 1° | 1 y | > 50nmol/l | 115 | 248 | IRR | 1.00 | Reference | 0.362 | B
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | ≥ 75 nmol/l | NR | 64 | RR | 3.66 | 1.88, 5.45 | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | | | | | | | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | 50–74nmol/l | NR | 148 | RR | 2.32 | 0.89, 3.75 | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | | | | | | | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | 25–49 nmol/l | NR | 255 | RR | 1.64 | 0.28, 3.01 | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | | | | | | | <0.001 | A
Michael, 2011^189^ US (various) | | Primary-Physical performance summary score | 1° | 6 y | ≤ 25 nmol/l | NR | 67 | RR | 1 | Reference | <0.001 | A

###### RCTs of Vitamin D Supplementation Identified for the Current Report that Assessed the Effects on Falls and Muscle Strength

Two RCTs were identified for the current report that examined the effects of vitamin D supplementation on the risk for falls among older adults (both rated A). A 1-year study of 242 adults in Germany,70 to 91 years of age (average age 77, 75% women) randomized the group to receive 800IU vitamin D and 1000mg calcium daily or calcium and placebo alone; the vitamin D group had a significant decrease in the number of first fallers (OR 0.73 [0.54, 0.96]).186 A 1-year study of 382 postmenopausal Australian women, 70 to 90 years of age randomized the women to receive 1000IU vitamin D_2_ and 1000mg calcium daily or placebos; supplemented women had a significantly decreased risk of falling especially in winter and a decreased risk for first falls but not for two or more falls.187

Two RCTs were identified for the current report that examined the effects of 1 year of vitamin D supplementation on muscle strength (both rated A). The two studies assessed the effect of supplementation with vitamin D and calcium (compared with calcium alone) on strength in older adults. A 1-year study of 242 adults in Germany,70 to 91 years of age (average age 77, 75% women) randomized the group to receive 800IU vitamin D and 1000mg calcium daily or calcium and placebo alone; the vitamin D group had significant improvements in muscle strength and in timed up and go.186 A study of 261 community dwelling, vitamin D insufficient, Australian women, 70 to 90 years of age, were randomized to 1,000IU vitamin D and 1000 mg calcium daily or calcium alone: only women with the lowest baseline muscle strength had significant improvements.188

###### Observational Studies of Muscle Strength and Risk for Falls

Four prospective cohort studies were identified for the current report that assessed the association between serum 25(OHD) concentrations and muscle strength or loss among older adults. Among a subset of the WHI cohort serum 25(OH)D concentrations of 75nmol/L or more were associated with higher muscle strength and performance scores at 6 years' followup (study rated A).189 The Rancho Bernardo Study, which followed a cohort of 1,065 men and women of average age 74.6 over 2.5 years found that lower serum 25(OH)D concentrations were associated with declining muscle function in women but not in men (rated C).190 A study of 646 men and women in Tasmania, average age 62, over 2.6 years, found that serum 25(OH)D concentrations of 50nmol/L or less were associated lower muscle strength at followup (rated B).191 The Health ABC Study followed 2,641 men and women, ages 70 to 80, over 4 years and found that lower serum 25(OH)D concentrations were not associated with a faster rate of decline in muscle strength over time (rated B).192

The one cohort study that assessed the association between serum 25(OH)D and risk for falls followed 463 men and women, 70 to 90 years of age over 1 year and found that serum 25(OH)D of 50nmol/L or less was associated with an increased risk for falls (rated B). 193

###### Observational Studies of Fracture Prevention Identified for the Current Report

Eight prospective cohort and nested case control studies that assessed the association between vitamin D exposure and fracture risk were identified that met the inclusion criteria for the current study.

Hip fracture risk was assessed in five studies that ranged in followup from a median of 6.4 years to an average of 11 years. The Cardiovascular Health Study, a prospective cohort study that followed 1,621older community dwelling adults over 11 years and found a small but significant increase in hip fracture risk for those with the lowest serum levels of 25(OH)D (rated A).87 The Health ABC study, which followed a population of 2,501 older adults for a median of 6.4 years, found no significant association of 25(OH)D exposure and risk for hip fracture (rated B).194 A reassessment of a subgroup of women in the WHI Observational Study (OS) found an association of low vitamin D and increased risk for hip fracture (rated B).195 A study that assessed the risk for hip and other osteoporotic fracture among 4,749 NHANES III participants ages 65 and over found that among those followed for less than 10 years, serum 25(OH)D was a significant predictor for hip and other major osteoporotic fracture; however at 10 years or more, the association was no longer significant (rated A).196 The NOREPOS study followed a cohort of 21,774 men and women 65 to 79 years of age for 10.7 years and observed that low serum 25(OH)D (less than 42.2 nmol/L) predicted a 38 percent increased risk for hip fracture in this population (95% CI 9, 74) compared with a 25(OH)D concentration of 67.9 nmol/L or more (rated A).197 Nonvertebral fracture risk was assessed in two studies (both with B ratings). One nested case control study of the MrOS study population of older men found no association between low serum 25(OH)D alone and nonvertebral fracture risk.198 The Health ABC cohort study found no significant association of serum 25(OH)D with nonvertebral fracture risk.194

Total fragility fracture was assessed in two studies. A reassessment of WHI OS data after 8.6 years follow up found an association of lower serum 25(OH)D concentrations with a significantly increased fracture risk for white women but a much smaller association for black women, no association for Hispanic or native American women, and an association of higher 25(OH)D concentrations with higher risk for fragility fracture in Asian American women (results of the WHI CaD trial are discussed later in the section on vitamin D and calcium supplementation).199 The CEOR study, a study of postmenopausal Saudi women with a follow up of 5.2 years, observed that low vitamin D was an independent predictor of increased risk for osteoporotic fracture.200

###### Ottawa EPC Report: Fractures—Postmenopausal Women or Elderly Men

Overall, there is inconsistent evidence for an association between serum 25(OH)D concentrations and the risk of fractures. Fifteen studies (three prospective cohorts and twelve case-controls) reported on the association between serum 25(OH)D concentrations and fracture rates. One of three cohorts reported an inverse association between serum 25(OH)D concentrations and fracture rates, and nine of twelve case-control studies found significantly lower 25(OH)D concentrations in cases versus controls. Differences in results may be attributed to whether all relevant confounders were controlled for and differences in baseline serum 25(OH)D concentrations. Other factors may also contribute to the heterogeneity, such as diagnosis of fractures.

###### Ottawa EPC Report: Falls—Postmenopausal Women or Elderly Men

Overall, there is fair evidence of an association between lower serum 25(OH)D concentrations and an increased risk of falls in institutionalized elderly. One study suggested a serum 25(OH)D concentration below 39 nmol/L was associated with an increased risk of falls.

Five studies (one RCT, three cohorts and one case-control) evaluated the association between serum 25(OH)D concentrations and risk of falls. One RCT, two of the three cohorts and one case-control study reported an inverse association between serum 25(OH)D concentrations and a risk of falls. In one cohort with a low percentage of vitamin D deficient participants, the association did not persist after adjustment for age and illness severity. In another cohort with an undetermined proportion of vitamin D deficient participants no significant association between serum 25(OH)D concentrations and risk of falls was observed. One case-control study reported no significant association between serum 25(OH)D concentrations and risk of falls after adjusting for serum PTH.

###### Ottawa EPC Report: Performance Measures—Postmenopausal Women or Elderly Men

Overall, there is inconsistent evidence for an association of serum 25(OH)D concentrations with performance measures. In studies that reported an association, specific concentrations below which, declines in performance measures were increased, ranged from 50 to 87 nmol/L.

Seven studies (three RCTs and four cohorts) assessed the relation between 25(OH)D concentrations and performance related measures. Two of the three RCTs and two of the four cohorts reported an association between 25(OH)D concentrations and performance measures. The other studies did not find an association between 25(OH)D concentrations and performance measures.

###### Additional RCTs Published After the Ottawa EPC Report

We identified three additional RCTs (published after the Ottawa EPC report)183-185 that examined the effect of either vitamin D_2_ or D_3_ supplementation on total fractures, falls, or performance in elderly populations (≥71 years old). All three RCTs were rated C. In two of the three RCTs183,184 calcium supplementation (800 or 1200 mg/d) was given to all participants. Baseline serum 25(OH)D concentrations were less than 40 nmol/L. The other RCT did not provide any information on background calcium intake or baseline serum 25(OH)D concentrations.185 All three RCTs reported no significant reduction in the risk of total fracture or falls in elderly populations at daily vitamin D doses ranging from 400 IU to 822 IU.183-185 Only one of the three new RCTs among elderly reported data on performance measures. Vitamin D supplementation (400 IU/d) improved gait speed and body sway in healthy elderly subjects.183

###### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  A single RCT identified for the current report reported no significant effect of vitamin D supplementation of 12 to 14-year old girls on muscle strength, in spite of improved serum status. Not reviewed in the original report
- 19–50 y
  No data
- 51–70 y
  The Ottawa EPC report concluded that the associations between serum 25(OH)D concentrations and risk of fractures, falls, and performance measures are inconsistent. There were no new data since the Ottawa report
- ≥71 y
  Two of three trials identified for the current report that assessed the effects of vitamin D_2_ or D_3_ supplementation on the risk for falling among men and women 70 and older reported a significant decrease in the risk for some categories of falls. Two trials identified for the current report that assessed the effects of vitamin D_2_ or D_3_ supplementation on muscle strength reported some improvement but this finding was limited to those with lowest baseline strength in one study. Analysis of elderly adults in two large prospective cohort studies found a strong inverse association between serum 25(OH)D and risk for hip fracture and major osteoporotic fracture; however one of the studies observed the association only at followup times of 10 years or less. In the original report, findings from three new RCTs did not show significant effects of either vitamin D_2_ or D_3_ supplementation (daily doses ranged from 400 IU to 822 IU) in reducing the risk of total fractures or falls among men and women in this life stage.
- Postmenopause
  Of two trials identified for the current report that assessed the effects of vitamin D_2_ or D_3_ supplementation on the risk for falling among postmenopausal women 70 and older, one reported a significant decrease in the risk for some categories of falls, and one reported no effect. This trial reported improved muscle strength among postmenopausal women 70 and older but only in those with lowest baseline strength. The Ottawa EPC report concluded that the associations between serum 25(OH)D concentrations and risk of fractures, falls, and performance measures are inconsistent. There were no new data since the Ottawa report identified for the original report.
- Pregnant & lactating women
  Not reviewed

### Vitamin D and All-Cause Mortality

#### Synopsis

The current report identified 25 cohort studies that assessed the association between serum 25(OH)D concentration and risk for all-cause mortality. Of the 25, seven found no association (rated 1A, 6B), 16 found an association of lower 25(OH)D concentrations with increased risk for mortality (rated 6A, 9B: one article reported on two studies), and two reported an association of both higher and lower 25(OH)D concentrations with increased mortality risk (rated A and B).

The assessment of the literature on vitamin D and all-cause mortality in the original report was based on a reanalysis of a systematic review of RCTs on vitamin D supplementation for mortality.^i^ In addition, it summarizes four observational studies on the association of vitamin D and all-cause mortality.

Three RCTs from the previous systematic review and an additional C rated RCT were included in our reanalysis. Three used daily doses that ranged between 400 and 880 IU, and one used 100,000 IU every 3 months. Our meta-analysis of the 4 RCTs (13,833 participants) shows absence of significant effects of vitamin D supplementation on all-cause mortality (RR = 0.97, 95% CI: 0.92, 1.02; random effects model). There is little evidence for between-study heterogeneity in these analyses.

One cohort study (rated B for methodological quality) found a significant trend for lower odds for death with increasing 25(OH)D concentrations. Three other cohort studies did not find a significant association between 25(OH)D concentrations and all-cause mortality. These three studies were rated C for their methodological quality.

The above are applicable to older (50–70 y) and elderly (≥71 y) men and women (mean age was >70 y in the included studies).

#### Detailed Presentation

(Tables 37, 38, & 39)

Table 37 Summary of systematic review on vitamin D supplementation and all-cause mortality (not updated from original report)

Author Year [PMID] | Autier 2007^204^ [17846391]
Design (Search Years) | Randomized controlled trials (1992–2006)
Population | Community dwelling or institutionalized adults
Intervention (Exposure) and Comparator | Supplementary vitamin D (at least 1000 mg/d) without calcium vs. placebo or no treatment
Results | 18 trials of combined vitamin D and vitamin D + calcium RR: 0.93 (95% CI 0.87, 0.99); favoring vitamin D (± calcium) supplementation Statistically homogeneous In our reanalysis we and excluded 3 of 18 trials and separated studies with vitamin D only from those with vitamin D and calcium combination. For details and results of our reanalysis, see text.
Comments | See text in vitamin D and vitamin D + calcium sections for reanalyses of the separated trials. Study participants, vitamin D assays, and vitamin D status are not described in detail.
AMSTAR Criteria
A priori design? | Yes | Study quality assessment performed? | No
Two independent reviewers? | No | Study quality appropriately used in analysis? | NA
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | No
Included and excluded studies listed? | No | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes | The meta-analysis did not perform quality assessment (neither using individual quality items nor using quality scores)

Table 38 Vitamin D and all-cause mortality: Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle
Jia 2007^219^ UK (57°N) [17442130] | - Health status | Not terminally ill or demented | - Assay method | RIA | Comparison of various 25(OH)D concentration categories | | X | | X | X | X
Jia 2007^219^ UK (57°N) [17442130] | - Age range, y | >75 | - Assay method | RIA | Comparison of various 25(OH)D concentration categories | | X | | X | X | X
Jia 2007^219^ UK (57°N) [17442130] | - Male (%) | 52 | - Season blood drawn | ND | Comparison of various 25(OH)D concentration categories | | X | | X | X | X
Sambrook 2004 & 2006^220,221^ FREE^A^ Australia (33°S) [15531500 & 16598375] | - Health status | Not bedridden | - Assay method | RIA (Dia-sorin) | Association with log 25(OH)D | | X | | X
Sambrook 2004 & 2006^220,221^ FREE^A^ Australia (33°S) [15531500 & 16598375] | - Age range, y | >65 | - Assay method | RIA (Dia-sorin) | Association with log 25(OH)D | | X | | X
Sambrook 2004 & 2006^220,221^ FREE^A^ Australia (33°S) [15531500 & 16598375] | - Male (%) | 22 | - Season blood drawn | ND | Association with log 25(OH)D | | X | | X
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | - Health status | General population^B^ | - Assay method | Competitive protein binding | Comparison of various 25(OH)D concentration categories | | X | X | | | X
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | - Age range, y | >65 | - Assay method | Competitive protein binding | Comparison of various 25(OH)D concentration categories | | X | X | | | X
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | - Male (%) | 51 | - Season blood drawn | ND | Comparison of various 25(OH)D concentration categories | | X | X | | | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Health status | General population | - Assay method | RIA (Dia-sorin) | Comparison of various 25(OH)D concentration categories | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Age mean (range), y | 45 (≥20) | - Assay method | RIA (Dia-sorin) | Comparison of various 25(OH)D concentration categories | X | X | X | X | X | X
Melamed 2008^85^ NHANES III US (various) [18695076] | - Male (%) | 46 | - Season blood drawn | ND | Comparison of various 25(OH)D concentration categories | X | X | X | X | X | X
NEW Studies
Bolland 2010^58^ New Zealand | - Health status | Healthy Postmenopausal | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
Bolland 2010^58^ New Zealand | - Age range, y | 74 (SD 4.2) | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
Bolland 2010^58^ New Zealand | - Male (%) | 0% | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
Cawthon 2010^98^ MrOS (multisite) US | - Health status | >80% Excellent/good health status | | | Association with log 25(OH)D | X | X | X | X | X | X
Cawthon 2010^98^ MrOS (multisite) US | - Mean age (Age range), y | 74 (> or =65) | | | Association with log 25(OH)D | X | X | X | X | X | X
Cawthon 2010^98^ MrOS (multisite) US | - Male (%) | nd | | | Association with log 25(OH)D | X | X | X | X | X | X
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Health status | nd | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Mean Age (SD), y | 74 (SD 4.6) | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
de Boer 2012^87^ Cardiovascular Health Study US (various) | - Male (%) | 30% | | | Comparison of various 25(OH)D concentration categories | | X | X | X | | X
Eaton 2011^70^ WHI substudy US (multisite) | - Health status | nd | | | Postmenopausal women 50–79 years stratified by 25(OH)D quartiles | | | X | X | X | X
Eaton 2011^70^ WHI substudy US (multisite) | - Mean Age (SD), y | 65.1 (SD 7.6) | | | Postmenopausal women 50–79 years stratified by 25(OH)D quartiles | | | X | X | X | X
Eaton 2011^70^ WHI substudy US (multisite) | - Male (%) | 0% | | | Postmenopausal women 50–79 years stratified by 25(OH)D quartiles | | | X | X | X | X
Fedirko 2012^101^ EPIC US (4 sites) | - Health status | nd | | | Diagnosis at age of 62 stratified by 25(OH)D quintiles | | X | X | X | X | X
Fedirko 2012^101^ EPIC US (4 sites) | - Mean Age (SD), y | 62.1 (4.2) | | | Diagnosis at age of 62 stratified by 25(OH)D quintiles | | X | X | X | X | X
Fedirko 2012^101^ EPIC US (4 sites) | - Male (%) | 40.5% | | | Diagnosis at age of 62 stratified by 25(OH)D quintiles | | X | X | X | X | X
Hutchinson 2010^79^ Tromsø Study Tromso, Norway | - Health status | Nd | | | Smoking and non-smoking cause of death stratified by 25(OH)D quartiles | | X | X | X | | X
Hutchinson 2010^79^ Tromsø Study Tromso, Norway | - Mean Age (range), y | nd | | | Smoking and non-smoking cause of death stratified by 25(OH)D quartiles | | X | X | X | | X
Hutchinson 2010^79^ Tromsø Study Tromso, Norway | - Male (%) | nd | | | Smoking and non-smoking cause of death stratified by 25(OH)D quartiles | | X | X | X | | X
Jacobs 2011^144^ Women's Healthy Eating and Living Well (WHEL) Study | - Health status | Cancer in remission | | | Breast cancer survivors stratified by 25(OH)D concentration categories
Jacobs 2011^144^ Women's Healthy Eating and Living Well (WHEL) Study | - Mean Age (SD), y | 51.9 (SD 9) | | | Breast cancer survivors stratified by 25(OH)D concentration categories
Jacobs 2011^144^ Women's Healthy Eating and Living Well (WHEL) Study | - Male (%) | 0% | | | Breast cancer survivors stratified by 25(OH)D concentration categories
Johansson 2012^211^ MrOS Sweden: Gothenburg, Malmö, Uppsala | - Health status | Some with diabetes, htn, cancer, stroke, MI, angina | | | Death and mortality stratified by varying 25(OH)D concentration levels | | X | | X | | X
Johansson 2012^211^ MrOS Sweden: Gothenburg, Malmö, Uppsala | - Mean Age (SD), y | 75.7 (SD 3.4) | | | Death and mortality stratified by varying 25(OH)D concentration levels | | X | | X | | X
Johansson 2012^211^ MrOS Sweden: Gothenburg, Malmö, Uppsala | - Male (%) | 100% | | | Death and mortality stratified by varying 25(OH)D concentration levels | | X | | X | | X
Kestenbaum 2011^81^ Cardiovascular Health Study US (various) | - Health status | nd | | | All-cause mortality stratified by 25(OH)D quartiles
Kestenbaum 2011^81^ Cardiovascular Health Study US (various) | - Mean Age (range), y | 73 (SD 4) | | | All-cause mortality stratified by 25(OH)D quartiles
Kestenbaum 2011^81^ Cardiovascular Health Study US (various) | - Male (%) | 42% | | | All-cause mortality stratified by 25(OH)D quartiles
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study US Pittsburgh, Memphis | - Health status | Well-functioning | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study US Pittsburgh, Memphis | - Mean Age (SD), y | 74.7 (SD 2.9) | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study US Pittsburgh, Memphis | - Male (%) | 49% | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Lin 2012^83^ General Population Trial of Linxian, China | - Health status | Healthy, Hypertension | | | All-cause mortality stratified by continuous 25(OH)D | | X | X | X | | X
Lin 2012^83^ General Population Trial of Linxian, China | - Mean Age (SD), y | 56.5 (7.9) | | | All-cause mortality stratified by continuous 25(OH)D | | X | X | X | | X
Lin 2012^83^ General Population Trial of Linxian, China | - Male (%) | 55% | | | All-cause mortality stratified by continuous 25(OH)D | | X | X | X | | X
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Health status | More than 1/3 being treated for hypertension | | | Overall mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Mean Age (range), y | 71 (0.6) | | | Overall mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala, Sweden | - Male (%) | 100% | | | Overall mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Pilz 2009^73^ Hoorn Study Netherlands | - Health status | More than 20% Type 2 Diabetes or impaired glucose tolerance | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Pilz 2009^73^ Hoorn Study Netherlands | - Mean Age (range), y | 69.2 (6.5) | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Pilz 2009^73^ Hoorn Study Netherlands | - Male (%) | 50% | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Semba 2010^93^ InCHIANTI Italy | - Health status | Nd | | | All-cause mortality and cardiovascular mortality stratified by 25(OH)D quartiles | | X | X | | X | X
Semba 2010^93^ InCHIANTI Italy | - Mean Age (range), y | 78 (72–85) | | | All-cause mortality and cardiovascular mortality stratified by 25(OH)D quartiles | | X | X | | X | X
Semba 2010^93^ InCHIANTI Italy | - Male (%) | 67.3% | | | All-cause mortality and cardiovascular mortality stratified by 25(OH)D quartiles | | X | X | | X | X
Signorello 2013^74^ Southern Community Cohort Study US | - Health status | nd | | | All-cause mortality stratified by 25(OH)D quartiles | | | X | | | X
Signorello 2013^74^ Southern Community Cohort Study US | - Mean Age (range), y | nd | | | All-cause mortality stratified by 25(OH)D quartiles | | | X | | | X
Signorello 2013^74^ Southern Community Cohort Study US | - Male (%) | nd | | | All-cause mortality stratified by 25(OH)D quartiles | | | X | | | X
Smit 2012^213^ NHANES III US (various) | - Health status | Malnourished/frailty, pre-frail, not frail | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Smit 2012^213^ NHANES III US (various) | - Mean Age (SD), y | 69.4 (SD 0.3) | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Smit 2012^213^ NHANES III US (various) | - Male (%) | 46.5% | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | X | X
Szulc 2009^214^ MINOS Study Montceau les Mines, France | - Health status | nd | | | Mortality stratified by 25(OH)D quartiles | X | X | X | X | | X
Szulc 2009^214^ MINOS Study Montceau les Mines, France | - Mean Age (SD), y | 64 (SD 7) | | | Mortality stratified by 25(OH)D quartiles | X | X | X | X | | X
Szulc 2009^214^ MINOS Study Montceau les Mines, France | - Male (%) | 55% | | | Mortality stratified by 25(OH)D quartiles | X | X | X | X | | X
Szulc 2009^215^ MINOS Study Montceau les Mines, France | - Health status | nd | | | Mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Szulc 2009^215^ MINOS Study Montceau les Mines, France | - Mean Age (SD), y | 64 (SD 7) | | | Mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Szulc 2009^215^ MINOS Study Montceau les Mines, France | - Male (%) | 100% | | | Mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | - Health status | Postmenopausal, 54–62% hypertension | | | Overall mortality stratified by 25(OH)D tertiles | | X | X | X | | X
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | - Mean Age (range), y | 61.8 (53.4–72.7/SD 6.2) | | | Overall mortality stratified by 25(OH)D tertiles | | X | X | X | | X
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | - Male (%) | 48.6% | | | Overall mortality stratified by 25(OH)D tertiles | | X | X | X | | X
Welsh 2012^60^ MIDSPAN Family Study Renfrew and Paisley, UK | - Health status | vitamin D not deficient | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Welsh 2012^60^ MIDSPAN Family Study Renfrew and Paisley, UK | - Mean Age (range), y | 45.2 (6.2) | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Welsh 2012^60^ MIDSPAN Family Study Renfrew and Paisley, UK | - Male (%) | 46% | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | X | X | X | X
Tomson 2013^75^ Whitehall study London, UK | - Health status | self-reported health good/excellent 77.4% | | | Death (all non-vascular) and Death (al causes) stratified by 25(OH)D doubling concentration | | | X | X | | X
Tomson 2013^75^ Whitehall study London, UK | - Mean age (SD), y | 76.9 (SD 4.9) | | | Death (all non-vascular) and Death (al causes) stratified by 25(OH)D doubling concentration | | | X | X | | X
Tomson 2013^75^ Whitehall study London, UK | - Male (%) | 100% | | | Death (all non-vascular) and Death (al causes) stratified by 25(OH)D doubling concentration | | | X | X | | X
Skaaby 2013^86^ Monica10 and Inter99 Denmark | - Health status; - Mean age (SD), y; - Male (%) | NR Monica 10: 55.4 Inter 99: 46.1 Monica 10: 50.2 Inter 99: 49.2 | | | All-cause mortality stratified by 25(OH)D quartiles | | X | | X | X | X
Wong 2013^217^ Australia | - Health status | NR | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Wong 2013^217^ Australia | - Mean age (SD), y | 76 (70–88) | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Wong 2013^217^ Australia | - Male (%) | 100% | | | All-cause mortality stratified by 25(OH)D quartiles | | X | X | X | | X
Sempos 2013^218^ NHANES III US | - Health status | NR | | | All-cause mortality stratified by 25(OH)D in 9 categories | | X | | | X
Sempos 2013^218^ NHANES III US | - Mean age (SE), y | 45 (SE 0.47) | | | All-cause mortality stratified by 25(OH)D in 9 categories | | X | | | X
Sempos 2013^218^ NHANES III US | - Male (%) | 49% | | | All-cause mortality stratified by 25(OH)D in 9 categories | | X | | | X
Schottker 2013^76^ ESTHER Germany | - Health status | NR | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Mean age (SD), y | 62 (SD 6.5) | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Schottker 2013^76^ ESTHER Germany | - Male (%) | 43.8% | | | All-cause mortality stratified by 25(OH)D tertiles | X | X | | X | X | X
Formiga 2014^77^ Octabaix Spain | - Health status | Oldest old | | | Total mortality stratified by 25(OH)D quartiles | | X | | X
Formiga 2014^77^ Octabaix Spain | - Mean age (SD), y | 85 (SD 0) | | | Total mortality stratified by 25(OH)D quartiles | | X | | X
Formiga 2014^77^ Octabaix Spain | - Male (%) | 39.4% | | | Total mortality stratified by 25(OH)D quartiles | | X | | X

A Fracture Risk Epidemiology in the Elderly

B ∼40% with CVD and ∼60% arthritis

Table 39 Vitamin D and all-cause mortality: Results of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Age Range, Sex | Outcome | Followup Duration (Time to Dx) | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR | 95% CI | P for trend | Study Quality
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 6.0–23.0 (M)/ 7.0–19.0 (F) | 41 | 75 | 1.74 | 0.91, 3.34 | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | | | | | | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 23.1–30.0 (M)/ 29.1–24.0 (F) | 34 | 86 | 1.4 | 0.73, 2.70 | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | | | | | | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 30.1–37.0 (M)/ 24.1–30.2 (F) | 21 | 80 | 0.9 | 0.45, 1.79 | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | | | | | | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 37.1–47.0 (M)/ 30.3–39.0 (F) | 17 | 78 | 0.8 | 0.39, 1.62 | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | | | | | | 0.03 | B
Jia 2007^219^ UK (57°N) [17442130] | >75, both sexes | Mortality | 69 | 25(OH)D | 47.1–82.0 (M)/ 39.1–82.0 (F) | 16 | 79 | 1 | Reference | 0.03 | B
Sambrook 2004 & 2006^220,221^ FREE^A^ Australia (33°S) [15531500 & 16598375] | >65, both sexes | Mortality | 27 | 25(OH)D | NA | 559 | 1112 | 0.87^B^ | 0.75, 1.01 | nd | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | <25 | 66 | 127 | 1.28 | 0.85, 1.92 | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | | | | | | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | 25–49.9 | 42 | 462 | 1 | 0.72, 1.40 | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | | | | | | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | 50–74.9 | 30 | 440 | 0.91 | 0.65, 1.26 | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | | | | | | 0.19 | C
Visser 2006^222^ Longitudinal Aging Study Netherlands (52°N) [16960177] | >65, both sexes | Mortality | 72 | 25(OH)D | ≥75 | 29 | 231 | 1 | Reference | 0.19 | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.26 | 1.08, 1.46 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1.06 | 0.89, 1.24 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.93 | 0.79, 1.10 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1 | Reference | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.04 | 0.83, 1.30 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 0.94 | 0.75, 1.19 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.82 | 0.64, 1.05 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, men only | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1 | Reference | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.55 | 1.15, 1.98 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1.27 | 0.97, 1.66 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 1.16 | 0.87, 1.55 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | >20, women only | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1 | Reference | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.28 | 0.93, 1.76 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 1.13 | 0.81, 1.56 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.81 | 0.58, 1.14 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | 20–65, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1 | Reference | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | <17.8 | nd | nd | 1.26 | 1.03, 1.54 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | 17.8–24.3 | nd | nd | 0.99 | 0.82, 1.20 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | 24.4–32.1 | nd | nd | 0.97 | 0.79, 0.82 | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | | | | | | nd | C
Melamed 2008^85^ NHANES III US (various) [18695076] | ^3^65, both sexes | Mortality | 104 | 25(OH)D | >32.1 | nd | nd | 1 | Reference | nd | C
NEW studies
Bolland 2010^58^ New Zealand | Post-menopausal women | Primary-Death | 5 yrs | 25(OH)D | <50 nmol/L | 13 | 373 | HR=0.90 | 0.4, 2.0 | 0.82 | A
Bolland 2010^58^ New Zealand | Post-menopausal women | Primary-Death | 5 yrs | 25(OH)D | | | | | | 0.82 | A
Bolland 2010^58^ New Zealand | Post-menopausal women | Primary-Death | 5 yrs | 25(OH)D | ≥50 nmol/L | 16 | 366 | 1.00 | Reference | 0.82 | A
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Quartile 1: <49.75 nmol/L | | 372 | HR=0.95 | 0.68, 1.34 | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Quartile 2: ≥49.75 to <63.0 nmol/L | | 370 | 1.05 | 0.75, 1.47 | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Quartile 3: ≥63.0 to <75.0 nmol/L | | 372 | 0.89 | 0.64, 1.24 | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Quartile 4: ≥75.0 | | 376 | 1.00 | Reference | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.961 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Deficient, <50 nmol/L | | 376 | 0.94 | 0.67, 1.32 | 0.706 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.706 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Insufficient, 50 to <75 nmol/L | | 737 | 0.97 | 0.72, 1.30 | 0.706 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | 0.706 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | Sufficient, ≥75 nmol/L | | 377 | 1.00 | Reference | 0.706 | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | | | | | | | B
Cawthon 2010^98^ MrOS (multisite) US | Men (51-70 yrs; ≥71 years) | all-cause mortality | 7.3 yrs | 25(OH)D | per SD decrease | | | 1.01 | 0.89, 1.14 | | B
de Boer 2012^87^ Cardiovascular Health Study US (various) | White older adults | Death | 11 yrs | 25(OH)D | Normal level | 539 | 1126 | HR=1.00 | Reference | NR | A
de Boer 2012^87^ Cardiovascular Health Study US (various) | White older adults | Death | 11 yrs | 25(OH)D | Low level (season specific, ranges 43–61 nmol/L) | 287 | 495 | 1.32 | 1.14, 1.53 | NR | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | Quartile 1: 3.25–36.50 nmol/L | | 608 | HR=1.25 | 0.80–1.95 | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | | | | | | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | Quartile 2: 36.51–49.95 nmol/L | | 606 | 1.13 | 0.73–1.75 | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | | | | | | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | Quartile 3: 49.96–65.38 nmol/L | | 608 | 1.17 | 0.75–1.81 | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | | | | | | 0.39 | A
Eaton 2011^70^ WHI substudy US (multisite) | Postmenopausal women 50–79 years | all-cause mortality | 10 yrs | 25(OH)D | Quartile 4: 65.39–146.67 nmol/L | | 607 | 1.00 | Reference | 0.39 | A
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | <36.3 | 128 | 242 | HR=1.00 | Reference | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | | | | | | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | 36.4–48.6 | 108 | 239 | 0.82 | 0.63, 1.07 | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | | | | | | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | 48.7–60.5 | 117 | 241 | 0.91 | 0.70, 1.18 | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | | | | | | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | 60.6–76.8 | 95 | 240 | 0.78 | 0.59, 1.03 | <0.01 | B
Fedirko 2012^101^ EPIC US (4 sites) | Men and women (diagnosed at an average age of 62) | overall mortality | 73 mos | 25(OH)D | >76.8 | 93 | 240 | 0.67 | 0.50, 0.88 | <0.01 | B
Hutchinson 2010^79^ Tromsø Study (Norway) | Men(55–74 yrs) Women (50–74 yrs) | all-cause death | 11.7 yrs | 25(OH)D | Quartile 1: mean=33.8 (sd=7.6) | 247 | 1184 | HR=1.32 | 1.07–1.62 | NR | B
nonsmokers | | | | | Quartile 2: mean=46.7 (sd=6.0) | 198 | 1187 | 1.06 | 0.86–1.31 | NR | B
nonsmokers | | | | | | | | | | NR | B
nonsmokers | | | | | Quartile 3: mean=56.2 (sd=6.0) | 190 | 1192 | 1.09 | 0.88–1.34 | NR | B
nonsmokers | | | | | | | | | | NR | B
nonsmokers | | | | | Quartile 4: mean=72.3 (sd=13.2) | 163 | 1188 | 1.00 | Reference | NR | B
| | | | | | | | | | | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | Quartile 1: mean=33.8 (sd=7.6) | 156 | 597 | 1.06 | 0.83–1.35 | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | | | | | | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | Quartile 2: mean=46.7 (sd=6.0) | 143 | 606 | 0.97 | 0.76–1.25 | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | | | | | | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | Quartile 3: mean=56.2 (sd=6.0) | 138 | 607 | 1.04 | 0.81–1.33 | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | | | | | | NR | B
smokers | | all-cause death | 11.7 yrs | 25(OH)D | Quartile 4: mean=72.3 (sd=13.2) | 124 | 600 | 1.00 | Reference | NR | B
Jacobs 2011^144^ Women's Healthy Eating and Living Well (WHEL) Study | Breast cancer survivors who had completed primary treatment of early stage breast cancer within the previous 4 years | mortality | 7.3 yrs | 25(OH)D | Insufficient, <50 nmol/L | 164 | | 1.13 | 0.72, 1.79 | 0.59 | B
Jacobs 2011^144^ Women's Healthy Eating and Living Well (WHEL) Study | Breast cancer survivors who had completed primary treatment of early stage breast cancer within the previous 4 years | mortality | 7.3 yrs | 25(OH)D | Sufficient, ≥50 nmol/L | 336 | | 1.00 | Reference | 0.59 | B
Johansson 2012^211^ MrOS (Sweden) | Men (70–81 yrs) | death | 8.2 yrs | 25(OH)D | per SD decrease | 577 | 2878 | HR=1.16 | 1.06, 1.26 | NR | A
Kestenbaum 2011^81^ Cardiovascular Health Study | >65 years | Primary-all-cause mortality | 14 yrs | 25(OH)D | >75 nmol/L | 329 | 681 | HR=1.00 | Reference | 0.012 | B
Kestenbaum 2011^81^ Cardiovascular Health Study | >65 years | Primary-all-cause mortality | 14 yrs | 25(OH)D | 37.5–75.0 nmol/L | 668 | 1247 | 1.15 | 1.00, 1.33 | 0.012 | B
Kestenbaum 2011^81^ Cardiovascular Health Study | >65 years | Primary-all-cause mortality | 14 yrs | 25(OH)D | <37.5 nmol/L | 229 | 384 | 1.29 | 1.05, 1.57 | 0.012 | B
Kestenbaum 2011^81^ Cardiovascular Health Study | >65 years | Primary-all-cause mortality | 14 yrs | 25(OH)D | continuous per 25 nmol/L | 1226 | 2312 | 1.09 | 1.02, 1.17 | 0.012 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | < 25 nmol/L | 44 | 108 | HR=2.27 | 1.59, 3.24 | <0.001 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | 25 to <50 nmol/L | 241 | 750 | 1.48 | 1.20, 1.84 | <0.001 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | | | | | | <0.001 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | 50 to <75 nmol/L | 229 | 931 | 1.25 | 1.02, 1.52 | <0.001 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | | | | | | <0.001 | B
Kritchevsky 2012^212^ Health, Aging, and Body Composition (ABC) Study | Older community dwelling men and women (70–79 yrs) | all-cause mortality | 8.5 yrs | 25(OH)D | ≥75 nmol/L | 177 | 849 | 1.00 | Reference | <0.001 | B
whites | | all-cause mortality | 8.5 yrs | 25(OH)D | < 25 nmol/L | 10 | 25 | 2.02 | 1.02, 3.99 | 0.001 | B
whites | | all-cause mortality | 8.5 yrs | 25(OH)D | 25 to <50 nmol/L | 82 | 279 | 1.54 | 1.16, 2.06 | 0.001 | B
whites | | all-cause mortality | 8.5 yrs | 25(OH)D | 50 to <75 nmol/L | 138 | 620 | 1.22 | 0.96, 1.55 | 0.001 | B
whites | | all-cause mortality | 8.5 yrs | 25(OH)D | ≥75 nmol/L | 143 | 691 | 1.00 | Reference | 0.001 | B
| | | | | | | | | | | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | <25 nmol/L | 34 | 83 | 2.59 | 1.57, 4.26 | <0.001 | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | 25 to <50 nmol/L | 159 | 471 | 1.76 | 1.20, 2.57 | <0.001 | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | | | | | | <0.001 | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | 50 to <75 nmol/L | 91 | 311 | 1.60 | 1.07, 2.39 | <0.001 | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | | | | | | <0.001 | B
blacks | | all-cause mortality | 8.5 yrs | 25(OH)D | ≥75 nmol/L | 34 | 158 | 1.00 | Reference | <0.001 | B
Lin 2012^83^ General Population Trial of Linxian (China) | | all-cause mortality | 24 yrs | 25(OH)D | continuous 25(OH)D | 793 | 1101 | HR=1.01 | 0.97, 1.05 | 0.735 | B
Lin 2012^83^ General Population Trial of Linxian (China) | | all-cause mortality | 24 yrs | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ General Population Trial of Linxian (China) | Men 40–69 yrs | all-cause mortality | 24 yrs | 25(OH)D | continuous 25(OH)D | 479 | 608 | 0.99 | 0.94, 1.04 | 0.7 | B
Lin 2012^83^ General Population Trial of Linxian (China) | | all-cause mortality | 24 yrs | 25(OH)D | continuous 25(OH)D | | | | | | B
Lin 2012^83^ General Population Trial of Linxian (China) | Women 40–69 yrs | all-cause mortality | 24 yrs | 25(OH)D | continuous 25(OH)D | 314 | 493 | 1.03 | 0.97, 1.10 | 0.348 | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala (Sweden) | Elderly men birth 1920–1924 | overall mortality | 12.7 yrs | 25(OH)D | < 10th percentile (<46 nmol/L) | 76 | 119 | HR=1.43 | 1.11, 1.84 | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala (Sweden) | Elderly men birth 1920–1924 | overall mortality | 12.7 yrs | 25(OH)D | | | | | | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala (Sweden) | Elderly men birth 1920–1924 | overall mortality | 12.7 yrs | 25(OH)D | 10th–90th percentile (46–93 nmol/L) | 444 | 956 | 1.00 | Reference | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala (Sweden) | Elderly men birth 1920–1924 | overall mortality | 12.7 yrs | 25(OH)D | | | | | | | B
Michaelsson 2010^84^ Uppsala Longitudinal Study of Adult Men Uppsala (Sweden) | Elderly men birth 1920–1924 | overall mortality | 12.7 yrs | 25(OH)D | >90th percentile (>93 nmol/L) | 64 | 119 | 1.27 | 0.97, 1.66 | | B
Pilz 2009^73^ Hoorn Study Netherlands | Men and women (50–75 yrs) | all-cause mortality | 6.2 yrs | 25(OH)D | 1st quartile (mean 25(OH)D 30.6 nmol/L) | 21 | 152 | HR=1.97 | 1.08, 3.58 | 0.027 | B
Pilz 2009^73^ Hoorn Study Netherlands | Men and women (50–75 yrs) | all-cause mortality | 6.2 yrs | 25(OH)D | | | | | | 0.027 | B
Pilz 2009^73^ Hoorn Study Netherlands | Men and women (50–75 yrs) | all-cause mortality | 6.2 yrs | 25(OH)D | 2nd–4th quartiles (mean 25(OH)D 45.6–78.9) | 30 | 462 | 1.00 | Reference | 0.027 | B
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D | 1st quartile: <26.3 nmol/L | NR | 252 | HR 2.11 | 1.22, 3.64
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D | 2nd quartile: 26.3–40.0 nmol/L | NR | 254 | HR 1.41 | 0.83, 2.40
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D | 3rd quartile: 40.3–64 nmol/L | NR | 247 | HR 1.12 | 1.09, 1.15
Semba 2010 93 InCHIANTI Italy | | all-cause mortality | 6.5 yrs | 25(OH)D | 4th quartile: >64 nmol/L | NR | 253 | HR 1.00 | Reference
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 4: (>54.1nmol/L) | 364 | 827 | 1.00 | Reference | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 3: (37.9–54.1 nmol/L) | 405 | 868 | 1.17 | 0.95, 1.45 | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 2: (25.5–37.9 nmol/L) | 482 | 945 | 1.41 | 1.14, 1.74 | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
Signorello 2013^74^ Southern Community Cohort Study US | Men and women (40–79 yrs) | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 1: <25.5 nmol/L) | 601 | 1064 | 1.80 | 1.43, 2.27 | <0.001 | A
| | | | | | | | | | | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 4: (>54.1nmol/L) | 181 | 400 | 1.00 | Reference | 0.003 | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 3: (37.9–54.1 nmol/L) | 266 | 565 | 1.15 | 0.87, 1.53 | 0.003 | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | 0.003 | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 2: (25.5–37.9nmol/L) | 353 | 730 | 1.19 | 0.91, 1.57 | 0.003 | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | 0.003 | A
African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 1: <25.5 nmol/L) | 475 | 855 | 1.60 | 1.20, 2.14 | 0.003 | A
| | | | | | | | | | 0.003 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 4: (>54.1nmol/L) | 179 | 419 | 1.00 | Reference | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 3: (37.9–54.1 nmol/L) | 136 | 296 | 1.09 | 0.78, 1.52 | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 2: (25.5–37.9 nmol/L) | 129 | 214 | 1.99 | 1.37, 2.90 | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | | | | | | <0.001 | A
non-African Americans | | all-cause mortality | 1 yr or more | 25(OH)D | Quartile 1: <25.5 nmol/L) | 122 | 203 | 2.11 | 1.39, 3.21 | <0.001 | A
Smit 2012^213^ NHANES III | Adults (60 and over) | mortality | 12 yrs | 25(OH)D | Quartile 1: <49.5 nmol/l | NR | NR | 2.98 | 2.01, 4.42 | | A
| | mortality | 12 yrs | 25(OH)D | | | | | | | A
frail | | mortality | 12 yrs | 25(OH)D | Quartile 2: 49.5–66.4 nmol/l | NR | NR | 2.37 | 1.44, 3.89 | | A
frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
frail | | mortality | 12 yrs | 25(OH)D | Quartile 3: 66.5–84.1 nmol/l | NR | NR | 2.50 | 1.48, 4.21 | | A
frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
frail | | mortality | 12 yrs | 25(OH)D | Quartile 4: >84.1 nmol/l | NR | NR | 1.43 | 0.83, 2.46 | | A
| | | | | | | | | | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | Quartile 1: <49.5 nmol/l | NR | NR | 1.97 | 1.61, 2.40 | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | Quartile 2: 49.5–66.4 nmol/l | NR | NR | 1.62 | 1.29, 2.03 | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | Quartile 3: 66.5–84.1 nmol/l | NR | NR | 1.51 | 1.16, 1.97 | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
pre-frail | | mortality | 12 yrs | 25(OH)D | Quartile 4: >84.1 nmol/l | NR | NR | 1.82 | 1.41, 2.35 | | A
| | | | | | | | | | | A
not frail | | mortality | 12 yrs | 25(OH)D | Quartile 1: <49.5 nmol/l | NR | NR | 1.25 | 0.97, 1.60 | | A
not frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
not frail | | mortality | 12 yrs | 25(OH)D | Quartile 2: 49.5–66.4 nmol/l | NR | NR | 1.20 | 0.96, 1.49 | | A
not frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
not frail | | mortality | 12 yrs | 25(OH)D | Quartile 3: 66.5–84.1 nmol/l | NR | NR | 1.11 | 0.88, 1.40 | | A
not frail | | mortality | 12 yrs | 25(OH)D | | | | | | | A
not frail | | mortality | 12 yrs | 25(OH)D | Quartile 4: >84.1 nmol/l | NR | NR | 1.00 | Reference | | A
Szulc 2009^214^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | per SD decrease | 600 | 782 | 1.22 | 1.01, 1.48 | | A
Szulc 2009^214^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | Quartile 1 <65 nmol/l summer or <40 nmol/l other months | NR | NR | 1.44 | 1.03, 2.03 | | A
Szulc 2009^214^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | | | | | | | A
Szulc 2009^214^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | Quartiles 2–4 | NR | NR | 1.00 | Reference | | A
Szulc 2009^215^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | Quartile 1 | NR | NR | 1.6–1.8 | NR | <0.05 | A
Szulc 2009^215^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | | | | | | <0.05 | A
Szulc 2009^215^ MINOS Study | Men(50 yrs and over) | mortality | 10 yrs | 25(OH)D | Quartiles 2–4 | NR | NR | 1.00 | Reference | <0.05 | A
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | Men (average age 61.8) | mortality | 9.1 yrs | 25(OH)D | Tertile 1: 8.9–34.0 nmol/L | 39 | 379 | 2.06 | 1.12, 3.80 | 0.02 | A
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | Men (average age 61.8) | mortality | 9.1 yrs | 25(OH)D | Tertile 2: 34.1–50.8 nmol/L | 31 | 378 | 1.68 | 0.92, 3.07 | 0.02 | A
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | Men (average age 61.8) | mortality | 9.1 yrs | 25(OH)D | | | | | | 0.02 | A
Virtanen 2011^216^ Kuopio Ischaemic Heart Disease Risk Factor (KIHD) Study Finland | Men (average age 61.8) | mortality | 9.1 yrs | 25(OH)D | Tertile 3: 50.9–112.8 nmol/L | 17 | 379 | 1.00 | Reference | 0.02 | A
Welsh 2012^60^ MIDSPAN Family Study Scotland | | Primary-all-cause mortality | 14.4 yrs | 25(OH)D | per 1 SD increase | 70 | 1492 | 0.74 | 0.56, 0.99 | | B
Welsh 2012^60^ MIDSPAN Family Study Scotland | | Primary-all-cause mortality | 14.4 yrs | 25(OH)D | | | | | | | B
Welsh 2012^60^ MIDSPAN Family Study Scotland | Men and women | Primary-all-cause mortality | 14.4 yrs | 25(OH)D | Deficient, <37.5 nmol/L | NR | 689 | 2.02 | 1.17, 3.51 | | B
Welsh 2012^60^ MIDSPAN Family Study Scotland | Men and women | Primary-all-cause mortality | 14.4 yrs | 25(OH)D | | | | | | | B
Welsh 2012^60^ MIDSPAN Family Study Scotland | Men and women | Primary-all-cause mortality | 14.4 yrs | 25(OH)D | Not deficient ≥37.5 nmol/L | NR | 803 | 1.00 | Reference | | B
Tomson 2013^75^ Whitehall study | | Death, all non-vascular | 13.1 yrs | 25(OH)D | Doubling Concentration | 1857 | 5409 | 0.77 | 0.69, 0.86 | | B
Tomson 2013^75^ Whitehall study | | | 13.1 yrs | 25(OH)D | Doubling Concentration | | | | | | B
Tomson 2013^75^ Whitehall study | | Death, all causes | 13.1 yrs | 25(OH)D | Doubling Concentration | 3215 | 5409 | 0.78 | 0.72,0.85 | | B
Skaaby 2013^86^ Monica10 and Inter99 | | all-cause mortality | 10 yrs | 25(OH)D | per 10nmol/L | 633 | 8329 | 0.95 | 0.92, 0.99 | 0.005 | B
Skaaby 2013^86^ Monica10 and Inter99 | | all-cause mortality | 10 yrs | 25(OH)D | Q1 | 633 | 8329 | 1.00 | Reference | 0.041 | B
Skaaby 2013^86^ Monica10 and Inter99 | | all-cause mortality | 10 yrs | 25(OH)D | Q2 | 633 | 8329 | 0.79 | 0.64, 0.98 | 0.041 | B
Skaaby 2013^86^ Monica10 and Inter99 | | all-cause mortality | 10 yrs | 25(OH)D | Q3 | 633 | 8329 | 0.81 | 0.65, 1.01 | 0.041 | B
Skaaby 2013^86^ Monica10 and Inter99 | | all-cause mortality | 10 yrs | 25(OH)D | Q4 | 633 | 8329 | 0.73 | 0.57, 0.92 | 0.041 | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | per 10nmol/L decrease in 25(OH)D | 1144 | 4203 | 1.04 | 1.01, 1.07 | | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | halving of 25(OH)D | 1144 | 4203 | 1.21 | 1.08, 1.35 | | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | Q1: 10–52.8 | 1144 | 4203 | 1.20 | 1.02, 1.42 | | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | Q2: 52.9–67.3 | 1144 | 4203 | 1.00 | Reference | | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | Q3: 67.4–81.6 | 1144 | 4203 | 0.99 | 0.84, 1.17 | | B
Wong 2013^217^ | | all-cause mortality | 6.7 yrs | 25(OH)D | Q4: 81.7–238.4 | 1144 | 4203 | 0.99 | 0.83, 1.17 | | B
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | <20 | 79 | 251 | 1.6 | 1.2, 2.2 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 20–29 | 297 | 1270 | 1.5 | 1.2, 1.8 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 30–39 | 592 | 2340 | 1.3 | 1.1, 1.5 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 40–49 | 694 | 2790 | 1.1 | 0.96, 1.3 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 50–59 | 668 | 2526 | 1.2 | 1.01, 1.30 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 60–74 | 775 | 3046 | 1.1 | 0.99, 1.30 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 75–99 | 533 | 2156 | 1.0 | Reference | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | 100–119 | 110 | 518 | 1.1 | 0.9, 1.4 | | A
Sempos 2013^218^ NHANES III | | death from all-cause | 15 yrs | 25(OH)D | >=120 | 36 | 202 | 1.4 | 0.9, 2.2 | | A
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | <30 | 238 | 1444 | 1.68 | 1.41, 2.01 | | B
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | 30–50 | 448 | 4199 | 1.17 | 1.01, 1.35 | | B
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | >50 | 397 | 3935 | 1.00 | Reference | | B
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | <30 | 142 | 609 | 1.41 | 1.13, 1.77 | | B
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | 30–50 | 269 | 1706 | 1.09 | 0.90,1.31 | | B
Schottker 2013^76^ ESTHER | >=65 yrs of age | all-cause mortality | 9.5 yrs | 25(OH)D | >50 | 236 | 1394 | 1.00 | Reference | | B
Schottker 2013^76^ ESTHER | | | | | | | | | | | B
Schottker 2013^76^ ESTHER | <65 yrs of age | | | | <30 | 238 | 835 | 2.08 | 1.58, 2.76 | | B
Schottker 2013^76^ ESTHER | <65 yrs of age | | | | 30–50 | 448 | 2493 | 1.30 | 1.04, 1.63 | | B
Schottker 2013^76^ ESTHER | <65 yrs of age | | | | >50 | 397 | 2541 | 1.00 | Reference | | B
Formiga 2014^77^ Octabaix | | total mortality | 2.8 yrs | 25(OH)D | Q1: <34.94 | 15 | 71 | 1.28 | 0.61, 2.6 | 0.41 | B
Formiga 2014^77^ Octabaix | | total mortality | 2.8 yrs | 25(OH)D | Q2: 34.94–61.65 | 18 | 77 | 1.36 | 0.67, 2.74 | 0.41 | B
Formiga 2014^77^ Octabaix | | total mortality | 2.8 yrs | 25(OH)D | Q3: 61.66–83.37 | 11 | 84 | 0.76 | 0.34, 1.68 | 0.41 | B
Formiga 2014^77^ Octabaix | | total mortality | 2.8 yrs | 25(OH)D | Q4:>83.37 | 14 | 80 | 1.00 | Reference | 0.41 | B

A Fracture Risk Epidemiology in the Elderly

B Per unit change in the log-transformed concentration

The current report identified 25 observational studies that assessed the association between serum 25(OH)D concentrations and all-cause mortality as an outcome. None of the outcomes fit the criteria needed to be included in the meta-analysis that was conducted for the original report and are described below. As mentioned in the Methods section, the original report updated and reanalyzed published meta-analyses of mortality outcomes. That report drew its own conclusions based on its analyses. The original report also commented on the concordance of its conclusions with those of the published meta-analyses.

##### Relevant Published Systematic Reviews of RCTs (With Meta-Analyses)

The original report identified two systematic reviews (with meta-analyses) of RCTs that summarized the effect of vitamin D supplementation with or without calcium on mortality.204,205 One systematic review (Avenell 2008) examined only trials on fall prevention, and briefly described results on mortality.205 The second meta-analysis (Autier 2007) focused specifically on mortality.204 It included all RCTs identified in the first, as well as additional trials (which were not eligible for the primary analysis of the Avenell 2008 systematic review, namely prevention of falls).204 Therefore, the Autier 2007 meta-analysis was used as the basis for our reanalysis.

Table 37 summarizes the findings of the Autier 2007 systematic review.

##### Additional Identified RCTs (Not Included in Published Systematic Reviews)

No RCTs were identified for the current report that assessed the effect of vitamin D or vitamin D and calcium supplementation on risk for all-cause mortality. For the original report, Lyons 2007 (n=3343, 24% males) used monthly supplementation with 100,000 IU of vitamin D_2_, orally for 3 years.185 The trial took place in South Wales (latitude ∼52°N) and included older people (mean age 84 y) living in sheltered accommodation. The primary outcome was prevention of fractures. The Lyons 2007 RCT received grade “C” for the all-cause mortality outcome, because of inconsistencies in the reported data. This RCT is included in the reanalysis described below.

##### Reanalysis

For the re-analysis conducted in the original report, they excluded 5 of 18 trials in the Autier 2007 meta-analysis: One trial was on patients with congestive heart failure,206 one was published only in abstract form,207 in one trial the controls also received supplementation with vitamin D, albeit with a smaller dose,208 and two trials used vitamin D injections.209,210 One additional eligible RCT (Lyons 2007)185 was identified and included in our meta-analysis.

Overall, four trials (13,899 patients) used only vitamin D supplementation without calcium. Among the four trials, sample sizes ranged from 2578 to 5292 participants. Followup periods ranged from 36 to 60 months. Vitamin D doses in most trials ranged between 400 and 830 IU per day.

Overall, there were no significant effects of vitamin D supplementation on mortality. The RR was 0.97 (95% CI 0.92, 1.02), with no evidence for between-study heterogeneity (P=0.39, I^2^=0%).

##### Cohort Studies

The current report identified 25 cohort studies (one article reported on two studies, and one study was reported in two articles) that assessed the association between serum 25(OH)D concentration and risk for all-cause mortality. Of the 25, six found no association (rated 1 rated A, 6 rated B).58,70,77,79,83,98,144 These studies ranged in length of followup from 3 to 24 years. Sixteen found an association of lower 25(OH)D concentrations with increased risk for mortality (6 rated A, 9 rated B: one article reported on two studies);60,73-77,81,86,87,101,211-218 most associations were small, limited to a particular subgroup, or limited to the first 3 years after baseline measurement.211 Two studies reported an association of both higher and lower 25(OH)D concentrations with increased mortality risk, that is a j-shaped association (rated A and B).84,218 A 15-year followup assessment of 15,099 NHANES participants (age 20 and older) reported the lowest association with all-cause mortality at a 25(OH)D concentration of 81 nmol/L. For 25(OH)D concentrations less than 20nmol/L, the RR for all-cause mortality was 2.2 (95% CI 1.6, 2.9) and for 25(OH)D concentrations greater than 120nmol/L, the RR was 1.5 (95% CI 1.02, 2.30).218 These same associations were seen for both men and women, for adults 20 to 64 years of age and for non-Hispanic whites.

The original report identified four prospective cohort studies described in 5 publications.85,219-222 The characteristics of the four cohorts are shown in Table 38. One was rated “B”219 for methodological quality and the remaining were rated “C.”

Table 39 summarizes the findings of the four studies. Briefly, only Jia 2007^219^ found a statistically significant trend between increasing 25(OH)D concentrations and lower odds for all-cause mortality (P=0.03). However, none of the odds ratios of the different 25(OH)D categories was significant, and if anything, they suggest an U shaped relationship between 25(OH)D and mortality. All other cohorts did not find significant associations. Melamed 2008^85^ performed analyses in subgroups of men and women, and <65 or ≥65 years of age, and found no significant associations (Table 33).

#### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  No data
- 3–8 y
  No data
- 9–18 y
  No data
- 19–50 y
  A 15-year followup analysis of NHANES III data identified for the current report observed a j-shaped association of serum 25(OH)D concentrations with all-cause mortality for adults 20 to 64 years of age, with serum concentrations less than 30 nmol/L and greater than 120nmol/L associated with a higher risk. A subgroup analysis of people younger than 65 years in NHANES III identified for the original report (Melamed 2008) found no significant associations between 25(OH)D concentrations and all-cause mortality.
- 51–70 y
  The current report identified one study that observed a significant association of serum 25(OH)D concentrations and all-cause mortality among adults 50 to 74 years of age. Overall, there were no significant effects of vitamin D supplementation on mortality.
  ○ In a random effects model meta-analysis of five RCTs (n=13,899) the summary RR was 0.97 (95% CI 0.92, 1.02), with no evidence for between-study heterogeneity (p=0.39, I^2^=0%). The mean participant age was more than 70 years in these RCTs.
  ○ Overall, data from four cohorts suggest no association between baseline 25(OH)D measurements and all-cause mortality (one cohort found a statistically significant trend for ). A subgroup analysis of people aged 65 years or older in NHANES III (Melamed 2008) found no significant associations between 25(OH)D concentrations and all-cause mortality.
- ≥71 y
  Of three cohort studies identified for the current report that assessed the association between serum 25(OH)D and all-cause mortality, one in men who were 85 years old at baseline, one in individuals 70 to 88 years old followed up to 9.2 years, and the third in individuals who were 77 years old at baseline, one reported no association and two observed an association between lower serum 25(OH)D concentrations and increased all-cause mortality. For studies identified for the original report, the above (51–70 y) are applicable.
- Postmenopause
  No data
- Pregnant & lactating women
  No data

### Vitamin D and Hypertension and Blood Pressure

We searched for systematic reviews and primary studies that evaluated associations between vitamin D supplementation or serum concentrations and incidence of hypertension and change in blood pressure. For the outcome incidence of hypertension, we reviewed RCTs and other longitudinal studies. For the outcome change in blood pressure, we reviewed only RCTs. The EPC and the TEP agreed that due to the large volume of literature, the limited resources would not be expended on reviewing observational studies for the surrogate outcome blood pressure. We included only studies of adults. Studies of pregnancy-related hypertension and blood pressure control are included in the “Pregnancy-related outcomes” section.

#### Hypertension

##### Synopsis

No systematic reviews evaluated the association between vitamin D intake or serum 25(OH)D concentrations and incidence of hypertension. A large prospective cohort study identified for the current report that evaluated the association between serum 25(OH)D concentration and the risk for hypertension using the Intermountain database found a highly significant association of very low and low baseline serum 25(OH)D concentrations and the prevalence of hypertension at an average of 1.3 years followup. An assessment of the association between serum 25(OH)D and incident hypertension in 1,211 participants in the Physicians' Health Study at a mean followup of 15.3 years (maximum 27 years) showed a marginally significant j-shaped association. A combined analysis of a small subset of the Health Professionals Followup (HPFS) and Nurses Health Studies (NHS) evaluated the association with serum 25(OH)D concentrations. The analysis found higher incidence of hypertension at 4 and 8 years in men with baseline 25(OH)D concentration less than 37.5 nmol/L (OR∼3–6). In women, serum 25(OH)D concentrations less than 37.5 nmol/L also had a significantly higher incidence of hypertension at 4 years (OR∼3), but not at 8 years (OR∼1.5).

##### Detailed Presentation

(Tables 40 & 41)

Table 40 Vitamin D and hypertension: Characteristics of cohort studies (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Confounders/Effect Modifiers Adjusted | | | | | | Comments
Author Year Study Name Location (Latitude) [PMID] | Population | | Vitamin D Concentration | | Comparisons | Nutrients | Demograph | Anthrop | Medical | UV Exposure | Lifestyle | Comments
Forman 2007^225^ HPFS, NHS US (various) [17372031] | - Health status | Any | - Assay method | RIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | | X | X | | | X
Forman 2007^225^ HPFS, NHS US (various) [17372031] | - Mean age (SD), y | Men 65 (8) Women 57 (7) | - Assay method | RIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | | X | X | | | X
Forman 2007^225^ HPFS, NHS US (various) [17372031] | - Male (%) | 34 | - Season blood drawn | All | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | | X | X | | | X
Forman 2008^226^ NHS 2 US (various) [18838623] | - Health status | No HTN, CVD, DM, obesity, cancer | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | X | X | X | | X
Forman 2008^226^ NHS 2 US (various) [18838623] | - Mean age (SD), y | 43 (40–46) | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | X | X | X | | X
Forman 2008^226^ NHS 2 US (various) [18838623] | - Male (%) | 0 | - Season blood drawn | All | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories) | X | X | X | | X
NEW Cohort Study
Anderson 2010^223^ US | - Health status | nd | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories)
Anderson 2010^223^ US | - Mean age (SD), y | 55 (21) | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories)
Anderson 2010^223^ US | - Male (%) | 25.2% | - Season blood drawn | All | Hypertension incidence stratified by 25(OH)D categories (2 and 3 categories)
Wang 2013^224^ Physicians' Health Study (PHS) US | - Health status | Healthy | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D quartiles | X | X | X | | | X
Wang 2013^224^ Physicians' Health Study (PHS) US | - Mean age (SD), y | 57.6 (SD 7.6) | - Assay method | EIA | Hypertension incidence stratified by 25(OH)D quartiles | X | X | X | | | X
Wang 2013^224^ Physicians' Health Study (PHS) US | - Male (%) | 100% | - Season blood drawn | All | Hypertension incidence stratified by 25(OH)D quartiles | X | X | X | | | X

Table 41 Vitamin D and hypertension: Results of cohort and nested case-control studies (updated from original report)

Author Year Study Name [PMID] | Mean (SD) Age, Sex | Outcome (n/N; Incidence) | Followup Duration | Vit D Measure | Concentration, nmol/L | No. of Cases | No. in Category | Adjusted OR, HR, RR | 95% CI | P for Trend | Study Quality
Men
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | <37.5 | 6 | 33 | 6.13 | 1.00, 37.8^*^ | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | 37.5–75 | 33 | 247 | 1.12 | 0.51, 2.48 | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | ≥75 | 22 | 233 | 1 | Reference | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | | | | | | | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | <37.5 | 6 | 33 | 5.68 | 1.01, 32.3^*^ | <0.05 | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | | | | | | <0.05 | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (61/613; 0.100) | 4 y | 25(OH)D | ≥37.5 | 55 | 580 | 1 | Reference | <0.05 | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | | | | | | | | | | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | <37.5 | 9 | 33 | 3.53 | 1.02, 12.3^*^ | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | 37.5–75 | nd | 247 | nd | nd | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | ≥75 | nd | 233 | 1 | Reference | nd | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | | | | | | | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | <37.5 | 9 | 33 | 3.03 | 0.94, 9.76 | NS | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | | | | | | NS | B
Forman 2007^225^ HPFS [17372031] | 65 (8), Men | Hypertension (131/613; 0.214) | 8 y | 25(OH)D | ≥37.5 | 124 | 580 | 1 | Reference | NS | B
Women
Forman 2008^226^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ∼7 y | 25(OH)D | 41.75 (15.5–52.5) | 208 | 371 | 1.66 | 1.11, 2.48 | 0.01 | B
Forman 2008^226^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ∼7 y | 25(OH)D | 59.5 (52.75-66.25) | 188 | 370 | 1.55 | 1.07, 2.23 | 0.01 | B
Forman 2008^226^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ∼7 y | 25(OH)D | 73.0 (66.5–80.5) | 195 | 374 | 1.52 | 1.06, 2.18 | 0.01 | B
Forman 2008^226^ NHS 2 [18838623] | 43 (40–46, range), Women | Hypertension (742 cases; 742 controls) Nested case control | ∼7 y | 25(OH)D | 94.75 (80.75–224) | 151 | 369 | 1 | Reference | 0.01 | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | <37.5 | 11 | nd^A^ | 2.67 | 1.05, 6.79^*^ | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | 37.5–75 | 60 | nd | 0.85 | 0.53, 1.34 | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | ≥75 | 58 | nd | 1 | Reference | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | | | | | | | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | <37.5 | 11 | nd | 2.98 | 1.24, 7.20^*^ | <0.05 | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | | | | | | <0.05 | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (129/1198; 0.108) | 4 y | 25(OH)D | ≥37.5 | 118 | nd | 1 | Reference | <0.05 | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | | | | | | | | | | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | <37.5 | 20 | nd^A^ | 1.7 | 0.92, 3.16 | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | 37.5–75 | nd | nd | nd | nd | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | | | | | | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | ≥75 | nd | nd | 1 | Reference | nd | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | | | | | | | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | <37.5 | 20 | nd | 1.42 | 0.79, 2.56 | NS | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | | | | | | NS | B
Forman 2007^225^ NHS [17372031] | 57 (7), Women | Hypertension (274/613; 0.229) | 8 y | 25(OH)D | ≥37.5 | 254 | nd | 1 | Reference | NS | B
NEW Cohort Studies
Anderson 2010^223^ US | 19–50, 51–70 yrs | Hypertension | 1.3 yrs on average | serum 25(OH)D | very low (Vit D level ≤37.5 nmol/L) | 7848 | 15,121 | HR= 1.62 | 1.38, 1.89 | p<0.0001 | B
Anderson 2010^223^ US | 19–50, 51–70 yrs | Hypertension | 1.3 yrs on average | serum 25(OH)D | | | | | | | B
Anderson 2010^223^ US | 19–50, 51–70 yrs | Hypertension | 1.3 yrs on average | serum 25(OH)D | low (Vit D level 56–75 nmol/L | 8530 | 19,474 | 1.18 | 1.05, 1.33 | p=0.005 | B
Anderson 2010^223^ US | 19–50, 51–70 yrs | Hypertension | 1.3 yrs on average | serum 25(OH)D | | | | | | | B
Anderson 2010^223^ US | 19–50, 51–70 yrs | Hypertension | 1.3 yrs on average | serum 25(OH)D | normal (Vit D level > 75 nmol/L) | 2750 | 6,909 | 1 | | | B
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | Q1: 13.0–57.8 | 97 | 164 | 1.00 | Reference | 0.43 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | Q2: 37.0–74.9 | 97 | 164 | 0.94 | 0.69, 1.27 | 0.43 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | Q3: 48.6–93.5 | 79 | 167 | 0.69 | 0.50, 0.96 | 0.43 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | Q4: 68.8–167.2 | 94 | 165 | 0.82 | 0.60, 1.13 | 0.43 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | <50 | 73 | 136 | 1.00 | Reference | 0.32 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | 50–74 | 144 | 244 | 1.03 | 0.75, 1.42 | 0.32 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | 75–99 | 93 | 178 | 0.79 | 0.56, 1.11 | 0.32 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 25(OH)D | >=100 | 57 | 102 | 0.94 | 0.62, 1.40 | 0.32 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | | | | | | | | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 1,25(OH)D | Q1: 29.9–79.3 | 87 | 162 | 1.00 | Reference | 0.16 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 1,25(OH)D | Q2: 68.0–88.2 | 80 | 162 | 0.92 | 0.66, 1.27 | 0.16 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 1,25(OH)D | Q3: 80.8–101.8 | 95 | 165 | 1.12 | 0.82, 1.54 | 0.16 | A
Wang 2013^224^ Physicians' Health Study (PHS) | | Hypertension | 15.3 yrs | 1,25(OH)D | Q4: 94.0–177.6 | 101 | 162 | 1.19 | 0.86, 1.63 | 0.16 | A

* Statistically significant (P<0.05).

A Due to formatting error in study table, no data on numbers of women in each category.

A prospective cohort study identified for the current report analyzed records of 19,128 patients, age 50 and over, in the Intermountain Database for which baseline serum 25(OH)D concentrations were available (25% male) (rated C). Those with serum 25(OH)D concentrations less than 37.5 nmol/L and between 40 and 75 nmol/L were significantly more likely than those with normal serum 25(OH)D concentrations (>75 nmol/L) (HR 1.62, HR 1.18, respectively) to have hypertension within an average followup time of 1.3 years. No subgroup analyses were done by sex or age.223 An assessment of the association between serum 25(OH)D and incident hypertension in 1,211 participants in the Physicians' Health Study (men of mean age 57.6) at a mean followup of 15.3 years (maximum 27 years) showed a marginally significant j-shaped association, with men in the lowest two quartiles and in the highest quartile at higher risk for incident hypertension than those in the third quartile (rated A).224

One analysis (methodological quality B) identified for the original report evaluated the incidence of hypertension in a combined set of 613 men from the HPFS and 1198 women from the NHS who had serum 25(OH)D concentrations measured.225 The men were on average 65 years old and the women 57 years old. Among the men at 4 years, those with serum 25(OH)D concentrations less than 37.5 nmol/L were significantly more likely to have new onset hypertension than either men with 25(OH)D concentrations above 75 nmol/L (OR=6.1) or above 37.5 nmol/L (OR=5.7). The association remained significant at 8 years, although with a smaller effect size (OR=3.5 and 3.0, respectively). In women, a similar, though weaker, effect was seen at 4 years, such that those with 25(OH)D concentrations less than 37.5 nmol/L were significantly more likely to have new onset hypertension than either women with 25(OH)D concentrations above 75 nmol/L (OR=2.7) or above 37.5 nmol/L (OR=3.0). However, this effect was smaller and nonsignificant at 8 years (OR=1.7 and 1.4, respectively). The study was limited primarily by its inclusion of only a relatively small subset of participants and its reliance on self-reported hypertension without assessment of blood pressure measurements.

In the second analysis by the same investigators, the NHS 2 study was analyzed for the association between serum 25(OH)D concentration and hypertension as a nested case-control study.226 These women were on average 43 years old. Cases and controls (per the 2005 biennial questionnaire) were chosen from among those women without hypertension, cardiovascular disease, diabetes, obesity, or cancer at baseline (blood samples drawn from 1997 to 1999). After approximately 7 years, a statistically significant trend was found such that women in the three quartiles with serum 25(OH)D concentrations of 80.5 nmol/L or less were about 50 to 60 percent more likely to develop hypertension than those women with higher serum concentrations of 25(OH)D (adjusted OR = 1.52 to 1.66, each of which was statistically significant compared to the highest quartile). The study was graded methodological quality B for similar reasons as the analysis of the HPFS and NHS studies.

##### Findings per Vitamin D Concentration

The Intermountain data were analyzed with 25(OH)D cutpoints of 37.5 and 75 nmol/L. Significant associations were identified for those with serum concentrations below 75 nmol/L. The HPFS and NHS studies were analyzed with 25(OH)D cutpoints of 37.5 and 75 nmol/L. Significant associations were found for those with serum concentrations below 37.5 nmol/L. The NHS 2 study was analyzed with 25(OH)D quartiles, such that significant associations were found for those with serum concentrations of 80.5 nmol/L or less.

##### Findings per Age and Sex

See above Detailed presentation of the HPFS and NHS for the separate analyses by sex. No subgroup analyses were reported by life stage. The participants in the studies were approximately 40 to 80 years old.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed 19–50 y The NHS 2 included all women within the life stage. After approximately 7 years, those with serum 25(OH)D concentrations of 80.5 nmol/L or less were about 50 to 60 percent more likely to develop hypertension.
- 51–70 y
  Individuals 50 and over with serum 25(OH)D concentrations less than 75nmol/L, identified in the Intermountain Health Database for the current study, had higher prevalence of hypertension at 1.3 years (average) followup. No subgroup analysis was conducted to further assess individuals over 70 or risk by sex. An assessment of the association between serum 25(OH)D and incident hypertension in men in the Physicians' Health Study (mean age 57.6) at a mean followup of 15.3 years (maximum 27 years) showed a marginally significant j-shaped association, with men in the lowest two quartiles and in the highest quartile at higher risk for incident hypertension than those in the third quartile. HPFS and NHS included participants mostly within this life stage. In men and women, the study found higher incidence of hypertension at 4 years follow up in those with serum 25(OH)D concentrations less than 37.5 nmol/L; at 8 years, the association was significant only for men.
- ≥71 y
  A minority of the men and few of the women appear to have been in this life stage. No unique conclusions are possible for this life stage separate from those for people 51 to 70 years.
- Postmenopause
  The majority of the women in NHS were postmenopausal. A significant association between serum 25(OH)D concentrations less than 37.5 nmol/L and increased hypertension was found at 4 years, but not 8 years follow up.
- Pregnant & lactating women
  Not reviewed

#### Vitamin D and Blood Pressure

##### Synopsis

No qualified systematic reviews have evaluated the association between vitamin D intake or serum 25(OH)D concentrations and changes in blood pressure. The current study identified ten RCTs that assessed the effects of one or more dosage levels of vitamin D compared with placebo on blood pressure in adults. Dosages ranged from 125IU to 7000IU per day. Followup ranged from 3 months to one year. Participants included postmenopausal women, middle aged U.S. blacks, overweight young Chinese and Danish adults, healthy South Asian women residing in the UK, and healthy young women. Of the ten RCTs, no effect of vitamin D supplementation was observed in seven, vitamin D significantly decreased systolic blood pressure in two studies (both systolic and diastolic in one of those two), and in the tenth, systolic blood pressure actually increased slightly in the supplemented group.

Three trials from Germany, UK, and India identified for the original report compared different doses of vitamin D (800 IU daily, a single dose of 100,000 IU, or 120,000 IU every 2 weeks) with placebo, with or without supplemental calcium in both groups. The study participants also varied: either older men, older men and women, or men mostly in their 40s. Both recruited older adults (over 63 or 70 years). All trials reported no significant effect on diastolic blood pressure. The A quality British study of a single dose of vitamin D 100,000 IU found no difference in systolic blood pressure after 5 weeks. The B quality German study found a significant net reduction of 7 mm Hg after 8 weeks in older women taking vitamin D 800 IU daily. The B quality Indian study of obese men mostly in their 40s, found a nearly significant net increase of 4 mm Hg after 6 weeks of vitamin D 120,000 IU every 2 weeks. No long term data were available.

##### Detailed Presentation

(Tables 42 & 43)

Table 42 Vitamin D and blood pressure: Characteristics of RCTs (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Scragg 1995^237^ Cambridge, UK (52°N) [7498100] | - Health status | No HTN | 25(OH)D: 34.5 nmol/L (treatment group), 32.25 nmol/L (control group) | Vit D_3_ 100,000 IU (2.5 mg) one-time dose vs. Placebo | nd | Complete trial performed in winter
Scragg 1995^237^ Cambridge, UK (52°N) [7498100] | - Mean age (range), y | 70 (63–76) | 25(OH)D: 34.5 nmol/L (treatment group), 32.25 nmol/L (control group) | Vit D_3_ 100,000 IU (2.5 mg) one-time dose vs. Placebo | nd | Complete trial performed in winter
Scragg 1995^237^ Cambridge, UK (52°N) [7498100] | - Male (%) | 46% | 25(OH)D: 34.5 nmol/L (treatment group), 32.25 nmol/L (control group) | Vit D_3_ 100,000 IU (2.5 mg) one-time dose vs. Placebo | nd | Complete trial performed in winter
Pfeifer 2001^238^ Lower Saxony, Germany (52°N) [11297596] | - Health status | Healthy, low Vit D | 25(OH)D < 50 nmol/L | Vit D_3_ + Ca supplement vs. Ca supplement | 95±12% for the Ca tablets and 96±10% for the Vit D_3_ + Ca tablets (pill counting)
Pfeifer 2001^238^ Lower Saxony, Germany (52°N) [11297596] | - Mean age (range), y | 75 (70–86) | 25(OH)D < 50 nmol/L | Vit D_3_ + Ca supplement vs. Ca supplement | 95±12% for the Ca tablets and 96±10% for the Vit D_3_ + Ca tablets (pill counting)
Pfeifer 2001^238^ Lower Saxony, Germany (52°N) [11297596] | - Male (%) | 0 | 25(OH)D < 50 nmol/L | Vit D_3_ + Ca supplement vs. Ca supplement | 95±12% for the Ca tablets and 96±10% for the Vit D_3_ + Ca tablets (pill counting)
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Health status | Healthy, obese | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Mean age (SD), y | 44 (8) | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws
Nagpal 2009^96^ New Delhi, India (28.5°N) [19125756] | - Male (%) | 100% | 25(OH)D: 36.5 nmol/L (treatment group), 30.0 nmol/L (control group) | Vit D_3_ 120,000 IU every 2 weeks vs. Placebo | 100% (implied); supervised home visits | Excluded subjects who refused subsequent blood draws
NEW Studies
Forman 2013^227^ Boston, MA | - Health status | Healthy | Serum vitamin D- 39.3 (26.8–83.5 IQR) nmol/L | Vit D_3_ 100,000 IU/day Vs. Vit D_3_ 2000 IU/day Vs. Vit D_3_ 4000 IU/day Vs. placebo | 96.6%
Forman 2013^227^ Boston, MA | - Mean age (range), y | 51 (44–59) | Serum vitamin D- 39.3 (26.8–83.5 IQR) nmol/L | Vit D_3_ 100,000 IU/day Vs. Vit D_3_ 2000 IU/day Vs. Vit D_3_ 4000 IU/day Vs. placebo | 96.6%
Forman 2013^227^ Boston, MA | - Male (%) | 34.6% | Serum vitamin D- 39.3 (26.8–83.5 IQR) nmol/L | Vit D_3_ 100,000 IU/day Vs. Vit D_3_ 2000 IU/day Vs. Vit D_3_ 4000 IU/day Vs. placebo | 96.6%
Gepner 2012^229^ Madison, WI | - Health status | Healthy Postmenopausal | Serum vitamin D- 78.3+/-26.5 nmol/L | Placebo Vs. Vit D_3_ 2500 IU/day | nd
Gepner 2012^229^ Madison, WI | - Mean age (range), y | 63.9 (SD 3) | Serum vitamin D- 78.3+/-26.5 nmol/L | Placebo Vs. Vit D_3_ 2500 IU/day | nd
Gepner 2012^229^ Madison, WI | - Male (%) | 0% | Serum vitamin D- 78.3+/-26.5 nmol/L | Placebo Vs. Vit D_3_ 2500 IU/day | nd
Jorde 2010^230^ Norway | - Health status | Using blood pressure or lipid lowering medication Overweight/Obese | 58.0 ± 21.1 nmol/L | DD (40,000 IU Vit D_3_/week)+500 mg calcium/day Vs. DP (20,000 IU Vit D_3_/week)+500 mg calcium/day Vs. PP (placebo)+500 mg calcium/day | Vitamin D/placebo capsules 95%-DD group, 96%-DP group and 96%-PP group calcium tablets 82%, 84% and 83%,respectively.
Jorde 2010^230^ Norway | - Mean age (SD), y | 47.5 (SD 11.4) | 58.0 ± 21.1 nmol/L | DD (40,000 IU Vit D_3_/week)+500 mg calcium/day Vs. DP (20,000 IU Vit D_3_/week)+500 mg calcium/day Vs. PP (placebo)+500 mg calcium/day | Vitamin D/placebo capsules 95%-DD group, 96%-DP group and 96%-PP group calcium tablets 82%, 84% and 83%,respectively.
Jorde 2010^230^ Norway | - Male (%) | 35.8% | 58.0 ± 21.1 nmol/L | DD (40,000 IU Vit D_3_/week)+500 mg calcium/day Vs. DP (20,000 IU Vit D_3_/week)+500 mg calcium/day Vs. PP (placebo)+500 mg calcium/day | Vitamin D/placebo capsules 95%-DD group, 96%-DP group and 96%-PP group calcium tablets 82%, 84% and 83%,respectively.
Wood 2012^231^ Aberdeen, UK | - Health status | Healthy Postmenopausal | Serum 25(OH)D placebo: 36.18 ± 17.1 nmol/l 400 IU D3 group: 32.74 ± 12.9 nmol/l 1000 IU D3 group: 32.41 ± 13.8 nmol/l | 400 IU Vit D/day Vs. placebo | nd
Wood 2012^231^ Aberdeen, UK | - Mean age (range), y | 63.9 (SD 2.3) | Serum 25(OH)D placebo: 36.18 ± 17.1 nmol/l 400 IU D3 group: 32.74 ± 12.9 nmol/l 1000 IU D3 group: 32.41 ± 13.8 nmol/l | 400 IU Vit D/day Vs. placebo | nd
Wood 2012^231^ Aberdeen, UK | - Male (%) | 0% | Serum 25(OH)D placebo: 36.18 ± 17.1 nmol/l 400 IU D3 group: 32.74 ± 12.9 nmol/l 1000 IU D3 group: 32.41 ± 13.8 nmol/l | 400 IU Vit D/day Vs. placebo | nd
Zhu 2013^232^ Shanghai, China | - Health status | Healthy | Habitual Ca intake CaD group—426.5 +/- 152.2 mg/d Control group—392.1 +/- 141.1 mg/d | (energy-restricted diet+600 mg calcium+125 IU Vit D)/day Vs. energy-restricted diet alone (control) | 95.8% in the calcium+D group
Zhu 2013^232^ Shanghai, China | - Mean age (range), y | 20.3 (SD 0.8) | Habitual Ca intake CaD group—426.5 +/- 152.2 mg/d Control group—392.1 +/- 141.1 mg/d | (energy-restricted diet+600 mg calcium+125 IU Vit D)/day Vs. energy-restricted diet alone (control) | 95.8% in the calcium+D group
Zhu 2013^232^ Shanghai, China | - Male (%) | 14.3% | Habitual Ca intake CaD group—426.5 +/- 152.2 mg/d Control group—392.1 +/- 141.1 mg/d | (energy-restricted diet+600 mg calcium+125 IU Vit D)/day Vs. energy-restricted diet alone (control) | 95.8% in the calcium+D group
Daly 2009^233^ Melbourne, Australia | - Health status | Healthy, obese | Serum 25(OH)D milk group: 78 ± 23 nmol/l control group: 76 ± 23 nmol/l | (400 ml reduced fact milk fortified with 1000 mg calcium+800 IU Vit D)/day Vs. control (no additional fortified milk) (400 ml reduced fact milk fortified with 1000 mg clacium+800 IU Vit D)/day Vs. control (no additional fortified milk) | 85 ± 21%
Daly 2009^233^ Melbourne, Australia | - Mean age (SD), y | 61.2 (SD 7.5) | Serum 25(OH)D milk group: 78 ± 23 nmol/l control group: 76 ± 23 nmol/l | | 85 ± 21%
Daly 2009^233^ Melbourne, Australia | - Male (%) | 100% | Serum 25(OH)D milk group: 78 ± 23 nmol/l control group: 76 ± 23 nmol/l | | 85 ± 21%
Salehpour 2012^234^ Tehran, Iran | - Health status | Overweight, obese | Serum 25(OH)D Vit D group—36.8 +/- 30 nmol/l Placebo group—46.9 +/- 32 nmol/l | Vit D 25 μg/day Vs. placebo | nd
Salehpour 2012^234^ Tehran, Iran | - Mean age (SD), y | 38 (SD 8.1) | Serum 25(OH)D Vit D group—36.8 +/- 30 nmol/l Placebo group—46.9 +/- 32 nmol/l | Vit D 25 μg/day Vs. placebo | nd
Salehpour 2012^234^ Tehran, Iran | - Male (%) | 0% | Serum 25(OH)D Vit D group—36.8 +/- 30 nmol/l Placebo group—46.9 +/- 32 nmol/l | Vit D 25 μg/day Vs. placebo | nd
Witham 2013^235^ UK | - Health status | Healthy | <50 nmol/L | Vit d3 100,000 units Vs. placebo | nd
Witham 2013^235^ UK | - Mean age (SD), y | 39.4 (SD 11.8) | <50 nmol/L | Vit d3 100,000 units Vs. placebo | nd
Witham 2013^235^ UK | - Male (%) | 0% | <50 nmol/L | Vit d3 100,000 units Vs. placebo | nd
Toxqui 2013^228^ Spain | - Health status | Healthy | Serum: D-placebo 62.9 ± 20.8 nmol/L D-fortified 62.3 ± 20.8 nmol/L | vit d 200 IU/day Vs. placebo | >96%
Toxqui 2013^228^ Spain | - Mean age (SD), y | 26.5 (SD 3.8) | Serum: D-placebo 62.9 ± 20.8 nmol/L D-fortified 62.3 ± 20.8 nmol/L | vit d 200 IU/day Vs. placebo | >96%
Toxqui 2013^228^ Spain | - Male (%) | 0% | Serum: D-placebo 62.9 ± 20.8 nmol/L D-fortified 62.3 ± 20.8 nmol/L | vit d 200 IU/day Vs. placebo | >96%
Wamberg 2013^236^ | - Health status | Overweight/obese | 34.6±10.3 nmol/L | 7000 IU cholecalciferol vs. placebo | 94±8%
Wamberg 2013^236^ | - Mean age (SD), y | 41.2 (18–50) (SD 6.8) | 34.6±10.3 nmol/L | 7000 IU cholecalciferol vs. placebo | 94±8%
Wamberg 2013^236^ | - Male (%) | 27% | 34.6±10.3 nmol/L | 7000 IU cholecalciferol vs. placebo | 94±8%

Table 43 Vitamin D and blood pressure: Results of RCTs

Author Year Study Name [PMID] | Age Range, Sex | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change/final | Change/final 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
SYSTOLIC BLOOD PRESSURE
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | SBP | 1° | 5 wk | Vit D_3_ 100,000 IU (2.5 mg), 1 dose | 95 | mm Hg | 149 | -5 | -14.4, 4.4^A^ | 0 | -4.2, 4.2^A^ | 0.81 | A
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | SBP | 1° | 5 wk | | | | | | | | | | A
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | SBP | 1° | 5 wk | Placebo | 94 | | 147 | -5 | -17.9, 7.9^A^ | | | | A
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Vit D_3_ 800 IU +Ca carbonate 1200 mg | 73 | mm Hg | 144.1 | -13.1 | nd | -7.4 | -13.6, -1.2^A^ | 0.02 | B
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | | | | | | | | | | B
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Ca carbonate 1200 mg | 72 | | 140.6 | -5.7 | nd | | | | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | mm Hg | 124 | 0.6 | -2.7, 3.9 | 4 | -0.02, 8.0 | 0.06 | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | | | | | | | | | | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Placebo | 36 | | 124 | -3.4 | -5.8, -1.0 | | | | B
DIASTOLIC BLOOD PRESSURE
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | DBP | 1° | 5 wk | Vit D_3_ 100,000 IU (2.5 mg), 1 dose | 95 | mm Hg | 82 | -1 | -6.8, 4.8^A^ | 0 | -2.8, 2.8^A^ | 0.92 | A
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | DBP | 1° | 5 wk | | | | | | | | | | A
Scragg 1995^237^ UK [7498100] | 63–76 y, Both | DBP | 1° | 5 wk | Placebo | 94 | | 82 | -1 | -6.8, 4.8^A^ | | | | A
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Vit D_3_ 800 IU +Ca carbonate 1200 mg | 73 | mm Hg | 84.7 | -7.2 | nd | -0.3 | -0.7, -0.1^A^ | 0.1 | B
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | | | | | | | | | | B
Pfeifer 2001^238^ Germany [11297596] | 70–86 y, Women | SBP | 1° | 8 wk | Ca carbonate 1200 mg | 72 | | 82.6 | 6.9 | nd | | | | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Vit D_3_ 120,000 IU every 2 wk | 35 | mm Hg | 78 | 0.4 | -2.1, 3.0 | 1.7 | -1.5, 4.9 | 0.31 | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | | | | | | | | | | B
Nagpal 2009^96^ New Delhi, India [19125756] | 44 (8, SD) Men | SBP | 2° | 6 wk | Placebo | 36 | | 77 | -1.3 | -3.2, 0.7 | | | | B
NEW Studies
Forman 2013^227^ Boston, MA | 19–50 yrs | DBP | 1° | 3 months | Vit D_3_ 1000 IU/day | 68 | mmHg | 79.8 | final=78.0 | se=1.6 | -0.9^B^ | -5.7, 3.9 | 0.71 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | DBP | 1° | 3 months | Vit D_3_ 2000 IU/day | 73 | | 77.6 | final=76.0 | se=1.8 | -2.9^B^ | -7.9, 2.1 | 0.26 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | DBP | 1° | 3 months | Vit D_3_ 4000 IU/day | 70 | | 79.8 | final=78.0 | se=1.6 | -0.9^B^ | -5.7, 3.9 | 0.71 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | DBP | 1° | 3 months | placebo | 72 | | 78 | final=78.9 | se=1.8 | | | | A
Forman 2013^227^ Boston, MA | 19–50 yrs | SBP | 1° | 3 months | Vit D_3_ 1000 IU/day | 68 | | 124.7 | final=122.5 | se=2.0 | -2.4^B^ | -8.6, 3.8 | 0.45 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | SBP | 1° | 3 months | Vit D_3_ 2000 IU/day | 73 | | 122.8 | final=120.0 | se=2.4 | -4.9^B^ | -11.6, 1.8 | 0.15 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | SBP | 1° | 3 months | Vit D_3_ 4000 IU/day | 70 | | 130.4 | final=126.6 | se=2.6 | +1.7^B^ | -5.3, 8.7 | 0.63 | A
Forman 2013^227^ Boston, MA | 19–50 yrs | SBP | 1° | 3 months | placebo | 72 | | 122.2 | final=124.9 | se=2.4 | | | | A
Gepner 2012^229^ Madison, WI | Postmenopause | brachial DBP | 2° | 4 months | placebo | 57 | mmHg | 72.6 | change=-0.4 | sd=4.4 | | | | A
Gepner 2012^229^ Madison, WI | Postmenopause | brachial DBP | 2° | 4 months | Vit D_3_ 2500 IU/day | 57 | | 72.45 | change=-0.7 | sd=5.1 | -0.3 | -2.1, 1.5 | 0.73 | A
Gepner 2012^229^ Madison, WI | Postmenopause | brachial SBP | 2° | 4 months | placebo | 57 | | 122.2 | change=-2.5 | sd=10.9 | | | | A
Gepner 2012^229^ Madison, WI | Postmenopause | brachial SBP | 2° | 4 months | Vit D_3_ 2500 IU/day | 57 | | 122.3 | change=-0.3 | sd=8.4 | +2.2 | -1.4, 5.8 | 0.23 | A
Gepner 2012^229^ Madison, WI | Postmenopause | central DBP | 2° | 4 months | placebo | 57 | | 73.7 | change=-0.5 | sd=4.4 | | | | A
Gepner 2012^229^ Madison, WI | Postmenopause | central DBP | 2° | 4 months | Vit D_3_ 2500 IU/day | 57 | | 73.5 | change=-0.7 | sd=5.1 | -0.2 | -2.0, 1.6 | 0.82 | A
Gepner 2012^229^ Madison, WI | Postmenopause | central SBP | 2° | 4 months | placebo | 57 | | 115.6 | change=-2.1 | sd=9.7 | | | | A
Gepner 2012^229^ Madison, WI | Postmenopause | central SBP | 2° | 4 months | Vit D_3_ 2500 IU/day | 57 | | 116.7 | change=-0.3 | sd=7.0 | +1.8 | -1.3, 4.9 | 0.26 | A
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | DBP | 1° | 1 yr | DD (40,000 IU Vit D_3_/week)+500 mg calcium/day | 114 | mmHg | 76.5 | change=1.0 | sd=7.4 | +0.8 | -1.3, 2.9 | 0.45 | B
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | DBP | 1° | 1 yr | DP (20,000 IU Vit D_3_/week)+500 mg calcium/day | 104 | | 74.9 | change=1.0 | sd=8.3 | +0.8 | -1.4, 3.0 | 0.48 | B
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | DBP | 1° | 1 yr | PP (placebo)+500 mg calcium/day | 112 | | 74.8 | change=0.2 | sd=8.3 | | | | B
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | SBP | 1° | 1 yr | DD (40,000 IU Vit D_3_/week)+500 mg calcium/day | 114 | | 124 | change=1.2 | sd=11.4 | +2.3 | -0.9, 5.5 | 0.15 | B
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | SBP | 1° | 1 yr | DP (20,000 IU Vit D_3_/week)+500 mg calcium/day | 104 | | 121 | change=3.5 | sd=11.8 | +4.6 | 1.3, 7.9 | <0.001 | B
Jorde 2010^230^ Norway | 19–50, 51–70 yrs | SBP | 1° | 1 yr | PP (placebo)+500 mg calcium/day | 112 | | 125 | change=-1.1 | sd=12.8 | | | | B
Wood 2012^231^ Aberdeen, UK | Postmenopause | DBP | 1° | 1 yr | 400 IU Vit D/day | 97 | mmHg | 77.68 | change=-2.5 | -3.6, -1.4 | -0.4 | -1.9, 1.1 | 0.60 | A
Wood 2012^231^ Aberdeen, UK | Postmenopause | DBP | 1° | 1 yr | placebo | 100 | | 77.7 | change=-2.1 | -3.1, -1.0 | | | | A
Wood 2012^231^ Aberdeen, UK | Postmenopause | SBP | 1° | 1 yr | 400 IU Vit D/day | 96 | | 128.16 | change=-2.2 | -3.3, -0.7 | +0.2 | -2.2, 2.6 | 0.87 | A
Wood 2012^231^ Aberdeen, UK | Postmenopause | SBP | 1° | 1 yr | placebo | 98 | | 128.18 | change=-2.4 | -4.5, -0.2 | | | | A
Zhu 2013^232^ Shanghai, China | 19–50 yrs | DBP | 1° | 12 weeks | (energy-restricted diet+600 mg calcium+125 IU Vit D)/day | 22 | mmHg | 70.7 | final=64.2 | sd=4.7 | -1.2 | -4.6, 2.2 | 0.48 | B
Zhu 2013^232^ Shanghai, China | 19–50 yrs | DBP | 1° | 12 weeks | energy-restricted diet alone (control) | 21 | | 70 | final=65.4 | sd=6.3 | | | | B
Zhu 2013^232^ Shanghai, China | 19–50 yrs | SBP | 1° | 12 weeks | (energy-restricted diet+600 mg calcium+125 IU Vit D)/day | 22 | | 119.2 | final=109.6 | sd=9.9 | -2.3 | -8.6, 4.0 | 0.46 | B
Zhu 2013^232^ Shanghai, China | 19–50 yrs | SBP | 1° | 12 weeks | energy-restricted diet alone (control) | 21 | | 123 | final=111.9 | sd=10.4 | | | | B
Daly 2009^233^ Melbourne, Australia | 51–70 yrs | DBP | 1° | 2 yrs | (400 ml reduced fact milk fortified with 1000 mg calcium+800 IU Vit D)/day | 66 | mmHg | 69.5 | change=4.2 | 2.1, 6.2 | +0.3 | -2.6, 3.2 | 0.84 | A
Daly 2009^233^ Melbourne, Australia | 51–70 yrs | DBP | 1° | 2 yrs | control (no additional fortified milk) | 58 | | 71 | change=3.9 | 2.0, 5.8 | | | | A
Daly 2009^233^ Melbourne, Australia | 51–70 yrs | SBP | 1° | 2 yrs | (400 ml reduced fact milk fortified with 1000 mg clacium+800 IU Vit D)/day | 66 | | 123.7 | change=6.8 | 4.2, 9.3 | +1.5 | -2.4, 5.4 | 0.45 | A
Daly 2009^233^ Melbourne, Australia | 51–70 yrs | SBP | 1° | 2 yrs | control (no additional fortified milk) | 58 | | 120.4 | change=5.3 | 2.4, 8.2 | | | | A

Note: Outcomes cells are shaded for the Control rows.

A Estimated from available data;

B Estimated net difference and p-value from data

Of the ten RCTs identified for the current report, one RCT found a decrease in systolic blood pressure of 0.2mm Hg for every 25nmol/L increase in supplemental plasma vitamin D. This U.S. trial randomized 283 overweight and obese (but otherwise healthy) black adults, 44 to 59 years of age and 63% female, to 1000, 2000, or 3000 IU/day cholecalciferol or placebo for 3 months (study rated A). Supplementation did not affect diastolic blood pressure. The effect was greater for those with lower baseline 25(OH)D concentrations but did not differ by baseline blood pressure. No subgroup analysis was performed by sex or use of antihypertensives.227 One Spanish 16-week RCT that supplemented healthy young women (18 to 35 years of age) with 200 IU vitamin D per day found a decrease in both systolic blood pressure (compared with 8-week levels) and diastolic blood pressure (compared with baseline) (rated B).228 Eight RCTs reported no effect on or an increase in systolic blood pressure (three rated A, two rated B, and one rated C).229-236

In the original report, the A quality trial of single-dose vitamin D, performed in Cambridge, UK, recruited older adults (63 to 76 years, mean 70 years) who were not taking antihypertensive medications.237 During the winter, they were given either a one-time dose of vitamin D_3_ (100,000 IU [2.5 mg]) or placebo, and blood pressure was rechecked at 5 weeks. In both study arms, systolic and diastolic blood pressures fell by equal amounts, resulting in no net difference between vitamin D supplemented and placebo groups. No subgroup analyses were reported.

The German B quality trial of supplementation with combined vitamin D and calcium versus calcium alone recruited older women (70 to 86 years) without severe hypertension.238 For 8 weeks, the women took either vitamin D_3_ 800 IU and calcium carbonate 1200 mg or calcium carbonate 1200 mg alone daily. Systolic blood pressure decreased by 13 mm Hg in those supplemented with vitamin D and calcium compared with a 6 mm Hg decrease in those taking calcium alone (P=0.02). Diastolic blood pressure declined by 7 mm Hg in both groups. No subgroup analyses were reported. The study was limited by inadequate reporting of its study methods and lack of blinding.

The Indian B quality study compared every other week vitamin D_3_ supplementation 120,000 IU with placebo for 3 weeks in generally healthy but obese men without hypertension.96 The men who received the vitamin D supplements had a net increase in systolic blood pressure of 4 mm Hg, which was close to statistically significant (P=0.06), but no significant difference in diastolic blood pressure. The study was limited by a high dropout rate (26 percent).

##### Findings per Intake Level

No conclusions can be reached about an intake level threshold. In individual trials, a single dose of 100,000 IU of cholecalciferol had no significant effect on systolic and diastolic blood pressure after 5 weeks, a daily dose of vitamin D_3_ 800 IU together with calcium significantly lowered systolic blood pressure more than calcium alone, but every other week vitamin D_3_ 120,000 IU resulted in a nearly statistically significant increase in systolic blood pressure.

##### Findings per Age and Sex

No conclusions can be reached about differences in effect based on age or sex. None of the studies identified for the current report stratified by age or sex. The study of older women identified for the original report found a significant decrease in systolic blood pressure with relatively low dose vitamin D, a higher dose study of similarly aged men and women found no effect on blood pressure, and the highest dose study of men mostly in their 40s found an increase in systolic blood pressure.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  One study of black U.S. residents 44–59 years of age found significant decreases in systolic blood pressure with vitamin D supplementation. A study of Spanish women 18–50 years found significant decreases in both systolic and diastolic blood pressure with modest daily supplementation. Eight studies identified for the current report, including those of overweight Chinese young adults, ages 18 to 25 years, and overweight Norwegian adults, 21 to 70 years of age found no effect of vitamin D supplementation on blood pressure. A single study of men in this life stage found a near significant increase in systolic blood pressure with vitamin D and no effect on diastolic blood pressure.
- 51–70 y
  One trial included people with an average age of 70 years, implying that about half were within this life stage. No significant effect on blood pressure was found of a single large dose of vitamin D.
- ≥71 y
  Both trials included people within this life stage. The trial of people with an average age of 70 years found no significant effect of a single large dose of vitamin D. The single trial of women over age 70 years found a significant benefit for systolic blood pressure for vitamin D_3_ 800 IU and calcium carbonate 1200 mg compared with calcium carbonate 1200 mg alone.
- Postmenopause
  A study identified for the current report of healthy postmenopausal women (60–70 years of age) reported no effect of vitamin D supplementation on blood pressure, although serum 25(OH)D concentrations varied significantly with season of blood draw. The women in both trials were postmenopausal. See the ≥71 y life stage.
- Pregnant & lactating women
  Not reviewed

### Vitamin D and Bone Mineral Density or Bone Mineral Content

The current report identified a number of RCTs that examined the effect of supplementation with vitamin D alone or vitamin D plus calcium on bone mineral density(BMD)/content (BMC), falls, and muscle strength and met criteria for inclusion. Studies that report on supplementation with vitamin D plus calcium (compared with a placebo) are described later in the report.

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), the original report relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 28).8 Because the Ottawa's EPC report did not have separate analyses on the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation are presented in “Combined vitamin D and Calcium” section.

The Ottawa EPC report was updated with literature published between January 2006 and September 2008, selected according to our eligibility criteria. For adults, only bone mineral density (BMD) indices were included. For children, only bone mineral content (BMC) indices were included. Only RCTs with duration more than 1 year qualified for inclusion.

#### Synopsis

Eight studies were identified for the current report that assessed the effects of supplemental vitamin D on bone mineral content or density. Of the seven studies, a study in infants and a study in postmenopausal women, showed a trend toward increasing BMC or BMD, respectively.

The Ottawa EPC report concluded that observational studies suggested a correlation between higher serum 25(OH)D concentrations and larger values of BMC indices for older children and adolescents (6 months through 18 years old). Furthermore, Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck in postmenopausal women and elderly men. However, there was discordance between the results from RCTs and the majority of observational studies.8 Three new RCTs identify from our updated search all showed no significant effects of vitamin D supplementation on BMC or BMD in children or adults, respectively.

Our updated search did not identify any new RCTs examining the effect of vitamin D on BMD and related outcomes in pregnant or lactating women.

#### Detailed Presentation

(Tables 44 & 45)

Table 44 Vitamin D and bone mineral density: Characteristics of RCTs published after the Ottawa EPC report (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Zhu 2008^247^ Perth, Australia (32 °S) [18410225] | - Health status | nd (based on the inclusion and exclusion criteria, assume subjects were not very healthy but normal physical functioning) | 25(OH)D: 44.3 nmol/L Ca: 1097 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. Ca citrate 1200 mg/d | 86.7% and 86.8% in the vitamin D and the control groups (tablet counting)
Zhu 2008^247^ Perth, Australia (32 °S) [18410225] | - Mean age (SD), y | 77 (4.5) | 25(OH)D: 44.3 nmol/L Ca: 1097 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. Ca citrate 1200 mg/d | 86.7% and 86.8% in the vitamin D and the control groups (tablet counting)
Zhu 2008^247^ Perth, Australia (32 °S) [18410225] | - Male (%) | 0 | 25(OH)D: 44.3 nmol/L Ca: 1097 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. Ca citrate 1200 mg/d | 86.7% and 86.8% in the vitamin D and the control groups (tablet counting)
Andersen 2008^246^ Copenhagen, Denmark (55 N°) [18208636] | - Health status | Healthy | 25(OH)D: Adolescent girls: 11 nmol/L Women: 12 nmol/L Men: 21 nmol/L Ca: Adolescent girls: 510 mg/d Women: 495 mg/d Men: 548 mg/d | Vit D3 400 IU/d, or Vit D3 800 IU/d vs. placebo | The median compliance was 85 (range 43–100), 92 (42–115) and 93 (33–105)% for girls, women, and men, respectively (pill counting) | Pakistani, living in Denmark.Compliance was lower for girls.
Andersen 2008^246^ Copenhagen, Denmark (55 N°) [18208636] | - Mean age (range), y | Adolescent girls: 12.2 (10.1–14.7) Women: 36.2 (18.1–52.7) Men: 38.3 (17.9–63.5) | 25(OH)D: Adolescent girls: 11 nmol/L Women: 12 nmol/L Men: 21 nmol/L Ca: Adolescent girls: 510 mg/d Women: 495 mg/d Men: 548 mg/d | Vit D3 400 IU/d, or Vit D3 800 IU/d vs. placebo | The median compliance was 85 (range 43–100), 92 (42–115) and 93 (33–105)% for girls, women, and men, respectively (pill counting) | Pakistani, living in Denmark.Compliance was lower for girls.
Andersen 2008^246^ Copenhagen, Denmark (55 N°) [18208636] | - Male (%) | 42 | 25(OH)D: Adolescent girls: 11 nmol/L Women: 12 nmol/L Men: 21 nmol/L Ca: Adolescent girls: 510 mg/d Women: 495 mg/d Men: 548 mg/d | Vit D3 400 IU/d, or Vit D3 800 IU/d vs. placebo | The median compliance was 85 (range 43–100), 92 (42–115) and 93 (33–105)% for girls, women, and men, respectively (pill counting) | Pakistani, living in Denmark.Compliance was lower for girls.
El-Hajj 2006^48^ Beirut, Lebanon (33°53'N) [16278262] | - Health status | Healthy | 25(OH)D: 34.9 nmol/L Ca: 677 mg/d | Weekly oral Vit D doses of 1400 IU (=Vit D 200 IU/d ) or 14,000 IU ( Vit D 2000 IU/d) vs. placebo | Placebo—98%, Low dose group—98%, High dose group—97% (pill counting)
El-Hajj 2006^48^ Beirut, Lebanon (33°53'N) [16278262] | - Mean age (range), y | 13.2 (10–17) | 25(OH)D: 34.9 nmol/L Ca: 677 mg/d | Weekly oral Vit D doses of 1400 IU (=Vit D 200 IU/d ) or 14,000 IU ( Vit D 2000 IU/d) vs. placebo | Placebo—98%, Low dose group—98%, High dose group—97% (pill counting)
El-Hajj 2006^48^ Beirut, Lebanon (33°53'N) [16278262] | - Male (%) | 0 | 25(OH)D: 34.9 nmol/L Ca: 677 mg/d | Weekly oral Vit D doses of 1400 IU (=Vit D 200 IU/d ) or 14,000 IU ( Vit D 2000 IU/d) vs. placebo | Placebo—98%, Low dose group—98%, High dose group—97% (pill counting)
NEW Studies
Grimnes 2012^241^ Norway | - Health status | Postmenopausal | Serum vitamin D: high dose group- 70.7+/-23.0 nmol/L; standard dose group- 71.2+/-22.3 nmol/L | high dose (6500 IU/day)+1000 mg elemental calcium/day vs. standard dose(800 IU/day)+1000 mg elemental calcium/day | 97% compliance
Grimnes 2012^241^ Norway | - Mean age (SD), y | 63.5 (SD 6.8) | Serum vitamin D: high dose group- 70.7+/-23.0 nmol/L; standard dose group- 71.2+/-22.3 nmol/L | high dose (6500 IU/day)+1000 mg elemental calcium/day vs. standard dose(800 IU/day)+1000 mg elemental calcium/day | 97% compliance
Grimnes 2012^241^ Norway | - Male (%) | 0% | Serum vitamin D: high dose group- 70.7+/-23.0 nmol/L; standard dose group- 71.2+/-22.3 nmol/L | high dose (6500 IU/day)+1000 mg elemental calcium/day vs. standard dose(800 IU/day)+1000 mg elemental calcium/day | 97% compliance
Holmlund-Suila 2012^239^ Helsinki, Finland | - Health status | nd | 53 nmol/L | Vit D_3_ 1600 IU/day Vs. Vit D_3_ 1200 IU/day Vs. Vit D_3_ 400 IU/day | 82% compliance | .
Holmlund-Suila 2012^239^ Helsinki, Finland | - Mean age (range), y | Birth | 53 nmol/L | Vit D_3_ 1600 IU/day Vs. Vit D_3_ 1200 IU/day Vs. Vit D_3_ 400 IU/day | 82% compliance | .
Holmlund-Suila 2012^239^ Helsinki, Finland | - Male (%) | 50% | 53 nmol/L | Vit D_3_ 1600 IU/day Vs. Vit D_3_ 1200 IU/day Vs. Vit D_3_ 400 IU/day | 82% compliance | .
Iuliano-Burns 2012^242^ Australiano Antarctic Division | - Health status | Healthy | Monthly- 55+/-14 nmol/L Bi-monthly- 60+/-15 nmol/L Single dose-63+/-12 nmol/L | monthly (Vit D_3_ 50,000 IU/month) vs. bimonthly (Vit D_3_ 50,000 IU in alternate months) vs. single dose (one does of Vit D_3_ 50,000 IU pre departure)
Iuliano-Burns 2012^242^ Australiano Antarctic Division | - Mean age (range), y | 41 (24–65) | Monthly- 55+/-14 nmol/L Bi-monthly- 60+/-15 nmol/L Single dose-63+/-12 nmol/L | monthly (Vit D_3_ 50,000 IU/month) vs. bimonthly (Vit D_3_ 50,000 IU in alternate months) vs. single dose (one does of Vit D_3_ 50,000 IU pre departure)
Iuliano-Burns 2012^242^ Australiano Antarctic Division | - Male (%) | 83% | Monthly- 55+/-14 nmol/L Bi-monthly- 60+/-15 nmol/L Single dose-63+/-12 nmol/L | monthly (Vit D_3_ 50,000 IU/month) vs. bimonthly (Vit D_3_ 50,000 IU in alternate months) vs. single dose (one does of Vit D_3_ 50,000 IU pre departure)
Jorde 2010^243^ nd | - Health status | Overweight/Obese | 57.7 +/-20.7 nmol/L | DD (Vit D_3_ 40,000 IU/week+500 mg calcium Vs.) DP (Vit D_3_ 20,000 IU/week+500 mg calcium) Vs. PP (Placebo+500 mg calcium) | Vitamin D- DD-95%, DP-96%, PP-96%, calcium-82%, 84%, and 83%
Jorde 2010^243^ nd | - Mean age (SD), y | 50.8 (10.7) | 57.7 +/-20.7 nmol/L | DD (Vit D_3_ 40,000 IU/week+500 mg calcium Vs.) DP (Vit D_3_ 20,000 IU/week+500 mg calcium) Vs. PP (Placebo+500 mg calcium) | Vitamin D- DD-95%, DP-96%, PP-96%, calcium-82%, 84%, and 83%
Jorde 2010^243^ nd | - Male (%) | nd | 57.7 +/-20.7 nmol/L | DD (Vit D_3_ 40,000 IU/week+500 mg calcium Vs.) DP (Vit D_3_ 20,000 IU/week+500 mg calcium) Vs. PP (Placebo+500 mg calcium) | Vitamin D- DD-95%, DP-96%, PP-96%, calcium-82%, 84%, and 83%
Khadilkar 2010^240^ Pune, India | - Health status | nd | Vit D + Ca- 24.5 nmol/L (12.7–33.2) Placebo +Ca- 20.8 nmol/L (12.7–30.4) | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day Vs. Placebo × 4 times/year + 250 mg elemental calcium/day | nd
Khadilkar 2010^240^ Pune, India | - Mean age (range), y | 14.6 (14.3–15.3) | Vit D + Ca- 24.5 nmol/L (12.7–33.2) Placebo +Ca- 20.8 nmol/L (12.7–30.4) | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day Vs. Placebo × 4 times/year + 250 mg elemental calcium/day | nd
Khadilkar 2010^240^ Pune, India | - Male (%) | 0% | Vit D + Ca- 24.5 nmol/L (12.7–33.2) Placebo +Ca- 20.8 nmol/L (12.7–30.4) | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day Vs. Placebo × 4 times/year + 250 mg elemental calcium/day | nd
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | - Health status | Healthy | Vitamin D intake: pacebo-2.6±1.4ug/d Serum vitamin D level:placebo-43.4±17.1 nmol/L Calcium intake: placebo-955±588 mg/d | 10 μg Vit D_3_/day Vs. 5 μg Vit D_3_/day Vs. placebo | placebo:88±12 5ug/d: 90±10 10ug/d 88±11
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | - Mean age (SD), y | 11.4 (SD 0.2) | Vitamin D intake: pacebo-2.6±1.4ug/d Serum vitamin D level:placebo-43.4±17.1 nmol/L Calcium intake: placebo-955±588 mg/d | 10 μg Vit D_3_/day Vs. 5 μg Vit D_3_/day Vs. placebo | placebo:88±12 5ug/d: 90±10 10ug/d 88±11
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | - Male (%) | 0% | Vitamin D intake: pacebo-2.6±1.4ug/d Serum vitamin D level:placebo-43.4±17.1 nmol/L Calcium intake: placebo-955±588 mg/d | 10 μg Vit D_3_/day Vs. 5 μg Vit D_3_/day Vs. placebo | placebo:88±12 5ug/d: 90±10 10ug/d 88±11
Nieves 2012^244^ New York, US | - Health status | Vit D deficient/depleted | Serum 25(OH)D: 29.0±14.3 nmol/L | 1,000 IU Vit D_3_ Vs. placebo | 95%
Nieves 2012^244^ New York, US | - Mean age (SD), y | 61.2 (SD 7.6) | Serum 25(OH)D: 29.0±14.3 nmol/L | 1,000 IU Vit D_3_ Vs. placebo | 95%
Nieves 2012^244^ New York, US | - Male (%) | 0% | Serum 25(OH)D: 29.0±14.3 nmol/L | 1,000 IU Vit D_3_ Vs. placebo | 95%
Macdonald 2013^245^ Scotland, UK | - Health status | Healthy, post menopausal | 35.8±16.4 nmol/L | Vit d3 400 IU Vs. Vit d3 1000 IU Vs. placebo | 92% (range 72% to 98%)
Macdonald 2013^245^ Scotland, UK | - Mean age (SD), y | 64.6 (SD 2.3) | 35.8±16.4 nmol/L | Vit d3 400 IU Vs. Vit d3 1000 IU Vs. placebo | 92% (range 72% to 98%)
Macdonald 2013^245^ Scotland, UK | - Male (%) | 0% | 35.8±16.4 nmol/L | Vit d3 400 IU Vs. Vit d3 1000 IU Vs. placebo | 92% (range 72% to 98%)
Macdonald 2013^245^ Scotland, UK | - Health status; - Mean age (SD), y; - Male (%) | | 35.8±16.4 nmol/L | Vit d3 400 IU Vs. Vit d3 1000 IU Vs. placebo | 92% (range 72% to 98%)

Table 45 Vitamin D and bone mineral density or bone mineral contents: Results of RCTs published after the Ottawa EPC report (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change/ Final | Change/ final 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Zhu 2008^247^ Perth, Australia (32°S) [18410225] | 71+. Women only | Hip BMD | 1° | 12 | Vit D_2_ 1000 IU + Ca citrate 1200 mg | 123 | mg/cm^2^ | 851 | 0.50% | -0.09, 1.09 | 0.30% | nd | NS | A
Zhu 2008^247^ Perth, Australia (32°S) [18410225] | 71+. Women only | Hip BMD | 1° | 12 | | | | | | | | | | A
Zhu 2008^247^ Perth, Australia (32°S) [18410225] | 71+. Women only | Hip BMD | 1° | 12 | Ca citrate 1200 mg | 133 | | 826 | 0.20% | -0.19, 0.59 | | | | A
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 400 | 30/21^A^ | mg/cm^2^ | 1.06 | 0% | nd | -1% | nd | NS | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | | | | | | | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 800 | 30/21 | | 0.98 | 1% | nd | 0% | nd | NS | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | | | | | | | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–53, Women only | Lumbar spine BMD | 1° | 12 | Placebo | 29/18 | | 0.99 | 1% | nd | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 400 | 25/19^A^ | mg/cm^2^ | 1.03 | 2% | nd | 0% | nd | NS | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | | | | | | | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Vit D_3_ 800 | 31/26 | | 0.92 | 7% | nd | 5% | nd | NS | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | | | | | | | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 18–64, Men only | Lumbar spine BMD | 1° | 12 | Placebo | 27/19 | | 1.03 | 2% | nd | | | | B
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 10–15 y girls | BMC | 1° | 12 | Vit D_3_ 400 | 9/7^A^ | kg | 1.3 | 22% | nd | 7% | nd | NS | C^B^
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 10–15 y girls | BMC | 1° | 12 | | | | | | | | | | C^B^
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 10–15 y girls | BMC | 1° | 12 | Vit D_3_ 800 | 7-Sep | | 1.5 | 10% | nd | -5% | nd | NS | C^B^
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 10–15 y girls | BMC | 1° | 12 | | | | | | | | | | C^B^
Andersen 2008^246^ Copenhagen, Denmark (55°N) [18208636] | 10–15 y girls | BMC | 1° | 12 | Placebo | 7-Aug | | 1.7 | 15% | nd | | | | C^B^
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Vit D 2000 IU | 55 | kg | 1.2 | 6.20% | 4.7, 7.7 | 0.10% | -1.1, 2.0^C^ | NS | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | | | | | | | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Vit D 200 IU | 58 | | 1.1 | 6.10% | 4.6, 7.6 | 1.10% | -0.8, 3.2^C^ | NS | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | | | | | | | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | 10–17 y girls | BMC | 1° | 12 | Placebo | 55 | | 1.1 | 5.00% | 3.8, 6.2 | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | | | | | | | | | | | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | Subgroup– Premenarchal girls, mean age 10 y | BMC | 1° | 12 | Vit D 2000 IU | 14 | kg | 0.8 | 11.60% | 9.4, 13.8 | 4.20% | 0.7, 7.7^C^ | NS | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | Subgroup– Premenarchal girls, mean age 10 y | BMC | 1° | 12 | | | | | | | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | Subgroup– Premenarchal girls, mean age 10 y | BMC | 1° | 12 | Vit D 200 IU | 12 | | 0.7 | 11.40% | 9.1, 13.7 | 4.00% | 0.5, 7.5^C^ | NS | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | Subgroup– Premenarchal girls, mean age 10 y | BMC | 1° | 12 | | | | | | | | | | C
El-Hajj 2006^48^ Beirut, Lebanon (33°N) [16278262] | Subgroup– Premenarchal girls, mean age 10 y | BMC | 1° | 12 | Placebo | 8 | | 0.8 | 7.40% | 4.7, 10.1 | | | | C
NEW Studies
Grimnes 2012^241^ Norway | Postmenopause | Total hip BMD | 1° | 1 yr | high dose (6500 IU/day)+1000 mg elemental calcium/day | 149 | g/cm^2^ | 0.79 | change=0.31 | sd=1.59 | -0.25 | -0.63, 0.13 | 0.19 | A
Grimnes 2012^241^ Norway | Postmenopause | Total hip BMD | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | Total hip BMD | 1° | 1 yr | standard dose(800 IU/day)+1000 mg elemental calcium/day | 148 | g/cm^2^ | 0.791 | change=0.56 | sd=1.70 | | | | A
Grimnes 2012^241^ Norway | Postmenopause | | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | Femoral neck BMD | 1° | 1 yr | high dose (6500 IU/day)+1000 mg elemental calcium/day | 149 | g/cm^2^ | 0.758 | change=0.03 | sd=2.08 | -0.14 | -0.59, 0.31 | 0.86 | A
Grimnes 2012^241^ Norway | Postmenopause | Femoral neck BMD | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | Femoral neck BMD | 1° | 1 yr | standard dose(800 IU/day)+1000 mg elemental calcium/day | 148 | g/cm^2^ | 0.757 | change=0.17 | sd=1.87 | | | | A
Grimnes 2012^241^ Norway | Postmenopause | | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | L2-L4 BMD | 1° | 1 yr | high dose (6500 IU/day)+1000 mg elemental calcium/day | 149 | g/cm^2^ | 0.901 | change=0.25 | sd=3.19 | -0.07 | -0.80, 0.66 | 0.85 | A
Grimnes 2012^241^ Norway | Postmenopause | L2-L4 BMD | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | L2-L4 BMD | 1° | 1 yr | standard dose(800 IU/day)+1000 mg elemental calcium/day | 148 | g/cm^2^ | 0.902 | change=0.32 | sd=3.23 | | | | A
Grimnes 2012^241^ Norway | Postmenopause | | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | Total Body BMD | 1° | 1 yr | high dose (6500 IU/day)+1000 mg elemental calcium/day | 149 | g/cm^2^ | 1 | change=0.18 | sd=1.14 | -0.02 | -0.29, 0.25 | 0.88 | A
Grimnes 2012^241^ Norway | Postmenopause | Total Body BMD | 1° | 1 yr | | | | | | | | | | A
Grimnes 2012^241^ Norway | Postmenopause | Total Body BMD | 1° | 1 yr | standard dose(800 IU/day)+1000 mg elemental calcium/day | 148 | g/cm^2^ | 1.002 | change=0.20 | sd=1.23 | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | cortical bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 1600 IU/day | 29 | g/cm^3^ | NR | final=716 | se=7 | -8 | -12.1,-3.9 | <0.001 | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | cortical bone density | 2° | 10 week (age of 3 months) | | | | | | | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | cortical bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 1200 IU/day | 28 | | NR | final=726 | se=7 | +2 | -2.1, 6.1 | 0.34 | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | cortical bone density | 2° | 10 week (age of 3 months) | | | | | | | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | cortical bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 400 IU/day | 25 | | NR | final=724 | se=8 | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | | 2° | 10 week (age of 3 months) | | | | | | | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | total and trabecular bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 1600 IU/day | 29 | | NR | final=430 | se=12 | -18 | -25, -11 | <0.001 | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | total and trabecular bone density | 2° | 10 week (age of 3 months) | | | | | | | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | total and trabecular bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 1200 IU/day | 28 | | NR | final=451 | se=12 | +3 | -4, 10 | 0.39 | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | total and trabecular bone density | 2° | 10 week (age of 3 months) | | | | | | | | | | A
Holmlund-Suila 2012^239^ Helsinki, Finland | 0–6 mos | total and trabecular bone density | 2° | 10 week (age of 3 months) | Vit D_3_ 400 IU/day | 25 | | NR | final=448 | se=13 | | | | A
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Femoral neck BMD | 1° | up to 12 months (end of expedition) | monthly (Vit D_3_ 50,000 IU/month) | 36 | g/cm^2^ | 0.86 | final=0.85 | sd=0.13 | -0.06 | -0.12, 0 | 0.06 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Femoral neck BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Femoral neck BMD | 1° | up to 12 months (end of expedition) | bimonthly (Vit D_3_ 50,000 IU in alternate months) | 35 | | 0.82 | final=0.82 | sd=0.10 | -0.09 | -0.15, -0.03 | <0.001 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Femoral neck BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Femoral neck BMD | 1° | up to 12 months (end of expedition) | single dose (one dose of Vit D_3_ 50,000 IU pre departure) | 31 | | 0.9 | final=0.91 | sd=0.13 | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Lumbar spine (L1-L4) BMD | 1° | up to 12 months (end of expedition) | monthly (Vit D_3_ 50,000 IU/month) | 36 | | 1 | final=0.98 | sd=0.16 | -0.09 | -0.17, -0.01 | 0.03 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Lumbar spine (L1-L4) BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Lumbar spine (L1-L4) BMD | 1° | up to 12 months (end of expedition) | bimonthly (Vit D_3_ 50,000 IU in alternate months) | 35 | | 1 | final=1.00 | sd=0.09 | -0.07 | -0.14, -0.0 | 0.05 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Lumbar spine (L1-L4) BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Lumbar spine (L1-L4) BMD | 1° | up to 12 months (end of expedition) | single dose (one dose of Vit D_3_ 50,000 IU pre departure) | 31 | | 1.08 | final=1.07 | sd=0.18 | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Total proximal femur BMD | 1° | up to 12 months (end of expedition) | monthly (Vit D_3_ 50,000 IU/month) | 36 | | 1.02 | final=0.85 | sd=0.13 | -0.23 | -0.30, -0.16 | <0.001 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Total proximal femur BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Total proximal femur BMD | 1° | up to 12 months (end of expedition) | bimonthly (Vit D_3_ 50,000 IU in alternate months) | 35 | | 1.01 | final=1.01 | sd=0.08 | -0.07 | -0.13, -0.01 | 0.02 | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Total proximal femur BMD | 1° | up to 12 months (end of expedition) | | | | | | | | | | B
Iuliano-Burns 2012^242^ Australian Antarctic Division | 19–50, 0–70 yrs | Total proximal femur BMD | 1° | up to 12 months (end of expedition) | single dose (one dose of Vit D_3_ 50,000 IU pre departure) | 31 | | 1.08 | final=1.08 | sd=0.15 | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD L2-L4 | 1° | 1 yr | DD (Vit D_3_ 40,000 IU/week+500 mg calcium) | 110 | g/cm^2^ | 1.27 | change=0.008 | sd=0.036 | +0.00 | -0.01, 0.01 | 0.85 | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD L2-L4 | 1° | 1 yr | | | | | | | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD L2-L4 | 1° | 1 yr | DP (Vit D_3_ 20,000 IU/week+500 mg calcium) | 97 | | 1.235 | change=0.008 | sd=0.039 | +0.01 | 0.0, 0.01 | 0.86 | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD L2-L4 | 1° | 1 yr | | | | | | | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD L2-L4 | 1° | 1 yr | PP (Placebo+500 mg calcium) | 105 | | 1.251 | change=0.007 | sd=0.042 | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | | 1° | 1 yr | | | | | | | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD total hip | 1° | 1 yr | DD (Vit D_3_ 40,000 IU/week+500 mg calcium) | 110 | | 1.107 | change=0.008 | sd=0.014 | -0.00 | -0.01, 0.0 | 0.64 | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD total hip | 1° | 1 yr | | | | | | | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD total hip | 1° | 1 yr | DP (Vit D_3_ 20,000 IU/week+500 mg calcium) | 97 | | 1.067 | change=0.011 | sd=0.014 | +0.0 | -0.0, 0.01 | 0.36 | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD total hip | 1° | 1 yr | | | | | | | | | | B
Jorde 2010^243^ nd | 19–50, 51–70 yrs | BMD total hip | 1° | 1 yr | PP (Placebo+500 mg calcium) | 105 | | 1.092 | change=0.009 | sd=0.017 | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 bone mineral apparent density | 1° | 1 yr | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day | 25 | g/cm^3^ | NR | change=4.2 | 0.6, 9.3 | +0.5 | NC | NC | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 bone mineral apparent density | 1° | 1 yr | | | | | | | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 bone mineral apparent density | 1° | 1 yr | Placebo × 4 times/year + 250 mg elemental calcium/day | 24 | g/cm^3^ | NR | change=3.7 | 1.0, 7.7 | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | | 1° | 1 yr | | | | | | | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 BMC | 1° | 1 yr | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day | 25 | g | NR | change=10.5 | 4.6, 17.2 | -0.8 | NC | NC | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 BMC | 1° | 1 yr | | | | | | | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | L2-L4 BMC | 1° | 1 yr | Placebo × 4 times/year + 250 mg elemental calcium/day | 24 | g | NR | change=11.3 | 5.4, 18.0 | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | | 1° | 1 yr | | | | | | | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | Total BMC | 1° | 1 yr | Vit D_2_ 300,000 IU × 4 times/year + 250 mg elemental calcium/day | 25 | g | NR | change=10.1 | 6.1, 14.7 | +1.9 | NC | NC | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | Total BMC | 1° | 1 yr | | | | | | | | | | B
Khadilkar 2010^240^ Pune, India | 9–18 yrs | Total BMC | 1° | 1 yr | Placebo × 4 times/year + 250 mg elemental calcium/day | 24 | g | NR | change=8.2 | 4.9, 12.6 | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMC | 1° | 12 months | 10 μg Vit D_3_/day | 74 | g | 28.9 | final=36.3 | sd=8.6 | -1.2 | -4.3, 1.9 | 0.44 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMC | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMC | 1° | 12 months | 5 μg Vit D_3_/day | 73 | g | 29.4 | final=37.6 | sd=10.3 | +0.1 | -3.2, 3.4 | 0.95 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMC | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMC | 1° | 12 months | placebo | 74 | g | 29.2 | final=37.5 | sd=10.2 | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMD | 1° | 12 months | 10 μg Vit D_3_/day | 74 | g/cm^2^ | 0.695 | final=0.780 | sd=0.113 | -0.01 | -0.05, 0.03 | 0.68 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMD | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMD | 1° | 12 months | 5 μg Vit D_3_/day | 73 | g/cm^2^ | 0.698 | final=0.786 | sd=0.115 | -0.0 | -0.04, 0.04 | 0.91 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMD | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | L1-L4 BMD | 1° | 12 months | placebo | 74 | g/cm^2^ | 0.697 | final=0.788 | sd=0.121 | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMD | 1° | 12 months | 10 μg Vit D_3_/day | 74 | g/cm^2^ | 0.872 | final=0.917 | sd=0.080 | +0.01 | -0.02, 0.03 | 0.53 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMD | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMD | 1° | 12 months | 5 μg Vit D_3_/day | 73 | g/cm^2^ | 0.866 | final=0.915 | sd=0.075 | +0.01 | -0.02, 0.03 | 0.63 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMD | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMD | 1° | 12 months | placebo | 74 | g/cm^2^ | 0.863 | final=0.909 | sd=0.075 | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMC | 1° | 12 months | 10 μg Vit D_3_/day | 74 | g | 1308 | final=1561 | sd=366 | +38 | -74, 150 | 0.50 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMC | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMC | 1° | 12 months | 5 μg Vit D_3_/day | 73 | g | 1311 | final=1559 | sd=324 | +36 | -70, 142 | 0.50 | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMC | 1° | 12 months | | | | | | | | | | B
Molgaard 2010^248^ Copenhagen and Frederiksberg, Denmark | 9–18 yrs | whole body BMC | 1° | 12 months | placebo | 74 | g | 1277 | final=1523 | sd=324 | | | | B
Nieves 2012^244^ New York, US | Postmenopause | femoral neck BMD | 1° | 2 yrs | 1,000 IU Vit D_3_ | 55 | g/cm^2^ | NR | change=-0.2 | NR | +0.6 | NC | NC | A
Nieves 2012^244^ New York, US | Postmenopause | femoral neck BMD | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | femoral neck BMD | 1° | 2 yrs | placebo | 48 | | NR | change=-0.8 | NR | | | | A
Nieves 2012^244^ New York, US | Postmenopause | | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | spine BMD | 1° | 2 yrs | 1,000 IU Vit D_3_ | 55 | | 1.154 | change=-0.5 | NR | +0.1 | NC | NC | A
Nieves 2012^244^ New York, US | Postmenopause | spine BMD | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | spine BMD | 1° | 2 yrs | placebo | 48 | | 1.212 | change=-0.6 | NR | | | | A
Nieves 2012^244^ New York, US | Postmenopause | | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | total hip BMD | 1° | 2 yrs | 1,000 IU Vit D_3_ | 55 | | 1.043 | change=-0.5 | NR | +0.2 | NC | NC | A
Nieves 2012^244^ New York, US | Postmenopause | total hip BMD | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | total hip BMD | 1° | 2 yrs | placebo | 48 | | 1.04 | change=-0.7 | NR | | | | A
Nieves 2012^244^ New York, US | Postmenopause | | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | trochanter BMD | 1° | 2 yrs | 1,000 IU Vit D_3_ | 55 | | NR | change=-0.3 | NR | +0.15 | NC | NC | A
Nieves 2012^244^ New York, US | Postmenopause | trochanter BMD | 1° | 2 yrs | | | | | | | | | | A
Nieves 2012^244^ New York, US | Postmenopause | trochanter BMD | 1° | 2 yrs | placebo | 48 | | NR | change=-0.45 | NR | | | | A
Macdonald 2013^245^ | | total hip BMD | 1° | 1 yr | Vit d3 400 IU | 83 | g/cm^2^ | 0.917 | final=0.912 | sd=0.103 | -0.002 | -0.036, 0.032 | 0.91 | A
Macdonald 2013^245^ | | total hip BMD | 1° | 1 yr | Vit d3 1000 IU | 88 | | 0.923 | final=0.923 | sd=0.135 | +0.009 | -0.029, 0.047 | 0.64 | A
Macdonald 2013^245^ | | total hip BMD | 1° | 1 yr | placebo | 88 | | 0.92 | final=0.914 | sd=0.118 | | | | A
Macdonald 2013^245^ | | total lumbar spine BMD | | | Vit d3 400 IU | 83 | | 1.075 | final=1.076 | sd=0.135 | +0.006 | -0.038, 0.050 | 0.79 | A
Macdonald 2013^245^ | | total lumbar spine BMD | | | Vit d3 1000 IU | 88 | | 1.068 | final=1.071 | sd=0.164 | +0.001 | -0.046, 0.048 | 0.97 | A
Macdonald 2013^245^ | | total lumbar spine BMD | | | placebo | 88 | | 1.081 | final=1.070 | sd=0.153 | | | | A

Note: Outcomes cells are shaded for the Control rows.

A Baseline/final sample size

B Downgraded to C because very small sample size (insufficient power) and no adjustments for confounders

C Estimated from available data

##### Current Report

Eight studies examined the effects of supplementation with vitamin D alone (or vitamin D plus calcium compared with calcium alone): one in infants,239 two in adolescent girls in India240 and Denmark and the remainder in adults.241-245 Study duration ranged from 10 weeks (for the infants) to 2 years, with most lasting 1 year. Daily doses ranged from 200IU to 5700IU.

The study of infants (rated A), which administered doses ranging from 400IU to 1600IU daily from 2 weeks of age to 12 weeks of age observed a trend toward increasing BMC.239 One study of adolescents (rated B) showed slightly increased BMC in girls within 2 years of menarche. And a study of 305 postmenopausal Scottish women who received 0, 400, or 1000IU/d showed decreased loss of hip but not spine BMD with 1000IU/d.240,245 The remaining studies (one rated A, three B, one C) found no effects of vitamin D supplementation on BMD.

##### Ottawa EPC Report: Bone Mineral Content—Infants (0 Through 12 months)

Overall, there is inconsistent evidence for an association between a specific serum 25(OH)D concentration and the bone health outcome BMC in infants. Of the two RCTs examining BMC, one demonstrated no significant benefit of higher serum 25(OH)D concentrations on radial bone mass while the other showed a transient increase of BMC compared to the unsupplemented group at 12 weeks but not 26 weeks. Of the three case-control studies, greater whole body BMC, was related to higher serum 25(OH)D concentrations.

##### Ottawa EPC Report: Bone Mineral Content or Density—Older Children (6 Months Through Before Puberty) and Adolescents (Onset of Puberty Through 18 Years)

Overall, there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. However, the results from two RCTs of vitamin D supplementation have not confirmed a consistent benefit on BMD or BMC across sites and age groups.

There were seven studies in older children and adolescents (two RCTs, three cohorts, one case-control and one before-after study) that evaluated the relationship between serum 25(OH)D concentrations and BMC or BMD. In older children, there was one RCT, one prospective cohort and one before-after study. One RCT did not find an association between serum 25(OH)D concentrations and distal radial BMC. Two of three studies found an association between lower baseline serum 25(OH)D concentrations and lower BMC or BMD. The effect of bone size and muscle mass on these outcomes in relation to baseline serum 25(OH)D concentrations was not reported. One RCT demonstrated a significant relation between baseline serum 25(OH)D concentrations and baseline BMD of the lumbar spine, femoral neck and radius. However, only high dose supplementation with 14,000 IU/wk of vitamin D_3_ increased BMC of the total hip.

##### Ottawa EPC Report: Bone Mineral Density—Postmenopausal Women and Elderly Men

Overall, there was discordance between the results from RCTs and the majority of observational studies that may be due to the limitations of observational studies to control for all relevant confounders. Five RCTs, and three cohort studies did not find an association between serum 25(OH)D concentrations and BMD or bone loss. Four cohort studies found a significant association between 25(OH)D concentrations and bone loss, which was most evident at the hip sites but the evidence for an association between 25(OH)D concentrations and lumbar spine BMD was weak. Six case-control studies suggested an association between 25(OH)D concentrations and BMD and the association was most consistent at the femoral neck BMD.

Based on the results from the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. Specific circulating concentrations of 25(OH)D below which bone loss at the hip was increased ranged from 30–80 nmol/L.

##### Ottawa EPC Report: Bone Mineral Density—Pregnant or Lactating Women

One cohort study did not find an association between serum 25(OH)D concentrations and change in BMD that occurred during lactation. Limitations in the study design and sources of bias highlight the need for additional research on vitamin D status in pregnancy and lactation, and the association with bone health outcomes.

##### Additional Studies Published After the Ottawa EPC Report

One A-quality RCT compared the effect of vitamin D_2_ supplementation on hip BMC in 256 elderly women between 70 and 90 years of age. All elderly women in this trial had normal physical functioning. They were randomly assigned to receive either vitamin D_2_ (1000 IU/d) plus calcium (1200 mg/d) supplement or calcium (1200 mg/d) supplement alone for one year. The mean baseline dietary calcium intake was 1097 mg/d and mean 25(OH)D concentration was 44.3 nmol/L. Total hip BMD increased significantly in both groups, with no difference between the vitamin D_2_ plus calcium and calcium alone groups (hip BMD change: vitamin D, +0.5%; control, +0.2%).

One B quality RCT analyzed 89 and 83 healthy adult women and men separately.246 The participants were Pakistani immigrants living in the Copenhagen area of Denmark (latitude 55 N°). Women and men were randomly assigned to receive either daily dose of 400 IU or 800 IU vitamin D_3_, or placebo for one year. For women, the mean baseline dietary calcium intake was 495 mg/d and mean 25(OH)D concentration was 12 nmol/L. For men, the mean baseline dietary calcium intake was 548 mg/d and mean 25(OH)D concentration was 21 nmol/L. At the end of study, in both women and men, there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.

Two RCTs, both rated C, compared the effect of vitamin D supplementation on BMC in healthy girls, aged between 10 and 17 years old.48,246 The first RCT analyzed 26 healthy girls, who were Pakistani immigrants primarily living in the Copenhagen area Denmark (latitude 55 N°).246 Girls were randomly assigned to receive either daily dose 400 IU or 800 IU vitamin D_3_, or placebo for one year. The mean baseline dietary calcium intake was 510 mg/d and mean 25(OH)D concentration was 11 nmol/L. At the end of study, there were no significant differences in whole body BMC changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups. The second RCT analyzed 168 healthy girls, living in the Greater Beirut area, Lebanon (latitude 33°N).48 Girls were randomly assigned to receive either weekly oral vitamin D doses of 1400 IU (equivalent to 200 IU/d) or 14,000 IU (equivalent to 2000 IU/d) or placebo for one year. The mean baseline dietary calcium intake was 677 mg/d and mean 25(OH)D concentration was 35 nmol/L. At the end of study, there were no significant differences in whole body BMC changes between either low-dose vitamin D (200 IU/d) or high-dose vitamin D (2000 IU/d) and the placebo groups. The same findings were seen when analyses were restricted to either premenarchal or postmenarchal girls. Both RCTs were rated C because the results were not adjusted for important potential confounders, such as height, bone area, lean mass, sun exposure, and pubertal status.

#### Findings by Life Stage

- 0–6 mo
  One study identified for the current report found a trend toward increasing BMC for infants given high-dose supplements of vitamin D. The Ottawa EPC report concluded that there is inconsistent evidence for an association between a specific serum 25(OH)D concentration and the bone health outcome BMC in infants. There were no new data since the Ottawa report.
- 7 mo–2 y
  The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. There were no new data since the Ottawa report.
- 3–8 y
  The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. There were no new data since the Ottawa report.
- 9–18 y
  Two RCTs identified for the current report assessed the effects of vitamin D supplementation on BMC in adolescent girls: One, which administered high doses, observed a trend for girls within two years of menarche. The other saw no effects. The Ottawa EPC report concluded that there was fair evidence of an association between 25(OH)D concentrations and baseline BMD and change in BMD or BMC indices from the studies in older children and adolescents. Two new RCTs enrolled only girls in this life stage. The results showed no significant differences in whole body BMC changes between either lower doses of vitamin D (200 or 400 IU/d) or higher dose of vitamin D (800 or 2000 IU/d) and the placebo groups.
- 19–50 y
  RCTs identified for the current report for populations of adults observed no effects of vitamin D on BMD. The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled primarily men and women in this life stage. The results showed that there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.
- 51–70 y
  RCTs identified for the current report for populations of adults observed no effects of vitamin D on BMD. The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled some men in this life stage. The results showed that there were no significant differences in lumbar spine BMD changes between the two doses of vitamin D_3_ (400 IU/d or 800 IU/d) and the placebo groups.
- ≥71 y
  The Ottawa EPC report concluded that there was discordance between the results from RCTs and the majority of observational studies in postmenopausal women and elderly men. Based on results of the observational studies, there is fair evidence to support an association between serum 25(OH)D and BMD or changes in BMD at the femoral neck. One new RCT enrolled only elderly women in this life stage. The results showed that vitamin D_2_ supplementation (1000 IU/d) had no additional effect on hip BMD compared to calcium supplementation alone.
- Postmenopause
  Two RCTs of vitamin D supplementation of postmenopausal women identified for the current report found no effect. One RCT found an effect on hip BMD but not spinal BMD and only at the higher of two doses (1000IU vs. 400IU/d). There were no new data since the Ottawa report.
- Pregnant & lactating women
  No studies identified for the current report enrolled this population. There were no new data since the Ottawa report.

## Combined Vitamin D and Calcium and Health Outcomes

### Women's Health Initiative (WHI) Trial

The WHI trial provided data for numerous health outcomes of interest. For this reason and because of some methodological issues unique to this trial, the study is discussed here. The trial compared combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg daily versus placebo in a 7-year trial in 36,282 postmenopausal women (age 50–79 y). The Tufts EPC, members of the Technical Expert Panel, and reviewers of the draft report debated about the quality of this trial. It was generally agreed that the overall methodological rigor and analyses were of good quality for most outcomes. However, there was not complete consensus on how to regard the fact that the women in both groups of this 7-year trial were allowed to take additional vitamin D supplements up to 600 IU and later 1000 IU per day and calcium supplements up to 1000 mg per day. At baseline, about one-third of women in both supplement and placebo groups were taking vitamin D supplements of at least 400 IU/d and 29 percent were taking at least 500 mg/d of supplemental calcium; by the end of the trial 69 percent of women were taking any additional supplemental calcium. During the 7 years, only about 60 percent of women (in any given year) were taking at least 80 percent of the study pills; at the end of the trial, only 76 percent were still taking any study medications. Regarding the overall quality of the study, arguments were put forward that this was a high quality effectiveness trial (in contrast with a more standardized efficacy trial) and thus had increased relevance to the actual use of supplements, that the crossover of interventions affects the applicability more than the methodological quality, and that the trial should not be downgraded because data reporting was more complete than for most trials. However, it was the consensus among the Tufts EPC that overall, the methodological quality of the trial was B, particularly when the trial is being used to guide decisions about DRI, as opposed to decisions about whether to actively recommend supplementation for an individual woman.

### Combined Vitamin D and Calcium and Growth

The current report did not consider growth as an outcome, except for prenatal growth. No new studies were identified. The original report reviewed primary studies that evaluated relationships between vitamin D and calcium and growth parameters in infants and children.

#### Synopsis

One C-rated nonrandomized study compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth.

#### Detailed Presentation

(Tables 4 & 6)

##### Infant 0–6 Months; 7 Months–2 Years; Pregnant or Lactating Women

The original report identified a study from India that included a nonrandomized comparison between combined vitamin D (1200 IU/d) and calcium (375 mg/d) for the expectant mothers versus no supplementation. The outcome was infant birth weight.54 This study has already been described in the “Vitamin D and Growth” section, as it also included a vitamin D only intervention arm. The study included expectant mothers with daily milk intake less than 500 mL and estimated daily vitamin D intake less than 30 IU. It was rated C for methodological quality, because of the lack of randomization and incomplete reporting of analyses. According to the reported analysis, infants of women who received supplementation were significantly heavier at birth by 160 g on average (95% CI 0, 320).

#### Findings by Life Stage

- 0–6 mo
  One C-rated nonrandomized study from India compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth by 160 g on average (95% CI 0, 320). (See also the Pregnant & lactating women.)
- 7 mo–2 y
  No identified study covered this life stage.
- 3–8 y
  No identified study covered this life stage.
- 9–18 y
  No identified study covered this life stage.
- 19–50 y
  Not reviewed
- 51–70 y
  Not reviewed
- ≥71 y
  Not reviewed
- Postmenopause
  Not reviewed
- Pregnant & lactating women
  One C-rated nonrandomized study from India compared combined vitamin D (1200 IU/d) and calcium (375 mg/d) to no supplementation in women in their third trimester of pregnancy. Infants of women who received supplementation were significantly heavier at birth by 160 g on average (95% CI 0, 320). (See also the 0–6 mo category.)

### Combined Vitamin D and Calcium and Cardiovascular Disease

#### Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores or serum concentrations, and cardiovascular events. As described in the original report, a variety of cardiovascular events after 7 years were evaluated in the Women's Health Initiative (WHI) trial of combined daily vitamin D_3_ 400 IU and calcium carbonate 1000 mg versus placebo in 50 to 79 year old women. No statistically significant effect was found with combined vitamin D and calcium supplementation on any cardiovascular outcome. However, near significant associations were found for three outcomes, suggesting increased risk with supplementation for a composite cardiac outcome that included invasive cardiac interventions, invasive cardiac interventions, and transient ischemic attacks. No significant associations were found for cardiovascular death, a composite cardiac outcome (myocardial infarction or cardiac death), coronary heart disease death, myocardial infarction, hospitalization for heart failure, angina, combined stroke or transient ischemic attack, stroke alone, or cerebrovascular death.

A reassessment of the WHI Ca-D Trial data that controlled for women's use of personal dietary supplements found no effects of the intervention vitamin D and calcium supplements on risk for cardiovascular outcomes.

#### Detailed Presentation

(Tables 46 & 47)

Table 46 Combined vitamin D and calcium and cardiovascular outcomes: Characteristics of RCTs (formerly Table 85) (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Hsia 2007^249^ LaCroix 2009^250^ WHI US (various) [17309935 19221190] | - Health status | Any | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group Low Ca intake (<800 mg/day): 34% | Combined Vit D & Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
Hsia 2007^249^ LaCroix 2009^250^ WHI US (various) [17309935 19221190] | - Mean age (range), y | 62 (50-79) | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group Low Ca intake (<800 mg/day): 34% | Combined Vit D & Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
Hsia 2007^249^ LaCroix 2009^250^ WHI US (various) [17309935 19221190] | - Male (%) | 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group Low Ca intake (<800 mg/day): 34% | Combined Vit D & Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
NEW Studies
Prentice 2013^2^ WHI US (various) | - Health status | Postmenopausal | nd | 1000mg/day of Ca & 400IU/day of Vit D3 Vs. placebo | nd
Prentice 2013^2^ WHI US (various) | - Mean age (range), y | 50–54: 14.2% (50-79) | nd | 1000mg/day of Ca & 400IU/day of Vit D3 Vs. placebo | nd
Prentice 2013^2^ WHI US (various) | - Male (%) | 0% | nd | 1000mg/day of Ca & 400IU/day of Vit D3 Vs. placebo | nd

Table 47 Combined vitamin D and calcium and cardiovascular outcomes: Results of RCTs (formerly Table 86) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiovascular death | 2° | 7 | Vit D + Ca | 226 | 18,176 | HR (Suppl/Placebo) | 0.92* | 0.77, 1.10 | NS | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiovascular death | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiovascular death | 2° | 7 | Placebo | 244 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI, CHD death, CABG, or PCI) | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 920 | 18,176 | HR | 1.08 | 0.99, 1.19 | 0.1 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI, CHD death, CABG, or PCI) | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI, CHD death, CABG, or PCI) | 2° | 7 | Placebo | 841 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI or CHD death) | 2° | 7 | Vit D + Ca | 499 | 18,176 | HR | 1.04 | 0.92, 1.18 | 0.5 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI or CHD death) | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cardiac composite (MI or CHD death) | 2° | 7 | Placebo | 475 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CHD death | 2° | 7 | Vit D + Ca | 130 | 18,176 | HR | 1.01* | 0.79, 1.29 | 0.92 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CHD death | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CHD death | 2° | 7 | Placebo | 128 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | MI | 2° | 7 | Vit D + Ca | 411 | 18,176 | HR | 1.05 | 0.91, 1.20 | 0.52 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | MI | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | MI | 2° | 7 | Placebo | 390 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CABG or PCI | 2° | 7 | Vit D + Ca | 674 | 18,176 | HR | 1.09 | 0.98, 1.22 | 0.12 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CABG or PCI | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | CABG or PCI | 2° | 7 | Placebo | 607 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Hospitalized for heart failure | 2° | 7 | Vit D + Ca | 394 | 18,176 | HR | 0.95 | 0.83, 1.10 | 0.5 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Hospitalized for heart failure | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Hospitalized for heart failure | 2° | 7 | Placebo | 407 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Angina | 2° | 7 | Vit D + Ca | 404 | 18,176 | HR | 1.08 | 0.94, 1.24 | 0.3 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Angina | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Angina | 2° | 7 | Placebo | 377 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular composite (Stroke or TIA) | 2° | 7 | Vit D + Ca | 563 | 18,176 | HR | 1.02 | 0.91, 1.15 | 0.75 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular composite (Stroke or TIA) | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular composite (Stroke or TIA) | 2° | 7 | Placebo | 547 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Stroke | 2° | 7 | Vit D + Ca | 362 | 18,176 | HR | 0.95 | 0.82, 1.10 | 0.51 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Stroke | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Stroke | 2° | 7 | Placebo | 377 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | TIA | 2° | 7 | Vit D + Ca | 213 | 18,176 | HR | 1.16 | 0.95, 1.42 | 0.13 | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | TIA | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | TIA | 2° | 7 | Placebo | 182 | 18,106 | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | | | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular death | 2° | 7 | Vit D + Ca | 213 | 18,176 | HR | 0.89* | 0.62, 1.29 | NS | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular death | 2° | 7 | | | | | | | | B
Hsia 2007^249^ LaCroix 2009^250^ WHI [17309935] [19221190] | 50–79 y, Women | Cerebrovascular death | 2° | 7 | Placebo | 182 | 18,106 | | | | | B
New studies
Prentice 2013^2^ WHI US (various) | | Primary - MI | 1° | 7 | 1000mg/day of Ca & 400IU/day of Vit D3 | 193 | 7,718 | HR | 1.18 | 0.88, 1.59 | 0.17 | A
Prentice 2013^2^ WHI US (various) | | Primary - MI | 1° | 7 | placebo | 167 | 7,584 | | 1.00 | Reference | | A
Prentice 2013^2^ WHI US (various) | | | | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Coronary heart disease | 1° | 7 | 1000mg/day of Ca & 400IU/day of Vit D3 | 229 | 7,718 | HR | 1.08 | 0.82, 1.42 | 0.4 | A
Prentice 2013^2^ WHI US (various) | | Primary - Coronary heart disease | 1° | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Coronary heart disease | 1° | 7 | placebo | 211 | 7,584 | | 1.00 | Reference | | A
Prentice 2013^2^ WHI US (various) | | | | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Total heart disease | 1° | 7 | 1000mg/day of Ca & 400IU/day of Vit D3 | 621 | 7,718 | HR | 1.00 | 0.86, 1.18 | 0.56 | A
Prentice 2013^2^ WHI US (various) | | Primary - Total heart disease | 1° | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Total heart disease | 1° | 7 | placebo | 642 | 7,584 | | 1.00 | Reference | | A
Prentice 2013^2^ WHI US (various) | | | | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Stroke | 1° | 7 | 1000mg/day of Ca & 400IU/day of Vit D3 | 184 | 7,718 | HR | 1.18 | 0.86, 1.62 | 0.96 | A
Prentice 2013^2^ WHI US (various) | | Primary - Stroke | 1° | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Stroke | 1° | 7 | placebo | 162 | 7,584 | | 1.00 | Reference | | A
Prentice 2013^2^ WHI US (various) | | | | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Total cardiovascular disease | 1° | 7 | 1000mg/day of Ca & 400IU/day of Vit D3 | 848 | 7,718 | HR | 1.04 | 0.90, 1.19 | 0.77 | A
Prentice 2013^2^ WHI US (various) | | Primary - Total cardiovascular disease | 1° | 7 | | | | | | | | A
Prentice 2013^2^ WHI US (various) | | Primary - Total cardiovascular disease | 1° | 7 | placebo | 813 | 7,584 | | 1.00 | Reference | | A

Note: Outcomes cells are shaded for the Control rows.

The original report described the findings of the WHI CaD with respect to cardiovascular outcomes. In the WHI trial, discussed above, the evaluated cardiovascular outcomes were all prespecified secondary outcomes.249,250 On average, the women had normal blood pressure. There were no significant effects of the supplementation on any of the outcomes, though three of the outcomes did approach statistical significance suggesting increased events with supplementation: composite cardiac events (HR = 1.08 [95% CI 0.99, 1.19]), coronary artery bypass grafting or percutaneous coronary interventions (HR=1.09 [95% CI 0.98, 1.22]), and transient ischemic attacks (HR=1.16 [95% CI 0.95, 1.42]). The authors, however, concluded that calcium and vitamin D supplementation neither increased nor decreased coronary or cerebrovascular risk in generally healthy postmenopausal women. The outcomes cardiac death and stroke were evaluated by age decade. No interaction was found with age (no significant difference across age groups). A similar analysis based on total calcium intake (dietary plus supplemental) also found no interaction.

A post hoc analysis of the WHI CaD Trial data was found for the current report that assessed the effects of the study intervention after controlling for women's use of personal dietary supplements. This analysis found no effects of the intervention vitamin D and calcium supplements on risk for cardiovascular outcomes among women who did not use Ca or vitamin D supplements at the start of the trial (rated A). 2

#### Findings per Intake Level

No conclusions are possible about a dose effect from this single study, especially since the women were allowed to take additional concurrent calcium and vitamin D supplements. However, no interaction was found with total reported calcium intake.

#### Findings by Age and Sex

The study investigated postmenopausal women 50 to 79 years old. No interaction of effects with decade of age was found.

#### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  No data available
- 51–70 y
  One large trial that included women mostly within this life stage (WHI) found no significant effect of combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) on cardiovascular outcomes after 7 years.
- ≥71 y
  Inadequate available data.
- Postmenopause
  All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women
  Not reviewed

### Combined Vitamin D and Calcium and Body Weight

The current report did not consider the topic of body weight. The original report searched for systematic reviews and primary studies that evaluated associations between combined vitamin D and calcium and incidence of overweight or obesity; no such studies were found. For the outcome weight change (in kilograms or body mass index units), that report included only randomized controlled trials. The EPC and the TEP agreed that the limited resources would not be expended on reviewing observational studies for the surrogate outcome body weight (where overweight or obesity are considered to be the clinical outcomes). We included only studies of adults. Studies of weight gain in children are included in the “Growth” section.

#### Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and body weight in adults. One RCT each tested the effect of combined vitamin D and calcium in the setting of either an isocaloric diet or an energy restricted diet. Both used vitamin D_2_ 400 IU/d and calcium carbonate (one 1000 mg/d, one 1200 mg/d) and were restricted to women. In the WHI trial of postmenopausal women on an isocaloric diet after 7 years, there was a statistically significant 0.1 kg smaller weight gain in those assigned to the supplement. The effect was statistically similar across age groups. In a Quebec study of 63 overweight premenopausal women, the apparent effect of supplementation in the setting of an energy restricted diet was greater than the WHI trial (net change −1.0 kg), but this was not a significant difference between the supplement and placebo groups.

#### Detailed Presentation

(Tables 48 & 49)

Table 48 Combined vitamin D and calcium and weight: Characteristics of RCTs (formerly Table 87) (no new studies in the current report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Caan 2007^251^ WHI US (various) [17502530] | - Health status | All, postmenopause | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group | Vit D & Ca carbonate vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Factorial design with HT vs. Placebo
Caan 2007^251^ WHI US (various) [17502530] | - Mean age (range), y | 62 (50-79) | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group | Vit D & Ca carbonate vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Factorial design with HT vs. Placebo
Caan 2007^251^ WHI US (various) [17502530] | - Male (%) | 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group | Vit D & Ca carbonate vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Factorial design with HT vs. Placebo
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Health status | Overweight, healthy, pre-menopause | Ca 704 mg/d | Vit D + Ca carbonate vs. Placebo | nd | Energy restriction
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Mean age (range/SD), y | 43 (5.5) | Ca 704 mg/d | Vit D + Ca carbonate vs. Placebo | nd | Energy restriction
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Male (%) | 0 | Ca 704 mg/d | Vit D + Ca carbonate vs. Placebo | nd | Energy restriction

Table 49 Combined vitamin D and calcium and weight: Results of RCTs (formerly Table 88) [no new studies in the current report]

Author Year Study Name [PMID] | Age Range, Sex (Subgroup) | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Isocaloric Diet
Caan 2007^251^ WHI [17502530] | 50–79 y, Women | Weight | 2° | 7 y | Vit D_2_ 400 IU + Ca carbonate 1000 mg | 18,129 | kg | 76.0 | nd | nd | -0.13 | -0.21, -0.05 | .001^A^ | B
Caan 2007^251^ WHI [17502530] | 50–79 y, Women | Weight | 2° | 7 y | Placebo | 18,055 | | 75.9 | nd | nd | | | | B
Caan 2007^251^ WHI [17502530] | (50-54 y) | | | | Vit D_3_ + Ca | 2592 | kg | nd | nd | | -0.24 | -0.45, -0.03 | <0.05^B^ | B
Caan 2007^251^ WHI [17502530] | (50-54 y) | | | | Placebo | 2561 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (55-59 y) | | | | Vit D_3_ + Ca | 4134 | kg | nd | nd | | -0.08 | -0.24, +0.09 | NS | B
Caan 2007^251^ WHI [17502530] | (55-59 y) | | | | Placebo | 4135 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (60-69 y) | | | | Vit D_3_ + Ca | 8276 | kg | nd | nd | | -0.15 | -0.27, -0.03 | <0.05 | B
Caan 2007^251^ WHI [17502530] | (60-69 y) | | | | Placebo | 8243 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (70-79 y) | | | | Vit D_3_ + Ca | 3174 | kg | nd | nd | | -0.10 | -0.27, +0.09 | NS | B
Caan 2007^251^ WHI [17502530] | (70-79 y) | | | | Placebo | 2561 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (White) | | | | Vit D_3_ + Ca | 15,047 | kg | nd | nd | | -0.13 | -0.22, -0.04 | <0.05^C^ | B
Caan 2007^251^ WHI [17502530] | (White) | | | | Placebo | 15,106 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (Black) | | | | Vit D_3_ + Ca | 1682 | kg | nd | nd | | -0.32 | -0.59, -0.06 | <0.05 | B
Caan 2007^251^ WHI [17502530] | (Black) | | | | Placebo | 1635 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (Hispanic) | | | | Vit D_3_ + Ca | 789 | kg | nd | nd | | -0.08 | -0.48, +0.32 | NS | B
Caan 2007^251^ WHI [17502530] | (Hispanic) | | | | Placebo | 718 | | nd | nd | | | | | B
Caan 2007^251^ WHI [17502530] | (Asian / Pacific Islander) | | | | Vit D_3_ + Ca | 369 | kg | nd | nd | | +0.19 | -0.37, +0.75 | NS | B
Caan 2007^251^ WHI [17502530] | (Asian / Pacific Islander) | | | | Placebo | 353 | | nd | nd | | | | | B
Energy Restricted Diet
Major 2007^252^ Quebec City, Canada [17209177] | 43 (SD) | Weight | 2° | 15 wk | Vit D_2_ 400 IU + Ca carbonate 1200 mg | 30 | kg | 81.5 | -4.0 | +-9.0 | -1.0 | -2.31. +0.31 | 0.19 | C
Major 2007^252^ Quebec City, Canada [17209177] | 43 (SD) | Weight | 2° | 15 wk | Placebo | 33 | | 83.6 | -3.0 | +-11.7 | | | | C

Note: Outcomes cells are shaded for the Control rows

A In addition, subgroup analyses by baseline BMI and baseline dietary calcium intake are reported.

B No statistically significant interaction with age.

C No statistically significant interaction with ethnicity.

##### Isocaloric Diet

The WHI trial was analyzed for the effect of daily combined vitamin D_2_ 400 IU and calcium carbonate 1000 mg on weight.251 The trial included about 36,000 postmenopausal women aged 50 to 79 years. The methodological quality of the study was B. At 7 year follow up, the net change in body weight (supplemented minus control) was -0.13 kg (95% CI -0.21, -0.05; less weight gained in supplement group). This was of questionable clinical significance, but was statistically significant. The investigators performed numerous subgroup analyses including those based on age. There were no substantive or statistically significant differences among the evaluated age subgroups.

##### Energy Restricted Diet

A trial performed in Quebec City analyzed 63 premenopausal overweight or obese women (mean age 43) comparing daily vitamin D_2_ 400 IU and calcium carbonate 1200 mg versus placebo.252 Women in both study groups were placed on a weight-loss intervention which consisted of a 700 Kcal/day decrease in energy intake for 15 weeks; the women met biweekly with a nutritionist. The trial was rated methodological quality C due to a high dropout rate (25 percent) and poor description of the methodology. Women in both study groups on average lost weight, with those in the supplement group losing 1.0 kg more (4 vs. 3 kg). However, this effect was not statistically significant (P=0.19).

###### Findings per Vitamin D and Calcium Dose

No conclusion could be reached about a possible effect of vitamin D and calcium dose.

###### Findings per Age and Sex

The trials included only women. The effect of supplementation on postmenopausal women not on an energy restricted diet was of questionable clinical significance after 7 years. The effect of supplementation for 15 weeks on overweight and obese premenopausal women (in an approximate age range of 32 to 54 years) on an energy restricted diet was relatively large (-4 vs. -3 kg), but this difference between the supplemented and control groups was not statistically significant.

#### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  A single trial of women on an energy restricted diet found a nonsignificant difference in weight loss between that those assigned to vitamin D 300 IU and calcium 1200 mg supplementation for 15 weeks.
- 51–70 y
  The WHI trial found no clinically significant effect on weight of vitamin D 300 IU and calcium 1000 mg after 7 years.
- ≥71 y
  The subgroup of women in the WHI trial in this life stage had a similar net weight change as all the study participants as a whole, but the effect was not statistically significant.
- Postmenopause
  All the women in the WHI trial were postmenopausal.
- Pregnant & lactating women
  Not reviewed

### Combined Vitamin D and Calcium and Cancer

This section explores cancer from all causes and total cancer mortality.

#### Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and total cancer incidence or mortality. Two RCTs reported different effects of combined vitamin D_3_ and calcium supplementation on the risk of total cancer. The WHI showed no effects,131 while the trial conducted in Nebraska (latitude 41°N) reported significant reduction of risk of total cancer.102 However, both vitamin D doses and baseline vitamin D status were substantially different between these two RCTs. Therefore, the effects from these two RCTs were not comparable.

#### Detailed Presentation

(Tables 50 & 51)

Table 50 Combined vitamin D and calcium and total cancer incidence: Characteristics of RCTs (formerly Table 89) (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Health status | Postmenopausal women | Ca intake (mg/d): <800, 34%; 800–200, 26%; ≥1200, 40% Median 25(OH)D: 42 nmol/L | Vit D_3_ 400 IU/d + Ca 1000 mg/d vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Mean age (range/SD), y | nd (50–79) | Ca intake (mg/d): <800, 34%; 800–200, 26%; ≥1200, 40% Median 25(OH)D: 42 nmol/L | Vit D_3_ 400 IU/d + Ca 1000 mg/d vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | - Health status | Mentally and physically fit; postmenopause | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
Lappe 2007^102^ Nebraska, US (41º N) [17556697] | - Mean age (range/SD), y | 67 (7.3) | 25(OH)D: 71.8 nmol/L | Vit D_3_ 1000 IU/d + Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. Ca (citrate 1400 mg/d or carbonate 1500 mg/d) vs. placebo | nd
NEW Studies
Prentice 2013^2^ WHI US (various) | - Health status | Postmenopausal women | nd | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate Vs. placebo | nd
Prentice 2013^2^ WHI US (various) | - Mean age (range/SD), y | 50–54: 14.2%; 55–59: 22.8%; 60–69: 45.5%; 70–79: 17.5%; (50–79) | nd | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate Vs. placebo | nd
Brunner 2011^253^ WHI nd | - Health status | nd | nd | 1,000 mg elemental calcium + 400 IU of vitamin D3 Vs. placebo | nd
Brunner 2011^253^ WHI nd | - Mean age (range/SD), y | (50–79) | nd | 1,000 mg elemental calcium + 400 IU of vitamin D3 Vs. placebo | nd

Table 51 Combined vitamin D and calcium and total cancer incidence: Results of RCTs (formerly Table 90) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Followup, year | Interventions, Daily Dose | n Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Incident cancer (all causes) | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 1634 | 18176 | Adjusted HR (Vit D+Ca)/placebo | 0.98 | 0.91, 1.05 | 0.53 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Incident cancer (all causes) | 2° | 7 | Placebo | 1655 | 18106 | | | | | B
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Total cancer mortality | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 344 | 18176 | Adjusted HR (Vit D+Ca)/placebo | 0.89 | 0.77, 1.03 | 0.12 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Total cancer mortality | 2° | 7 | Placebo | 382 | 18106 | | | | | B
Lappe 2007^102^ [17556697] | Postmenopausal women | Incident cancer (all causes) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 13 | 446 | RR (Vit D+Ca)/placebo | 0.4 | 0.20, -0.82 | 0.01 | B
Lappe 2007^102^ [17556697] | Postmenopausal women | Incident cancer (all causes) | 2° | 4 | Placebo | 20 | 288 | | | | | B
Lappe 2007^102^ [17556697] | Postmenopausal women | Incident cancer (restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Vit D_3_ 1000 IU + Ca (citrate 1400 mg or carbonate 1500 mg) | 8 | 403 | RR (Vit D+Ca)/placebo | 0.23 | 0.09, -0.60 | <0.005 | B
Lappe 2007^102^ [17556697] | Postmenopausal women | Incident cancer (restrict to subjects who were free of cancer at 1 y intervention) | 2° | 4 | Placebo | 20 | 288 | | | | | B
NEW Studies
Prentice 2013^2^ WHI US (various) | | Secondary - Total invasive cancer | 1° | 7.2 yrs | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate | 553 | 7718 | adjusted HR | 0.88 | 0.78, 0.98 | NR | A
Prentice 2013^2^ WHI US (various) | | Secondary - Total invasive cancer | 1° | 7.2 yrs | placebo | 617 | 7584 | adjusted HR | 1.00 | Reference | | A
Brunner 2011^253^ WHI nd | Postmenopausal women | Total cancer | 1° | 7 yrs | 1,000 mg elemental calcium + 400 IU of vitamin D3 | 1306 | 18176 | adjusted HR | 0.98 | 0.90, 1.05 | 0.78 | A
Brunner 2011^253^ WHI nd | Postmenopausal women | Total cancer | 1° | 7 yrs | placebo | 1333 | 18106 | adjusted HR | 1.00 | Reference | | A

Note: Outcomes cells are shaded for the Control rows.

The 7-year WHI trial that enrolled 36,282 postmenopausal women across the United States compared a daily supplement of vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo and evaluated incidence of total cancer and total cancer mortality as part of multiple secondary analyses.131 The median serum 25(OH)D level of the study population was 42 nmol/L. The trial did not find significant effect of combined vitamin D_3_ and calcium supplementation on either the risk of total cancer (adjusted HR: 0.98, 95% CI 0.91, 1.05) or total cancer mortality (adjusted HR: 0.89, 95% CI 0.77, 1.03). The methodological quality of this study was rated B.

A 4-year population-based RCT102 sampled from a 9-county, largely rural area in eastern Nebraska (latitude 41°N), aimed to determine the efficacy of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d), or calcium alone (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d), compared to placebo in reducing the incidence of fracture. Incidence of cancer was a secondary outcome in this trial. A total of 734 postmenopausal women, aged more than 55 years old, were analyzed for the effect of vitamin D_3_ (1000 IU/d) plus calcium (either calcium citrate 1400 mg/d or calcium carbonate 1500 mg/d). The mean 25(OH)D concentration at baseline was 72 nmol/L. Compared to the placebo group, the relative risk of developing cancer at the end of study was 0.40 (95% CI 0.20, 0.82; P=0.013) for the vitamin D_3_ plus calcium group. On the hypothesis that cancers diagnosed early in the study would have been present, although unrecognized at entry, the analyses were restricted to women who were free of cancer at 1 year intervention. The relative risk of developing cancer at the end of study for the vitamin D_3_ plus calcium group changed to 0.23 (95% CI 0.09, 0.60; P= 0.005). The methodological quality of this study was rated B.

#### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  No data
- 3–8 y
  No data
- 9–18 y
  No data
- 19–50 y
  No data
- 51–70 y
  No data
- ≥71 y
  No data
- Postmenopause
  The WHI trial using vitamin D_3_ 400 IU/d plus calcium carbonate 1000 mg/d showed no effects, while the trial in Nebraska using vitamin D_3_ 1000 IU/d plus calcium citrate or carbonate 1500 mg/d showed significant reduction of risk of total cancer.
- Pregnant & lactating women
  No Data

#### Colorectal Cancer

##### Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and colorectal cancer mortality or incidence. One B quality RCT of postmenopausal women reported no significant association between supplemental vitamin D_3_ and calcium and, colorectal cancer mortality or incidence.

##### Detailed Presentation

(Tables 52 & 53)

Table 52 Combined vitamin D with calcium and colorectal cancer: Characteristics of RCTs (formerly Table 91) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Health status | Postmenopausal women | Total Ca intake (mg/d) (Mean for both groups: 1151) Ca + Vit D arm: 1148; - <800: 34%; - 800-<1200: 26%; - ≥1200: 39%; Placebo arm: 1154; - <800: 33%; - 800–<1200: 26%; - ≥1200: 40%; Total Vit D intake (IU/d) (Mean for both groups: 367) Ca + Vit D arm: nd; - <200: 38%; - 200–<400: 19%; - 400–<600: 23%; - 600: 19%; Placebo arm: nd; - <200: 37%; - 200–<400: 19%; - 400–<600: 24%; - 600: 19% | Ca 1000 mg/d + Vit D_3_ 400 IU/d vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | The outcomes were based on self-reported questionnaires. Only colorectal cancers were verified centrally. Colorectal cancer screening was not mandated in the protocol. Lost to follow up:; - Ca + Vit D arm: 0.8%; - Placebo arm: 0.8%; Withdrawn:; - Ca + Vit D arm: 1.9%; - Placebo arm: 1.8%
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Mean age (range), y | nd (50–79) | | Ca 1000 mg/d + Vit D_3_ 400 IU/d vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”
Wactawski-Wende 2006^131^ WHI US (various) [16481636] | - Male (%) | 0 | | Ca 1000 mg/d + Vit D_3_ 400 IU/d vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation”

Table 53 Combined vitamin D with calcium and colorectal cancer: Results of RCTs (formerly Table 92) [no new studies in the current report]

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Colorectal cancer mortality | 2° | 7 | Vit D3 400 IU + Ca carbonate 1000 mg | 34 | 18,176 | HR (Suppl/Placebo) | 0.82 | 0.52, 1.29 | 0.39 | B
Wactawski-Wende 2006^131^ WHI [16481636] | Postmenopausal women | Colorectal cancer mortality | 2° | 7 | Placebo | 41 | 18,106 | | | | | B
Wactawski-Wende 2006^131^ WHI [16481636] | | Colorectal cancer | 2° | | Vit D + Ca | 168 | 18,176 | HR | 1.08 | 0.86, 1.34 | 0.51
Wactawski-Wende 2006^131^ WHI [16481636] | | Colorectal cancer | 2° | | Placebo | 154 | 18,106
Wactawski-Wende 2006^131^ WHI [16481636] | | Colon cancer | 2° | | Vit D + Ca | 128 | 18,176 | HR | 1.00 | 0.78, 1.28 | 0.99
Wactawski-Wende 2006^131^ WHI [16481636] | | Colon cancer | 2° | | Placebo | 126 | 18,106
Wactawski-Wende 2006^131^ WHI [16481636] | | Rectal cancer | 2° | | Vit D + Ca | 44 | 18,176 | HR | 1.46 | 0.92, 2.32 | 0.11
Wactawski-Wende 2006^131^ WHI [16481636] | | Rectal cancer | 2° | | Placebo | 30 | 18,106

Note: Outcomes cells are shaded for the Control rows.

The WHI CaD trial, described in the original report, compared daily supplemental vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo in 36,282 postmenopausal women. Colorectal cancer was evaluated as a secondary endpoint.131 The primary endpoint was the prevention of hip fracture. At 7 years vitamin D_3_ and calcium supplementation had no significant effect on colorectal cancer mortality (P=0.39) or incidence (P=0.51). In a subgroup analysis, risks of colon cancer and rectal cancer were also not significantly different between the supplemented and unsupplemented groups (P=0.99 and P=0.11, respectively). This trial was rated B because it did not restrict the participants from taking personal calcium or vitamin D supplements; they had mean daily total calcium intake of 1151 mg and vitamin D intake of 367 IU at enrollment. A post hoc analysis of the WHI CaD 7-year trial data identified for the current report compared the risk for colorectal cancer among participants who had not been taking personal calcium and vitamin D supplements at baseline with that of participants who had taken supplements; the hazard ratio for colorectal cancer risk among all participants was 1.30 (95% CI 0.88, 1.92), compared with 0.99 (95% CI 0.56, 1.77) for women who had taken no personal supplements.2

##### Findings for Special Populations

The WHI performed 18 subgroup analyses based on baseline participant characteristics including ethnic groups, body mass index, smoking status, and geographic regions according to solar irradiance.131 No significant interactions were found with these baseline characteristics. The same RCT with multifactorial design reported an interaction between estrogen alone or combined estrogen and progestin therapy, and combined vitamin D and calcium supplementation for colorectal cancer risk in a post hoc analysis.254 Among women concurrently assigned to hormone replacement therapies, colorectal cancer incidence was increased in the combined supplemental vitamin D and calcium arm compared to placebo (HR 1.50, 95% CI 0.96, 2.33), whereas among those concurrently assigned to placebo in the estrogen trials, colorectal cancer risk was reduced in the vitamin D plus calcium arm compared to placebo (HR 0.71, 95% CI 0.46, 1.09) (P for interaction = 0.02).

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
  3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  No data
- 51–70 y
  One trial that included women mostly within this life stage (WHI) found no significant association between combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) and colorectal cancer mortality or incidence.
- 71+
  The WHI included some people within this life stage, but no study adequately evaluated this life stage.
- Postmenopause
  The WHI exclusively focused on postmenopausal women. The study found no association between vitamin D and calcium intake and colorectal cancer mortality or incidence.
- Pregnant & lactating women
  Not reviewed

#### Colorectal Adenoma

##### Synopsis

No qualified systematic reviews evaluated the association between combined vitamin D and calcium, body stores, or serum concentrations, and incidence of intestinal adenoma. One B quality RCT of postmenopausal women found no significant effect of combined vitamin D_3_ and calcium supplements on the incidence of colorectal adenoma. Another B quality post hoc subgroup analysis of a secondary prevention trial of adenomatous adenoma reported that calcium supplemented patients with higher baseline 25(OH)D concentrations had significantly lower risk of relapse compared to placebo (interaction P = 0.01 between subgroups). In contrast, no significant difference in relapse rates was found in calcium supplemented patients with lower baseline 25(OH)D concentrations compared to placebo.

##### Detailed Presentation

(Tables 52 & 53)

The WHI compared a daily supplement of vitamin D_3_ (400 IU) and elemental calcium (1000 mg) with placebo and evaluated incidence of self-reported colorectal adenoma as part of multiple secondary analyses.131 At 7 years, the incidence of adenoma was not significantly different between the supplement and placebo groups (p=0.71). All the adenoma cases were based on self-reported data, not verified by medical record review or histopathology report.

A post hoc subgroup analysis of the CPP trial of secondary adenoma prevention on the basis of calcium supplementation (1200 mg of elemental calcium) evaluated the risk of colorectal adenoma stratified by baseline 25(OH)D concentrations.255 The primary endpoint of the original trial was the risk of recurrent adenoma. After 4 years, in the subgroup with 25(OH)D concentrations greater than 72.6 nmol/L at baseline, subjects who received supplemental calcium had a significantly lower incidence of recurrent adenoma compared to placebo (HR=0.71 [95% CI 0.57,0.89] versus HR=1.05 [95% CI 0.85, 1.29]; interaction P=0.01). In the subgroup with 25(OH)D concentrations lower than 72.6 nmol/L, the risk of recurrence was not significantly different between supplemental calcium and placebo. No subgroup data were available regarding sex, separate life stages, or other special populations (e.g., obese, smokers, ethnic groups, or users of contraceptives).

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  The CPP included some people within this life stage, but no study adequately evaluated this life stage.
- 51–70 y
  The analysis of the CPP with a mean age of 61 years included participants mostly within this life stage. The study found a significant association between supplemental calcium and reduced risk of colorectal adenoma in a subgroup with 25(OH)D concentrations higher than 72.6 nmol/L.
- 71+
  The CPP included some people within this life stage, but no study adequately evaluated this life stage.
- Postmenopause
  The WHI found no association between combined vitamin D_3_ and calcium supplements and the incidence of colorectal adenoma.
- Pregnant & lactating women
  Not reviewed

#### Breast Cancer

##### Synopsis

No qualified systematic reviews evaluated the association between vitamin D and calcium intake, body stores, or serum concentrations, and breast cancer. Breast cancer incidence and breast cancer related mortality after 7 years were evaluated in the WHI CaD trial versus placebo in 50 to 79 year old women without a prior history of breast cancer, identified for the original report.256 No statistically significant effect was found with combined vitamin D and calcium supplementation on incident breast cancer outcome. No significant associations were found for breast cancer related mortality.

##### Detailed Presentation

(Tables 54 & 55)

Table 54 Combined vitamin D and calcium and breast cancer outcomes: Characteristics of RCTs (formerly Table 93) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Chlebowski 2008^256^ WHI US (various) [19001601] | - Health status | No breast cancer | Baseline Ca supplementation: Vit D & Ca arm <800: 34.3% 800–<1200: 26.5% ≥1200: 39.3% Placebo arm <800: 33.8% 800–<1200: 26.2% ≥1200: 40.0% Baseline Vit D supplementation: Vit D & Ca arm Yes: 47.1% No: 52.9% Placebo arm Yes 47. 6% No 52.4% | Combined Vit D & Ca supplement vs. Placebo | See page 242 | Intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.
Chlebowski 2008^256^ WHI US (various) [19001601] | - Mean age (range), y | 50-79 | | Combined Vit D & Ca supplement vs. Placebo | See page 242 | Intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.
Chlebowski 2008^256^ WHI US (various) [19001601] | - Male (%) | 0 | | Combined Vit D & Ca supplement vs. Placebo | See page 242 | Intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.

Table 55 Combined vitamin D and calcium and breast cancer outcomes: Results of RCTs (formerly Table 94) [no new studies in the current report]

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Breast cancer incidence | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 668 | 18176 | HR (Suppl/Placebo) | 0.96 | 0.86, 1.07 | NS | B
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Breast cancer incidence | 2° | 7 | Placebo | 693 | 18106 | | | | | B
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Death from breast cancer | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 23 | 18176 | HR | 0.99 | 0.55, 1.76 | NS | B
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Death from breast cancer | 2° | 7 | Placebo | 23 | 18106 | | | | | B
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup >67.6 baseline 25(OH)D | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 86 | 195 | Adj OR | 0.89 | 0.58, 1.36 | NS
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup >67.6 baseline 25(OH)D | 2° | 7 | Placebo | 76 | 185
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 55.4–<67.6 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 95 | 171 | Adj OR | 1.25 | 0.83, 1.90 | NS
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 55.4–<67.6 baseline 25(OH)D | 2° | 7 | Placebo | 86 | 171
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 43.9– <55.4 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 102 | 176 | Adj OR | 1.07 | 0.70, 1.62 | NS
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 43.9– <55.4 baseline 25(OH)D | 2° | 7 | Placebo | 92 | 195
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 32.4–<43.9 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 71 | 185 | Adj OR | 0.69 | 0.45, 1.06 | NS
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup 32.4–<43.9 baseline 25(OH)D | 2° | 7 | Placebo | 102 | 171
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup <32.4 baseline 25(OH)D | 2° | 7 | Vit D_3_ + Ca | 94 | 171 | Adj OR | 0.91 | 0.60, 1.39 | NS
Chlebowski 2008^256^ WHI [19001601] | 50–79 y, Women | Invasive breast cancer–subgroup <32.4 baseline 25(OH)D | 2° | 7 | Placebo | 91 | 176

Note: Outcomes cells are shaded for the Control rows.

In the WHI trial, the evaluated breast cancer incidence and breast cancer related mortality outcomes were secondary outcomes.256 There were no significant effects of combined vitamin D and calcium supplementation on both outcomes. The authors concluded that invasive breast cancer incidence was similar in the two groups of healthy postmenopausal women: calcium and vitamin D supplementation and placebo groups. The relationship of 25(OH)D serum concentrations and the risk of breast cancer was examined in a nested case-control design. The study found no relationship between total vitamin D intake and 25(OH)D serum concentrations with the risk of breast cancer. A post hoc analysis of the WHI CaD 7-year trial data identified for the current report compared the risk for breast cancer among participants who had not been taking personal calcium and vitamin D supplements at baseline with that of participants who had 0.89 (95% CI 0.72, 1.11), compared with 0.73 (95% CI 0.52, 1.02) for women who had taken no personal supplements, suggesting a trend toward decreased risk for breast cancer among those who did not use supplements at baseline.2

###### Findings per Intake Level

No conclusions are possible regarding a dose effect from this single study, especially since the women in the intervention and placebo groups were allowed to take additional concurrent calcium and vitamin D supplements.

###### Findings by Age and Sex

The study investigated postmenopausal women 50 to 79 years old.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  No data available
- 51–70 y
  The WHI trial that included women mostly within this life stage found no significant effect of combined vitamin D_3_ (400 IU) and calcium carbonate (1000 mg) on incident breast cancer and mortality from breast cancer after 7 years.
- ≥71 y
  Inadequate available data.
- Postmenopause
  All women in the WHI trial were postmenopausal.
- Pregnant & lactating women
  Not reviewed

### Combined Vitamin D and Calcium and Pregnancy-Related Outcomes

#### Preeclampsia

##### Synopsis

Based on data from a single RCT identified for the original report, there is no significant effect of combined vitamin D and calcium supplementation on the prevention of preeclampsia.

##### Detailed Presentation

(Tables 56 & 57)

Table 56 Combined vitamin D and calcium and preeclampsia: Characteristics of RCTs (formerly Table 95) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Marya 1987^257^ India (29°N) [3623260] | - Health status | Any | Ca: 500 mg/d in in diet; Vit D: ∼40 IU/d (unclear how it was quantified) | Combined Vit D (1200 IU/d) & Ca (375 mg/d) supplement vs. no supplement | nd
Marya 1987^257^ India (29°N) [3623260] | - Age range, y | 20–35 | Ca: 500 mg/d in in diet; Vit D: ∼40 IU/d (unclear how it was quantified) | Combined Vit D (1200 IU/d) & Ca (375 mg/d) supplement vs. no supplement | nd

Table 57 Combined vitamin D and calcium and preeclampsia: Results of RCTs (formerly Table 96) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Marya 1987^257^ India (29°N) [3623260] | Pregnancy | Toxemia (preeclampsia) | 1° | ND | Vit D (1200 IU) & calcium (375 mg) | 12 | 200 | RR (combined Vit D & Ca vs. nothing) | 0.67 | 0.33, 1.35 | 0.26 | C
Marya 1987^257^ India (29°N) [3623260] | Pregnancy | Toxemia (preeclampsia) | 1° | ND | No supplement | 18 | 200 | RR (combined Vit D & Ca vs. nothing) | | | 0.26 | C

Note: Outcomes cells are shaded for the Control rows.

One RCT from India used a combination of vitamin D (1200 IU/d) and calcium (375 mg/d) for the prevention of preeclampsia.257 Table 56 describes the characteristics of the trial. The trial found no significant difference between the compared arms (Table 57).

##### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  Not applicable
- 3–8 y
  Not applicable
- 9–18 y
  Not applicable
- 19–50 y
  [see pregnant and lactating women]
- 51–70 y
  Not applicable
- 71+
  Not applicable
- Postmenopause
  Not applicable
- Pregnant & lactating women
  Based on data from a single RCT, there is no significant effect of combined vitamin D (1200 IU/d) and calcium (375 mg/d) supplementation on the prevention of preeclampsia.

#### Other Pregnancy-Related Outcomes

##### Synopsis

We did not identify any eligible studies on the relationship of vitamin D with calcium and high blood pressure, preterm birth, or small for gestational age infant.

### Combined Vitamin D and Calcium and Clinical Outcomes of Bone Health

#### Rickets, Fractures, Falls, or Performance Measures

For the current report, we identified no new studies on the effect of vitamin D and calcium supplementation on rickets that met the inclusion criteria; we identified two RCTs that assessed the effect of vitamin D and calcium supplementation on fracture risk (described in Table 59 and the accompanying text), one RCT that assessed effects on muscle strength (Table 60), and one that assessed effects on risk for falling (Table 60) (studies that assessed the effects of supplementation with vitamin D and calcium on bone mineral density or bone mineral content are described in Table 66 and the accompanying text).

Table 60 Combined vitamin D and calcium and bone health: Results of RCTs published after the Ottawa EPC report (performance measures) (formerly Table 99) (updated from original report)

Author Year Study Name [PMID] | Life Stage | Outcome | 1/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change SD | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Brunner 2008^258^ [18755319] | Postmenopause | Grip strength | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1185 | kg | 22.81 | -2.49 | 5.81 | 0.15 | 0.24 | 0.52 | C
Brunner 2008^258^ [18755319] | Postmenopause | Grip strength | 2° | 60 | Placebo | 1162 | | 22.96 | -2.64 | 5.69 | | | | C
Brunner 2008^258^ [18755319] | Postmenopause | Chair stands | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1065 | counts | 6.52 | -0.38 | 1.81 | 0.04 | 0.08 | 0.603
Brunner 2008^258^ [18755319] | Postmenopause | Chair stands | 2° | 60 | Placebo | 1053 | | 6.63 | -0.43 | 1.81
Brunner 2008^258^ [18755319] | Postmenopause | Walking time | 2° | 60 | Vit D 400 IU + Ca carbonate 1000 mg | 1160 | seconds | | 0.26 | 6.28 | -0.54 | 0.26 | 0.03
Brunner 2008^258^ [18755319] | Postmenopause | Walking time | 2° | 60 | Placebo | 1141 | | | 0.81 | 6.43
NEW Studies
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Step test | 1° | 18 mos | Ig & 800 IU daily | 43 | unit number | 9.90 | final=11.4 | SD=3.00 | -6 | -2.0, 0.75 | 0.38 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Step test | 1° | 18 mos | Control | 42 | unit number | 10.30 | final=12.0 | SD=3.30 | reference | | | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Gait speed | 1° | 18 mos | Ig & 800 IU daily | 43 | m/s | 2.84 | final=2.79 | SD=1.17 | +0.13 | -0,36, 0.62 | 0.60 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Gait speed | 1° | 18 mos | Control | 42 | m/s | 3.08 | final=2.66 | SD=1.12 | reference | | | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes open, on floor | 1° | 18 mos | Ig & 800 IU daily | 43 | mm2 | 294.0 | final=326 | SD=344 | +147 | 32.4, 261.6 | 0.01 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes open, on floor | 1° | 18 mos | Control | 42 | mm2 | 320.0 | final=179 | SD=147 | reference | | | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes closed, on floor | 1° | 18 mos | Ig & 800 IU daily | 43 | mm2 | 364.0 | final=241 | SD=192 | -79 | -207, 49 | 0.22 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes closed, on floor | 1° | 18 mos | Control | 42 | mm2 | 285.0 | final=320 | SD=373 | reference | | | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes open, on foam | 1° | 18 mos | Ig & 800 IU daily | 43 | mm2 | 737.0 | final=596 | SD=733 | +248 | 9, 487 | 0.04 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes open, on foam | 1° | 18 mos | Control | 42 | mm2 | 597.0 | final=348 | SD=266 | reference | | | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes closed, on foam | 1° | 18 mos | Ig & 800 IU daily | 43 | mm2 | 1317.00 | final=1045 | SD=787 | -209 | -721, 303 | 0.42 | A
Kukuljan 2009^261^ Victoria, Australia | 51–70 yrs | Sway, eyes closed, on foam | 1° | 18 mos | Control | 42 | mm2 | 1437.00 | final=1254 | SD=1489 | reference | | | A

Note: Outcomes cells are shaded for the Control rows.

Table 66 Combined vitamin D and calcium and bone mineral density/content: Results of RCTs published after the Ottawa EPC report (formerly Table 105) [no new studies in the current report]

Author Year Study Name [PMID] | Life Stage | Outcome | 1°/2° | Mean Followup, mo | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
Cheng 2005^273^ [16280447] | 10–12 y girls | BMC | 1° | 24 | Vit D 200 IU + Ca carbonate 1000 mg | 46 | kg | 1.3 | 34.70% | 34.3%, 35.1% | -0.3% | -0.8, 0.2^A^ | NS | C
Cheng 2005^273^ [16280447] | 10–12 y girls | BMC | 1° | 24 | | | | | | | | | | C
Cheng 2005^273^ [16280447] | 10–12 y girls | BMC | 1° | 24 | Placebo | 39 | | 1.3 | 35.00% | 34.6%, 35.4% | | | | C
Bolton-Smith 2007^274^ [17243866] | Postmenopausal women | Femoral neck BMD | nd | 24 | Vit D_3_ 400 IU + Elemental Ca 100 mg | 50 | mg/cm^2^ | nd | 1.9 | -6.5, 10.3 | 1.2 | -12.6, 15.0^A^ | NS | B
Bolton-Smith 2007^274^ [17243866] | Postmenopausal women | Femoral neck BMD | nd | 24 | | | | | | | | | | B
Bolton-Smith 2007^274^ [17243866] | Postmenopausal women | Femoral neck BMD | nd | 24 | Placebo | 56 | | nd | 0.7 | -10.2, 11.6 | | | | B
Zhu 2008^275^ Australia CIFOS [18089701] | Postmenopausal women | Hip BMD | 1° | 60 | Vit D_2_ 1000 IU + Ca citrate 1200 mg | 39/33^B^ | mg/cm^2^ | 783 | nd | | 2.20% | 1.9, 2.5 | 0.05 | B
Zhu 2008^275^ Australia CIFOS [18089701] | Postmenopausal women | Hip BMD | 1° | 60 | | | | | | | | | | B
Zhu 2008^275^ Australia CIFOS [18089701] | Postmenopausal women | Hip BMD | 1° | 60 | Placebo | 41/36^B^ | | 828 | nd | | | | | B
Moschonis 2006^276^ [17181890] | Postmenopausal women | Total body BMD | 1° | 12 | Vit D_3_ 300 IU + Ca 1200 mg (from low fat dairy products) | 39 | mg/cm^2^ | 1.13 | 1.50% | 0.9%, 2.2% | 2.20% | 1.3, 3.1^A^ | <0.05 | C
Moschonis 2006^276^ [17181890] | Postmenopausal women | Total body BMD | 1° | 12 | | | | | | | | | | C
Moschonis 2006^276^ [17181890] | Postmenopausal women | Total body BMD | 1° | 12 | Control (usual diet) | 36 | | 1.12 | -0.70% | -1.4%, -0.1% | | | | C
NEW Studies
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMC | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g | 3.384 | change=0.061 | sd=0.205 | +0.14 | 0.05, 0.22 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMC | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g | 3.436 | change=0.069 | sd=0.174 | +0.14 | 0.07, 0.22 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMC | 1° | 1 yr | Placebo | 35 | g | 3.316 | change=-0.075 | sd=0.146 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMD | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g/cm^2^ | 0.8 | change=0.012 | sd=0.028 | +0.02 | 0.01, 0.03 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMD | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g/cm^2^ | 0.799 | change=0.013 | sd=0.030 | +0.02 | 0.01, 0.03 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Femoral neck BMD | 1° | 1 yr | Placebo | 35 | g/cm^2^ | 0.768 | change=-0.010 | sd=0.012 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMC | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g | 32.548 | change=0.620 | sd=2.442 | +0.58 | -0.84, 2.00 | 0.42 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMC | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g | 31.782 | change=0.687 | sd=2.761 | +0.65 | -0.82, 2.12 | 0.39 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMC | 1° | 1 yr | Placebo | 35 | g | 32.399 | change=0.042 | sd=3.673 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMD | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g/cm^2^ | 0.898 | change=0.013 | sd=0.036 | +0.02 | -0, 0.04 | 0.12 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMD | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g/cm^2^ | 0.895 | change=0.010 | sd=0.042 | +0.01 | -0.01, 0.03 | 0.22 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Lumbar spine L2-L4 BMD | 1° | 1 yr | Placebo | 35 | g/cm^2^ | 0.891 | change=-0.003 | sd=0.049 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMC | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g | 5.818 | change=0.158 | sd=0.549 | +0.31 | 0.09, 0.53 | 0.01 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMC | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g | 5.877 | change=0.090 | sd=0.419 | +0.24 | 0.06, 0.43 | 0.01 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMC | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMC | 1° | 1 yr | Placebo | 35 | g | 5.885 | change=-0.151 | sd=0.389 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMD | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g/cm^2^ | 0.634 | change=0.002 | sd=0.021 | +0.02 | 0.01, 0.03 | 0.002 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMD | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g/cm^2^ | 0.625 | change=0.001 | sd=0.026 | +0.02 | 0.01, 0.03 | 0.01 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Trochanter BMD | 1° | 1 yr | Placebo | 35 | g/cm^2^ | 0.619 | change=-0.017 | sd=0.029 | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Ward's triangle BMD | 1° | 1 yr | VD (Vit D 10 μg)/day | 40 | g/cm^2^ | 0.654 | change=0.010 | sd=0.035 | +0.03 | 0.01, 0.04 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Ward's triangle BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Ward's triangle BMD | 1° | 1 yr | VD-Ca (Vit D 10 μg + calcium 600 mg)/day | 41 | g/cm^2^ | 0.654 | change=0.015 | sd=0.031 | +0.03 | 0.02, 0.05 | <0.001 | A
Islam 2010^267^ | 9–18, 19–50 yrs | Ward's triangle BMD | 1° | 1 yr | | | | | | | | | | A
Islam 2010^267^ | 9–18, 19–50 yrs | Ward's triangle BMD | 1° | 1 yr | Placebo | 35 | g/cm^2^ | 0.628 | change=-0.018 | sd=0.027 | | | | A
Jackson 2011^268^ | Postmenopause | Intertrochanteric BMD | 1° | year 6 | (400 IU Vit D_3_+1000 mg elemental calcium)/day | 777 | g/cm^2^ | 0.746 | final=0.749 | sd=0.135 | +0.02 | 0.01, 0.04 | <0.001 | A
Jackson 2011^268^ | Postmenopause | Intertrochanteric BMD | 1° | year 6 | | | | | | | | | | A
Jackson 2011^268^ | Postmenopause | Intertrochanteric BMD | 1° | year 6 | placebo | 751 | | 0.725 | final=0.725 | sd=0.137 | | | | A
Jackson 2011^268^ | Postmenopause | | 1° | year 6 | | | | | | | | | | A
Jackson 2011^268^ | Postmenopause | Narrow neck BMD | 1° | year 6 | (400 IU Vit D_3_ + 1000 mg elemental calcium)/day | 777 | | 0.736 | final=0.742 | sd=0.133 | +0.02 | 0.01, 0.03 | 0.003 | A
Jackson 2011^268^ | Postmenopause | Narrow neck BMD | 1° | year 6 | | | | | | | | | | A
Jackson 2011^268^ | Postmenopause | Narrow neck BMD | 1° | year 6 | placebo | 751 | | 0.723 | final=0.722 | sd=0.136 | | | | A
Jackson 2011^268^ | Postmenopause | | 1° | year 6 | | | | | | | | | | A
Jackson 2011^268^ | Postmenopause | Shaft BMD | 1° | year 6 | (400 IU Vit D_3_ + 1000 mg elemental calcium)/day | 777 | | 1.18 | final=1.199 | sd=0.189 | +0.03 | 0.01, 0.05 | <0.001 | A
Jackson 2011^268^ | Postmenopause | Shaft BMD | 1° | year 6 | | | | | | | | | | A
Jackson 2011^268^ | Postmenopause | Shaft BMD | 1° | year 6 | placebo | 751 | | 1.155 | final=1.165 | sd=0.190 | | | | A
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Femoral neck BMD | 1° | 3 yrs | Vit D 800 IU + calcium 1,000 mg | 280 | g/cm^2^ | 0.866 | final=0.848 | sd=0.13 | -0.002 | -0.02, 0.02 | 0.85 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Femoral neck BMD | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Femoral neck BMD | 1° | 3 yrs | control (neither supplementation nor placebo) | 311 | | 0.865 | final=0.850 | sd=0.12 | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Lumbar spine BMD | 1° | 3 yrs | Vit D 800 IU + calcium 1,000 mg | 259 | | 1.039 | final=1.047 | sd=0.17 | 0.013 | -0.04, 0.02 | 0.37 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Lumbar spine BMD | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Lumbar spine BMD | 1° | 3 yrs | control (neither supplementation nor placebo) | 285 | | 1.052 | final=1.060 | sd=0.17 | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Total body BMD | 1° | 3 yrs | Vit D 800 IU+calcium 1,000 mg | 195 | | 1.069 | final=1.078 | sd=0.10 | -0.003 | -0.02, 0.02 | 0.76 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Total body BMD | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Total body BMD | 1° | 3 yrs | control (neither supplementation nor placebo) | 238 | | 1.079 | final=1.081 | sd=0.10 | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Total proximal femur BMD | 1° | 3 yrs | Vit D 800 IU+calcium 1,000 mg | 280 | | 0.948 | final=0.934 | sd=0.14 | -0.005 | -0.03, 0.02 | 0.65 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Total proximal femur BMD | 1° | 3 yrs | control (neither supplementation nor placebo) | 310 | | 0.953 | final=0.939 | sd=0.13 | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Trochanter BMD | 1° | 3 yrs | Vit D 800 IU+calcium 1,000 mg | 280 | | 0.783 | final=0.779 | sd=0.13 | -0.01 | -0.03, 0.01 | 0.31 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Trochanter BMD | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Trochanter BMD | 1° | 3 yrs | control (neither supplementation nor placebo) | 310 | | 0.797 | final=0.790 | sd=0.13 | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Ward's triangle | 1° | 3 yrs | Vit D 800 IU + calcium 1,000 mg | 280 | | 0.67 | final=0.652 | sd=0.14 | -0.001 | -0.02, 0.02 | 0.93 | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Ward's triangle | 1° | 3 yrs | | | | | | | | | | C
Karkkainen 2010^269^ OSTPRE-FPS | 51–70 yrs | Ward's triangle | 1° | 3 yrs | control (neither supplementation nor placebo) | 310 | | 0.672 | final=0.653 | sd=0.13 | | | | C
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 total volumetric BMD | 1° | 18 months | fortified milk (400 ml/day containing 1000 mg calcium + 800 IU Vit D_3_) | 45 | g/cm^3^ | 164 | change=-0.6 | -2.1, 0.8 | -0.6 | -2.7, 1.6 | 0.61 | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 total volumetric BMD | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 total volumetric BMD | 1° | 18 months | controls | 44 | | 171 | change=-0.05 | -1.5, 1.4 | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 trabecular volumetric BMD | 1° | 18 months | fortified milk (400 ml/day containing 1000 mg calcium + 800 IU Vit D_3_) | 45 | | 115 | change=-1.5 | -3.1, 0.9 | -2.3 | -6.4, 1.8 | 0.26 | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 trabecular volumetric BMD | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | L1-L3 trabecular volumetric BMD | 1° | 18 months | controls | 44 | | 120 | change=0.8 | -2.9, 1.2 | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-femur cortical volumetric BMD | 1° | 18 months | fortified milk (400 ml/day containing 1000 mg calcium + 800 IU Vit D_3_) | 45 | | 1104 | change=-1.0 | -1.4, -0.6 | -0.3 | -1.0, 0.4 | 0.41 | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-femur cortical volumetric BMD | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-femur cortical volumetric BMD | 1° | 18 months | controls | 44 | | 1108 | change=-0.7 | -1.3, -0.2 | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-tibia cortical volumetric BMD | 1° | 18 months | fortified milk (400 ml/day containing 1000 mg calcium + 800 IU Vit D_3_) | 45 | | 1105 | change=-1.2 | -1.7, -0.7 | -0.1 | -0.8, 0.6 | 0.78 | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-tibia cortical volumetric BMD | 1° | 18 months | | | | | | | | | | A
Kukuljan 2011^272^ | 51–70, 71+ yrs | mid-tibia cortical volumetric BMD | 1° | 18 months | controls | 44 | | 1113 | change=-1.1 | -1.6, -0.5 | | | | A
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | heel BMD | 1° | 12 months | CaD (800 mg calcium + 10 μg Vit D_3_)/day | 26 | g/cm^2^ | 0.476 | final=0.459 | sd=0.081 | -0.002 | -0.04, 0.04 | 0.92 | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | heel BMD | 1° | 12 months | | | | | | | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | heel BMD | 1° | 12 months | Control | 39 | | 0.472 | final=0.461 | sd=0.083 | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | | 1° | 12 months | | | | | | | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | L2-L4 BMD | 1° | 12 months | CaD (800 mg calcium + 10 μg Vit D_3_)/day | 26 | | 1.121 | final=1.113 | sd=0.160 | +0.01 | -0.07, 0.10 | 0.77 | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | L2-L4 BMD | 1° | 12 months | | | | | | | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | L2-L4 BMD | 1° | 12 months | control | 39 | | 1.134 | final=1.101 | sd=0.167 | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | | 1° | 12 months | | | | | | | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | total body BMD | 1° | 12 months | CaD (800 mg calcium+10 μg Vit D_3_)/day | 26 | | 1.112 | final=1.135 | sd=0.083 | +0.04 | 0, 0.08 | 0.05 | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | total body BMD | 1° | 12 months | | | | | | | | | | B
Moschonis 2011^271^ Postmenopausal Health Study | Postmenopause | total body BMD | 1° | 12 months | control | 39 | | 1.095 | final=1.094 | sd=0.079 | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | pelvis BMD | 1° | 30 months | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months | 35 | g/cm^2^ | 1.096 | final=1.089 | sd=0.087 | +0.02 | -0.02, 0.06 | 0.30 | B
Moschonis 2010^270^ Postmenopausal Health Study | | pelvis BMD | 1° | 30 months | | | | | | | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | pelvis BMD | 1° | 30 months | control (neither counselling nor dietary products) | 31 | | 1.067 | final=1.067 | sd=0.084 | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | | 1° | 30 months | | | | | | | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | total body BMD | 1° | 30 months | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months | 35 | | 1.134 | final=1.135 | sd=0.067 | +0.03 | -0.01, 0.06 | 0.11 | B
Moschonis 2010^270^ Postmenopausal Health Study | | total body BMD | 1° | 30 months | | | | | | | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | total body BMD | 1° | 30 months | control (neither counselling nor dietary products) | 31 | | 1.124 | final=1.106 | sd=0.078 | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | | 1° | 30 months | | | | | | | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | total spine BMD | 1° | 30 months | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months | 35 | | 1.119 | final=1.234 | sd=0.135 | +0.04 | -0.03, 0.11 | 0.23 | B
Moschonis 2010^270^ Postmenopausal Health Study | | total spine BMD | 1° | 30 months | | | | | | | | | | B
Moschonis 2010^270^ Postmenopausal Health Study | | total spine BMD | 1° | 30 months | control (neither counselling nor dietary products) | 31 | | 1.139 | final=1.193 | sd=0.139 | | | | B
Zhu 2008^266^ | 9–18 yrs | midriff BMDsc | 1° | 2 yrs | 560 mg calcium + 5–8 μg Vit D/school day | 112 | mg/cm^1.586^ | 1585 | final=1803 | sd=446 | +43 | -79, 165 | 0.49 | B
Zhu 2008^266^ | 9–18 yrs | midriff BMDsc | 1° | 2 yrs | | | | | | | | | | B
Zhu 2008^266^ | 9–18 yrs | midriff BMDsc | 1° | 2 yrs | control (no supplementary milk and habitual diet) | 123 | mg/cm^1.586^ | 1584 | final=1760 | sd=499 | | | | B
Zhu 2008^266^ | 9–18 yrs | | 1° | 2 yrs | | | | | | | | | | B
Zhu 2008^266^ | 9–18 yrs | pelvis BMDsc | 1° | 2 yrs | 560 mg calcium + 5–8 μg Vit D/school day | 112 | mg/cm^3.082^ | 46 | final=49 | sd=7 | 0 | -1.9, 1.9 | 1 | B
Zhu 2008^266^ | 9–18 yrs | pelvis BMDsc | 1° | 2 yrs | | | | | | | | | | B
Zhu 2008^266^ | 9–18 yrs | pelvis BMDsc | 1° | 2 yrs | control (no supplementary milk and habitual diet) | 123 | mg/cm^3.082^ | 47 | final=49 | sd=8 | | | | B
Zhu 2008^266^ | 9–18 yrs | | 1° | 2 yrs | | | | | | | | | | B
Zhu 2008^266^ | 9–18 yrs | total body BMDsc | 1° | 2 yrs | 560 mg calcium + 5–8 μg Vit D/school day | 112 | mg/cm^2.528^ | 93 | final=95 | sd=10 | +3 | 0.3, 5.7 | 0.03 | B
Zhu 2008^266^ | 9–18 yrs | total body BMDsc | 1° | 2 yrs | | | | | | | | | | B
Zhu 2008^266^ | 9–18 yrs | total body BMDsc | 1° | 2 yrs | control (no supplementary milk and habitual diet) | 123 | mg/cm^2.528^ | 95 | final=92 | sd=11 | | | | B

Note: Outcomes cells are shaded for the Control rows.

A Estimated from reported data.

B Baseline/followup number of subjects analyzed.

For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), the original report relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 34).8 Because the Ottawa's EPC report did not have separate analyses for the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation are presented in this section.

The Ottawa EPC report was updated with literature published between January 2006 and April 2009, selected according to our eligibility criteria. Only RCTs qualified for inclusion.

##### Synopsis

The current report identified two RCTs that found no effect of an intervention with vitamin D and calcium on osteoporotic fracture risk among postmenopausal women, one RCT of vitamin D and calcium that found no effect on muscle strength in middle-age and older men, and one RCT that found no effect on risk for falls among older women.

The Ottawa EPC report concluded that supplementation with vitamin D (most studies used D_3_) plus calcium is effective in reducing fractures in institutionalized populations, but there is inconsistent evidence that supplemental vitamin D reduces falls in postmenopausal women and older men. Our update search did not identify new RCT examining the combined effect of vitamin D plus calcium supplementation on rickets, fractures, or falls in postmenopausal women and older men.

One study published after the Ottawa EPC report and included in the original report analyzed the performance measure outcomes in a small sample of postmenopausal women from WHI trial showed generally no differences in performance measures between vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation or placebo groups after 5 years of follow up.258 One RCT of premenopausal women, aged 17 to 35 years old, showed that 800 IU/d of vitamin D in combination with 2000 mg/d of calcium supplementation can reduce the risk of stress fracture from military training compared to placebo.259

##### Detailed Presentation

(Tables 34, 58, 59, & 60)

Table 58 Combined vitamin D and calcium and bone health: Characteristics of RCTs published after the Ottawa EPC report (formerly Table 97) (updated from original report)

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Lappe 2008^259^ Great Lakes, IL, US (41°N) [18433305] | - Health status | Assumed healthy (Navy recruits) | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Lappe 2008^259^ Great Lakes, IL, US (41°N) [18433305] | - Mean age (range), y | 19 (17–35) | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Lappe 2008^259^ Great Lakes, IL, US (41°N) [18433305] | - Male (%) | 0 | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Brunner 2008^258^ WHI US (various) [18755319] | - Health status | nd (for the sub sample from WHI trial) | nd | Vit D 400 IU/d + Ca 1000 mg/d vs. Placebo | nd (however, adherence was assessed at least annually from the weight of remaining pills along with a structured interview in WHI trial) | A sub sample from WHI trial. Post hoc analyses of a RCT.
Brunner 2008^258^ WHI US (various) [18755319] | - Mean age (range), y | 50–79 | nd | Vit D 400 IU/d + Ca 1000 mg/d vs. Placebo | nd (however, adherence was assessed at least annually from the weight of remaining pills along with a structured interview in WHI trial) | A sub sample from WHI trial. Post hoc analyses of a RCT.
Brunner 2008^258^ WHI US (various) [18755319] | - Male (%) | 0 | nd | Vit D 400 IU/d + Ca 1000 mg/d vs. Placebo | nd (however, adherence was assessed at least annually from the weight of remaining pills along with a structured interview in WHI trial) | A sub sample from WHI trial. Post hoc analyses of a RCT.
NEW Studies
Prentice 2013^2^ WHI US (various) | - Health status | Postmenopausal | nd | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate Vs. placebo | nd
Prentice 2013^2^ WHI US (various) | - Mean age (range), y | 50–54: 14.2%; 55–59: 22.8%; 60–69: 45.5%; 70–79: 17.5%; (50–79) | nd | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate Vs. placebo | nd
Prentice 2013^2^ WHI US (various) | - Male (%) | 0% | nd | 400 IU Vit D3 + 1,000 mg elemental calcium carbonate Vs. placebo | nd
Salovaara 2010^260^ OSTPRE Study nd | - Health status | nd | Serum vitamin D: 49.1±17.7 nmol/L | 400 IU cholecalciferol + 500 mg calcium carbonate Vs. control (no intervention or placebo) | nd
Salovaara 2010^260^ OSTPRE Study nd | - Mean age (SD), y | 67.3 (SD 1.8) | Serum vitamin D: 49.1±17.7 nmol/L | 400 IU cholecalciferol + 500 mg calcium carbonate Vs. control (no intervention or placebo) | nd
Salovaara 2010^260^ OSTPRE Study nd | - Male (%) | 0% | Serum vitamin D: 49.1±17.7 nmol/L | 400 IU cholecalciferol + 500 mg calcium carbonate Vs. control (no intervention or placebo) | nd
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | - Health status | nd | Intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (P = 0.544) | 1g/daily & 800 IU/daily Vs. Placebo | 78% compliance
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | - Mean age (SD), y | 67.4 (SD 1.9) Range: 65–71 | Intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (P = 0.544) | 1g/daily & 800 IU/daily Vs. Placebo | 78% compliance
Karkkainen 2010^262^ OSTPRE-FPS Kuopio, Finland | - Male (%) | 0% | Intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (P = 0.544) | 1g/daily & 800 IU/daily Vs. Placebo | 78% compliance
Kukuljan 2009^261^ Victoria, Australia | - Health status | Healthy | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Kukuljan 2009^261^ Victoria, Australia | - Mean age (SD), y | 59.9 (SD 7.4) Range: 50–79 | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.
Kukuljan 2009^261^ Victoria, Australia | - Male (%) | 0% | Mean dairy servings/wk = 6 (ranged 1–26) | Vit D 800 IU/d + Ca 2000 mg/d vs. Placebo | Monitor pill taking: project staff observed the galley food lines, visited recruits in their quarters, and conducted an exit interview.

The current report identified two RCTs of vitamin D and calcium that assessed osteoporotic fracture risk. One, a re-analysis of data from the WHI CaD trial that attempted to assess the effects of the intervention alone (separate from use of additional personal supplements), found no significant effect of the intervention on overall fracture risk at 6 years (rated B).2 The second RCT, the OSTPRE study, also found no effect of 3 years' supplementation with calcium and vitamin D on risk for total, nonvertebral, distal forearm, upper extremity, or lower extremity fragility fractures among 3,195 postmenopausal women, 65 to 71 years of age (rated B).260

One RCT on middle-age and older Australian men (age 50 to 79) tested the effect of an 18-month intervention of daily vitamin D (800IU) and calcium (1000mg) on measures of muscle function (rated A). No effect was seen on any measure of muscle function, including step test, gait speed or sway. 261

An RCT that tested the effect of a 3-year intervention of daily vitamin D (800IU) and calcium (1000mg) on risk for falls among 812 older Finnish women (mean age 67) found no effect on fall risk (study rated C). 262

In the original report, one RCT of female Navy recruits, aged 17 to 35 years, aimed to determine whether supplementation with vitamin D (800 IU/d) plus calcium (2000 mg/d) can reduce the risk of stress fractures from military training near the Great Lakes (41°N).259 The median dairy intake was <1 serving/day, which provided less than 300 mg of calcium. The combined supplementation significantly reduced the risk of stress fractures by 20 percent compared to placebo. The methodological quality of this study was rated B.

One study analyzed the performance measure outcomes in a sample of 2928 postmenopausal women from the WHI trial who had objective physical function measures.258 The results showed that physical function, measured by grip strength, chair stands, and walking time, had generally declined in postmenopausal women who were assigned to either vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation or placebo group. However, women who had received vitamin D plus calcium supplementation showed less declines in walking time than those who had received placebo. The methodological quality of this study was rated C because only a small proportion of women from the WHI trial were in the analyses and their baseline characteristics were unclear.

###### From the Ottawa EPC Report: Fractures—Postmenopausal Women and Older Men

Fifteen RCTs examined the effect of either vitamin D_2_ or D_3_ alone or in combination with calcium on total, nonvertebral and hip fractures in postmenopausal women or older men. Few trials evaluated vertebral fractures. Most trials used vitamin D_3_. There were no trials identified in premenopausal women.

Meta-analysis results from 13 RCTs of vitamin D_2_ or D_3_ with or without calcium showed a nonsignificant reduction in the risk of total fractures that persisted when only trials of higher quality were combined. Most trials used vitamin D3. When combining seven RCTs of vitamin D3 (400–800 IU) plus calcium, there was a reduction in the risk of total and hip fractures. However, in a subgroup analysis (800 IU vitamin D3), this benefit was only evident in trials of institutionalized elderly subjects. One possible explanation for the discrepancy is that the mean serum 25(OH)D concentration achieved in trials of institutionalized participants was higher than in the trials on community dwellers. The combined estimate from trials with higher end-of-study serum 25(OH)D concentrations (>74 nmol/L) was consistent with a significant reduction in the risk of fractures.

###### In Ottawa EPC Report: Falls—Postmenopausal Women and Older Men

Meta-analysis results from 12 RCTs demonstrated a small reduction in the risk of falls with supplemental vitamin D2 or D3 (oral or injectable) with or without calcium (OR 0.89, 95% CI 0.80, 0.99). The individual treatment effects ranged from OR 0.28 (95% CI 0.12, 0.67) to 1.16 (95% CI 0.70, 1.92). In the two cluster RCTs, one demonstrated a significant reduction in the risk of falls in postmenopausal women taking vitamin D3 plus calcium (RR 0.88, 95% CI 0.79, 0.98), whereas the other trial did not show a significant reduction in the risk of falls in elderly individuals taking vitamin D2 (RR 1.09, 95% CI 0.95, 1.25). Meta-analysis of eight RCTs of oral vitamin D2/D3 supplementation with calcium showed a reduction in the risk of falls, whereas four RCTs of oral vitamin D3 alone did not. Subgroup analyses showed a significant reduction in the risk of falls when only trials of postmenopausal women were combined. Sensitivity analyses showed a significant reduction in the risk of falls when combining (1) RCTs that explicitly defined falls and the method of fall ascertainment and (2) those in which the allocation concealment was unclear. However, combining trials by degree of compliance and loss to follow up did not.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  The Ottawa EPC report concluded that supplementation with vitamin D (most studies used D_3_) plus calcium is effective in reducing the risk of fractures in institutionalized populations, but there is inconsistent evidence that supplemental vitamin D reduces the risk of falls in postmenopausal women and older men. One RCT of female Navy recruit, aged 17 to 35 years old, showed that vitamin D (800 IU/d) in combination of calcium (2000 mg/d) supplementation can reduce the risk of stress fractures from military training compared to placebo.
- 51–70 y
  One RCT identified for the current report found no differences in any measure of muscle strength between men (50 to 70) who received supplemental vitamin D and calcium for 18 months and those who received placebos. No new data were identified for the original report since the Ottawa report
- 71+
  No new data since the Ottawa report
- Postmenopause
  Two studies identified for the current report (one a reanalysis of data from the WHI study) found no differences in fracture risk between women supplemented with vitamin D and calcium and placebo groups (3 to 6 years). One study analyzed the performance measure outcomes in a small sample of postmenopausal women from the WHI trial showed generally no differences in performance measures between vitamin D (400 IU/d) plus calcium (1000 mg/d) supplementation and placebo groups after 5 years of follow up.
- Pregnant & lactating women
  No data

### Combined Vitamin D and Calcium and All-Cause Mortality

#### Synopsis

This synopsis is based on a meta-analysis of RCTs of combined vitamin D and calcium supplementation evaluating mortality. No new studies were identified for this outcome. Numerical data were extracted from previous systematic reviews. Most trials used daily regimens; in these trials, vitamin D doses ranged between 300 and 880 IU per day. Most trials combined vitamin D and calcium supplementation; when used, calcium doses ranged between 500 and 1200 mg per day.

Our meta-analysis of 11 RCTs (44,688 participants) suggests no significant relationship between combined supplementation of vitamin D and calcium all-cause mortality (RR=0.93, 95% CI 0.86, 1.01; random effects model). There is little evidence for between-study heterogeneity in these analyses. Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95% CI 0.86, 1.00), again with little evidence for between-study heterogeneity.

Although the meta-analyses suggest decreased risk for all-cause mortality with combined vitamin D and calcium supplementation, the relationship is not statistically significant in the performed analyses.

#### Detailed Presentation

(Table 37; Figure 11)

Figure 11 Forest plot of trials of combined vitamin D and calcium supplementation and effects on all-cause mortality (formerly Figure 22)

This forest plot displays the trials of combined vitamin D and calcium supplementation and effects on all-cause mortality. The first column shows the 11 studies. The second column shows the n. The third column shows the counts. The fourth column is the graph, which displays the estimate and its 95 percent confidence interval (CI). The fifth column is the confidence interval. The studies plotted in the graph are further described in the text above the figure.

As mentioned in the Methods section, the original report updated and reanalyzed published meta-analyses of mortality outcomes. The authors of that report drew conclusions based on their own analyses and also comment on the concordance of these conclusions with those of the published meta-analyses.

##### Relevant Published Systematic Reviews of RCTs (With Meta-Analyses)

As described in the vitamin D and all-cause mortality sections, the original report identified two potentially eligible systematic reviews,204,205 and selected one as the basis for our reanalysis (Autier 2007).204 Table 37 in the “Vitamin D” section summarizes the findings of the Autier 2007 systematic review.

As detailed below, the original report identified one additional trial of combined vitamin D and calcium supplementation reporting all-cause mortality.263

##### Eligible Studies Published After the Systematic Reviews

The literature searches in Autier 2007 extended up to November 2006. Two additional RCT reports were identified for the original report published after November 2006.^131,263^ One publication131 reported on the same trial as another publication264 in the Autier 2007 meta-analysis, and was therefore excluded from our reanalysis. The other RCT (Bjorkman 2008)263 was included in our meta-analysis.

One three-arm RCT (Bjorkman 2008^263^, n=218) compared no supplementation versus daily supplementation with 400 IU and 1200 IU of vitamin D_3_ and 500 mg of calcium. Mortality was assessed at 6 months. It included people older than 65 years, with chronically impaired mobility and stable general condition. The Bjorkman 2008 RCT was assigned grade “A” for overall reporting quality.

##### Reanalysis

The re-analysis conducted for the original report excluded 5 of 18 trials in the Autier 2007 meta-analysis: One trial was on patients with congestive heart failure,206 one was published only in abstract form,207 and in the last trial the controls also received supplementation with vitamin D, albeit with a smaller dose,208 and two used injections of vitamin D.209,210 Altogether, 11 RCTs were included in the reanalysis of combined vitamin D and calcium supplementation and all-cause mortality (i.e., 10 out of 18 in the Autier 2007 meta-analysis, and a subsequently published one263).

Among the 12 trials, sample sizes ranged from 55 to 36, 282 participants, with 7 studies including more than 500 participants. Followup periods ranged from 6 to 84 months (median 24 months). Vitamin D doses in most trials ranged between 300 and 880 IU per day. One trial used 100,000 IU orally every 4 months. Calcium supplementation doses ranged between 500 to 1200 mg per day.

Overall, a meta-analysis of the 11 RCTs (44,688 participants; Figure 11 [formerly 22]) found no statistically significant relationship between vitamin D and all-cause mortality (RR=0.93, 95% CI 0.86, 1.01). There is little evidence for between-study heterogeneity in these analyses (P=0.58, I^2^=0%). Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95% CI 0.86, 1.00), again with little evidence for between-study heterogeneity (P=0.46, I^2^=0%). There are no RCTs with mean participant age below 50 years. It is unclear whether these findings are directly applicable to other life stages. In addition, in a subgroup analysis among 8 RCTs (n=8109) where the mean participant age was above 70 years, the summary random effects RR=0.98 (95% CI 0.84, 1.15), with little evidence for between study heterogeneity (P=0.33, I^2^=13%).

#### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  No data
- 3–8 y
  No data
- 9–18 y
  No data
- 19–50 y
  No data
- 51–70 y
  Our meta-analysis of 12 RCTs (44,838 participants) suggests no significant relationship between combined supplementation of vitamin D and calcium all-cause mortality (RR=0.94, 95% CI 0.87, 1.01; random effects model). There is little evidence for between-study heterogeneity in these analyses.
- 71+
  The above are likely applicable here. In addition, in a subgroup analysis among 8 RCTs (n=8109) where the mean participant age was above 70 years, the summary random effects RR=0.98 (95% CI 0.84, 1.15), with little evidence for between study heterogeneity.
- Postmenopause
  Among 8 RCTs on 44,281 postmenopausal women, the summary random effects RR was 0.93 (95% CI 0.86, 1.00), again with little evidence for between-study heterogeneity.
- Pregnant & lactating women
  No data

### Combined Vitamin D and Calcium and Hypertension and Blood Pressure

For the current report, we identified no new studies that addressed these outcomes. The original report reviewed systematic reviews and primary studies that evaluated associations between combined vitamin D and calcium intake and incidence of hypertension or change in blood pressure. For the outcome incidence of hypertension, we included RCTs and other longitudinal studies. For the outcome change in blood pressure, we included only RCTs. We included only studies of adults. Studies of pregnancy-related hypertension and blood pressure control are included in the “Pregnancy-Related Outcomes” section.

#### Combined Vitamin D and Calcium and Hypertension

##### Synopsis

No new studies were identified for this outcome. No systematic reviews that met our inclusion criteria evaluated the association between combined vitamin D and calcium intake, body stores, or serum concentrations and incidence of hypertension. The WHI trial reported an analysis of the risk of developing hypertension among the subset of women without hypertension at baseline. Over 7 years, combined vitamin D and calcium supplementation had no effect on the risk of hypertension.

##### Detailed Presentation

(Tables 61 & 62)

Table 61 Combined vitamin D and calcium and incident hypertension: Characteristics of RCTs [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Margolis 2008^265^ WHI US (various) [18824662] | - Health status | No HTN | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d (based on all subjects, including those with hypertension) | Combined Vit D + Ca supplement vs. Placebo | See page 242 | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups (based on all subjects, including those with hypertension)
Margolis 2008^265^ WHI US (various) [18824662] | - Mean age (range), y | 62 (50‐79) | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d (based on all subjects, including those with hypertension) | Combined Vit D + Ca supplement vs. Placebo | See page 242 | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups (based on all subjects, including those with hypertension)
Margolis 2008^265^ WHI US (various) [18824662] | - Male (%) | 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d (based on all subjects, including those with hypertension) | Combined Vit D + Ca supplement vs. Placebo | See page 242 | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups (based on all subjects, including those with hypertension)

Table 62 Combined vitamin D and calcium and incident hypertension: Results of RCTs [no new studies in the current report]

Author Year Study Name [PMID] | Life Stage [Subgroup] | Outcome | 1°/2° | Mean Followup, y | Interventions, Daily Dose | N Event | N Total | Outcome Metric (Comparison) | Result | 95% CI | P Btw | Study Quality
Margolis 2008^265^ WHI [18824662] | 50–79 y, Women | HTN | 2° | 7 | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 3377 | ∼8578 | HR (Suppl/Placebo) | 1.01 | 0.96, 1.06 | 0.69 | B
Margolis 2008^265^ WHI [18824662] | 50–79 y, Women | HTN | 2° | 7 | Placebo | 3315 | ∼8544 | | | | | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D <34.4 nmol/L] | | | | Vit D + Ca | 53 | | | 1.52 | 0.89, 2.59 | NS | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D <34.4 nmol/L] | | | | Placebo | 38 | | | | | | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D 34.4‐47.6 nmol/L] | | | | Vit D + Ca | 39 | | | 1.48 | 0.89, 2.46 | NS | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D 34.4‐47.6 nmol/L] | | | | Placebo | 48 | | | | | | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D 47.7‐64.6 nmol/L] | | | | Vit D + Ca | 45 | | | 1.15 | 0.69, 1.92 | NS | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D 47.7‐64.6 nmol/L] | | | | Placebo | 45 | | | | | | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D ≥64.7 nmol/L] | | | | Vit D + Ca | 48 | | | 0.79 | 0.51, 1.22 | NS | B
Margolis 2008^265^ WHI [18824662] | [25(OH)D ≥64.7 nmol/L] | | | | Placebo | 61 | | | | | | B

Note: Outcomes cells are shaded for the Control rows.

The WHI trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg supplement daily versus placebo had methodological quality B for the blood pressure outcome. The 36,282 women were postmenopausal (age 50–79 y) with a background calcium intake on average of about 1150 mg/day (from diet and supplements).265 The women were allowed to take additional concurrent calcium and vitamin D supplements. The analysis of incident hypertension was reported briefly in a larger analysis of the blood pressure outcome (see Combined Vitamin D and Calcium and Blood Pressure). Among 17,122 initially nonhypertensive women, 39 percent either were prescribed medication for hypertension or developed blood pressure above 140/90 mm Hg. The adjusted HR of developing hypertension over 7 years was 1.01 (95% CI 0.96, 1.06). Among 377 women with available data, there was a statistically significant trend across subgroups based on serum 25(OH)D concentration such that combined vitamin D and calcium supplementation increased the risk of developing hypertension more in those women with progressively lower baseline 25(OH)D (P<0.01 for trend). Other subgroup analyses based on age, race or ethnicity, weight, or baseline total calcium intake did not find any interactions with the effect of the supplement intervention.

###### Findings per Intake Level

This single trial did not analyze different actual intake levels.

###### Findings by Age and Sex

This trial found no difference in (lack of) effect by age among postmenopausal women.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  No data.
- 51–70 y
  One large trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- ≥71 y
  The WHI trial included some women within the life stage, but no study adequately evaluated this life stage.
- Postmenopause
  All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women
  Not reviewed

#### Combined Vitamin D and Calcium and Blood Pressure

##### Synopsis

No new studies were identified that addressed this outcome. No systematic reviews that met our inclusion criteria evaluated the association between vitamin D and calcium intake, body stores, or serum concentrations, and changes in blood pressure. Two RCTs compared combined vitamin D and calcium supplementation with placebo. Both the small trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1200 mg supplement daily and the WHI trial found no significant effect of supplementation on blood pressure after 15 weeks or 6.1 years, respectively. The WHI trial analyzed blood pressure changes in a variety of subgroups, including by age, ethnicity, baseline total calcium intake, and baseline diagnosis of hypertension, but found no significant differences in effect across any subgroup.

##### Detailed Presentation

(Tables 63 & 64)

Table 63 Combined vitamin D and calcium and blood pressure: Characteristics of RCTs (formerly Table 102) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Margolis 2008^265^ WHI US (various) [18824662] | - Health status | Any | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d | Combined Vit D + Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups
Margolis 2008^265^ WHI US (various) [18824662] | - Mean age (range), y | 62 (50‐79) | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d | Combined Vit D + Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups
Margolis 2008^265^ WHI US (various) [18824662] | - Male (%) | 0 | Ca: 1148 (654) mg/d in treatment group; 1154 (658) in placebo group 52% used Ca supplements 40% had intake ≥1200 mg/d | Combined Vit D + Ca supplement vs. Placebo | See discussion of use of personal supplements in the WHI trial in “Colorectal Cancer, Detailed Presentation” | Mean dose of open label supplemental Ca increased by <100 mg/d from 325 mg/d at enrollment; similar in both groups
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Health status | Healthy, Overweight, low Ca intake | Ca: ∼704 mg/d; all <800 mg/d | Combined Vit D + Ca supplement vs. Placebo | nd
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Mean age (SD), y | 43 (5.5) | Ca: ∼704 mg/d; all <800 mg/d | Combined Vit D + Ca supplement vs. Placebo | nd
Major 2007^252^ Quebec City, Canada (47°N) [17209177] | - Male (%) | 0 | Ca: ∼704 mg/d; all <800 mg/d | Combined Vit D + Ca supplement vs. Placebo | nd

Table 64 Combined vitamin D and calcium and blood pressure: Results of RCTs (formerly Table 103) [no new studies in the current report]

Author Year Study Name [PMID] | Age Range, Sex | Outcome | 1°/2° | Mean Followup | Interventions, Daily Dose | No. Analyzed | Unit | Baseline | Change | Change 95% CI | Net Diff | Net Diff 95% CI | P Btw | Study Quality
SYSTOLIC BLOOD PRESSURE
Margolis 2008^265^ WHI [18824662] | 50–79, Women | SBP | 2° | 6.1 y | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 18,176 | mm Hg | 127^A^ | +1.1%^A^ | 0.9, 1.3 | +0.22 | ‐0.05, +0.49 | 0.11 | B
Margolis 2008^265^ WHI [18824662] | 50–79, Women | SBP | 2° | 6.1 y | Placebo | 18,106 | | 128^A^ | +0.7%^A^ | 0.5, 0.9 | | | | B
Major 2007^252^ Quebec City [17209177] | 43 (5.5), Women | SBP | 2° | 15 wk | Vit D_3_ 400 IU + Ca carbonate 1200 mg (energy restriction diet) | 30 | mm Hg | 112.4 | -4.1 | -6.5, -1.7 | -2.5 | ‐6.2, 1.2* | 0.18 | C
Major 2007^252^ Quebec City [17209177] | 43 (5.5), Women | SBP | 2° | 15 wk | Placebo (energy restriction diet) | 33 | | 109.5 | -1.6 | -4.2, 1.0 | | | | C
DIASTOLIC BLOOD PRESSURE
Margolis 2008^265^ WHI [18824662] | 50–79, Women | DBP | 2° | 6.1 y | Vit D_3_ 400 IU + Ca carbonate 1000 mg | 18,176 | mm Hg | 76^A^ | -0.2%^A^ | -0.4, -0.02 | +0.11 | -0.04, +0.27 | 0.14 | B
Margolis 2008^265^ WHI [18824662] | 50–79, Women | DBP | 2° | 6.1 y | Placebo | 18,106 | | 76^A^ | -0.6%^A^ | -0.8, -0.4 | | | | B
Major 2007^252^ Quebec City [17209177] | 43 (5.5), Women | DBP | 2° | 15 wk | Vit D_3_ 400 IU + Ca carbonate 1200 mg (energy restriction diet) | 30 | mm Hg | 74.9 | -3.0 | -4.8, -1.2 | 0 | -2.7, 2.7* | 1.0 | C
Major 2007^252^ Quebec City [17209177] | 43 (5.5), Women | DBP | 2° | 15 wk | Placebo (energy restriction diet) | 33 | | 75.2 | -3.0 | -5.0, -1.0 | | | | C

Note: Outcomes cells are shaded for the Control rows.

A Hsia 2007^249^ [17309935]

The WHI trial of a combined vitamin D_3_ 400 IU and calcium carbonate 1000 mg supplement daily versus placebo had methodological quality B for the blood pressure outcome. The 36,282 women were postmenopausal (age 50–79 y) with a background calcium intake on average of about 1150 mg/day (from diet and supplements).265 On average, the women had normal blood pressure and were allowed to take additional concurrent calcium and vitamin D supplements. At 74 months, the women's mean systolic blood pressure had risen and diastolic blood pressure had fallen in both trial arms (by less than about 2 mm Hg each at 2 years249). The absolute changes were not significantly different in the women assigned to the supplement than placebo (net difference 0.2 mm Hg systolic and 0.1 mm Hg diastolic). In subgroup analyses there was no differences in results by age, ethnicity, baseline total calcium intake, baseline diagnosis of hypertension, or a variety of other factors.

The C quality trial of combined vitamin D and calcium, performed in Quebec City, recruited premenopausal women (mean age 43 y) with low calcium intake (800 mg calcium per day) who did not have severe hypertension (blood pressure over 160/95 mm Hg).252 The mean baseline calcium intake was 704 mg/day. On average, the 63 women had normal blood pressure. They were given either combined vitamin D_3_ 400 IU and calcium carbonate 1200 mg daily or placebo. All women were on an energy restriction diet with a 700 kcal/day deficit. At 15 weeks, systolic and diastolic blood pressures were reduced in both study groups; systolic blood pressure was reduced by 2.5 mm Hg more in women on vitamin D and calcium than placebo, but this difference was not statistically significant. Diastolic blood pressure was reduced by the same amount in both groups. No subgroup analyses were reported. The study was limited by a 25 percent dropout rate due to lack of compliance with the diet and exercise portion of the trial, without performing an intention to treat analysis, an adequate description of the study methods, or a complete statistical analysis.

###### Findings per Intake Level

Both trials used similar doses, vitamin D_3_ 400 IU and calcium carbonate 1000 or 1200 mg daily. The background calcium intake was lower in the study of premenopausal women (800 mg/day) than the WHI trial (1150 mg/day). The WHI trial found no significant difference in (lack of) effect in subgroups with different baseline total calcium intake.

###### Findings by Age and Sex

Both the one small, short term, C quality trial of premenopausal women and the 6 year WHI trial of postmenopausal women found no effect. The WHI trial also found no difference in effect in subgroups of women based on age. No trials of men were found.

##### Findings by Life Stage

- 0–6 mo
  Not reviewed
- 7 mo–2 y
  Not reviewed
- 3–8 y
  Not reviewed
- 9–18 y
  Not reviewed
- 19–50 y
  One small trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- 51–70 y
  One large trial that included women mostly within this life stage found no significant effect of combined vitamin D and calcium supplementation.
- ≥71 y
  The WHI trial included some women within the life stage, but no study adequately evaluated this life stage.
- Postmenopause
  All women in the WHI trial were postmenopausal. See 51–71 y life stage.
- Pregnant & lactating women
  Not reviewed

### Combined Vitamin D and Calcium and Bone Mineral Density or Bone Mineral Content

For the current report, we identified seven studies of the effect of combined calcium and vitamin D supplementation on bone mineral density or content (Table 66). For bone health outcomes (e.g., bone mineral density, fracture, fall or muscle strength), the original report relied on a recent comprehensive systematic review performed by the Ottawa EPC (Table 34).8 Because the Ottawa's EPC report did not have separate analyses on the effect of vitamin D supplementation alone, the results for the effect of vitamin D alone or in combination with calcium supplementation were presented in this section.

The Ottawa EPC report was updated with literature published between January 2006 and April 2009, selected according to our eligibility criteria. For adults, only BMD indices were included. For children, only BMC indices were included. Only RCTs with duration more than 1 year qualified for inclusion.

#### Synopsis

Of the seven RCTs identified for this report on the effect of vitamin D and calcium supplementation on bone density or content, six reported positive effects on BMD. Followup times ranged from 1 to 6 years. Vitamin D supplementation ranged from 200 to 800IU per day, with calcium ranging from 600 to 1200mg per day.

In the original study, one RCT found that, compared to placebo, there was no significant effect of supplementation with vitamin D3 (200 IU/d) plus calcium (1000 mg/d) on BMC changes in healthy girls, between 10 and 12 years.

Overall, findings from the Ottawa EPC report showed that vitamin D_3_ (≤ 800 IU/d) plus calcium (∼500 mg/d) supplementation resulted in small increases in BMD of the spine, total body, femoral neck and total hip in predominantly populations of late menopausal women.8 Two of the three new RCTs showed consistent findings in postmenopausal women, comparing vitamin D_3_ or D_2_ (300 or 1000 IU/d, respectively) plus calcium (1200 mg/d) to placebo.

#### Detailed Presentation

(Tables 34, 65, & 66)

Table 65 Combined vitamin D and calcium and bone mineral density/content: Characteristics of RCTs published after the Ottawa EPC report (formerly Table 104) [no new studies in the current report]

Author Year Study Name Location (Latitude) [PMID] | Population | | Background Calcium Intake & Vitamin D Data | Comparisons | Compliance | Comments
Cheng 2005^273^ Jyvaskyla, Finland (62°24'N) [16280447] | - Health status | Healthy | Diet Vit D: 100 IU/d Ca: 670 mg/d | Vit D_3_ 200 IU/d + Ca carbonate 1000 mg/d vs. placebo | 65% completed intervention with >50% compliance
Cheng 2005^273^ Jyvaskyla, Finland (62°24'N) [16280447] | - Mean age (range), y | 11.2 (10–12) | Diet Vit D: 100 IU/d Ca: 670 mg/d | Vit D_3_ 200 IU/d + Ca carbonate 1000 mg/d vs. placebo | 65% completed intervention with >50% compliance
Cheng 2005^273^ Jyvaskyla, Finland (62°24'N) [16280447] | - Male (%) | 0 | Diet Vit D: 100 IU/d Ca: 670 mg/d | Vit D_3_ 200 IU/d + Ca carbonate 1000 mg/d vs. placebo | 65% completed intervention with >50% compliance
Bolton-Smith 2007^274^ (UK 54ºN) [17243866] | - Health status | Healthy (assumed postmenopausal) | 25(OH)D: 59.4 nmol/L Ca: 1548 mg/d | Vit D_3_ 400 IU/d + Elemental Ca 100 mg/d vs. placebo | Good supplement adherence based on pill count (median, 99; IQE 97.3–99.8%). | Noncompliant women were excluded.
Bolton-Smith 2007^274^ (UK 54ºN) [17243866] | - Mean age (range), y | 68 (≥60) | 25(OH)D: 59.4 nmol/L Ca: 1548 mg/d | Vit D_3_ 400 IU/d + Elemental Ca 100 mg/d vs. placebo | Good supplement adherence based on pill count (median, 99; IQE 97.3–99.8%). | Noncompliant women were excluded.
Bolton-Smith 2007^274^ (UK 54ºN) [17243866] | - Male (%) | 0 | 25(OH)D: 59.4 nmol/L Ca: 1548 mg/d | Vit D_3_ 400 IU/d + Elemental Ca 100 mg/d vs. placebo | Good supplement adherence based on pill count (median, 99; IQE 97.3–99.8%). | Noncompliant women were excluded.
Zhu 2008^275^ CIFOS Western Australia [18089701] | - Health status | nd (assumed postmenopausal) | 25(OH)D: 68.0 nmol/L Ca: 1010 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. placebo | No differences in adherence among groups (81–89% by tablet counting)
Zhu 2008^275^ CIFOS Western Australia [18089701] | - Mean age (SD), y | 74.8 (2.6) | 25(OH)D: 68.0 nmol/L Ca: 1010 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. placebo | No differences in adherence among groups (81–89% by tablet counting)
Zhu 2008^275^ CIFOS Western Australia [18089701] | - Male (%) | 0 | 25(OH)D: 68.0 nmol/L Ca: 1010 mg/d | Vit D_2_ 1000 IU/d + Ca citrate 1200 mg/d vs. placebo | No differences in adherence among groups (81–89% by tablet counting)
Moschonis 2006^276^ Greece (31ºN) [17181890] | - Health status | Postmenopausal | Diet Vit D: 23.6 IU/d Ca 680 mg/d | Vit D_3_ 300 IU/d + Ca 1200 mg/d (from low fat dairy products) vs. control (usual diet) | Dairy group 93% (assessed via information obtained at the biweekly sessions | Control group had no intervention ( or usual diet ) so compliance issue not applicable
Moschonis 2006^276^ Greece (31ºN) [17181890] | - Mean age (range), y | 61 (55–65) | Diet Vit D: 23.6 IU/d Ca 680 mg/d | Vit D_3_ 300 IU/d + Ca 1200 mg/d (from low fat dairy products) vs. control (usual diet) | Dairy group 93% (assessed via information obtained at the biweekly sessions | Control group had no intervention ( or usual diet ) so compliance issue not applicable
Moschonis 2006^276^ Greece (31ºN) [17181890] | - Male (%) | 0 | Diet Vit D: 23.6 IU/d Ca 680 mg/d | Vit D_3_ 300 IU/d + Ca 1200 mg/d (from low fat dairy products) vs. control (usual diet) | Dairy group 93% (assessed via information obtained at the biweekly sessions | Control group had no intervention ( or usual diet ) so compliance issue not applicable
NEW Studies
Islam 2010^267^ Dhaka, Bangladesh | - Health status | Healthy | placebo-35.0 +/-9.4 nmol/L Vit D-37.1+/-12.1 nmol/L VitD+Ca- 37.8+/-10.9 nmol/L MMN+D+Ca-36.9+/-12.5 nmol/L | VD (Vit D 10 μg)/day Vs. VD-Ca (Vit D 10 μg + calcium 600 mg)/day Vs. Placebo | compliance not given but 18.5% dropped out
Islam 2010^267^ Dhaka, Bangladesh | - Mean age (range), y | 22.9 (SD 3.9) | placebo-35.0 +/-9.4 nmol/L Vit D-37.1+/-12.1 nmol/L VitD+Ca- 37.8+/-10.9 nmol/L MMN+D+Ca-36.9+/-12.5 nmol/L | VD (Vit D 10 μg)/day Vs. VD-Ca (Vit D 10 μg + calcium 600 mg)/day Vs. Placebo | compliance not given but 18.5% dropped out
Islam 2010^267^ Dhaka, Bangladesh | - Male (%) | 0% | placebo-35.0 +/-9.4 nmol/L Vit D-37.1+/-12.1 nmol/L VitD+Ca- 37.8+/-10.9 nmol/L MMN+D+Ca-36.9+/-12.5 nmol/L | VD (Vit D 10 μg)/day Vs. VD-Ca (Vit D 10 μg + calcium 600 mg)/day Vs. Placebo | compliance not given but 18.5% dropped out
Jackson 2011^268^ WHI US (various) | - Health status | Post menopausal | vitamin D intake: placebo- 7.54+/-6.36 ug/d, CaD- 7.42+/-5.84 ug/d calcium intake: placebo- 1049+/-625.7 mg/d, CaD- 1,039+/-635.1 mg/d | (400 IU Vit D_3_+1000 mg elemental calcium)/day Vs. placebo | 80% or greater compliance-968 women (placebo = 500, CaD= 468)
Jackson 2011^268^ WHI US (various) | - Mean age (range), y | nd | vitamin D intake: placebo- 7.54+/-6.36 ug/d, CaD- 7.42+/-5.84 ug/d calcium intake: placebo- 1049+/-625.7 mg/d, CaD- 1,039+/-635.1 mg/d | (400 IU Vit D_3_+1000 mg elemental calcium)/day Vs. placebo | 80% or greater compliance-968 women (placebo = 500, CaD= 468)
Jackson 2011^268^ WHI US (various) | - Male (%) | 0% | vitamin D intake: placebo- 7.54+/-6.36 ug/d, CaD- 7.42+/-5.84 ug/d calcium intake: placebo- 1049+/-625.7 mg/d, CaD- 1,039+/-635.1 mg/d | (400 IU Vit D_3_+1000 mg elemental calcium)/day Vs. placebo | 80% or greater compliance-968 women (placebo = 500, CaD= 468)
Karkkainen 2010^269^ OSTPRE-FPS Kuopio, Finland | - Health status | Post menopausal | intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (p=0.544) | Vit D 800 IU+calcium 1,000 mg Vs. control (neither supplementation nor placebo) | 79% compliance
Karkkainen 2010^269^ OSTPRE-FPS Kuopio, Finland | - Mean age (SD), y | 67.4 (SD 1.9) | intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (p=0.544) | Vit D 800 IU+calcium 1,000 mg Vs. control (neither supplementation nor placebo) | 79% compliance
Karkkainen 2010^269^ OSTPRE-FPS Kuopio, Finland | - Male (%) | 0% | intervention- 50.1 (18.8) nmol/l control- 49.2 (17.7) nmol/l (p=0.544) | Vit D 800 IU+calcium 1,000 mg Vs. control (neither supplementation nor placebo) | 79% compliance
Kukuljan 2011^272^ Geelong, Australia | - Health status | Healthy | calcium intake: 911–1064 mg/d Serum vitamin D level: 86.3+/-36.0 nmol/L | fortified milk (400 ml/day containing 1000 mg calcium+800 IU Vit D_3_) vs. controls | exercise program- 63% (95% CI: 57, 69) fortified milk- 90% (95% CI, 87, 93),
Kukuljan 2011^272^ Geelong, Australia | - Mean age (range), y | 59.9 (SD 7.4) | calcium intake: 911–1064 mg/d Serum vitamin D level: 86.3+/-36.0 nmol/L | fortified milk (400 ml/day containing 1000 mg calcium+800 IU Vit D_3_) vs. controls | exercise program- 63% (95% CI: 57, 69) fortified milk- 90% (95% CI, 87, 93),
Kukuljan 2011^272^ Geelong, Australia | - Male (%) | 100% | calcium intake: 911–1064 mg/d Serum vitamin D level: 86.3+/-36.0 nmol/L | fortified milk (400 ml/day containing 1000 mg calcium+800 IU Vit D_3_) vs. controls | exercise program- 63% (95% CI: 57, 69) fortified milk- 90% (95% CI, 87, 93),
Moschonis 2011^271^ Postmenopausal Health Study Greece | - Health status | Healthy | Vitamin D intake: 0.89±0.66ug/d Calcium intake: 789.6±213.5mg/d | CaD (800 mg calcium+10 μg Vit D_3_)/day Vs. control | NR
Moschonis 2011^271^ Postmenopausal Health Study Greece | - Mean age (range), y | 62.4 (SD 5.3) | Vitamin D intake: 0.89±0.66ug/d Calcium intake: 789.6±213.5mg/d | CaD (800 mg calcium+10 μg Vit D_3_)/day Vs. control | NR
Moschonis 2011^271^ Postmenopausal Health Study Greece | - Male (%) | 0% | Vitamin D intake: 0.89±0.66ug/d Calcium intake: 789.6±213.5mg/d | CaD (800 mg calcium+10 μg Vit D_3_)/day Vs. control | NR
Moschonis 2010^270^ Postmenopausal Health Study Greece | - Health status | Healthy | Vitamin D intake: 0.61±0.61 ug/d Serum vitamin D level:26.2±8.5 nmol/L Calcium intake: 682.9±226.1 mg/d | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months Vs. control (neither counselling nor dietary products) | nd
Moschonis 2010^270^ Postmenopausal Health Study Greece | - Mean age (SD), y | 60.7 (SD 5) | Vitamin D intake: 0.61±0.61 ug/d Serum vitamin D level:26.2±8.5 nmol/L Calcium intake: 682.9±226.1 mg/d | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months Vs. control (neither counselling nor dietary products) | nd
Moschonis 2010^270^ Postmenopausal Health Study Greece | - Male (%) | 0% | Vitamin D intake: 0.61±0.61 ug/d Serum vitamin D level:26.2±8.5 nmol/L Calcium intake: 682.9±226.1 mg/d | (1200 mg calcium+7.5 μg D_3_)/day for the first 12 months + (1200 mg calcium+22.5 μg D_3_)/day for the next 18 months Vs. control (neither counselling nor dietary products) | nd
Zhu 2008^266^ Beijing, China | - Health status | Healthy | Vit D intake Control group—0.9 ± 0.6μg/d CaD milk—0.9 ± 0.6μg/d | 560 mg calcium + 5-8 μg Vit D/school day Vs. control (no supplementary milk and habitual diet) | nd
Zhu 2008^266^ Beijing, China | - Mean age (range), y | 10.1 (SD 0.3) | Vit D intake Control group—0.9 ± 0.6μg/d CaD milk—0.9 ± 0.6μg/d | 560 mg calcium + 5-8 μg Vit D/school day Vs. control (no supplementary milk and habitual diet) | nd
Zhu 2008^266^ Beijing, China | - Male (%) | 0% | Vit D intake Control group—0.9 ± 0.6μg/d CaD milk—0.9 ± 0.6μg/d | 560 mg calcium + 5-8 μg Vit D/school day Vs. control (no supplementary milk and habitual diet) | nd

One RCT identified for the current study that randomized 10-year-old girls in China by school compared the effects of 560mg daily calcium and 200 to 320IU vitamin D-supplemented milk per day to habitual diet and found that total body BMD was significantly increased after 2 years. 266

A 1-year intervention with vitamin D-depleted Indian women, 16 to 36 years of age, compared the effects of 400IU vitamin D and 600mg calcium per day to those of placebo and found significantly increased femoral neck but not lumbar spine BMD (study rated A). 267

Four studies assessed the effect of vitamin D and calcium supplementation on postmenopausal women. A study conducted on a subgroup of 1,529 WHI participants on the ability of 400IU vitamin D and 1000mg calcium per day to preserve BMD found significant effects on specific areas such as the femoral narrow neck but only trends toward increased preservation of intertrochanteric and shaft BMD at year 6 (rated A).268 The OSTPRE-FPS trial of Finnish women, 65 to 71 years of age, found that 800IU vitamin D and 1,000 mg calcium daily significantly increased total body BMD but did not significantly increase femoral neck, lumbar spine or trochanteric BMD at 3 years (rated C).269 The Postmenopausal Health Study randomized 66 women, 55 to 65 years, to 300IU vitamin D and1200mg calcium or placebos daily for 12 months and then 900IU vitamin D plus 1200mg calcium for the next 18 months: Significant increases were achieved in total body and spinal BMD at 30 months (rated B).270 The Postmenopausal Health Study II randomized 65 women, 55 to 65 years, to 400IU vitamin D and 800mg calcium or control for 12 months: Significant increases were achieved in total body but not spinal BMD (rated B).271

One RCT randomized 89 healthy, vitamin D-replete Australian men, 50 to 79 years of age, to milk fortified with 800IU vitamin D and 1000mg calcium per day or a control group; the fortified milk had no significant effects on BMD in any area in these men (rated A). 272

One RCT identified for the original report compared the effect of vitamin D3 (200 IU/d) plus calcium (1000 mg/d) supplementation to placebo on bone indices in healthy girls, aged 10 and 12 years.273 The mean background dietary calcium intake was 670 mg/d. The intention-to-treat analyses showed that after 2 years of supplementation, there was no significant difference in the BMC changes between girls who received vitamin D plus calcium supplement or placebo. The methodological quality of this study was rated C, due to underpower and low compliance rate.

Three RCTs (two were rated B and one was rated C) examined the effect of vitamin D plus calcium supplementation on BMD changes. All three trials were conducted in postmenopausal women. However, the doses of vitamin D and calcium combinations varied. One RCT used daily dose of 400 IU vitamin D_3_ plus 100 mg elemental calcium for 2 years.274 The second RCT used daily dose of 1000 IU vitamin D_2_ plus 1200 mg calcium citrate for 5 years.275 The third RCT used a daily dose of vitamin D_3_ 300 IU plus calcium citrate 1200 mg from calcium supplemented low-fat dairy products for 1 year.276 The latter two RCTs resulted in a significant increase in hip or total BMD comparing vitamin D plus calcium supplementation to placebo.275,276 The one RCT that did not show significant change in femoral neck BMD comparing vitamin D plus calcium supplementation to placebo used a substantially lower dose of calcium (100 mg/d) than the other two RCTs.

##### In Ottawa EPC Report—Bone Mineral Density and Women of Reproductive Age, Postmenopausal Women, and Older Men

Overall, there is good evidence that vitamin D3 plus calcium supplementation resulted in small increases in BMD of the spine, total body, femoral neck and total hip. Based on included trials, it was less certain whether vitamin D3 supplementation alone has a significant effect on BMD.

Seventeen RCTs evaluated the effect of supplemental vitamin D2 or D3 on BMD, predominantly in populations of late menopausal women. Only one small RCT included premenopausal women, and two trials included older men (> 60 years). Most trials were two to three years in duration and used vitamin D doses of ≤ 800 IU daily. Most trials used vitamin D3 and also included calcium 500 mg as a cointervention.

Meta-analysis results of 17 RCTs of vitamin D3 plus calcium versus placebo were consistent with a small effect on lumbar spine, femoral neck, and total body BMD. The WHI trial found a significant benefit of 400 IU vitamin D3 plus 1000 mg calcium supplementation on total hip BMD. However, when the effect of vitamin D3 plus calcium versus calcium alone supplementation is assessed, no significant increase in BMD was observed with either intervention, suggesting vitamin D3 may be of less benefit in calcium replete postmenopausal women. Vitamin D3 alone versus placebo did not result in a significant increase in BMD in postmenopausal women, except in one trial that noted an increase in femoral neck BMD. Only a few trials reported the impact of baseline serum 25(OH)D concentrations on BMD and in all of these trials, baseline 25(OH)D concentration was not associated with increased BMD.

#### Findings by Life Stage

- 0–6 mo
  No data
- 7 mo–2 y
  No data
- 3–8 y
  No data
- 9–18 y
  One RCT showed that, compared to placebo, there was no significant effect of vitamin D3 (200 IU/d) plus calcium (1000 mg/d) on BMC changes in healthy girls, aged between 10 and 12 years old.
- 19–50 y
  No data
- 51–70 y
  No new data since the Ottawa EPC report
- ≥71 y
  No new data since the Ottawa EPC report
- Postmenopause
  Findings from the Ottawa EPC report showed that vitamin D_3_ (≤ 800 IU/d) plus calcium (∼500 mg/d) supplementation resulted in small increases in BMD of the spine, total body, femoral neck, and total hip in predominantly populations of late menopausal women. Two of the three new RCTs showed a significant increase in hip or total BMD in postmenopausal women, comparing D_3_ or D_2_ (300 or 1000 IU/d, respectively) plus calcium (1200 mg/d) to placebo.
- Pregnant & lactating women
  No new data since the Ottawa EPC report

## How Does Dietary Intake of Vitamin D From Fortified Foods and Vitamin D Supplementation Affect Serum 25(OH)D Concentrations (Arrow 4)?

The evidence for this question comes from studies identified in our literature search that crossed vitamin D terms with various outcomes terms as well as a high-quality systematic review. Studies that addressed this question but do not report any of the outcomes of interest would not have been identified in this manner. Because the availability of serum 25(OH)D concentration is unlikely to be adequately indexed in the MEDLINE^®^ citation, it would be difficult to comprehensively search the literature for this question. To do so would require retrieving all vitamin D supplements full text articles (in excess of 10,000) to look for serum 25(OH)D concentration data. Given that there is no plausible reason for a systematic bias of studies of a specific outcome choosing to report serum 25(OH)D concentration, we believe that the evidence found, while not comprehensive, is a small but representative random sample. Only RCTs were included for this question. RCTs of different regimens but with the same dose of vitamin D supplementation were excluded (e.g., comparison of daily, weekly versus monthly dose).

This question was also addressed in the Ottawa EPC report.8 When appropriate, we extracted relevant data from the Ottawa EPC report to be incorporated into our analyses.

### RCTs on Dietary Intakes of Vitamin D From Fortified Foods and Serum 25(OH)D Concentrations

#### Synopsis

The current report identified one systematic review published since the original report that addressed the question as well as eighteen new RCTs that met the inclusion criteria (two that used fortified foods and the remainder that used supplements). The systematic review reported widely varying increases in serum concentrations of 25(OH) for similar doses of vitamin D, with a general increase in serum concentration with dietary intake.

For the original report, the updated search did not identify new RCT evaluating the effect of food fortification on serum 25(OH)D concentrations since the Ottawa EPC report.8 The Ottawa EPC report concluded that there is “good” evidence that dietary intake of vitamin D increases serum 25(OH)D concentrations among adults.

#### Detailed Presentation

The current report identified one quality systematic review that addressed the relationship between vitamin D supplementation and net change in serum 25(OH)D concentrations.277 This review included 76 placebo-controlled and open-label trials published from 1984 through 2011 that assessed the effects of vitamin D supplementation (most trials used oral doses, although a small number of studies administered vitamin D via injection). Doses tested ranged from 200 to 10,000IU per day. Similar doses resulted in increases in serum 25(OH)D that varied by three to four fold. Meta-regression showed that serum concentrations increased by an average of 1.95 nmol/L for each 40IU per day supplementation; use of ergocalciferol in place of cholecalciferol resulted in smaller increases, and simultaneous supplementation with calcium resulted in non-significantly smaller increases in serum 25(OH)D concentrations. The small number of trials that used higher doses precludes assessment of whether the dose-response relationship plateaus at higher doses. Most studies did not stratify findings by sex, and the review itself did not stratify findings by assay method.

Eighteen of the RCTs that met inclusion criteria for the current report could be included in an assessment of dose response (Table 67). Two of the studies provided the Vitamin D as fortified foods;229,272 the remainder administered supplemental vitamin D alone or in combination with calcium.150,186,188,228,230,231,234-236,244,245,248,260,267,269,278 One study administered ergocalciferol.188

Table 67 The relationship between vitamin D_3_ daily doses and changes in 25(OH)D concentrations in RCTs (formerly Table 106) (updated from original report)

Author/Year | Assay Method | Life stage | Base 25(OH)D, nmol/L | Vit D_3_ Dose (IU/d) | Ca Dose (mg/d) | Duration (mo) | Vit D_3_ ± Ca Group | | | Placebo or Ca Group
Author/Year | Assay Method | Life stage | Base 25(OH)D, nmol/L | Vit D_3_ Dose (IU/d) | Ca Dose (mg/d) | Duration (mo) | n | Mean Change From Baseline | SD | n | Mean Change From Baseline | SD
New Studies
Gaanmaa, 2012^278^ | CLIA | 9-18 yrs | 17.8 | 800 | 0 | 6 | 57 | 31.9 | 11.1 | 55 | 9.6 | 9.7
Gepner, 2012^229^ | HPLC | Postmenopausal | 78.1 (26.5) | 2500 Fortified cookies | 0 | 4 | 55 | 39.2 | 23.2 | 55 | -0.5 | 15.2
Islam, 2010^267^ | RIA | 19–50 | 36.1 | 400 | 600 | 12 | 40 | 32·1 | 23·6 | 35 | 0·5 | 13·8
Jorde, 2010^230^ | RIA | 19–50, 51–70 | 57.8 | 2857 | 500 | 12 | 104 | 42.8 | 22.5 | 112 | -1.6 | 16.8
Jorde, 2010 | RIA | 19–50, 51–70 | 58.7 | 5,714 | 500 | 12 | 114 | 79.3 | 31.2 | 112 | -1.6- | 16.8
Karkainnen, 2010^269^ | RIA | 51–70, 70+ | 49.6 | 800 | 1000 | 36 | 287 | 24.7 | 24.1 | 306 | 6.8 | 19.3
Kukuljian, 2011 272 | RIA | 51–70, 71+ | 88.1 | Fortified milk 800 | 500 | 18 | 45 | 27.5 | 111.1 | 44 | 12.5 | 109.8
Li-Ng, 2009^150^ | RRA | 19–50, 51–70 | 63.7 | 2000 | 0 | 3 | 78 | 24.0 | 30.6 | 70 | -2.1 | 20.9
Macdonald, 2013^245^ | HPLC MS^2^ | 51–70 yrs | 34.6 | 400 | | 12 | 84 | 31.6 | 19.8 | 89 | -4.1 | 11.5
Macdonald. 2013 | HPLC MS^2^ | 51–70 yrs | 34.5 | 1000 | | 12 | 90 | 42.6 | 18.9 | 89 | -4.1 | 11.5
Molgaard, 2010^248^ | HPLC MS^2^ | 9–11 yrs | 42.6 | 200 | 0 | 12 | 73 | 11.0 | 10.3 | 74 | −3.1 | 9.8
Molgaard, 2010 | HPLC MS^2^ | 9–11 yrs | 40.0 | 400 | 0 | 12 | 74 | 13.3 | 10.8 | 74 | -3.1 | 9.8
Nieves, 2012^244^ | RIA | Postmenopause | 29.0 | 1000 | ≤1000 | 24 | 55 | 26.0 | 41.4 | 48 | 1.0 | 12.5
Pfeiffer, 2009^186^ | RIA | 71+ yrs | 54.5 | 800 | 1000 | 20 | 121 | -7 | 17.1 | 121 | -16 | 16.8
Salehpour, 2012^234^ | ELISA | 19–50 yrs | 41.9 () | 1000 | 0 | 3 | 39 | 38·2 | 32 | 38 | 4·6 | 14
Salovaara, 2010^260^ | RIA | 51–70, 71+ yrs | 49.5 | 800 | 1000 | 36 | 1586 | 24.6 | 20.5 | 1609 | 6.8 | 20.1
Toxqui, 2013^228^ | ELISA | 9–50 yrs | 62.6 | 200 | | 2 | 55 | 8.9 | 21.0 | 54 | 0.3 | 19.7
Wamberg, 2013^236^ | HPLC MS^2^ | 9–50 yrs | 33.5 | 7000 | | 6.5 | 22 | 77.2 | 18.4 | 21 | 12.8 | 15.0
Witham, 2013^235^ | ELISA | 9–71+ yrs | 27 | 1667 | | 2 | 25 | 10 | 10.2 | 25 | 0 | 10.2
Wood, 2012^231^ | HPLC MS^2^ | Postmenopause | 34.5 | 400 | 0 | 12 | 84 | 33.0 | 20.2 | 91 | -2.7 | 12.4
Wood, 2012 | HPLC MS^2^ | Postmenopause | 30.3 | 1000 | 0 | 12 | 90 | 42.9 | 19.0 | 91 | 2.7 | 12.4
Zhu, 2010^188^ | RIA | 71+ yrs | 44.7 | D2: 1000 | 1000 | 12 | 129 | 14.7 | 13.3 | 132 | 0.8 | 13.2
Old Studies
Bjorkman 2008^263^ | HPLC | 71+ | 23 | 400 | 0 | 6 | 60 | 26.5 | 11.8 | 59 | 1.9 | 10.2
Bjorkman 2008^263^ | HPLC | 71+ | 23 | 1200 | 0 | 6 | 63 | 49.1 | 19.5 | 59 | 1.9 | 10.2
Blum 2008^279^ | ND | 71+ | 73 | 700 | 500^A^ | 12 | 132 | 48.5 | 35.3 | 125 | 9.3 | 21.5
Bunout 2006^183^ | RIA | 71+ | 40 | 400 | 800^A^ | 9 | 46 | 33.4 | 14.3 | 46 | 3.5 | 10.0
Chapuy 1992^280^ | RIA | 71+ | 36 | 800 | 1200 | 18 | 73 | 65.0 | 16.5 | 69 | -4.5 | 13.5
Chel 2008^281^ | RIA | 71+ | 23 | 600 | 0 | 4 | 46 | 46.9 | 15.4 | 45 | 0.3 | 12.2
Deroisy 2002^282^ | RIA | 71+ | 28 | 200 | 500^A^ | 3 | 50 | 14.7 | 10.0 | 50 | 4.5 | 10.0
Himmelstein 1990^283^ | RRA | 71+ | 45 | 2000 | 0 | 1.5 | 15 | 39.7 | 15.7 | 15 | -2.7 | 13.4
Kenny 2003^284^ | RRA | 71+ | 62 | 1000 | 500^A^ | 6 | 29 | 22.3 | 10.1 | 31 | -2.5 | 11.4
Krieg 1999^285^ | RRA | 71+ | 29 | 880 | 500 | 24 | 34 | 36.5 | 14.0 | 38 | -15.0 | 11.1
Pfeifer 2000^286^ | RIA | 71+ | 25 | 880 | 1200^A^ | 2 | 74 | 40.5 | 27.0 | 74 | 18.3 | 20.9
Pfeifer 2001^238^ | RIA | 71+ | 25 | 800 | 1200 | 2 | 73 | 39.2 | 22.4 | 72 | 19.7 | 23.8
Sorva 1991^287^ | RRA | 71+ | 11 | 1000 | 1000 | 10 | 5 | 44.6 | 28.9 | 10 | -1.4 | 2.3
Zhu 2008^275^ | RIA | 71+ | 68 | 1000 | 1200^A^ | 60 | 29 | 36.2 | 27.5 | 34 | -2.9 | 27.4
Barnes 2006^288^ | Not available | adults | 52 | 600 | 1500^A^ | 2 | 12 | 38.6 | 15.1 | 15 | -7.2 | 11.3
Bolton-Smith 2007^274^ | RIA | adults | 60 | 400 | 100 | 24 | 50 | 12.0 | 15.1 | 56 | -8.2 | 14.3
Dawson-Hughes 1997^289^ | RRA | adults | 74 | 700 | 500 | 36 | 145 | 35.2 | 32.6 | 167 | -2.1 | 22.7
Harris 2002^290^ | HPLC/RRA | adults | 55 | 800 | 0 | 2 | 27 | 22.3 | 14.0 | 23 | -4.6 | 6.3
Heaney 2003^291^ | RIA | adults | 71 | 1000 | 0 | 5 | 16 | 12.0 | 16.0 | 16 | -11.4 | 17.6
Heaney 2003^291^ | RIA | adults | 71 | 5000 | 0 | 5 | 17 | 91.9 | 37.6 | 16 | -11.4 | 17.6
Heikkinen 1998^292^ | HPLC/RRA | adults | 26 | 300 | 500^A^ | 12 | 18 | 9.4 | 10.9 | 18 | -3.3 | 6.4
Honkanen 1990^293^ | Not available | adults | 31 | 1800 | 1550 | 2.75 | 55 | 39.5 | 12.1 | 60 | -13.1 | 9.2
Jensen 2002^294^ | RRA | adults | 41 | 400 | 1450 | 36 | 33 | 34.6 | 23.2 | 33 | 16.5 | 28.2
Nelson 2009^295^ | RIA | adults | 62 | 800 | 0 | 12 | 55 | 35.3 | 23.2 | 31 | 10.9 | 16.9
Orwoll 1988^296^ | RRA | adults | 58 | 1000 | 1000 | 12 | 46 | 25.0 | 19.1 | 46 | 3.0 | 19.1
Patel 2001^297^ | RIA | adults | 72 | 800 | 0 | 12 | 35 | 8.4 | 13.1 | 35 | -9.2 | 12.8
Riis 1984^298^ | Not available | adults | 41 | 2000 | 500 | 12 | 8 | 87.5 | 14.1 | 7 | -5.0 | 23.8
Trang 1998^299^ | RIA | adults | 42 | 4000 | 0 | 0.5 | 24 | 23.3 | 17.5 | 24 | 3.0 | 19.8
Chan 1982^300^ | RRA | children | 43 | 400 | 0 | 6 | 30 | 22.5 | 6.6 | 30 | -2.5 | 6.6
El-Hajj (Fuleihan) 2006^48^ | RRA | children | 35 | 200 | 0 | 12 | 58 | 7.5 | 19.8 | 55 | 5.0 | 18.8
El-Hajj (Fuleihan) 2006^48^ | RRA | children | 35 | 2000 | 0 | 12 | 55 | 59.9 | 67.1 | 55 | 5.0 | 18.8

A Calcium supplement was given to all patients.

The format of this table has been slightly modifies to fit each RCT in one line. RRAs and RIAs represent multiple procedures or commercial assay kits.

All studies reported an increase in serum 25(OH)D with supplementation. However, the studies varied by age group and health status of participants, baseline vitamin D status, dose, duration, and assay used to assess serum 25(OH)D. Further information on assay methods and performance is provided in Appendix G.

### RCTs on Vitamin D Supplementation and Serum 25(OH)D Concentrations

#### Synopsis

Because the availability of serum 25(OH)D concentration is unlikely to be adequately indexed in the Medline citation, it would be difficult to comprehensively search the literature for this question. We believe that studies summarized here are a small but representative random sample of all available data.

We plotted the net changes in serum 25(OH)D concentration against the doses of vitamin D supplementation using data from 44 RCTs with 50 comparisons in adults and children. Only RCTs of daily vitamin D_3_ supplementation (doses ranged from 200 to 5000 IU/d) alone or in combination with calcium supplementation (doses ranged from 500 to 1550 mg/d) that provided sufficient data for the calculations were included in the plot. It is important to note that the studies had varied compliance rates in the vitamin D intake; limited or no adjustment for skin pigmentations, calcium intake, or background sun exposure; different vitamin D assay methodologies and measurement (both intra- and interassay) variability. All these factors increase the heterogeneity and limit the usefulness of an overall summary estimate for an intake dose response in serum 25(OH)D concentration. Nonetheless, the relationship between increasing doses of vitamin D_3_ with increasing net change in 25(OH)D concentration was evident in both adults and children (Figure 12). It was also apparent that the dose-response relationships differ depending on study participants' serum 25(OH)D status (≤40 vs. >40 nmol/L) at baseline (Figure 13), and depending on duration of supplementation (≤3 vs. >3 months) (Figure 14). For the current report, we also plotted the relationship between dose of vitamin D_3_ and net change in 25(OH)D concentration according to the assay method reported (Figure 15). Vitamin D_2_ supplementation was more commonly used in RCTs of infants and pregnant or lactating women, than vitamin D_3_ supplementation. Results showed that supplementation of vitamin D_2_ significantly increased 25(OH)D concentrations in infants, lactating mothers and in cord blood.

Figure 12 Relationship between doses of vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs (formerly Figure 23)

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

This bubble plot displays the relationship between doses of vitamin D3 supplementation and net changes in serum 25(OH)D concentrations in RCTs. The image includes two graphs. The top graph shows the Y axis with the net change in 25(OH)D in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for adults. Each cell or bubble represents an individual study. The bottom graph shows the Y axis with the net change in 25(OH)D, nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-5000 for children. Each cell or bubble represents an individual study. The results are described in the text above the figure.

Figure 13 Relationship between doses of vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs by baseline vitamin D status among adults (formerly Figure 24)

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

This bubble plot displays the relationship between doses of vitamin D3 supplementation and net changes in serum 25(OH)D concentrations in RCTs by baseline vitamin D status among adults. This image includes two graphs. The top graph shows the Y axis with the net change in 25(OH)D, in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for adults with low 25(OH)D concentrations. Each cell or bubble represents an individual study. The bottom graph shows the Y axis with the net change in 25(OH)D, in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-5000 for adults with normal/high 25(OH)D concentrations. Each cell or bubble represents an individual study. The results are described in the text above figure 12.

Figure 14 Relationship between doses of vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs by duration of supplementation among adults (formerly Figure 25)

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

This bubble plot displays the relationship between doses of vitamin D3 supplementation and net changes in serum 25(OH)D concentrations in RCTs by duration of supplementation among adults. The image includes two graphs. The top graph shows the Y axis with the net change in 25(OH)D, nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-5000 for duration of supplementation less than or equal to 3 months. Each bubble or cell represents an individual study. The bottom graph shows the Y axis with the net change in 25(OH)D, in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for duration of supplementation greater than 3 months. Each bubble or cell represents an individual study. The results are described in the text above figure 12.

Figure 15 Relationship between doses of vitamin D_3_ supplementation and net changes in serum 25(OH)D concentrations in RCTs by assay type (new figure)

Legends: Each empty circle represents one study. The area of the circle is proportional to the inverse of the within-study variances. Typically, the larger the bubble, the larger the sample size and the smaller the standard error of the changes in 25(OH)D.

This bubble plot displays the relationship between doses of vitamin D3 supplementation and net changes in serum 25(OH)D concentrations in RCTs by duration of supplementation among adults. The image includes five graphs. The top left graph shows the Y axis with the net change in 25(OH)D, nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for HPLC method. Each bubble or cell represents an individual study. The top middle graph shows the Y axis with the net change in 25(OH)D, nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for RIA method. Each bubble or cell represents an individual study. The top right graph shows the Y axis with the net change in 25(OH)D, nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for RRA method. Each bubble or cell represents an individual study. The bottom left graph shows the Y axis with the net change in 25(OH)D, in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for the CLIA method. Each bubble or cell represents an individual study. The bottom right graph shows the Y axis with the net change in 25(OH)D, in nmol/L with a range from 0-100, and the X axis plots the vitamin D3 daily dose(IU) with a range from 0-6000 for the ELISA method. Each bubble or cell represents an individual study. The results are described in the text above figure 12.

#### Detailed Presentation

(Table 67; Figures 12, 13, 14, & 15)

The results from 26 RCTs with 28 comparisons in adults and two RCTs with three comparisons in children evaluating the effect of vitamin D_3_ supplementation alone or in combination with calcium supplementation on serum 25(OH)D concentrations are shown in Table 67. Most of the data included in the original report were extracted directly from the Ottawa EPC report. In adults included in studies from both the original and the current report, the doses of vitamin D_3_ ranged from 200 to 5000 IU/d, and the doses of calcium supplementation ranged from 500 to 1550 mg/d across the comparisons. In children, the doses of vitamin D_3_ ranged from 200 to 2000 IU/d. Duration of supplementation ranged from 0.5 to 60 months. Study populations and baseline vitamin D concentrations varied across these comparisons.

Figure 15 shows the dose-response results by reported assay method. Most studies reported using a radioimmunoassay, a radioreceptor assay (a heterogeneous group, as a number of different molecules are used as receptors), or a method involving HPCL-tandem mass spectrometry; few studies reported using a chemiluminescence assay (CLIA) or enzyme linked immunoadsorption assay (ELISA). The plots show slightly different patterns for the different assays.

The remainder of this section reports the results of the dose response assessment conducted for the 2006 evidence review and described in the original report.

##### Ottawa EPC Report -Adults

There were eleven RCTs (n=1281) of which seven (n=668) permitted a quantitative analysis. Ten of eleven trials found a significant effect of dietary intake from foods fortified with vitamin D on serum 25(OH)D concentrations. There was significant heterogeneity of the treatment effect. Potential sources of heterogeneity are the different 25(OH)D assays used (two studies each used HPLC, RIA or CPBA, and one study did not report the assay), the dietary vehicles used, and study populations. The increase in serum vitamin D concentration in the seven trials ranged from 15 (95% CI 11, 18) to 40 (95% CI 25, 55) nmol/L (fortification consisting of 100–1000 IU of vitamin D).

There can be a potential confounding of the data by the food source, the assay used to measure 25(OH)D and potential differences in the bioavailability and/or metabolism of vitamin D2 versus vitamin D3. Most studies in this review used dairy products as the source of fortified food. It is important to note that there is potential for study contamination through altered intake of other nutrients such as calcium, phosphate and acid load that can affect the study outcomes.

##### Ottawa EPC Report—Infants

Seven RCTs included infants and few trials used vitamin D_3_ supplementation. One RCT concluded that 200 IU of vitamin D_2_ may not be enough to prevent vitamin D deficiency in those infants residing at northern latitudes. A dose-response relationship was noted in this trial (100, 200, 400 IU/day). Consistent responses to vitamin D supplementation were noted across the seven trials, and some trials suggested that infants who are vitamin D deficient may respond differently and require higher doses of vitamin D to achieve serum 25(OH)D concentrations within the normal range.

##### Ottawa EPC Report—Pregnant or Lactating Women

There were six small RCTs of vitamin D supplementation in pregnant or lactating women. No randomized trials studied the effect of 400 IU vitamin D_3_/d. Three trials used 1000 IU vitamin D_2_/d and one trial used 1000 IU/d of vitamin D_3_. Supplementation of vitamin D_2_ 1000–3600 IU/d and vitamin D_3_ 1000 IU/d resulted in significant increases in serum 25(OH)D concentrations in lactating mothers and in cord blood. One trial found that supplementation of lactating mothers with 1000 IU vitamin D_2_/d during winter months did not significantly increase serum 25(OH)D concentrations in the infants.

##### Ottawa EPC Report—Children and Adolescents

There were four trials that examined the effect of vitamin D on serum 25(OH)D concentrations in children or adolescents with doses ranging from 200 to 2000 IU of vitamin D_3_ per day and 400 IU of vitamin D_2_. There were consistent increases in serum 25(OH)D concentrations ranging from 8 nmol/L (200 IU/d), 16.5 (with 600 IU D_3_/d) to 60 nmol/L (2000 IU of vitamin D_3_/d).

##### Ottawa EPC Report—Premenopausal Women and Younger Men

Ten small trials included premenopausal women and younger males. Three trials compared vitamin D2 to vitamin D3 in healthy young adults. Two of the three trials used RIA, and one used HPLC to measure serum 25(OH)D concentrations The doses of vitamin D3 ranged from 600 to 10,000 IU/day and vitamin D2 (4000 IU/d or 50,000 to 100,000 for single dose).

Three trials found that supplementation with vitamin D2 and D3 in healthy adults may have different effects on serum 25(OH)D concentrations. One trial compared 100,000 IU vitamin D2 given orally versus injection and found a greater variability in response with the intramuscular preparation. There appeared to be dose-response effect in those trials that used multiple doses of vitamin D3, although there were insufficient data to perform a meta-analysis.

##### Ottawa EPC Report—Postmenopausal Women and Older Men

Forty-four trials were conducted exclusively in postmenopausal women and older men, with 14 of these in elderly populations living in long-term care or nursing homes. One trial enrolled only women in early menopause (n=129). Doses of vitamin D3 ranged from 100 to 4000 IU/day and vitamin D_2_ was 9000 IU/day. One trial was conducted in African American women.

One trial found that wintertime declines in serum 25(OH)D concentrations were prevented with 500 IU vitamin D3 per day. A dose response with increasing doses of vitamin D3 was noted for serum 25(OH)D concentrations. There was variability in response to similar doses across trials that may have been due to differences in serum 25(OH)D assays or baseline 25(OH)D concentrations. Similarly, although some trials reported a greater response to vitamin D in populations that were vitamin D deficient at baseline compared to those who were not, there were insufficient data on which to base a definitive conclusion on this point.

## Stratification of Key Outcomes by Vitamin D Assay Method

In addition to plotting the data for Vitamin D dose-response by the method used to assay serum 25(OH)D (Figure 15), for all outcomes reported in three or more RCTs or seven or more observational studies, we stratified the studies according to the assay method used to assess serum 25(OH)D concentrations (radioimmunoassay, radioreceptor/ligand assay, enzyme-linked immunoadsorption assay, chemiluminescence assay, and HPLC-tandem mass spectrometry). These stratified tables appear in Appendix H.

## Outcomes for Tolerable Upper Intake Levels

We included only clinical outcomes of tolerable upper intake levels, such as all-cause mortality, cancer (incidence and mortality), soft tissue calcification, renal outcomes, and adverse events reported in RCTs.

Results of all-cause mortality and cancer have been described in previous sections. In brief, we did not find vitamin D and/or calcium associated with an increased risk of mortality. For cancer risk, there were some observational studies reporting high calcium intake may be associated with an increased risk of prostate cancer (see “Prostate cancer” in “Calcium and cancer” section). We did not identify any studies on soft tissue calcification and tolerable upper intake levels.

### Renal Outcomes

As described in the original report, the WHI trial on women aged 50 to 79 years examined the effect of vitamin D3 400 IU (the Recommended Dietary Allowance for women aged 50 to 70 years and below the 600 IU recommended intake for women > 70 years) in combination with 1000 mg calcium carbonate versus placebo and found an increase in the risk of renal stones (Hazard Ratio 1.17 95% CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.131 It should be noted that women in both groups were allowed to take additional vitamin D supplements up to 600 IU and later 1000 IU per day and calcium supplements up to 1000 mg per day. The baseline total calcium intakes (from foods and supplements) were high: 34% consumed less than 800 mg/d, 26% consumed 800 to 1200 mg/d, and 40% consumed more than 1200 mg/d. A prior publication from WHI trial provided the same data on the risk of renal stones was also included in the Ottawa EPC report.

No studies were identified for the original report that evaluated the effect of vitamin D, calcium, or combined vitamin D and calcium on other renal outcomes.

For the current report, two studies assessed the occurrence of nephrolithiasis among participants in RCTs that administered approximately 1100^201^ and 2000IU150 per day supplemental vitamin D without calcium. No incidents of nephrolithiasis were reported in either study.

### Adverse Events Reported in RCTs

The reporting of adverse events in RCTs was generally inadequate, and most trials were not adequately powered to detect adverse events. Among the 63 RCTs included in the original report, 47 did not report information on adverse events. Among 47 RCTs included in the current study, most did not include any information on adverse events.

For the current report, one study, which administered 2000 or 4000IU per day to 504 pregnant women, reported no adverse events during the interventions.42 Three studies reported on only one specific outcome, hypercalcemia/serum calcium, or reported on this outcome and stated no other AEs were reported.1,187,239 Supplementation ranged from 400 to 5000IU per day in these studies; only 1 case of hypercalcemia was reported across all 4 of the studies, in a trial that administered 1000IU per day plus 1000mg calcium.187 Seven other studies that assessed hypercalcemia also reported no cases.

Five studies reported on gastrointestinal symptoms,150,151,235,236,269 of which only one included supplemental calcium. Two studies reported on serious adverse events, including one death, cancer diagnoses, and acute surgeries, which were more prevalent in the placebo group and thus could not have been related to the use of vitamin D.152,201

For the original report, five RCTs (in 6 publications) that enrolled a total of 444 subjects reported no adverse events during the trial periods.48,96,290,301,302 Of these, one RCT administered combination of vitamin D_2_ (1600 or 3600 IU/d) and vitamin D_3_ (400 IU/d) supplements for 3 months, two RCTs administered vitamin D supplements (type of vitamin D not reported) with doses ranging from 200 to 2000 IU/d for 3 weeks or 1 year, one RCT used high-dose intermittent vitamin D_3_ supplement (120,000 IU sachets given 3 times, every 2 weeks, for 6 weeks), and one RCT administered 1200 IU/d vitamin D_2_ supplement for 5 years.

Eleven RCTs reported at least one adverse event (Table 68). Excessive gas, bloating, and gastrointestinal discomforts were reported to be associated with calcium supplementation (doses ranged from 600 to 1000 mg/d). Other RCTs of vitamin D (doses ranged from 400 to 5714 IU/d vitamin D_3_ or ranged from 5000 to 10,000 vitamin D_2_) and/or calcium supplementations (doses ranged from 200 to 1500 mg/d) reported few cases of gastrointestinal disruption (such as constipation, diarrhea, or upset stomach), musculoskeletal soreness, primary hyperparathyroidism, hypercalcemia, and renal calculi. One RCT reported some adverse events that required hospital admission, including retrosternal pain, a non-ST elevation myocardial infarction and a transient ischemic attack (all 3 cases in vitamin D 400 IU/d plus exercise training group) and one case of acute cholecystitis (in calcium, vitamin D plus exercise training group).183 Another RCT reported that “there were no significant differences between the vitamin D and the control groups in the rate of incident cancer and vascular disease (ischemic heart disease and stroke)” (actual data not provided), and one participant died during the study.247 However, these adverse events may or may not be associated with vitamin D and/or calcium supplementation in this study. Also described earlier in the “Renal outcomes” section, the WHI trial examined the effect of vitamin D3 400 IU in combination with 1000 mg calcium carbonate versus placebo and found an increase in the risk of renal stones (Hazard Ratio 1.17 95% CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.131

Table 68 Adverse events reported in RCTs (formerly Table 107) (updated from original report)

Author Year | N Enrolled | Vit D Dose (IU/d) | Ca Dose (mg/d) | Duration | Adverse Event Data (N=Case#)
New Studies
Wamberg236 | 52 | 7000IU/d | 0 | 26 wks | Intervention group: 13 reports of side effects Control group: 17 reports of side effects Side effects included constipation, nausea, tiredness, and headache No participants developed symptomatic hypercalcemia
Witham235 | 50 | 100,000IU single dose | 0 | 8 wks | Intervention group: 3 headaches, 1 complaint of diarrhea, 1 constipation, 1 urinary tract infection, 1 complaint of joint pains, 1 subconjunctival hemorrhage Control group: 2 headaches, 2 complaints of constipation, 1 vomiting, 1 diarrhea, 1 skin rash, 1 corneal ulcer, 1 menorrhagia, 1 chest wall pain, 1 insomnia No deaths, hospitalizations, or cases of hypercalcemia or renal calculi
Wagner42 | 504 | 2000, 4000IU/d | 0 | Throughout pregnancy | None found
Laaksi151 | 164 | 400IU/d | 0 | 5 mos | Intervention group: 2 withdrawals because of stomach ache, nausea, diarrhea Control: 1 case facial rash
Karkainnen269 | 593 | 800IU/d | 1000mg | 3 yrs | 17/290 withdrawals due to AEs: GI symptoms(9), exacerbation of diseases(2), mouth irritation, skin symptoms, nausea, cough, backache, weight increase (one each)
Prince187 | 302 | 1000IU/d | 1000mg | 1 yr | 1 case mild hypercalcemia in intervention group
Holmund, 2012^239^ | 113 | 400, 1200, 1600IU/d | 0 | 2.5 mos | No hypercalcemia in any arm; AEs assessed with pre-specified survey but none reported
Iuliano-Burns242 | 110 | 50,000IU/mo (∼1600IU/d) vs. 50,000IU alternate months vs. single 50,000IU dose | 0 | 1 yr | No cases of vitamin D toxicity or hypercalcemia
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | AE | Vitamin D | Placebo
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | GI | 7 | 6
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Musculoskeletal | 5 | 5
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Chest pain | 1 | 2
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Palpitations | 1 | 0
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Infection | 8 | 8
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Headache | 2 | 0
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Dizziness | 1 | 0
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Allergic rhinitis | 10 | 6
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Falls | 0 | 2
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Fatigue | 2 | 1
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Skin changes | 1 | 4
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | Nephrolithiasis | 0 | 0
Li-Ng150 | 162 | 2000IU/d | 0 | 3 mos | hypercalcemia | 0 | 0
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | Clinical AEs | Vitamin D | Placebo
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | One or more | 24 | 26
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | Serious | 3 | 3
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | Drug related | 1 | 4
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | Deaths | 1 | 0
Lips201 | 226 | 8,000IU/week | 0 | 4 mos | Renal stones | 0 | 0
Hollis 2011^1^ | 494 | 400, 2000, 4000IU/d | 0 | Up to 8 mos | No differences in serum calcium, no specific AEs reported
Roth44 | 160 | 5000IU/d | 0 | 3 mos | Neonatal clinical AEs: Serious nonfatal AEs: Vitamin D: 6 Placebo:7 Neonatal deaths: Vitamin D:1 Placebo: 3 Hypercalcemia: Vitamin D: 0 Placebo: 0
Grimnis 2012^241^ | 297 | 800 IU/d vs. 20,000 IU 2x per week (average daily dose of 6,500 | 1000 | 1 yr | No difference in total AEs reported between groups or in organ-specific AEs, no significant difference in rate of hypercalcemia or hyperphosphatemia
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | SAEs | Vitamin D | Placebo
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Cancer diagnosis/tx | 4 | 1
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Surgical procedure Acute | 3 | 5
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Elective | 8 | 5
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Trauma | 3 | 6
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Treatment for medical condition | 3 | 2
Murdoch152 | 322 | 200,000IU1st and 2^nd^ month, 100,000IU monthly | 0 | 18 mos | Hypercalcemia | 0 | 0
Original Studies
Yamamoto 1995^303^ | 471 | 0 | 1000 | 6 mo | Comparing calcium group to the placebo group, excessive gas and bloating were more frequently reported by white women at 3 months and by whites, in general, at 6 months, and white men reported more loose stools at 6 months.
Moschonis 2006^276^ | 112 | 300 D_3_ | 600 or 1200 | 12 mo | Bloating, constipation and intestinal discomfort apparently related to the calcium supplement
Bunout 2006^183^ | 96 | 400 | 800 | 9 mo | Adverse events that required hospital admission: Vit D plus exercise training group (n=3): retrosternal pain, a non-ST elevation myocardial infarction and a transient ischemic attack. Calcium, Vit D plus exercise training group (n=1): acute cholecystitis
Wactawski-Wende 2006^131^ | 36282 | 400 | 1000 | 7 y | The WHI trial found an increase in the risk of renal stones (Hazard Ratio 1.17 95% CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure.
Burleigh 2007^184^ | 205 | 800 D_3_ | 1200 | Median 1 mo | Hypercalcemia (n=2)
Lappe 2008^259^ | 5201 | 800 | 200 | 8 wks | GI disruption such as constipation, diarrhea, upset stomach (4%), and musculoskeletal soreness (0.9%)
Brooke 1980^47^ | 126 | 1000 | 0 | 3rd trimester only | Vit D group (hypocalcemia, n=0), placebo group (hypocalcemia, n=5)
Lappe 2007^102^ | 1180 | 1000 D_3_ | 1400–1500 | 4 y | Renal calculi in placebo (n=1), renal calculi in calcium only (n=3), renal calculi in calcium plus vit D (n=1)
Mastaglia 2006^304^ | 65 | 5000 or 10,000 D_2_ | 500 | 3 mo | Hypercalciuria (n=1) in control group
Zhu 2008^247^ | 256 | 1000 D_2_ | 1200 | 12 mo | There were no significant differences between the vitamin D and the control groups in the rate of incident cancer and vascular disease (ischemic heart disease and stroke). There were 8 and 5 adverse events in vitamin D and the control groups, respectively. One participant in the vitamin D group had mild asymptomatic hypercalcemia one occasion. No case of renal calculus was reported. 1 participant was deceased during the study.
Sneve 2008^95^ | 445 | Group 1: 2 capsules of vitamin D_3_ each 20,000 IU taken twice a week (Monday and Thursday): ∼5714 IU/d Group 2: 1 capsules of vitamin D_3_ each 20,000 IU taken twice a week (Monday and Thursday): ∼2857 IU/d | 500 | 12 mo | Primary hyperparathyroidism (n=2), increase in serum calcium to 2.62 mmol/L (n=1), transient increases in serum calcium > 2.59 mmol/L (n=4). 317 other adverse events were recorded, most of them related to GI discomfort. There were no significant differences between the treatment groups regarding adverse events.

#### Ottawa EPC Report

A total of 22 trials reported data on toxicity-related outcomes, 21 of which used doses above 400 IU/d. Toxicity results from trials with intakes of vitamin D above current reference intakes varied and this may have been related to different doses, baseline characteristics of populations or exposure times. Most trials excluded subjects with renal insufficiency or hypercalcemia, were of small sample sizes and had short durations of exposure to vitamin D. Event rates were low across trials in both the treatment and placebo arms.

i Numerical data were extracted from previous systematic reviews—no additional studies were identified. For this reason, we did not appraise studies for their methodological quality.