# References

1 Hollis BW, Johnson D, Hulsey TC, et al. (2011). Vitamin D supplementation during pregnancy: double-blind, randomized clinical trial of safety and effectiveness. J Bone Mine Res.
2 Prentice RL, Pettinger MB, Jackson RD, et al. (2013). Health risks and benefits from calcium and vitamin D supplementation: Women's Health Initiative clinical trial and cohort study. Osteoporos Int.
3 (2006). Dietary reference intakes : the essential guide to nutrient requirements: Institute of Medicine (IOM).
4 (2007). The development of DRIs 1994-2004 : lessons learned and new challenges: workshop summary: Institute of Medicine (IOM).
5 Russell R, Chung M, Balk EM, et al. (2009). Opportunities and challenges in conducting systematic reviews to support the development of nutrient reference values: vitamin A as an example. Am J Clin Nutr.
6 (2008). Vitamin D and Health in the 21st Century: an Update. Proceedings of a conference held September 2007 in Bethesda, Maryland, USA. Am J Cli Nutr.
7 Yetley EA, Brule D, Cheney MC, et al. (2009). Dietary Reference Intakes for vitamin D: justification for a review of the 1997 values. Am J Clin Nutr.
8 Cranney A, Horsley T, O'Donnell S, et al. (2007). Effectiveness and safety of vitamin D in relation to bone health. EvidenceReport/Technology Assessment No. 158.
9 Chung M, Balk EM, Brendel M, et al. (2009). Vitamin D and Calcium: A Systematic Review of Health Outcomes. Evidence Report No. 183.
10 Holick MF. (2007). Vitamin D deficiency. N Engl J Med.
11 DeLuca HF. (2004). Overview of general physiologic features and functions of vitamin D. Am J Clin Nutr.
12 Townsend K, Evans KN, Campbell MJ, et al. (2005). Biological actions of extra-renal 25-hydroxyvitamin D-1alpha-hydroxylase and implications for chemoprevention and treatment. J Steroid Biochem Mol Biol.
13 Norman AW. (2008). A vitamin D nutritional cornucopia: new insights concerning the serum 25-hydroxyvitamin D status of the US population. Am J Clin Nutr.
14 Bikle D. (2009). Nonclassic actions of vitamin D. J Clin Endocrinol Metab.
15 White JH. (2008). Vitamin D signaling, infectious diseases, and regulation of innate immunity. Infect Immun.
16 Mohr SB. (2009). A brief history of vitamin D and cancer prevention. Ann Epidemiol.
17 Dawson-Hughes B. (2008). Serum 25-hydroxyvitamin D and functional outcomes in the elderly. Am J Clin Nutr.
18 Buell JS, Dawson-Hughes B. (2008). Vitamin D and neurocognitive dysfunction: preventing “D”ecline?. Mol Aspects Med.
19 Quarles LD. (2008). Endocrine functions of bone in mineral metabolism regulation. J Clin Invest.
20 Hewison M. (2008). Vitamin D and innate immunity. Curr Opin Investig Drugs.
21 Hossein-nezhad A, Holick MF. (2013). Vitamin D for health: a global perspective. Mayo Clin Proc.
22 Bucher HC, Guyatt GH, Cook DJ, et al. (1999). Users' guides to the medical literature: XIX. Applying clinical trial results. A. How to use an article measuring the effect of an intervention on surrogate end points. Evidence-Based Medicine Working Group. JAMA.
23 Balk E, Chung M, Chew P, et al. (2005). Effects of Soy on Health Outcomes. Evidence Report/Technology Assessment No. 26.
24 Balk E, Chung M, Raman G, et al. (2006). B Vitamins and Berries and Age-Related Neurodegenerative Disorders. Evidence Report/Technology Assessment No. 134.
25 Balk E, Chung M, Lichtenstein A, et al. (2004). Effects of Omega-3 Fatty Acids on Cardiovascular Risk Factors and Intermediate Markers of Cardiovascular Disease. Evidence Report/Technology Assessment No. 93.
26 Ip S, Chung M, Raman G, et al. (2007). Breastfeeding and Maternal and Infant Health Outcomes in Developed Countries. Evidence Report/Technology Assessment No. 153.
27 Jordan H, Matthan N, Chung M, et al. (2004). Effects of omega-3 fatty acids on arrhythmogenic mechanisms in animal and isolated organ/cell culture studies. Evidence Report/Technology Assessment No. 92.
28 Wang C, Chung M, Lichtenstein A, et al. (2004). Effects of Omega-3 Fatty Acids on Cardiovascular Disease. Evidence Report/Technology Assessment No. 94.
29 Maclean CH, Newberry SJ, Mojica WA, et al. (2005). Effects of omega-3 fatty acids on cancer. Evid Rep Technol Assess (Summ).
30 Maclean CH, Issa AM, Newberry SJ, et al. (2005). Effects of omega-3 fatty acids on cognitive function with aging, dementia, and neurological diseases. Evid Rep Technol Assess (Summ).
31 Issa AM, Mojica WA, Morton SC, et al. (2006). The efficacy of omega-3 fatty acids on cognitive function in aging and dementia: a systematic review. Dement Geriatr Cogn Disord.
32 Crandall CJ, Newberry SJ, Diamant A, et al. (2012). Treatment To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis: Update of a 2007 Report. Comparative Effectiveness Review No. 53.
33 Holden JM, Lemar LE. (2008). Assessing vitamin D contents in foods and supplements: challenges and needs. Am J Clin Nutr.
34 Shea BJ, Grimshaw JM, Wells GA, et al. (2007). Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol.
35 Ballantyne JC, Carr DB, deFerranti S, et al. (1998). The comparative effects of postoperative analgesic therapies on pulmonary outcome: cumulative meta-analyses of randomized, controlled trials. Anesth Analg.
36 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
37 Higgins JP, Whitehead A, Turner RM, et al. (2001). Meta-analysis of continuous outcome data from individual patients. Stat Med.
38 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
39 Moher D, Schulz KF, Altman DG. (2003). The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomised trials. Clin Oral Investig.
40 von Elm E, Altman DG, Egger M, et al. (2007). The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. Lancet.
41 Chung M, Balk EM, Ip S, et al. (2009). Reporting of systematic reviews of micronutrients and health: a critical appraisal. Am J Clin Nutr.
42 Wagner CL, McNeil RB, Johnson DD, et al. (2013). Health characteristics and outcomes of two randomized vitamin D supplementation trials during pregnancy: a combined analysis. Journal of Steroid Biochemistry & Molecular Biology.
43 Kalra P, Das V, Agarwal A, et al. (2012). Effect of vitamin D supplementation during pregnancy on neonatal mineral homeostasis and anthropometry of the newborn and infant. Br J Nutr.
44 Roth DE, Al Mahmud A, Raqib R, et al. (2013). Randomized placebo-controlled trial of high-dose prenatal third-trimester vitamin D3 supplementation in Bangladesh: the AViDD trial. Nutr J.
45 Burris HH, Rifas-Shiman SL, Camargo CA, et al. (2012). Plasma 25-hydroxyvitamin D during pregnancy and small-for-gestational age in black and white infants. Ann Epidemiol.
46 Gernand AD, Simhan HN, Klebanoff MA, et al. (2013). Maternal serum 25-hydroxyvitamin D and measures of newborn and placental weight in a U.S. multicenter cohort study. J Clin Endocrinol Metab.
47 Brooke OG, Brown IR, Bone CD, et al. (1980). Vitamin D supplements in pregnant Asian women: effects on calcium status and fetal growth. BMJ.
48 El-Hajj FG, Nabulsi M, Tamim H, et al. (2006). Effect of vitamin D replacement on musculoskeletal parameters in school children: a randomized controlled trial. J Clin Endocrinol Metab.
49 Feliciano ES, Ho ML, Specker BL, et al. (1994). Seasonal and geographical variations in the growth rate of infants in China receiving increasing dosages of vitamin D supplements. J Trop Pediatr.
50 Marya RK, Rathee S, Dua V, et al. (1988). Effect of vitamin D supplementation during pregnancy on foetal growth. Indian J Med Res.
51 Maxwell JD, Ang L, Brooke OG, et al. (1981). Vitamin D supplements enhance weight gain and nutritional status in pregnant Asians. BJOG.
52 Wagner CL, Hulsey TC, Fanning D, et al. (2006). High-dose vitamin D3 supplementation in a cohort of breastfeeding mothers and their infants: a 6-month follow-up pilot study. Breastfeed Med.
53 Mallet E, Gugi B, Brunelle P, et al. (1986). Vitamin D supplementation in pregnancy: a controlled trial of two methods. Obstet Gynecol.
54 Marya RK, Rathee S, Lata V, et al. (1981). Effects of vitamin D supplementation in pregnancy. Gynecol Obstet Invest.
55 Gale CR, Robinson SM, Harvey NC, et al. (2008). Maternal vitamin D status during pregnancy and child outcomes. Eur J Clin Nutr.
56 Morley R, Carlin JB, Pasco JA, et al. (2006). Maternal 25-hydroxyvitamin D and parathyroid hormone concentrations and offspring birth size. J Clin Endocrinol Metab.
57 Wang L, Song Y, Manson JE, et al. (2012). Circulating 25-hydroxy-vitamin D and risk of cardiovascular disease: a meta-analysis of prospective studies. Circulation Circ Cardiovasc Qual Outcomes.
58 Bolland MJ, Bacon CJ, Horne AM, et al. (2010). Vitamin D insufficiency and health outcomes over 5 y in older women. Am J Clin Nutr.
59 Messenger W, Nielson CM, Li H, et al. (2012). Serum and dietary vitamin D and cardiovascular disease risk in elderly men: a prospective cohort study. Nutr Metab Cardiovasc Dis.
60 Welsh P, Doolin O, McConnachie A, et al. (2012). Circulating 25OHD, dietary vitamin D, PTH, and calcium associations with incident cardiovascular disease and mortality: the MIDSPAN Family Study. J Clin Endocrinol Metab.
61 Karakas M, Thorand B, Zierer A, et al. (2013). Low levels of serum 25-hydroxyvitamin D are associated with increased risk of myocardial infarction, especially in women: results from the MONICA/KORA Augsburg case-cohort study. J Clin Endocrinol Metab.
62 Robinson-Cohen C, Hoofnagle AN, Ix JH, et al. (2013). Racial differences in the association of serum 25-hydroxyvitamin D concentration with coronary heart disease events. JAMA.
63 Perna L, Schottker B, Holleczek B, et al. (2013). Serum 25-hydroxyvitamin d and incidence of fatal and nonfatal cardiovascular events: a prospective study with repeated measurements. J Clin Endocrinol Metab.
64 Hosseinpanah F, Yarjanli M, Sheikholeslami F, et al. (2011). Associations between vitamin D and cardiovascular outcomes; Tehran Lipid and Glucose Study. Atherosclerosis.
65 Kuhn T, Kaaks R, Teucher B, et al. (2013). Plasma 25-hydroxyvitamin D and its genetic determinants in relation to incident myocardial infarction and stroke in the European prospective investigation into cancer and nutrition (EPIC)-Germany study. PLoS ONE.
66 Trivedi DP, Doll R, Khaw KT. (2003). Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ.
67 Wang TJ, Pencina MJ, Booth SL, et al. (2008). Vitamin D deficiency and risk of cardiovascular disease. Circulation.
68 Giovannucci E, Liu Y, Hollis BW, et al. (2008). 25-hydroxyvitamin D and risk of myocardial infarction in men: a prospective study. Arch Intern Med.
69 Brondum-Jacobsen P, Benn M, Jensen GB, et al. (2012). 25-hydroxyvitamin d levels and risk of ischemic heart disease, myocardial infarction, and early death: population-based study and meta-analyses of 18 and 17 studies. Arterioscler Thromb Vasc Biol.
70 Eaton CB, Young A, Allison MA, et al. (2011). Prospective association of vitamin D concentrations with mortality in postmenopausal women: results from the Women's Health Initiative (WHI). Am J Clin Nutr.
71 Fiscella K, Franks P. (2010). Vitamin D, race, and cardiovascular mortality: findings from a national US sample. Ann Fam Med.
72 Ginde AA, Scragg R, Schwartz RS, et al. (2009). Prospective study of serum 25-hydroxyvitamin D level, cardiovascular disease mortality, and all-cause mortality in older U.S. adults. J Am Geriatr Soc.
73 Pilz S, Dobnig H, Nijpels G, et al. (2009). Vitamin D and mortality in older men and women. Clin Endocrinol (Oxf).
74 Signorello LB, Han X, Cai Q, et al. (2013). A prospective study of serum 25-hydroxyvitamin d levels and mortality among African Americans and non-African Americans. Am J Epidemiol.
75 Tomson J, Emberson J, Hill M, et al. (2013). Vitamin D and risk of death from vascular and non-vascular causes in the Whitehall study and meta-analyses of 12,000 deaths. Eur Heart J.
76 Schottker B, Haug U, Schomburg L, et al. (2013). Strong associations of 25-hydroxyvitamin D concentrations with all-cause, cardiovascular, cancer, and respiratory disease mortality in a large cohort study. Am J Clin Nutr.
77 Formiga F, Ferrer A, Megido MJ, et al. (2014). Low Serum Vitamin D is Not Associated with an Increase in Mortality in Oldest Old Subjects: The Octabaix Three-Year Follow-Up Study. Gerontology.
78 Deo R, Katz R, Shlipak MG, et al. (2011). Vitamin D, parathyroid hormone, and sudden cardiac death: results from the Cardiovascular Health Study. Hypertension.
79 Hutchinson MS, Grimnes G, Joakimsen RM, et al. (2010). Low serum 25-hydroxyvitamin D levels are associated with increased all-cause mortality risk in a general population: the Tromso study. Eur J Endocrinol.
80 Jassal SK, Chonchol M, von Muhlen D, et al. (2010). Vitamin d, parathyroid hormone, and cardiovascular mortality in older adults: the Rancho Bernardo study. Am J Med.
81 Kestenbaum B, Katz R, de Boer I, et al. (2011). Vitamin D, parathyroid hormone, and cardiovascular events among older adults. J Am Coll Cardiol.
82 Kilkkinen A, Knekt P, Aro A, et al. (2009). Vitamin D status and the risk of cardiovascular disease death. Am J Epidemiol.
83 Lin SW, Chen W, Fan JH, et al. (2012). Prospective study of serum 25-hydroxyvitamin D concentration and mortality in a Chinese population. Am J Epidemiol.
84 Michaelsson K, Baron JA, Snellman G, et al. (2010). Plasma vitamin D and mortality in older men: a community-based prospective cohort study. Am J Clin Nutr.
85 Melamed ML, Michos ED, Post W, et al. (2008). 25-hydroxyvitamin D levels and the risk of mortality in the general population. Arch Int Med.
86 Skaaby T, Husemoen LL, Pisinger C, et al. (2013). Vitamin D status and incident cardiovascular disease and all-cause mortality: a general population study. Endocrine.
87 de Boer IH, Levin G, Robinson-Cohen C, et al. (2012). Serum 25-hydroxyvitamin D concentration and risk for major clinical disease events in a community-based population of older adults: a cohort study. Ann Intern Med.
88 Schierbeck LL, Rejnmark L, Tofteng CL, et al. (2012). Vitamin D deficiency in postmenopausal, healthy women predicts increased cardiovascular events: a 16-year follow-up study. Eur J Endocrinol.
89 Marniemi J, Alanen E, Impivaara O, et al. (2005). Dietary and serum vitamins and minerals as predictors of myocardial infarction and stroke in elderly subjects. Nutr Metab Cardiovasc Dis.
90 Sun Q, Pan A, Hu FB, et al. (2012). 25-Hydroxyvitamin D levels and the risk of stroke: a prospective study and meta-analysis. Stroke.
91 Brodin E, Lerstad G, Grimnes G, et al. (2013). Serum levels of vitamin D are not associated with future risk of venous thromboembolism. The Tromso Study. Thromb Haemost.
92 Brondum-Jacobsen P, Nordestgaard BG, Schnohr P, et al. (2013). 25-hydroxyvitamin D and symptomatic ischemic stroke: an original study and meta-analysis. Annals of Neurology.
93 Semba RD, Houston DK, Bandinelli S, et al. (2010). Relationship of 25-hydroxyvitamin D with all-cause and cardiovascular disease mortality in older community-dwelling adults. J Clin Nutr.
94 Heikkinen AM, Tuppurainen MT, Niskanen L, et al. (1997). Long-term vitamin D3 supplementation may have adverse effects on serum lipids during postmenopausal hormone replacement therapy. Eur J Endocrinol.
95 Sneve M, Figenschau Y, Jorde R. (2008). Supplementation with cholecalciferol does not result in weight reduction in overweight and obese subjects. Eur J Endocrinol.
96 Nagpal J, Pande JN, Bhartia A. (2009). A double-blind, randomized, placebo-controlled trial of the short-term effect of vitamin D3 supplementation on insulin sensitivity in apparently healthy, middle-aged, centrally obese men. Diabet Med.
97 Ordonez-Mena JM, Schottker B, Haug U, et al. (2013). Serum 25-hydroxyvitamin d and cancer risk in older adults: results from a large German prospective cohort study. Cancer Epidemiol Biomarkers Prev.
98 Cawthon PM, Parimi N, Barrett-Connor E, et al. (2010). Serum 25-hydroxyvitamin D, parathyroid hormone, and mortality in older men. J Clin Endocrinol Metab.
99 Afzal S, Bojesen SE, Nordestgaard BG. (2013). Low plasma 25-hydroxyvitamin D and risk of tobacco-related cancer. Clin Chem.
100 Freedman DM, Looker AC, Abnet CC, et al. (2010). Serum 25-hydroxyvitamin D and cancer mortality in the NHANES III study (1988-2006). Cancer Res.
101 Fedirko V, Riboli E, Tjonneland A, et al. (2012). Prediagnostic 25-hydroxyvitamin D, VDR and CASR polymorphisms, and survival in patients with colorectal cancer in western European ppulations. Cancer Epidemiol Biomarkers Prev.
102 Lappe JM, Travers-Gustafson D, Davies KM, et al. (2007). Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr.
103 Freedman DM, Looker AC, Chang SC, et al. (2007). Prospective study of serum vitamin D and cancer mortality in the United States. J Natl Cancer Inst.
104 Barnett CM, Nielson CM, Shannon J, et al. (2010). Serum 25-OH vitamin D levels and risk of developing prostate cancer in older men. Cancer Causes Control.
105 Brandstedt J, Almquist M, Manjer J, et al. (2012). Vitamin D, PTH, and calcium and the risk of prostate cancer: a prospective nested case-control study. Cancer Causes Control.
106 Meyer HE, Robsahm TE, Bjorge T, et al. (2013). Vitamin D, season, and risk of prostate cancer: a nested case-control study within Norwegian health studies. Am J Clin Nutr.
107 Park SY, Cooney RV, Wilkens LR, et al. (2010). Plasma 25-hydroxyvitamin D and prostate cancer risk: the multiethnic cohort. Eur J Cancer.
108 Shui IM, Mucci LA, Kraft P, et al. (2012). Vitamin D-related genetic variation, plasma vitamin D, and risk of lethal prostate cancer: a prospective nested case-control study. J Natl Cancer Inst.
109 Travis RC, Crowe FL, Allen NE, et al. (2009). Serum vitamin D and risk of prostate cancer in a case-control analysis nested within the European Prospective Investigation into Cancer and Nutrition (EPIC). Am J Epidemiol.
110 Ahn J, Peters U, Albanes D, et al. (2008). Serum vitamin D concentration and prostate cancer risk: a nested case-control study. J Natl Cancer Inst.
111 Ahonen MH, Tenkanen L, Teppo L, et al. (2000). Prostate cancer risk and prediagnostic serum 25-hydroxyvitamin D levels (Finland). Cancer Causes Control.
112 Baron JA, Beach M, Wallace K, et al. (2005). Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev.
113 Braun MM, Helzlsouer KJ, Hollis BW, et al. (1995). Prostate cancer and prediagnostic levels of serum vitamin D metabolites (Maryland, United States). Cancer Causes Control.
114 Corder EH, Guess HA, Hulka BS, et al. (1993). Vitamin D and prostate cancer: a prediagnostic study with stored sera. Cancer Epidemiol Biomarkers Prev.
115 Jacobs ET, Giuliano AR, Martinez ME, et al. (2004). Plasma levels of 25-hydroxyvitamin D, 1,25-dihydroxyvitamin D and the risk of prostate cancer. J Steroid Biochem Mol Biol.
116 Li H, Stampfer MJ, Hollis JB, et al. (2007). A prospective study of plasma vitamin D metabolites, vitamin D receptor polymorphisms, and prostate cancer. PLoS Medicine/Public Library of Science.
117 Mikhak B, Hunter DJ, Spiegelman D, et al. (2007). Vitamin D receptor (VDR) gene polymorphisms and haplotypes, interactions with plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D, and prostate cancer risk. Prostate.
118 Nomura AM, Stemmermann GN, Lee J, et al. (1998). Serum vitamin D metabolite levels and the subsequent development of prostate cancer (Hawaii, United States). Cancer Causes Control.
119 Platz EA, Leitzmann MF, Hollis BW, et al. (2004). Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and subsequent risk of prostate cancer. Cancer Causes Control.
120 Tuohimaa P, Tenkanen L, Ahonen M, et al. (2004). Both high and low levels of blood vitamin D are associated with a higher prostate cancer risk: a longitudinal, nested case-control study in the Nordic countries. Int J Cancer.
121 Tuohimaa P, Tenkanen L, Syvala H, et al. (2007). Interaction of factors related to the metabolic syndrome and vitamin D on risk of prostate cancer. Cancer Epidemiol Biomarkers Prev.
122 Gann PH, Ma J, Hennekens CH, et al. (1996). Circulating vitamin D metabolites in relation to subsequent development of prostate cancer. Cancer Epidemiol Biomarkers Prev.
123 Jenab M, Bueno-de-Mesquita HB, Ferrari P, et al. (2010). Association between pre-diagnostic circulating vitamin D concentration and risk of colorectal cancer in European populations:a nested case-control study. BMJ.
124 Neuhouser ML, Manson JE, Millen A, et al. (2012). The influence of health and lifestyle characteristics on the relation of serum 25-hydroxyvitamin D with risk of colorectal and breast cancer in postmenopausal women. Am J Epidemiol.
125 Woolcott CG, Wilkens LR, Nomura AMY, et al. (2010). Plasma 25-hydroxyvitamin D levels and the risk of colorectal cancer: the multiethnic cohort study. Cancer Epidemiol Biomarkers Prev.
126 Lee JE, Li H, Chan AT, et al. (2011). Circulating levels of vitamin D and colon and rectal cancer: the Physicians' Health Study and a meta-analysis of prospective studies. Cancer Prev Res (Phila).
127 Tangrea J, Helzlsouer K, Pietinen P, et al. (1997). Serum levels of vitamin D metabolites and the subsequent risk of colon and rectal cancer in Finnish men. Cancer Causes Control.
128 Otani T, Iwasaki M, Sasazuki S, et al. (2007). Plasma vitamin D and risk of colorectal cancer: the Japan Public Health Center-Based Prospective Study. Br J Cancer.
129 Wu K, Feskanich D, Fuchs CS, et al. (2007). A nested case control study of plasma 25-hydroxyvitamin D concentrations and risk of colorectal cancer. J Natl Cancer Inst.
130 Feskanich D, Ma J, Fuchs CS, et al. (2004). Plasma vitamin D metabolites and risk of colorectal cancer in women. Cancer Epidemiol Biomarkers Prev.
131 Wactawski-Wende J, Kotchen JM, Anderson GL, et al. (2006). Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med.
132 Garland CF, Comstock GW, Garland FC, et al. (1989). Serum 25-hydroxyvitamin D and colon cancer: eight-year prospective study. Lancet.
133 Braun MM, Helzlsouer KJ, Hollis BW, et al. (1995). Colon cancer and serum vitamin D metabolite levels 10-17 years prior to diagnosis. Am J Epidemiol.
134 Platz EA, Hankinson SE, Hollis BW, et al. (2000). Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and adenomatous polyps of the distal colorectum. Cancer Epidemiol Biomarkers Prev.
135 Eliassen AH, Spiegelman D, Hollis BW, et al. (2011). Plasma 25-hydroxyvitamin D and risk of breast cancer in the Nurses' Health Study II. Breast Cancer Res.
136 McCullough ML, Stevens VL, Patel R, et al. (2009). Serum 25-hydroxyvitamin D concentrations and postmenopausal breast cancer risk: a nested case control study in the Cancer Prevention Study-II Nutrition Cohort. Breast Cancer Res.
137 Almquist M, Bondeson AG, Bondeson L, et al. (2010). Serum levels of vitamin D, PTH and calcium and breast cancer risk-a prospective nested case-control study. Int J Cancer.
138 Engel P, Fagherazzi G, Boutten A, et al. (2010). Serum 25(OH) vitamin D and risk of breast cancer: a nested case-control study from the French E3N cohort. Cancer Epidemiol Biomarkers Prev.
139 Rejnmark L, Tietze A, Vestergaard P, et al. (2009). Reduced prediagnostic 25-hydroxyvitamin D levels in women with breast cancer: a nested case-control study. Cancer Epidemiol Biomarkers Prev.
140 Bertone-Johnson ER, McTiernan A, Thomson CA, et al. (2012). Vitamin D and calcium supplementation and one-year change in mammographic density in the women's health initiative calcium and vitamin D trial. Cancer Epidemiol Biomarkers Prev.
141 Green AK, Hankinson SE, Bertone-Johnson ER, et al. (2010). Mammographic density, plasma vitamin D levels and risk of breast cancer in postmenopausal women. Int J Cancer.
142 Bertone-Johnson ER, Chen WY, Holick MF, et al. (2005). Plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D and risk of breast cancer. Cancer Epidemiol Biomarkers Prev.
143 Freedman DM, Chang SC, Falk RT, et al. (2008). Serum levels of vitamin D metabolites and breast cancer risk in the prostate, lung, colorectal, and ovarian cancer screening trial. Cancer Epidemiol Biomarkers Prev.
144 Jacobs ET, Thomson CA, Flatt SW, et al. (2011). Vitamin D and breast cancer recurrence in the Women's Healthy Eating and Living (WHEL) Study. Am J Clin Nutr.
145 Kuhn T, Kaaks R, Becker S, et al. (2013). Plasma 25-hydroxyvitamin D and the risk of breast cancer in the European prospective investigation into cancer and nutrition: a nested case-control study. Int J Cancer.
146 Stolzenberg-Solomon RZ, Jacobs EJ, Arslan AA, et al. (2010). Circulating 25-hydroxyvitamin D and risk of pancreatic cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol.
147 Stolzenberg-Solomon RZ, Vieth R, Azad A, et al. (2006). A prospective nested case-control study of vitamin D status and pancreatic cancer risk in male smokers. Cancer Res.
148 Stolzenberg-Solomon RZ, Hayes RB, Horst RL, et al. (2009). Serum vitamin D and risk of pancreatic cancer in the prostate, lung, colorectal, and ovarian screening trial. Cancer Res.
149 Manaseki-Holland S, Maroof Z, Bruce J, et al. (2012). Effect on the incidence of pneumonia of vitamin D supplementation by quarterly bolus dose to infants in Kabul: a randomised controlled superiority trial. Lancet.
150 Li-Ng M, Aloia JF, Pollack S, et al. (2009). A randomized controlled trial of vitamin D3 supplementation for the prevention of symptomatic upper respiratory tract infections. Epidemiol Infect.
151 Laaksi I, Ruohola JP, Mattila V, et al. (2010). Vitamin D supplementation for the prevention of acute respiratory tract infection: a randomized, double-blinded trial among young Finnish men. J Infect Dis.
152 Murdoch DR, Slow S, Chambers ST, et al. (2012). Effect of vitamin D3 supplementation on upper respiratory tract infections in healthy adults: the VIDARIS randomized controlled trial. JAMA.
153 Belderbos ME, Houben ML, Wilbrink B, et al. (2011). Cord blood vitamin D deficiency is associated with respiratory syncytial virus bronchiolitis. Pediatrics.
154 Camargo CA, Ingham T, Wickens K, et al. (2011). Cord-blood 25-hydroxyvitamin D levels and risk of respiratory infection, wheezing, and asthma. Pediatrics.
155 Shin YH, Yu J, Kim KW, et al. (2013). Association between cord blood 25-hydroxyvitamin D concentrations and respiratory tract infections in the first 6 months of age in a Korean population: a birth cohort study (COCOA). Korean J Pediatr.
156 Magnus MC, Stene LC, Haberg SE, et al. (2013). Prospective study of maternal mid-pregnancy 25-hydroxyvitamin D level and early childhood respiratory disorders. Paediatr Perinat Epidemiol.
157 Thornton KA, Marin C, Mora-Plazas M, et al. (2013). Vitamin D deficiency associated with increased incidence of gastrointestinal and ear infections in school-age children. Pediatr Infect Dis J.
158 Science M, Maguire JL, Russell ML, et al. (2013). Low serum 25-hydroxyvitamin D level and risk of upper respiratory tract infection in children and adolescents. Clin Infect Dis.
159 Sabetta JR, DePetrillo P, Cipriani RJ, et al. (2010). Serum 25-hydroxyvitamin d and the incidence of acute viral respiratory tract infections in healthy adults. PLoS ONE.
160 Aregbesola A, Voutilainen S, Nurmi T, et al. (2013). Serum 25-hydroxyvitamin D3 and the risk of pneumonia in an ageing general population. J Epidemiol Community Health.
161 Goldring ST, Griffiths CJ, Martineau AR, et al. (2013). Prenatal vitamin d supplementation and child respiratory health: a randomised controlled trial. PLoS ONE.
162 Jones AP, Palmer D, Zhang G, et al. (2012). Cord blood 25-hydroxyvitamin D3 and allergic disease during infancy. Pediatrics.
163 Pike KC, Inskip HM, Robinson S, et al. (2012). Maternal late-pregnancy serum 25-hydroxyvitamin D in relation to childhood wheeze and atopic outcomes. Thorax.
164 van Oeffelen AAM, Bekkers MBM, Smit HA, et al. (2011). Serum micronutrient concentrations and childhood asthma: the PIAMA birth cohort study. Pediatr Allergy Immunol.
165 Tolppanen AM, Sayers A, Granell R, et al. (2013). Prospective association of 25-hydroxyvitamin d3 and d2 with childhood lung function, asthma, wheezing, and flexural dermatitis. Epidemiology.
166 Mai XM, Langhammer A, Camargo CA, et al. (2012). Serum 25-hydroxyvitamin D levels and incident asthma in adults: the HUNT Study. Am J Epidemiol.
167 Racovan M, Walitt B, Collins CE, et al. (2012). Calcium and vitamin D supplementation and incident rheumatoid arthritis: the Women's Health Initiative Calcium plus Vitamin D trial. Rheumatolog Int.
168 Munger KL, Levin LI, Massa J, et al. (2013). Preclinical serum 25-hydroxyvitamin D levels and risk of type 1 diabetes in a cohort of US military personnel. Am J Epidemiol.
169 Sorensen IM, Joner G, Jenum PA, et al. (2012). Maternal serum levels of 25-hydroxy-vitamin D during pregnancy and risk of type 1 diabetes in the offspring. Diabetes.
170 Salzer J, Hallmans G, Nystrom M, et al. (2012). Vitamin D as a protective factor in multiple sclerosis. Neurology.
171 Simpson M, Brady H, Yin X, et al. (2011). No association of vitamin D intake or 25-hydroxyvitamin D levels in childhood with risk of islet autoimmunity and type 1 diabetes: the Diabetes Autoimmunity Study in the Young (DAISY). Diabetologia.
172 Wei SQ, Audibert F, Luo ZC, et al. (2013). Maternal plasma 25-hydroxyvitamin D levels, angiogenic factors, and preeclampsia. Am J Obstet Gynecol.
173 Scholl TO, Chen X, Stein TP. (2013). Vitamin D, secondary hyperparathyroidism, and preeclampsia. Am J Clin Nutr.
174 Wei SQ, Audibert F, Hidiroglou N, et al. (2012). Longitudinal vitamin D status in pregnancy and the risk of pre-eclampsia. BJOG.
175 Baker AM, Haeri S, Camargo CA, et al. (2010). A nested case-control study of midgestation vitamin D deficiency and risk of severe preeclampsia. J Clin Endocrinol Metab.
176 Woodham PC, Brittain JE, Baker AM, et al. (2011). Midgestation maternal serum 25-hydroxyvitamin D level and soluble fms-like tyrosine kinase 1/placental growth factor ratio as predictors of severe preeclampsia. Hypertension.
177 Shand AW, Nassar N, Von Dadelszen P, et al. (2010). Maternal vitamin D status in pregnancy and adverse pregnancy outcomes in a group at high risk for pre-eclampsia. BJOG.
178 Powe CE, Seely EW, Rana S, et al. (2010). First trimester vitamin D, vitamin D binding protein, and subsequent preeclampsia. Hypertension.
179 Bodnar LM, Catov JM, Simhan HN, et al. (2007). Maternal vitamin D deficiency increases the risk of preeclampsia. J Clin Endocrinol Metab.
180 Bodnar LM, Catov JM, Zmuda JM, et al. (2010). Maternal serum 25-hydroxyvitamin D concentrations are associated with small-for-gestational age births in white women. J Nutr.
181 Bodnar LM, Rouse DJ, Momirova V, et al. (2013). Maternal 25-hydroxyvitamin d and preterm birth in twin gestations. Obstet Gynecol.
182 Baker AM, Haeri S, Camargo CA, et al. (2011). A nested case-control study of first-trimester maternal vitamin D status and risk for spontaneous preterm birth. Am J Perinatol.
183 Bunout D, Barrera G, Leiva L, et al. (2006). Effects of vitamin D supplementation and exercise training on physical performance in Chilean vitamin D deficient elderly subjects. Exp Gerontol.
184 Burleigh E, McColl J, Potter J. (2007). Does vitamin D stop inpatients falling? A randomised controlled trial. Age Ageing.
185 Lyons RA, Johansen A, Brophy S, et al. (2007). Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int.
186 Pfeifer M, Begerow B, Minne HW, et al. (2009). Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int.
187 Prince RL, Austin N, Devine A, et al. (2008). Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med.
188 Zhu K, Austin N, Devine A, et al. (2010). A randomized controlled trial of the effects of vitamin D on muscle strength and mobility in older women with vitamin D insufficiency. J Am Geriatr Soc.
189 Michael YL, Smit E, Seguin R, et al. (2011). Serum 25-hydroxyvitamin D and physical performance in postmenopausal women. J Womens Health (Larchmt).
190 Dam TTL, von Muhlen D, Barrett-Connor EL. (2009). Sex-specific association of serum vitamin D levels with physical function in older adults. Osteoporos Int.
191 Scott D, Blizzard L, Fell J, et al. (2010). A prospective study of the associations between 25-hydroxy-vitamin D, sarcopenia progression and physical activity in older adults. Clin Endocrinol (Oxf).
192 Houston DK, Tooze JA, Neiberg RH, et al. (2012). 25-hydroxyvitamin D status and change in physical performance and strength in older adults: the Health, Aging, and Body Composition Study. Am J Epidemiol.
193 Menant JC, Close JCT, Delbaere K, et al. (2012). Relationships between serum vitamin D levels, neuromuscular and neuropsychological function and falls in older men and women. Osteoporos Int.
194 Barbour KE, Houston DK, Cummings SR, et al. (2012). Calciotropic hormones and the risk of hip and nonspine fractures in older adults: the Health ABC Study. J Bone Miner Res.
195 Cauley JA, Lacroix AZ, Wu L, et al. (2008). Serum 25-hydroxyvitamin D concentrations and risk for hip fractures. Ann Intern Med.
196 Looker AC. (2013). Serum 25-hydroxyvitamin D and risk of major osteoporotic fractures in older U.S. adults. J Bone Miner Res.
197 Holvik K, Ahmed LA, Forsmo S, et al. (2013). Low serum levels of 25-hydroxyvitamin D predict hip fracture in the elderly: a NOREPOS study. J Clin Endocrinol Metab.
198 Barrett-Connor E, Laughlin GA, Li H, et al. (2012). The association of concurrent vitamin D and sex hormone deficiency with bone loss and fracture risk in older men: the osteoporotic fractures in men (MrOS) study. J Bone Miner Res.
199 Cauley JA, Danielson ME, Boudreau R, et al. (2011). Serum 25-hydroxyvitamin D and clinical fracture risk in a multiethnic cohort of women: the Women's Health Initiative (WHI). J Bone Miner Res.
200 Rouzi AA, Al-Sibiani SA, Al-Senani NS, et al. (2012). Independent predictors of all osteoporosis-related fractures among healthy Saudi postmenopausal women: the CEOR Study. Bone.
201 Lips P, Binkley N, Pfeifer M, et al. (2010). Once-weekly dose of 8400 IU vitamin D(3) compared with placebo: effects on neuromuscular function and tolerability in older adults with vitamin D insufficiency. Am J Clin Nutr.
202 Ward KA, Das G, Roberts SA, et al. (2010). A randomized, controlled trial of vitamin D supplementation upon musculoskeletal health in postmenarchal females. J Clin Endocrinol Metab.
203 Burgi AA, Gorham ED, Garland CF, et al. (2011). High serum 25-hydroxyvitamin D is associated with a low incidence of stress fractures. J Bone Miner Res.
204 Autier P, Gandini S. (2007). Vitamin D supplementation and total mortality: a meta-analysis of randomized controlled trials. Arch Intern Med.
205 Avenell A, Gillespie WJ, Gillespie LD, et al. (2008). Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev.
206 Schleithoff SS, Zittermann A, Tenderich G, et al. (2006). Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial. Am J Clin Nutr.
207 Flicker L, MacInnis R, Stein M, et al. (2004). Should all older people in residential care receive Vitamin D to prevent falls? Results of a randomized trial. J Bone Miner Res.
208 Meyer HE, Smedshaug GB, Kvaavik E, et al. (2002). Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res.
209 Harwood RH, Sahota O, Gaynor K, et al. (2004). A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing.
210 Latham NK, Anderson CS, Lee A, et al. (2003). A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc.
211 Johansson H, Oden A, Kanis J, et al. (2012). Low serum vitamin D is associated with increased mortality in elderly men: MrOS Sweden. Osteoporos Int.
212 Kritchevsky SB, Tooze JA, Neiberg RH, et al. (2012). 25-Hydroxyvitamin D, parathyroid hormone, and mortality in black and white older adults: the health ABC study. J Clin Endocrinol Metab.
213 Smit E, Crespo CJ, Michael Y, et al. (2012). The effect of vitamin D and frailty on mortality among non-institutionalized US older adults. J Clin Nutr.
214 Szulc P, Claustrat B, Delmas PD. (2009). Serum concentrations of 17beta-E2 and 25-hydroxycholecalciferol (25OHD) in relation to all-cause mortality in older men--the MINOS study. Clin Endocrinol (Oxf).
215 Szulc P, Maurice C, Marchand F, et al. (2009). Increased bone resorption is associated with higher mortality in community-dwelling men >or=50 years of age: the MINOS study. J Bone Miner Res.
216 Virtanen JK, Nurmi T, Voutilainen S, et al. (2011). Association of serum 25-hydroxyvitamin D with the risk of death in a general older population in Finland. Eur J Nutr.
217 Wong YY, McCaul KA, Yeap BB, et al. (2013). Low vitamin D status is an independent predictor of increased frailty and all-cause mortality in older men: the Health in Men Study. J Clin Endocrinol Metab.
218 Sempos CT, Durazo-Arvizu RA, Dawson-Hughes B, et al. (2013). Is there a reverse J-shaped association between 25-hydroxyvitamin D and all-cause mortality? Results from the U.S. nationally representative NHANES. J Clin Endocrinol Metab.
219 Jia X, Aucott LS, McNeill G. (2007). Nutritional status and subsequent all-cause mortality in men and women aged 75 years or over living in the community. Br J Nutr.
220 Sambrook PN, Chen JS, March LM, et al. (2004). Serum parathyroid hormone is associated with increased mortality independent of 25-hydroxy vitamin d status, bone mass, and renal function in the frail and very old: a cohort study. J Clin Endocrinol Metab.
221 Sambrook PN, Chen CJ, March L, et al. (2006). High bone turnover is an independent predictor of mortality in the frail elderly. J Bone Miner Res.
222 Visser M, Deeg DJ, Puts MT, et al. (2006). Low serum concentrations of 25-hydroxyvitamin D in older persons and the risk of nursing home admission. Am J Clin Nutr.
223 Anderson JL, May HT, Horne BD, et al. (2010). Relation of vitamin D deficiency to cardiovascular risk factors, disease status, and incident events in a general healthcare population. Am J Cardiol.
224 Wang L, Ma J, Manson JE, et al. (2013). A prospective study of plasma vitamin D metabolites, vitamin D receptor gene polymorphisms, and risk of hypertension in men. Eur J Nutr.
225 Forman JP, Giovannucci E, Holmes MD, et al. (2007). Plasma 25-hydroxyvitamin D levels and risk of incident hypertension. Hypertension.
226 Forman JP, Curhan GC, Taylor EN. (2008). Plasma 25-hydroxyvitamin D levels and risk of incident hypertension among young women. Hypertension.
227 Forman JP, Scott JB, Ng K, et al. (2013). Effect of vitamin d supplementation on blood pressure in blacks. Hypertension.
228 Toxqui L, Blanco-Rojo R, Wright I, et al. (2013). Changes in blood pressure and lipid levels in young women consuming a vitamin d-fortified skimmed milk: a randomised controlled trial. Nutrients.
229 Gepner AD, Ramamurthy R, Krueger DC, et al. (2012). A prospective randomized controlled trial of the effects of vitamin D supplementation on cardiovascular disease risk. PLoS ONE.
230 Jorde R, Sneve M, Torjesen P, et al. (2010). No improvement in cardiovascular risk factors in overweight and obese subjects after supplementation with vitamin D3 for 1 year. J Intern Med.
231 Wood AD, Secombes KR, Thies F, et al. (2012). Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab.
232 Zhu W, Cai D, Wang Y, et al. (2013). Calcium plus vitamin D3 supplementation facilitated Fat loss in overweight and obese college students with very-low calcium consumption: a randomized controlled trial. Nutr J.
233 Daly RM, Nowson CA. (2009). Long-term effect of calcium-vitamin D(3) fortified milk on blood pressure and serum lipid concentrations in healthy older men. Eur J Clin Nutr.
234 Salehpour A, Shidfar F, Hosseinpanah F, et al. (2012). Vitamin D3 and the risk of CVD in overweight and obese women: a randomised controlled trial. Br J Nutr.
235 Witham MD, Adams F, Kabir G, et al. (2013). Effect of short-term vitamin D supplementation on markers of vascular health in South Asian women living in the UK--a randomised controlled trial. Atherosclerosis.
236 Wamberg L, Kampmann U, Stodkilde-Jorgensen H, et al. (2013). Effects of vitamin D supplementation on body fat accumulation, inflammation, and metabolic risk factors in obese adults with low vitamin D levels—results from a randomized trial. European J Intern Med.
237 Scragg R, Khaw KT, Murphy S. (1995). Effect of winter oral vitamin D3 supplementation on cardiovascular risk factors in elderly adults. Euro J Clin Nutr.
238 Pfeifer M, Begerow B, Minne HW, et al. (2001). Effects of a short-term vitamin D(3) and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. J Clin Endocrinol Metab.
239 Holmlund-Suila E, Viljakainen H, Hytinantti T, et al. (2012). High-dose vitamin d intervention in infants--effects on vitamin d status, calcium homeostasis, and bone strength. J Clin Endocrinol Metab.
240 Khadilkar AV, Sayyad MG, Sanwalka NJ, et al. (2010). Vitamin D supplementation and bone mass accrual in underprivileged adolescent Indian girls. Asia Pac J Clin Nutr.
241 Grimnes G, Joakimsen R, Figenschau Y, et al. (2012). The effect of high-dose vitamin D on bone mineral density and bone turnover markers in postmenopausal women with low bone mass--a randomized controlled 1-year trial. Osteoporos Int.
242 Iuliano-Burns S, Ayton J, Hillam S, et al. (2012). Skeletal and hormonal responses to vitamin D supplementation during sunlight deprivation in Antarctic expeditioners. Osteoporos Int.
243 Jorde R, Sneve M, Torjesen PA, et al. (2010). No significant effect on bone mineral density by high doses of vitamin D3 given to overweight subjects for one year. Nutr J.
244 Nieves JW, Cosman F, Grubert E, et al. (2012). Skeletal effects of vitamin D supplementation in postmenopausal black women. Calcif Tissue Int.
245 Macdonald HM, Wood AD, Aucott LS, et al. (2013). Hip bone loss is attenuated with 1000 IU but not 400 IU daily vitamin D3: a 1-year double-blind RCT in postmenopausal women. J Bone Miner Res.
246 Andersen R, Mølgaard C, Skovgaard LT, et al. (2008). Effect of vitamin D supplementation on bone and vitamin D status among Pakistani immigrants in Denmark: a randomised double-blinded placebo-controlled intervention study. The Br J Nutr.
247 Zhu K, Bruce D, Austin N, et al. (2008). Randomized controlled trial of the effects of calcium with or without vitamin D on bone structure and bone-related chemistry in elderly women with vitamin D insufficiency. J Bone Miner Res.
248 Molgaard C, Larnkjaer A, Cashman KD, et al. (2010). Does vitamin D supplementation of healthy Danish Caucasian girls affect bone turnover and bone mineralization?. Bone.
249 Hsia J, Heiss G, Ren H, et al. (2007). Calcium/vitamin D supplementation and cardiovascular events. Circulation.
250 LaCroix AZ, Kotchen J, Anderson G, et al. (2009). Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women's Health Initiative calcium-vitamin D randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
251 Caan B, Neuhouser M, Aragaki A, et al. (2007). Calcium plus vitamin D supplementation and the risk of postmenopausal weight gain. Arch Intern Med.
252 Major GC, Alarie F, Dore J, et al. (2007). Supplementation with calcium + vitamin D enhances the beneficial effect of weight loss on plasma lipid and lipoprotein concentrations. Am J Clin Nutr.
253 Brunner RL, Wactawski-Wende J, Caan BJ, et al. (2011). The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women's Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutrition and cancer.
254 Ding EL, Mehta S, Fawzi WW, et al. (2008). Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women's Health Initiative randomized trial. Int J Cancer.
255 Grau MV, Baron JA, Sandler RS, et al. (2003). Vitamin D, calcium supplementation, and colorectal adenomas: results of a randomized trial. J Natl Cancer Inst.
256 Chlebowski RT, Johnson KC, Kooperberg C, et al. (2008). Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst.
257 Marya RK, Rathee S, Manrow M. (1987). Effect of calcium and vitamin D supplementation on toxaemia of pregnancy. Gynecol Obstet Invest.
258 Brunner RL, Cochrane B, Jackson RD, et al. (2008). Calcium, vitamin D supplementation, and physical function in the Women's Health Initiative. Journal of the American Dietetic Association.
259 Lappe J, Cullen D, Haynatzki G, et al. (2008). Calcium and vitamin d supplementation decreases incidence of stress fractures in female navy recruits. J Bone Miner Res.
260 Salovaara K, Tuppurainen M, Karkkainen M, et al. (2010). Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial—the OSTPRE-FPS. J Bone Miner Res.
261 Kukuljan S, Nowson CA, Sanders K, et al. (2009). Effects of resistance exercise and fortified milk on skeletal muscle mass, muscle size, and functional performance in middle-aged and older men: an 18-mo randomized controlled trial. Journal of applied physiology (Bethesda).
262 Karkkainen MK, Tuppurainen M, Salovaara K, et al. (2010). Does daily vitamin D 800 IU and calcium 1000 mg supplementation decrease the risk of falling in ambulatory women aged 65-71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas.
263 Björkman M, Sorva A, Risteli J, et al. (2008). Vitamin D supplementation has minor effects on parathyroid hormone and bone turnover markers in vitamin D-deficient bedridden older patients. Age and ageing.
264 Jackson RD, Lacroix AZ, Gass M, et al. (2006). Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med.
265 Margolis KL, Ray RM, Horn L, et al. (2008). Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension.
266 Zhu K, Greenfield H, Du X, et al. (2008). Effects of two years' milk supplementation on size-corrected bone mineral density of Chinese girls. Asia Pac J Clin Nutr.
267 Islam MZ, Shamim AA, Viljakainen HT, et al. (2010). Effect of vitamin D, calcium and multiple micronutrient supplementation on vitamin D and bone status in Bangladeshi premenopausal garment factory workers with hypovitaminosis D: a double-blinded, randomised, placebo-controlled 1-year intervention. Br J Nutr.
268 Jackson RD, Wright NC, Beck TJ, et al. (2011). Calcium plus vitamin D supplementation has limited effects on femoral geometric strength in older postmenopausal women: the Women's Health Initiative. Calcif Tissue Int.
269 Karkkainen M, Tuppurainen M, Salovaara K, et al. (2010). Effect of calcium and vitamin D supplementation on bone mineral density in women aged 65-71years: a 3-year randomized population-based trial (OSTPRE-FPS). Osteoporos Int.
270 Moschonis G, Katsaroli I, Lyritis GP, et al. (2010). The effects of a 30-month dietary intervention on bone mineral density: the Postmenopausal Health Study. Br J Nutr.
271 Moschonis G, Kanellakis S, Papaioannou N, et al. (2011). Possible site-specific effect of an intervention combining nutrition and lifestyle counselling with consumption of fortified dairy products on bone mass: the Postmenopausal Health Study II. J Bone Miner Metab.
272 Kukuljan S, Nowson CA, Sanders KM, et al. (2011). Independent and combined effects of calcium-vitamin D3 and exercise on bone structure and strength in older men: an 18-month factorial design randomized controlled trial. J Clin Endocrinol Metab.
273 Cheng S, Lyytikainen A, Kroger H, et al. (2005). Effects of calcium, dairy product, and vitamin D supplementation on bone mass accrual and body composition in 10-12-y-old girls: a 2-y randomized trial. Am J Clin Nutr.
274 Bolton-Smith C, McMurdo ME, Paterson CR, et al. (2007). Two-year randomized controlled trial of vitamin K1 (phylloquinone) and vitamin D3 plus calcium on the bone health of older women. J Bone Miner Res.
275 Zhu K, Devine A, Dick IM, et al. (2008). Effects of calcium and vitamin D supplementation on hip bone mineral density and calcium-related analytes in elderly ambulatory Australian women: a five-year randomized controlled trial. J Clin Endocrinol Metab.
276 Moschonis G, Manios Y. (2006). Skeletal site-dependent response of bone mineral density and quantitative ultrasound parameters following a 12-month dietary intervention using dairy products fortified with calcium and vitamin D: the Postmenopausal Health Study. Br J Nutr.
277 Autier P, Gandini S, Mullie P. (2012). A systematic review: influence of vitamin D supplementation on serum 25-hydroxyvitamin D concentration. J Clin Endocrinol Metab.
278 Ganmaa D, Giovannucci E, Bloom BR, et al. (2012). Vitamin D, tuberculin skin test conversion, and latent tuberculosis in Mongolian school-age children: a randomized, double-blind, placebo-controlled feasibility trial. Am J Clin Nutr.
279 Blum M, Dallal GE, Dawson-Hughes B. (2008). Body size and serum 25 hydroxy vitamin D response to oral supplements in healthy older adults. J Am Coll Nutr.
280 Chapuy MC, Arlot ME, Duboeuf F, et al. (1992). Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med.
281 Chel V, Wijnhoven HA, Smit JH, et al. (2008). Efficacy of different doses and time intervals of oral vitamin D supplementation with or without calcium in elderly nursing home residents. Osteoporos Int.
282 Deroisy R, Collette J, Albert A, et al. (2002). Administration of a supplement containing both calcium and vitamin D is more effective than calcium alone to reduce secondary hyperparathyroidism in postmenopausal women with low 25(OH)vitamin D circulating levels. Aging Clin Exp Res.
283 Himmelstein S, Clemens TL, Rubin A, et al. (1990). Vitamin D supplementation in elderly nursing home residents increases 25(OH)D but not 1,25(OH)2D. Am J Clin Nutr.
284 Kenny AM, Biskup B, Robbins B, et al. (2003). Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. J Am Geriatr Soc.
285 Krieg MA, Jacquet AF, Bremgartner M, et al. (1999). Effect of supplementation with vitamin D3 and calcium on quantitative ultrasound of bone in elderly institutionalized women: a longitudinal study. Osteoporos Int.
286 Pfeifer M, Begerow B, Minne HW, et al. (2000). Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res.
287 Sorva A, Risteli J, Risteli L, et al. (1991). Effects of vitamin D and calcium on markers of bone metabolism in geriatric patients with low serum 25-hydroxyvitamin D levels. Calcif Tissue Int.
288 Barnes MS, Robson PJ, Bonham MP, et al. (2006). Effect of vitamin D supplementation on vitamin D status and bone turnover markers in young adults. Eur J Clin Nutr.
289 Dawson-Hughes B, Harris SS, Krall EA, et al. (1997). Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med.
290 Harris SS, Dawson-Hughes B. (2002). Plasma vitamin D and 25OHD responses of young and old men to supplementation with vitamin D3. J Am Coll Nutr.
291 Heaney RP, Davies KM, Chen TC, et al. (2003). Human serum 25-hydroxycholecalciferol response to extended oral dosing with cholecalciferol. Am J Clin Nutr.
292 Heikkinen A, Parviainen MT, Tuppurainen MT, et al. (1998). Effects of postmenopausal hormone replacement therapy with and without vitamin D3 on circulating levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D. Calcif Tissue Int.
293 Honkanen R, Alhava E, Parviainen M, et al. (1990). The necessity and safety of calcium and vitamin D in the elderly. J Am Geriatr Soc.
294 Jensen C, Holloway L, Block G, et al. (2002). Long-term effects of nutrient intervention on markers of bone remodeling and calciotropic hormones in late-postmenopausal women. Am J Clin Nutr.
295 Nelson ML, Blum JM, Hollis BW, et al. (2009). Supplements of 20 microg/d cholecalciferol optimized serum 25-hydroxyvitamin D concentrations in 80% of premenopausal women in winter. J Nutr.
296 Orwoll ES, Weigel RM, Oviatt SK, et al. (1988). Calcium and cholecalciferol: effects of small supplements in normal men. Am J Clin Nutr.
297 Patel R, Collins D, Bullock S, et al. (2001). The effect of season and vitamin D supplementation on bone mineral density in healthy women: a double-masked crossover study. Osteoporos Int.
298 Riis B, Christiansen C, Rodbro P. (1984). The effect of different vitamin D treatments on serum vitamin D levels in early postmenopausal women. Acta Vitaminol Enzymol.
299 Trang HM, Cole DE, Rubin LA, et al. (1998). Evidence that vitamin D3 increases serum 25-hydroxyvitamin D more efficiently than does vitamin D2. Am J Clin Nutr.
300 Chan GM, Roberts CC, Folland D, et al. (1982). Growth and bone mineralization of normal breast-fed infants and the effects of lactation on maternal bone mineral status. Am J Clin Nutr.
301 Basile LA, Taylor SN, Wagner CL, et al. (2006). The effect of high-dose vitamin D supplementation on serum vitamin D levels and milk calcium concentration in lactating women and their infants. Breastfeed Med.
302 Hollis BW, Wagner CL. (2004). Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypovitaminosis D for both the mother and the nursing infant. Am J Clin Nutr.
303 Yamamoto ME, Applegate WB, Klag MJ, et al. (1995). Lack of blood pressure effect with calcium and magnesium supplementation in adults with high-normal blood pressure. Results from Phase I of the Trials of Hypertension Prevention (TOHP). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol.
304 Mastaglia SR, Mautalen CA, Parisi MS, et al. (2006). Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. Eur J Clin Nutr.
305 Bonis PA, Chung M, Tatsioni A, et al. (2005). Effects of omega-3 fatty acids on organ transplantation. Evidence Report/Technology Assessment No. 115.
306 Whitlock EP, Lin JS, Chou R, et al. (2008). Using existing systematic reviews in complex systematic reviews. Ann Int Med.
307 Turpeinen U, Hohenthal U, Stenman UH. (2003). Determination of 25-Hydroxyvitamin D in Serum by HPLC and Immunoassay. Clin Chem.
308 Haddad JG, Chyu KJ. (1971). Competitive Protein-Binding Radioassay for 25-Hydroxycholecalciferol. J Clin Endocrinol Metab.
309 Preece MA, O'Riordan JLH, Lawson DEM, et al. (1974). A Competitive Protein-Binding Assay for 25-Hydroxycholecalciferol and 25-Hydroxyergocalciferol in Serum. Clinica Chimica Acta.
310 Reinhardt TA, Horst RL, Orf JW, et al. (1984). A Microassay for 1,25-Dihydroxyvitamin D Not Requiring High Performance Liquid Chromatography: Application to Clinical Studies. J Clin Endocrinol Metab.
311 Parviainen MT, Savolainen KE, Korhonen PH, et al. (1981). An improved method for routine determination of vitamin D and its hydroxylated metabolites in serum from children and adults. Clinica Chimica Acta.
312 Belsey R, Deluca HF, Potts JTJ. (1971). Competitive binding assay for vitamin D and 25-OH vitamin D. J Clinical Endocrinol Metab.
313 Redhwi AA, C AD, Smith GN. (1982). A simple method for the isolation of vitamin D metabolites from plasma extracts. Steroids.
314 orman AW, Bishop JE, Jongen M. (1984). Measurements of vitamin D metabolites Endocrine control of bone and calcium metabolism.
315 Shepard RM, Horst RL, Hamstra AJ, et al. (1979). Determination of vitamin D and its metabolites in plasma from normal and anephric man. Biochem J.
316 Pettifor JM, Ross FP, Wang J. (1976). A competitive protein-binding assay for 25-hydroxyvitamin D. Clin Sci Mol Med Suppl.
317 Binkley N, Drezner MK, Hollis BW. (2006). Laboratory reporting of 25-hydroxyvitamin D results: potential for clinical misinterpretation. Clin Chem.
318 Lensmeyer GL, Wiebe DA, Binkley N, et al. (2006). HPLC method for 25-hydroxyvitamin D measurement: comparison with contemporary assays. Clin Chem.
319 Jakobsen J, Bysted A, Andersen R, et al. (2009). Vitamin D status assessed by a validated HPLC method: within and between variation in subjects supplemented with vitamin D3. Scand J Clin Lab Invest.
320 Maunsell Z, Wright DJ, Rainbow SJ. (2005). Routine isotope-dilution liquid chromatography-tandem mass spectrometry assay for simultaneous measurement of the 25-hydroxy metabolites of vitamins D2 and D3. Clin Chem.