# Latitudes of Selected Cities

Latitude | Western Hemisphere | Eastern Hemisphere
64° N | Reykjavik, Iceland Nome, Alaska
60-61° N | Anchorage, Alaska | Oslo, Norway
56° N | | Copenhagen, Denmark
52° N | | Berlin, Germany Amsterdam, Netherlands
51° N | Calgary, Alberta | London, England
49° N | Vancouver, British Columbia | Paris, France
48° N | Seattle, Washington | Munich, Germany
47° N | Quebec City, Quebec Bismarck, North Dakota | Zurich, Switzerland
45° N | Ottawa, Ontario Minneapolis, Minnesota | Milan, Italy
44° N | Toronto, Ontario Portland, Maine
42° N | Boston, Massachusetts Chicago, Illinois | Rome, Italy
41° N | New York, New York Salt Lake City, Utah | Barcelona, Spain
40° N | Philadelphia, Pennsylvania Columbus, Ohio | Madrid, Spain Beijing, China
39° N | Washington, DC St Louis, Missouri Sacramento, California
38° N | Louisville, Kentucky Wichita, Kansas San Francisco, California | Athens, Greece
36° N | Raleigh, North Carolina Las Vegas, Nevada | Tokyo, Japan
34° N | Columbia, South Carolina Los Angeles, California | Fez, Morocco
33° N | Dallas, Texas
30° N | New Orleans, Louisiana | Cairo, Egypt
29° N | San Antonio, Texas | New Delhi, India
26° N | Miami, Florida
22° N | | Hong Kong, China
21° N | Honolulu, Hawaii
19° N | Mexico City, Mexico | Mumbai (Bombay), India
15° N | Guatemala City, Guatemala | Manila, Philippines
10° N | Caracas, Venezuela
4° N | Bogota, Columbia
1° N | | Singapore
12° S | Lima, Peru
23° S | Rio de Janeiro, Brazil
26° S | | Johannesburg, South Africa
34° S | | Sydney, Australia Cape Town, South Africa
35° S | Buenos Aires, Argentina
37° S | | Auckland, New Zealand
38° S | | Melbourne, Australia
41° S | | Wellington, New Zealand