# Peer Reviewers

- Patsy Brannon, Ph.D.
  Professor, Division of Nutritional Sciences
  Cornell University
  Ithaca, NY
- Kevin D. Cashman
  Professor of Food and Health
  School of Food & Nutritional Sciences
  University College Cork
  Cork, Ireland
- J. Christopher Gallagher, M.D.
  Professor of Endocrinology
  Director of Bone Metabolism Unit
  Creighton University
  Omaha, NE
- Michael F. Holick, Ph.D., M.D.
  Professor of Medicine, Physiology, and Biophysics
  Boston University School of Medicine
  Boston, MA
- Anne C. Looker, Ph.D.
  National Center for Health Statistics
  Centers for Disease Control and Prevention
  Hyattsville, MD