# Technical Expert Panel

- Glenville Jones, Ph.D.
  Professor, Biochemistry and Medicine
  Department of Biomedical & Molecular Sciences,
  Queen's University
  Kingston, Ontario, Canada
  Scientific Advisory Board
  Cytochroma Inc.
  Markham, Ontario, Canada
- Susan T. Mayne, Ph.D., F.A.C.E.
  Department Chair and C.-E.A. Winslow Professor
  Chronic Disease Epidemiology
  Yale School of Public Health
  Associate Director for Population Sciences Research
  Yale Cancer Center
  New Haven, CT
- Clifford Rosen, M.D.
  Senior Scientist
  Maine Medical Center Research Institute
  Scarborough, ME
  Director of Clinical and Translational Research
  Maine Medical Center
  Portland, ME