# Acknowledgments

We would like to thank Sean Rubin and Patricia Smith for their administrative support for the updated report. Additionally, we would like to thank Nono Ayivi-Guedehoussou, Dan Han, and Adeyemi Okunogbe for their support in helping with extracting the results data.