# Appendix H Studies Reporting Key Outcomes Stratified by Vitamin D Assay Method

Table 4 Vitamin D and growth outcomes: Characteristics of interventional studies (updated from original report)

Table 5 Vitamin D and growth outcomes: Characteristics of cohort studies (updated from original report)

Table 6 Vitamin D and growth outcomes: Results of RCTs (updated from original report)

Table 7 Vitamin D and growth outcomes: Results of cohort studies (updated from original report)

Table 14 Vitamin D and total cancer and total cancer mortality: Characteristics of RCTs [no new studies in the current report]

Table 15 Vitamin D and total cancer and total cancer mortality: Characteristics of cohort studies (updated from original report)

Table 16 Vitamin D and total cancer and total cancer mortality: Results of RCTs [no new studies in the current report]

Table 17 Vitamin D and total cancer and total cancer mortality: Results of cohort studies (updated from original report)

Table 18 Vitamin D and prostate cancer: Characteristics of observational studies (updated from original report)

Table 19 Vitamin D and prostate cancer: Results of observational studies (updated from original report)

Table 26a Vitamin D and breast cancer: Characteristics of nested case control studies (updated from original report)

Table 26b Vitamin D and breast cancer: Characteristics of prospective cohort studies (updated from original report)

Table 27a Vitamin D and breast cancer: Results of nested case control studies (updated from original report)

Table 27b Vitamin D and breast cancer: Results of prospective cohort studies (updated from original report)

Table 28 Vitamin D and pancreatic cancer: Characteristics of observational studies (updated from original report)

Table 29 Vitamin D and pancreatic cancer: Results of observational studies (updated from original report)

Table 30c Vitamin D and immunologic outcomes: Characteristics of Infectious Disease Continuous RCTs (updated from original report)

Table 30d Vitamin D and immunologic outcomes: Characteristics of Infectious Disease Dichotomous RCTs (updated from original report)

Table 31c Vitamin D and immunologic outcomes: Results of Infectious Disease RCTs-Continuous Outcomes (updated from original report)

Table 31d Vitamin D and immunologic outcomes: Results of Infectious Disease RCTs-Dichotomous Outcomes (updated from original report)

Table 32a Vitamin D and preeclampsia: Characteristics of observational studies (updated from original report)

Table 33a Vitamin D and preeclampsia: Results of observational studies (updated from original report)

Table 35d Vitamin D and Bone Health: Characteristics of Observational studies published after the Ottawa EPC report (updated from original report)

Table 36d Vitamin D and bone health: Results of observational studies published after the Ottawa EPC report (updated from original report)

Table 38 Vitamin D and all-cause mortality: Characteristics of cohort studies (updated from original report)

Table 39 Vitamin D and all-cause mortality: Results of cohort studies (updated from original report)

Table 42 Vitamin D and blood pressure: Characteristics of RCTs (updated from original report)

Table 43 Vitamin D and blood pressure: Results of RCTs

Table 44 Vitamin D and bone mineral density: Characteristics of RCTs published after the Ottawa EPC report (updated from original report)

Table 45 Vitamin D and bone mineral density or bone mineral contents: Results of RCTs published after the Ottawa EPC report (updated from original report)

Table 65 Combined vitamin D and calcium and bone mineral density/content: Characteristics of RCTs published after the Ottawa EPC report (formerly Table 104) [no new studies in the current report]

Table 66 Combined vitamin D and calcium and bone mineral density/content: Results of RCTs published after the Ottawa EPC report (formerly Table 105) [no new studies in the current report]

List of Acronyms and Abbreviations Included in Tables
Abbreviation: Term
ACS: Aortic calcification score
ADL: Activities of Daily Living
ASA: Acetyl salicylic acid (aspirin)
ATBC: Alpha Tocopherol, Beta Carotene Cancer Prevention Study
BMC: Bone mineral content
BMD: Bone mineral density
BMI: Body mass index
BP: Blood pressure
Ca: Calcium
CHS: Cardiovascular Health Study
CKD: Chronic kidney disease
CPS: Cancer Prevention Study
CRC: Colorectal cancer
CRP: C-reactive protein
CVD: Cardiovascular disease
d: Day
DBP: Diastolic blood pressure
DM: Diabetes mellitus
Dx: Diagnosis
eGFR: Estimated glomerular filtration rate
EPIC: European Prospective Investigation into Cancer and Nutrition
ESTHER: EStrogen and THromboEmbolism Risk Study
GFR: Glomerular filtration rate
HDL: High-density lipoprotein
HLA: Human leukocyte antigen
HPFS: Health Professionals Follow-Up Study
HPLC: high performance liquid chromatography
HR: Hazard ratio
HTN: Hypertension
InChianti: Invecchiare nel Chianti
INTAPP: International Trial of Antioxidants in the Prevention of Pre-eclampsia
IQR: Interquartile range
IU: International Units
KORA: Cooperative Health Research in the Region Augsburg
LDL: Low-density lipoprotein
MEC: Mobile Examination Center
MESA: Multi-ethnic Study of Atherosclerosis
MI: Myocardial infarction
MONICA: Multinational MONItoring of trends and determinants in CArdiovascular disease Study
MI: Myocardial infarction
n: Number
na: Not applicable
nd: No data
NHS: Nurses Health Study
nr: Not reported
NSAIDS: Non-steroidal Antiinflammatories
NHANES: National Health and Nutrition Examination Survey
nmol: nanomoles
OR: Odds ratio
PASE: Physical Activity Score For The Elderly
PLCO: Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial
PTH: Parathyroid hormone
Q: Quartile
RCT: Randomized controlled trial
RIA: radioimmunoassay;
RR: Relative risk
SC: Size-corrected
SD: Standard deviation
SBP: Systolic blood pressure
SES: Socioeconomic status
SPPB: Secondary-Short Physical Performance Battery
TUAG: Timed Up and Go
UK: United Kingdom
UV: Ultraviolet
Vit: Vitamin
VTE: Venous thromboembolism
WHI: Women's Health Iniative
Wk: Week
Y, y: year
YRS: Years