# Appendix G Serum Vitamin D Assay Reporting in Randomized Controlled Trials (RCTs)

Author, Year | Species | Method | Location of Study/Year of Assay | Inter-/Intra-Assay Variability | Reference Standard^a^
Studies in Original Report
Bjorkman, 2008^263^ | Serum 25(OH)D | HPLC307 | Finland/ assay dates not reported | Limit of quantification: 10 nmol/L. Intra-assay coefficient of variation: 5.6% (21.6 nmol/l; n=14) and 3.7% at 138nmol/l (n=15). Total CV: 7.3% at 16.4nmol/l (n=12) and 5.7% at 167nmol/l(n=15) | Not Reported (NR)
Blum, 2008^279^ | Serum 25(OH)D | Competitive protein binding assay | US/assay dates not reported | NR | NR
Bolton-Smith, 2007^274^ | Serum 25(OH)D | Radioimmunoassay (RIA) (DiaSorin, Wokingham, UK) | UK/assay dates not reported | NR | NR
Bunout, 2006^183^ | Serum 25(OH)D | Not described | NR | NR | NR
Chan, 1982^300^ | Serum 25(OH)D | Competitive protein binding assay308 | US/assay dates not reported | Coefficient of variation: 9% | NR
Chapuy, 1997^280^ | Serum 25(OH)D | RIA (Incstar Corp, Stillwater, MN) | France/assay dates not reported | Intra-assay variance: 5% Inter-assay variance: 11% | NR
Chel, 2008^281^ | Serum 25(OH)D | RIA (DiaSorin, Stillwater MN) | Netherlands/assay dates not reported | Inter-assay coefficient of variation:10% at 30 nmol/L | NR
Dawson-Hughes, 1997^289^ | Plasma 25(OH)D Plasma (1,25)D2 | 25(OH)D: Competitive protein binding assay309 1,25 di(OH)D: Competitive protein-binding method310 | US/assay dates not reported | NR | NR
DeRoisy, 2002^282^ | Serum 25(OH)D | RIA (Incstar, Stillwater, MN, USA). | Belgium/assay dates not reported | Intra-assay coefficient of variation: 8% Inter-assay coefficient of variation: < 12% | NR
El-Hajj-Fuleihan, 2006^48^ | Serum 25(OH)D Serum 1,25-dihydroxyvitamin D (1,25(OH)2D) | 25(OH)D: competitive protein binding assay (DiaSorin, Incstar, Saluggia, Italy) 1,25(OH)2D): RIA (IDS Immuno-Diagnostic Systems, Boldon, UK). | NR | Intra- and interassay Coefficients of Variation <13% at a serum concentration of 47 ng/ml. Intra- and interassay coefficients of variation < 10% at serum concentrations between 10 and 100 pg/ml | NR
Harris, 2002^290^ | Plasma 25(OH) D3 Plasma 25(OH)D | 25(OH)D3: high performance liquid chromatography 25(OH)D: competitive protein binding assay | US/Assay dates not reported | NR | NR
Heaney, 2003^291^ | Serum 25(OH)D | RIA (Nichols Institute Diagnostics, San Juan Capistrano CA) | US/assay dates not reported | NR | NR
Heikkinen, 1998^292^ | Serum 25OHD and 1,25(OH)2D | 25OHD and 1,25(OH)2D : competitive protein binding assays using vitamin D binding proteins following purification on dual HPLC with UV detection311 | Finland/assay dates not reported but conducted at baseline and 1 year later | Interassay coefficient of variation (CV) was less than 8% in serum 25OHD analysis | NR
Himmelstein, 1990^283^ | Serum 1,25(OH)2D 25OHD | 1,25(OH)2D: calf thymus radioreceptor assay310 25(OH)D: competitive protein binding assay309 | US/assay dates not reported | 1,25(OH)2D Intra-assay coefficient of variation:5% Inter-assay coefficient of variation: 11% 25(OH)D: Intra-assay coefficient of variation:5% Inter-assay coefficient of variation: 10% | NR
Honkanen, 1990^293^ | Serum 25(OH)D | 25(OH)D: competitive protein binding assay311 | Finland/assay dates not reported | NR | NR
Jensen, 2002^294^ | Serum 25(OH)D | Competitive protein-binding assay (Nichols Institute Diagnostics, San Juan Capistrano, CA) | US/assay dates not reported | NR | NR
Kenny, 2003^284^ | Serum 25(OH)D | Competitive protein binding assay (Endocrine Sciences Inc., Calabasas Hills, CA) | US/assay dates not reported | Intra-assay coefficient of variation: <10% | NR
Krieg, 1999^285^ | Serum 25(OH)D | Protein binding assay (Amersham Life Science, Little Chalfont, Bucks, UK) | Switzerland/assay dates not reported | NR | NR
Nelson, 2009^295^ | Serum 25(OH)D | RIA | US/2005–2006 | Intra-assay and inter-assay coefficients of variation <10% | NR
Orwoll, 1988^296^ | Serum 25(OH)D 1,25(OH)2D 24,25(OH)2D | 25(OH)D: Competitive protein binding assay312,313 1,25(OH)2D and 24,25(OH)2D determined by Anthony Norman314 | US/assay dates not reported | NR | NR
Patel, 2001^297^ | Serum 25(OH)D | RIA (INCSTAR) | UK/assay dates not reported | Sensitivity: 7.5nmol/l Intra-assay precision: 6.1% Inter-assay precision: 15.6% | NR
Pfeiffer, 2001^238^ | Serum 25OHD3, and 1,25-(OH)2D3 | RIA (Nichols Institute Diagnostics, San Juan Capistrano, CA) | Germany/assay dates not reported | Coefficients of variation: 5.5–7.9% | NR
Pfeiffer, 2000^286^ | Serum 25OHD3, and 1,25-(OH)2D3 | RIA (Nichols Institute Diagnostics, San Juan Capistrano, CA) | Germany/assay dates not reported | Coefficients of variation: 5.5–7.9% | NR
Riis, 1984^298^ | Serum 25OHD3, 24, 25 (OH)_2_D3, and 1,25-(OH)_2_D3 | 25(OH)D: UV detection 1,25(OH)2D and 24,25(OH)2D determined by competitive protein binding assay315 | Denmark/assay dates not reported | Intra-assay and inter-assay coefficients of variation: 1,25(OH)2D: 13% and 15% 24, 25(OH)2D: 14% and 17% 25(OH)D: 10% and 12% | NR
Trang, 1998^299^ | Serum 25(OH)D 1,25(OH)2D | 25(OH)D: RIA (INCSTAR, Stillwater MN) 1,25(OH)2D: calf thymus competitive protein binding assay | Canada/assay dates not reported | 25(OH) D consistently within 1SD of the method group mean for the International External Quality Assessment Scheme | Results of the 25(OH)D assay method were consistently within 1 SD of the method group mean in the International External Quality Assessment Scheme proficiency survey for this metabolite
Sorva, 1991^287^ | Serum 25(OH)D and 1,25-(OH)2D3 | 25(OH)D: competitive protein binding assay316 1,25(OH)2D3: competitive protein binding assay310 | Finland/assay dates not reported | NR | NR
Zhu, 2008^275^ | Serum 25(OH)D | RIA (DiaSorin, Stillwater MN) | Australia/assay dates not reported | NR | NR
Studies Identified for Current Report
Gaanmaa, 2012^278^ | Plasma 25(OH)D | CLIA TOTAL (LIAISON DiaSorin, Stillwater, MI, USA | US/4/10–6/10 | NR | NR
Gepner, 2012^229^ | Serum 25(OH)D | HPLC317,318 | US/assay dates not reported | NR | NR
Islam, 2010^267^ | Serum (OH)D | RIA OCTEIA (IDS, Boldon, UK) | Finland/assay dates not reported | Intra-and inter-assay coefficients of variation: 5·4 and 7·0 % | DEQAS
Jorde, 2010^230^ | Total 25(OH)D | RIA (DiaSorin, Stillwater MN) | Norway / Assay dates not reported | Intra-assay and total coefficient of variation: 6% and 14% | NR
Karkainnen, 2010^269^ | Serum 25(OH)D | RIA (DiaSorin, Stillwater MN) | Finland/assay dates not reported | Coefficient of Variation: 8.2% to 11.0% | NR
Kukuljian, 2011^272^ | Serum 25(OH)D | RIA kit DiaSorin (Stillwater, MN, USA) | Australia/assay dates not reported | Coefficient of Variation: 3.9 – 5.8% | NR
Li-Ng, 2009^150^ | Serum 25(OH)D | RIA kit DiaSorin (Stillwater, MN, USA) | US/assay dates not reported | Intra-assay Variability: 4.1% Inter-assay Variability:7.0%. | DEQAS
MacDonald, 2013^245^ | Serum 25(OH)D2 and 3 | HPLC-tandem mass spectrometry | UK/assay dates not reported | Interassay coefficients of variation <10% | NIST standard used. Lab also participates in DEQAS
Molgaard, 2010^248^ | Serum 25(OH)D | HPLC-based assay319 | Denmark/assay dates not reported | Intra- and inter-assay coefficients of variability: 4.3% and 6.3%, respectively | DEQAS
Nieves, 2012^244^ | Serum 25(OH)D and 1,25di(OH)D | RIA kit DiaSorin (Stillwater, MN, USA) | US/assay dates not reported | Coefficient of variation<12% | NR
Pfeifer, 2009^186^ | Serum 25(OH)D | RIA (Immunodiagnostic Systems, Boldon, UK) | Germany/assay dates not reported | NR | NR (validated against HPLC)
Salehpour, 2012 234 | Serum 25(OH)D | Enzyme immunoassay (Immunodiagnostic Systems Limited). | Iran/assay dates not reported | Intra- and inter-assay coefficients of variation: 6·9 and 8·1 %, respectively | NR
Salovaara, 2010^260^ | Serum 25(OH)D | RIA kit DiaSorin (Stillwater, MN, USA) | Finland/assay dates not reported | Coefficient of variation: 8.2% to 11.0% | NR
Toxqui, 2013^228^ | Serum 25(OH)D | Enzyme immunoassay (Immunodiagnostic Systems Limited, UK). | Spain/assay dates not reported | Intra- and inter-assay coefficients of variation: 5.6%, 6.4%, respectively | NR
Wamberg, 2013^236^ | Serum 25(OH)D2 and 3 | HPLC tandem mass spec320 | Denmark/assay dates not reported | NR | NR
Witham, 2013^235^ | Serum 25(OH)D | Enzyme immunoassay (Immunodiagnostic Systems Limited, UK). | UK/assay dates not reported | NR | NR
Wood, 2012^231^ | Serum 25(OH)D2 and 3 | HPLC tandem mass spec | UK/assay dates not reported | Coefficients of variation<10% | NR
Zhu, 2010^188^ | Serum 25OH)D | RIA kit DiaSorin (Stillwater, MN, USA) | Australia/assay dates not reported | NR | NR

Legend:

a The reference standard refers to a sample whose concentration of 25(OH)D has been ascertained by a recognized entity, such as the United States National Institute of Standards and Technology (NIST), that is used to establish the reliability of an assay. CLIA=chemiluminescence immunoassay CV=Coefficient of Variation; 25(OH)D=25-hydroxyvitamin D; 1,25(OH)_2_D=1,25-Dihydroxyvitamin D; 1,25 di(OH)D=1,25-dihydroxyvitamin D; 24,25(OH)_2_=Dihydroxyvitamin D; HPLC= High Performance Liquid Chromatography; nmol=nanomoles; NR=Not Reported; RCT=Randomized Controlled Trial(s); RIA=radioimmunoassay; UV=Ultraviolet