# Appendix F Excluded Studies

## Excluded Studies (From the Original Report)

Excluded Study | Reason
Aalberts JS, Weegels PL, van der HL et al. Calcium supplementation: effect on blood pressure and urinary mineral excretion in normotensive male lactoovovegetarians and omnivores. American Journal of Clinical Nutrition 48 (1):131-8, 1988. | No outcomes of interest
Abbasi AA, Chemplavil JK, Farah S, Muller BF, Arnstein AR. Hypercalcemia in active pulmonary tuberculosis. Annals of Internal Medicine 90 (3):324-8, 1979. | No UL outcomes
Abrams SA, Griffin IJ, Hawthorne KM, Ellis KJ. Effect of prebiotic supplementation and calcium intake on body mass index. Journal of Pediatrics 2007; 151(3):293-298. | Not a calcium intervention trial
Adams JS, Lee G. Gains in bone mineral density with resolution of Vitamin D intoxication. Annals of Internal Medicine 127 (3):203-6, 1997. | Case report
Akcakus M, Koklu E, Budak N, Kula M, Kurtoglu S, Koklu S. The relationship between birthweight, 25-hydroxyVitamin D concentrations and bone mineral status in neonates. Annals of Tropical Paediatrics 2006; 26(4):267-275. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Ala-Houhala M, Koskinen T, Terho A, Koivula T, Visakorpi J. Maternal compared with infant Vitamin D supplementation. Archives of Disease in Childhood 61 (12):1159-63, 1986. | Not RCT arrow 4 study
Ala-Houhala M. 25-HydroxyVitamin D levels during breast-feeding with or without maternal or infantile supplementation of Vitamin D. Journal of Pediatric Gastroenterology & Nutrition 4(2):220-6, 1985. | In Ottawa EPC report
Almendingen K, Hofstad B, Vatn MH. Dietary habits and growth and recurrence of colorectal adenomas: results from a three-year endoscopic follow-up study. Nutrition & Cancer 49 (2):131-8, 2004. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Almendingen K, Hofstad B, Vatn MH. Lifestyle-related factors and colorectal polyps: preliminary results from a Norwegian follow-up and intervention study. European Journal of Cancer Prevention 11(2):153-8, 2002. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Almendingen K, Trygg K, Hofstad B, Veierod MB, Vatn MH. Results from two repeated 5 day dietary records with a 1 y interval among patients with colorectal polyps. European Journal of Clinical Nutrition 55 (5):374-9, 2001. | No outcomes of interest
Al-oanzi ZH, Tuck SP, Raj N et al. Assessment of Vitamin D status in male osteoporosis. Clinical Chemistry 52 (2):248-54, 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Aloia JF, Talwar SA, Pollack S, Feuerman M, Yeh JK. Optimal Vitamin D status and serum parathyroid hormone concentrations in African American women. American Journal of Clinical Nutrition 84 (3):602-9, 2006. | No outcomes of interest
Anonymous. Calcium supplementation during pregnancy reduces the risk of developing preeclampsia in nulliparous women. Canadian Family Physician 45:614, 618-20, 1999. | Editorial-like brief review
Anonymous. Vitamin D supplementation for northern native communities. Indian and Inuit Health Committee, Canadian Paediatric Society. CMAJ Canadian Medical Association Journal 138 (3):229-30, 1988. | Review paper
Armitage NC, Rooney PS, Gifford KA, Clarke PA, Hardcastle JD. The effect of calcium supplements on rectal mucosal proliferation. British Journal of Cancer 71 (1):186-90, 1995. | No outcomes of interest
Armstrong AL, Oborne J, Coupland CA, Macpherson MB, Bassey EJ, Wallace WA. Effects of hormone replacement therapy on muscle performance and balance in post-menopausal women. Clinical Science 91 (6):685 -90, 1996. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Arunabh S, Pollack S, Yeh J, Aloia JF. Body fat content and 25-hydroxyVitamin D levels in healthy women. Journal of Clinical Endocrinology & Metabolism 88 (1):157-61, 2003. | Cross-sectional or retrospective assessment of diet after disease diagnosis
August P, Helseth G, Cook EF, Sison C. A prediction model for superimposed preeclampsia in women with chronic hypertension during pregnancy. American Journal of Obstetrics & Gynecology. 191(5):1666-72, 2004 Nov. | >=20% subjects with diseases
August P, Marcaccio B, Gertner JM, Druzin ML, Resnick LM, Laragh JH. Abnormal 1,25-dihydroxyVitamin D metabolism in preeclampsia. American Journal of Obstetrics & Gynecology 166 (4):1295-9, 1992. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Back O, Blomquist HK, Hernell O, Stenberg B. Does vitamin D intake during infancy promote the development of atopic allergy? Acta Dermato -Venereologica 89 (1):28 -32, 2009. | combination of vit D/Ca and other treatment w/o analysis of independent effect
Bailey BW, Sullivan DK, Kirk EP, Hall S, Donnelly JE. The influence of calcium consumption on weight and fat following 9 months of exercise in men and women. Journal of the American College of Nutrition 2007; 26(4):350-355. | No outcomes of interest
Bakker R, Rifas-Shiman SL, Kleinman KP, Lipshultz SE, Gillman MW. Maternal calcium intake during pregnancy and blood pressure in the offspring at age 3 years: a follow-up analysis of the Project Viva cohort. American Journal of Epidemiology 168 (12 ):1374 -80, 2008. | age <18 (BP outcome)
Baron JA, Beach M, Mandel JS et al. Calcium supplements and colorectal adenomas. Polyp Prevention Study Group. Annals of the New York Academy of Sciences 889:138-45, 1999. | Duplicate publication (see Baron 1999 NEJM)
Baron JA, Beach M, Mandel JS et al. Calcium supplements for the prevention of colorectal adenomas. Calcium Polyp Prevention Study Group. New England Journal of Medicine 340 (2):101-7, 1999. | In Weigarten 2008 systematic review
Baron JA, Tosteson TD, Wargovich MJ et al. Calcium supplementation and rectal mucosal proliferation: a randomized controlled trial. Journal of the National Cancer Institute 87 (17):1303-7, 1995. | No outcomes of interest
Barr SI. Calcium and body fat in peripubertal girls: cross-sectional and longitudinal observations. Obesity 2007; 15(5):1302-1310. | Not RCT growth study
Barsoum GH, Hendrickse C, Winslet MC et al. Reduction of mucosal crypt cell proliferation in patients with colorectal adenomatous polyps by dietary calcium supplementation. British Journal of Surgery 79 (6):581-3, 1992. | No outcomes of interest
Basile LA, Taylor SN, Wagner CL, Horst RL, Hollis BW. The effect of high-dose Vitamin D supplementation on serum Vitamin D levels and milk calcium concentration in lactating women and their infants. Breastfeeding Medicine: The Official Journal of the Academy of Breastfeeding Medicine 2006; 1(1):27-35. | In Ottawa EPC report
Belizan JM, Villar J, Bergel E et al. Long-term effect of calcium supplementation during pregnancy on the blood pressure of offspring: follow up of a randomised controlled trial.. BMJ 315 (7103):281-5, 1997. | In Hofmeyer 2007 systematic review
Belizan JM, Villar J, Gonzalez L, Campodonico L, Bergel E. Calcium supplementation to prevent hypertensive disorders of pregnancy.. New England Journal of Medicine 325 (20):1399 -405, 1991. | In Hofmeyer 2007 systematic review
Belizan JM, Villar J, Pineda O et al. Reduction of blood pressure with calcium supplementation in young adults. JAMA 249 (9):1161 -5, 1983. | In systematic review
Belizan JM, Villar J, Zalazar A, Rojas L, Chan D, Bryce GF. Preliminary evidence of the effect of calcium supplementation on blood pressure in normal pregnant women. American Journal of Obstetrics & Gynecology 146 (2):175 -80, 1983. | In Hofmeyer 2007 systematic review
Bell NH, Epstein S, Greene A, Shary J, Oexmann MJ, Shaw S. Evidence for alteration of the Vitamin D-endocrine system in obese subjects. Journal of Clinical Investigation 76 (1):370-3, 1985. | Not RCT arrow 4 study
Bell NH, Epstein S, Shary J, Greene V, Oexmann MJ, Shaw S. Evidence of a probable role for 25-hydroxyVitamin D in the regulation of human calcium metabolism. Journal of Bone & Mineral Research 3(5):489-95, 1988. | Not RCT arrow 4 study
Bell NH, Godsen RN, Henry DP, Shary J, Epstein S. The effects of muscle-building exercise on Vitamin D and mineral metabolism. Journal of Bone & Mineral Research 3(4):369-73, 1988. | No outcomes of interest
Bell NH. Hypercalcemic and hypocalcemic disorders: diagnosis and treatment. Nephron 23(2-3):147-51, 1979. | Review paper
Berggren M, Stenvall M, Olofsson B, Gustafson Y. Evaluation of a fall-prevention program in older people after femoral neck fracture: a one-year follow-up. Osteoporosis International 1919;801-9. | 100% patients with femoral neck fracture who admitted to the hospital
Berkey CS, Rockett HR, Willett WC, Colditz GA. Milk, dairy fat, dietary calcium, and weight gain: a longitudinal study of adolescents.. Archives of Pediatrics & Adolescent Medicine 159 (6):543 -50, 2005. | Not RCT growth study
Berube S, Diorio C, Masse B et al. Vitamin D and calcium intakes from food or supplements and mammographic breast density. Cancer Epidemiology, Biomarkers & Prevention 14(7):1653-9, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Bierenbaum ML, Fleischman AI, Raichelson RI. Long term human studies on the lipid effects of oral calcium. Lipids 7 (3):202-6, 1972. | No outcomes of interest
Bierenbaum ML, Wolf E, Bisgeier G, Maginnis WP. Dietary calcium. A method of lowering blood pressure. American Journal of Hypertension 1(3 Pt 3):149S -152S, 1988. | In systematic review
Bischoff HA, Stahelin HB, Dick W et al. Effects of Vitamin D and calcium supplementation on falls: a randomized controlled trial.. Journal of Bone & Mineral Research 18 (2):343-51, 2003. | In Ottawa EPC report
Bischoff-Ferrari HA, Conzelmann M, Stahelin HB et al. Is fall prevention by Vitamin D mediated by a change in postural or dynamic balance? Osteoporosis International 2006; 17(5):656-663. | Secondary analysis of an original RCT by Bischoff-Ferrari 2003, which is already in Ottawa's report
Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Archives of Internal Medicine 166 (4):424-30, 2006. | In Ottawa EPC report
Blum M, Kirsten M, Worth MH, Jr. Reversible hypertension. Caused by the hypercalcemia of hyperparathyroidism, Vitamin D toxicity, and calcium infusion. JAMA 237 (3):262 -3, 1977. | No 25(OH)D or dietary Ca
Boggess KA, Samuel L, Schmucker BC, Waters J, Easterling TR. A randomized controlled trial of the effect of third-trimester calcium supplementation on maternal hemodynamic function. Obstetrics & Gynecology 90 (2):157-61, 1997. | In Hofmeyer 2007 systematic review
Bonithon-Kopp C, Kronborg O, Giacosa A, Rath U, Faivre J. Calcium and fibre supplementation in prevention of colorectal adenoma recurrence: a randomised intervention trial. European Cancer Prevention Organisation Study Group. Lancet 356 (9238):1300-6, 2000. | In Weigarten 2008 systematic review
Bonithon-Kopp C, Piard F, Fenger C et al. Colorectal adenoma characteristics as predictors of recurrence. Diseases of the Colon & Rectum 47 (3):323-33, 2004. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Boon N, Koppes LL, Saris WH, Van MW. The relation between calcium intake and body composition in a Dutch population: The Amsterdam Growth and Health Longitudinal Study. American Journal of Epidemiology 162 (1):27-32, 2005. | No outcomes of interest
Bostick RM, Fosdick L, Grandits GA, Grambsch P, Gross M, Louis TA. Effect of calcium supplementation on serum cholesterol and blood pressure. A randomized, double-blind, placebo-controlled, clinical trial. Archives of Family Medicine 9(1):31-8 2000. | >=20% subjects with diseases
Bostick RM, Fosdick L, Wood JR et al. Calcium and colorectal epithelial cell proliferation in sporadic adenoma patients: a randomized, double-blinded, placebo-controlled clinical trial.. Journal of the National Cancer Institute 87 (17):1307-15, 1995. | No outcomes of interest
Bostick RM, Potter JD, Fosdick L et al. Calcium and colorectal epithelial cell proliferation: a preliminary randomized, double-blinded, placebo-controlled clinical trial. Journal of the National Cancer Institute. 85(2):132-41, 1993 Jan 20. | No outcomes of interest
Boutron MC, Faivre J, Marteau P, Couillault C, Senesse P, Quipourt V. Calcium, phosphorus, Vitamin D, dairy products and colorectal carcinogenesis: a French case--control study.. British Journal of Cancer 74 (1):145-51, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Bowen J, Noakes M, Clifton PM. Effect of calcium and dairy foods in high protein, energy-restricted diets on weight loss and metabolic parameters in overweight adults. International Journal of Obesity 29 (8):957-65, 2005. | In systematic review
Braverman AS. Evidence that high calcium and Vitamin D intake decrease the risk of breast cancer in premenopausal women: implications for breast cancer prevention and screening. Southern Medical Journal 100 (11):1061-2, 2007. | Review paper
Brekke HK, Ludvigsson J. Vitamin D supplementation and diabetes-related autoimmunity in the ABIS study. Pediatric Diabetes 2007; 8(1):11-14. | No 25(OH)D or dietary Ca
Broe KE, Chen TC, Weinberg J, Bischoff-Ferrari HA, Holick MF, Kiel DP. A higher dose of Vitamin d reduces the risk of falls in nursing home residents: a randomized, multiple-dose study. Journal of the American Geriatrics Society 2007; 55(2):234-239. | In Ottawa EPC report
Brooke OG, Butters F, Wood C. Intrauterine Vitamin D nutrition and postnatal growth in Asian infants. British Medical Journal Clinical Research Ed 283 (6298):1024, 1981. | No 25(OH)D or dietary Ca
Brooke OG. Supplementary Vitamin D in infancy and childhood. Archives of Disease in Childhood 1983; 58(8):573-574. | Review paper
Brunvand L, Quigstad E, Urdal P, Haug E. Vitamin D deficiency and fetal growth. Early Human Development 45 (1-2):27-33, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Brunvand L, Shah SS, Bergstrom S, Haug E. Vitamin D deficiency in pregnancy is not associated with obstructed labor. A study among Pakistani women in Karachi. Acta Obstetricia et Gynecologica Scandinavica 77 (3):303-6, 1998. | No outcomes of interest
Campbell CG, Chew BP, Luedecke LO, Shultz TD. Yogurt consumption does not enhance immune function in healthy premenopausal women. Nutrition & Cancer 37 (1):27-35, 2000. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Cancela L, Le BN, Miravet L. Relationship between the Vitamin D content of maternal milk and the Vitamin D status of nursing women and breast-fed infants. Journal of Endocrinology 110 (1):43-50, 1986. | Not RCT arrow 4 study
Canto-Costa MH, Kunii I, Hauache OM. Body fat and cholecalciferol supplementation in elderly homebound individuals. Brazilian Journal of Medical & Biological Research 39 (1):91-8, 2006. | Not RCT arrow 4 study
Caplan RH, Miller CD, Silva PD. Severe hypercalcemia in a lactating woman in association with moderate calcium carbonate supplementation: a case report. Journal of Reproductive Medicine 49 (3):214-7, 2004. | Case report
Cappuccio FP, Elliott P, Allender PS, Pryer J, Follman DA, Cutler JA. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. American Journal of Epidemiology 142 (9):935-45, 1995. | Meta-analysis
Carlon GC, Howland WS, Goldiner PL, Kahn RC, Bertoni G, Turnbull AD. Adverse effects of calcium administration. Report of two cases. Archives of Surgery 113 (7):882-5, 1978. | Case report
Carlson LA, Derblom H, Lanner A. Effect of different doses of Vitamin D on serum cholesterol and triglyceride levels in healthy men. Atherosclerosis 12 (2):313-7, 1970. | Multiple antioxidant trials analyses
Caruso JB, Patel RM, Julka K, Parish DC. Health-behavior induced disease: return of the milk-alkali syndrome. Journal of General Internal Medicine 2007; 22(7):1053-1055. | Case report
Cats A, Kleibeuker JH, van der MR et al. Randomized, double-blinded, placebo-controlled intervention study with supplemental calcium in families with hereditary nonpolyposis colorectal cancer. Journal of the National Cancer Institute 87 (8):598-603, 1995. | No outcomes of interest
Cervellin G, Bonino P, Palummeri E, Passeri M. Calcium phosphate and blood pressure: their relationships in a geriatric population. American Journal of Nephrology 6 Suppl 1:16-8, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Chan GM, Roberts CC, Folland D, Jackson R. Growth and bone mineralization of normal breast-fed infants and the effects of lactation on maternal bone mineral status. American Journal of Clinical Nutrition 36 (3):438-43, 1982. | In Ottawa EPC report
Chan GM. Growth and bone mineral status of discharged very low birth weight infants fed different formulas or human milk. Journal of Pediatrics 123 (3):439-43, 1993. | >=20% subjects with diseases
Chan JM, Pietinen P, Virtanen M et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes & Control 11(9):859-67, 2000. | Superseded by Mitrou 2007
Chen W, Dawsey SM, Qiao YL et al. Prospective study of serum 25(OH)-Vitamin D concentration and risk of oesophageal and gastric cancers. British Journal of Cancer 2007; 97(1):123-128. | No outcomes of interest
Chyou PH, Nomura AM, Stemmermann GN. Diet, alcohol, smoking and cancer of the upper aerodigestive tract: a prospective study among Hawaii Japanese men. International Journal of Cancer 60 (5):616-21, 1995. | No outcomes of interest
Cleghorn GJ, Tudehope DI. Neonatal intestinal obstruction associated with oral calcium supplementation. Australian Paediatric Journal 17(4):298-9, 1981. | Case report
Cockburn F, Belton NR, Purvis RJ et al. Maternal Vitamin D intake and mineral metabolism in mothers and their newborn infants. British Medical Journal 281 (6232):11-4, 1980. | Not RCT arrow 4 study
Cohen GR, Curet LB, Levine RJ et al. Ethnicity, nutrition, and birth outcomes in nulliparous women. American Journal of Obstetrics & Gynecology 2001; 185(3):660-667. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Colditz GA, Manson JE, Stampfer MJ, Rosner B, Willett WC, Speizer FE. Diet and risk of clinical diabetes in women. American Journal of Clinical Nutrition 55 (5):1018 -23, 1992. | No outcomes of interest
Combs GF, Jr., Hassan N, Dellagana N et al. Apparent efficacy of food-based calcium supplementation in preventing rickets in Bangladesh. Biological Trace Element Research 121 (3):193 -204, 2008. | >=20% subjects with diseases
Cong K, Chi S, Liu G. Calcium supplementation during pregnancy for reducing pregnancy induced hypertension. Chinese Medical Journal 108 (1):57-9, 1995. | In Hofmeyer 2007 systematic review
Corless D, Dawson E, Fraser F et al. Do Vitamin D supplements improve the physical capabilities of elderly hospital patients? Age & Ageing 14(2):76-84, 1985. | In Ottawa EPC report
Cosman F, Nieves J, Shen V, Lindsay R. Oral 1,25-dihydroxyVitamin D administration in osteoporotic women: effects of estrogen therapy. Journal of Bone & Mineral Research 10(4):594-600, 1995. | Not RCT arrow 4 study
Costenbader KH, Feskanich D, Holmes M, Karlson EW, ito-Garcia E. Vitamin D intake and risks of systemic lupus erythematosus and rheumatoid arthritis in women. Annals of the Rheumatic Diseases 67 (4):530-5, 2008. | Observational study estimated Vitamin D supplement doses
Crowther CA, Hiller JE, Pridmore B et al. Calcium supplementation in nulliparous women for the prevention of pregnancy-induced hypertension, preeclampsia and preterm birth: an Australian randomized trial. FRACOG and the ACT Study Group. Australian & New Zealand Journal of Obstetrics & Gynaecology 39 (1):12-8, 1999. | In Hofmeyer 2007 systematic review
Dahifar H, Faraji A, Yassobi S, Ghorbani A. Asymptomatic rickets in adolescent girls. Indian Journal of Pediatrics 2007; 74(6):571-575. | Not RCT arrow 4 study
Dattani JT, Exton-Smith AN, Stephen JM. Vitamin D status of the elderly in relation to age and exposure to sunlight. Human Nutrition - Clinical Nutrition 38 (2):131-7, 1984. | Not RCT arrow 4 study
Dauchet L, Kesse-Guyot E, Czernichow S et al. Dietary patterns and blood pressure change over 5-y follow-up in the SU.VI.MAX cohort. American Journal of Clinical Nutrition 2007; 85(6):1650-1656. | No 25(OH)D or dietary Ca
Davie MW, Abraham RR, Hewins B, Wynn V. Changes in bone and muscle constituents during dieting for obesity. Clinical Science 70 (3):285-93, 1986. | No outcomes of interest
Davies KM, Heaney RP, Recker RR et al. Calcium intake and body weight. Journal of Clinical Endocrinology & Metabolism 85 (12):4635-8, 2000. | Meta-analysis; five clinical studies
Deheeger M, Bellisle F, Rolland-Cachera MF. The French longitudinal study of growth and nutrition: data in adolescent males and females. Journal of Human Nutrition & Dietetics 15 (6):429-38, 2002. | Analysis did not relate exposure to outcome
DeJongh ED, Binkley TL, Specker BL. Fat mass gain is lower in calcium-supplemented than in unsupplemented preschool children with low dietary calcium intakes. American Journal of Clinical Nutrition 84 (5):1123-7, 2006. | <9y (a study on BMI)
Dent CE, Gupta MM. Plasma 25-hydroxyVitamin-D-levels during pregnancy in Caucasians and in vegetarian and non-vegetarian Asians. Lancet 2(7944):1057-60, 1975. | No outcomes of interest
DeSantiago S, Alonso L, Halhali A, Larrea F, Isoard F, Bourges H. Negative calcium balance during lactation in rural Mexican women. American Journal of Clinical Nutrition 76 (4):845-51, 2002. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Devereux G, Litonjua AA, Turner SW et al. Maternal Vitamin D intake during pregnancy and early childhood wheezing. American Journal of Clinical Nutrition 2007; 85(3):853-859. | No 25(OH)D or dietary Ca
Dewey KG, Lonnerdal B. Milk and nutrient intake of breast-fed infants from 1 to 6 months: relation to growth and fatness. Journal of Pediatric Gastroenterology & Nutrition 2(3):497 -506, 1983. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Dhesi JK, Bearne LM, Moniz C et al. Neuromuscular and psychomotor function in elderly subjects who fall and the relationship with Vitamin D status. Journal of Bone & Mineral Research 17(5):891-7, 2002. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Dhesi JK, Jackson SH, Bearne LM et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age & Ageing 33 (6):589-95, 2004. | Intramuscular injection of high dose ergocalciferol
Dijkstra SH, van BA, Janssen JW, de Vleeschouwer LH, Huysman WA, van den Akker EL. High prevalence of Vitamin D deficiency in newborn infants of high-risk mothers.[erratum appears in Arch Dis Child. 2007 Nov;92(11):1049]. Archives of Disease in Childhood 2007; 92(9):750-753. | Relationship between mother's 25(OH)D and infant's 25(OH)D levels
Dixon LB, Pellizzon MA, Jawad AF, Tershakovec AM. Calcium and dairy intake and measures of obesity in hyper- and normocholesterolemic children. Obesity Research 13(10):1727-38, 2005. | Outcome is BW but participants age is from 4 to 10y (mostly <9y)
Dobnig H, Pilz S, Scharnagl H et al. Independent association of low serum 25-hydroxyvitamin d and 1,25-dihydroxyvitamin d levels with all-cause and cardiovascular mortality. Archives of Internal Medicine 168 (12 ):1340 -9, 2008. | >=20% subjects with diseases
Doege C, Bauer J. Effect of high volume intake of mother's milk with an individualized supplementation of minerals and protein on early growth of preterm infants <28 weeks of gestation. Clinical Nutrition 26 (5):581-8, 2007. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Domrongkitchaiporn S, Ongphiphadhanakul B, Stitchantrakul W et al. Risk of calcium oxalate nephrolithiasis after calcium or combined calcium and calcitriol supplementation in postmenopausal women. Osteoporosis International 11(6):486-92, 2000. | No outcomes of interest, no UL outcomes
Drinka PJ, Nolten WE. Hazards of treating osteoporosis and hypertension concurrently with calcium, Vitamin D, and distal diuretics. Journal of the American Geriatrics Society 32 (5):405-7, 1984. | Case report
Drouillet P, Balkau B, Charles MA et al. Calcium consumption and insulin resistance syndrome parameters. Data from the Epidemiological Study on the Insulin Resistance Syndrome (DESIR). Nutrition Metabolism & Cardiovascular Diseases 2007; 17(7):486-492. | No outcomes of interest
Ehrenberg A. Non-medical prevention of pre-eclampsia. Acta Obstetricia et Gynecologica Scandinavica - Supplement 164:108-10, 1997. | Review paper
Epstein S, Bell NH, Shary J, Shaw S, Greene A, Oexmann MJ. Evidence that obesity does not influence the Vitamin D-endocrine system in blacks. Journal of Bone & Mineral Research 1(2):181-4, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Epstein S, Stern PH, Bell NH, Dowdeswell I, Turner RT. Evidence for abnormal regulation of circulating 1 alpha, 25-dihydroxyVitamin D in patients with pulmonary tuberculosis and normal calcium metabolism. Calcified Tissue International 36 (5):541-4, 1984. | Not RCT arrow 4 study
Ertbeg P, Norgaard P, Bang L, Nyholm H, Rudnicki M. Ionized magnesium in gestational diabetes. Magnesium Research 17(1):35-8, 2004. | No 25(OH)D or dietary Ca
Faivre J, Couillault C, Kronborg O et al. Chemoprevention of metachronous adenomas of the large bowel: design and interim results of a randomized trial of calcium and fibre. ECP Colon Group. European Journal of Cancer Prevention 6(2):132-8, 1997. | Design and interim results article
Farrerons J, Barnadas M, Rodriguez J et al. Clinically prescribed sunscreen (sun protection factor 15) does not decrease serum Vitamin D concentration sufficiently either to induce changes in parathyroid function or in metabolic markers. British Journal of Dermatology 139 (3):422-7, 1998. | No outcomes of interest
Faulkner KA, Cauley JA, Zmuda JM et al. Higher 1,25-dihydroxyVitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporosis International 2006; 17(9):1318-1328. | In Ottawa EPC report
Feeley RM, Eitenmiller RR, Jones JB, Jr., Barnhart H. Calcium, phosphorus, and magnesium contents of human milk during early lactation. Journal of Pediatric Gastroenterology & Nutrition 2(2):262-7, 1983. | No outcomes of interest
Felson DT, Niu J, Clancy M et al. Low levels of Vitamin D and worsening of knee osteoarthritis: results of two longitudinal studies. Arthritis & Rheumatism 2007; 56(1):129-136. | No outcomes of interest
Fleischman AR, Rosen JF, Cole J, Smith CM, DeLuca HF. Maternal and fetal serum 1,25-dihydroxyVitamin D levels at term. Journal of Pediatrics 1980; 97(4):640-642. | No outcomes of interest
Fleischman AR, Rosen JF, Nathenson G. 25-hydroxyVitamin D. Serum levels and oral administration of calcifediol in neonates. Archives of Internal Medicine 138 Spec No: 869-73, 1978. | Premature infants
Forman JP, Bischoff-Ferrari HA, Willett WC, Stampfer MJ, Curhan GC. Vitamin D intake and risk of incident hypertension: results from three large prospective cohort studies. Hypertension 46 (4):676-82, 2005. | No 25(OH)D or dietary Ca
Franco A, Sikalidis AK, Solis Herruzo JA. Colorectal cancer: influence of diet and lifestyle factors. Revista Espanola de Enfermedades Digestivas 97 (6):432-48, 2005. | Review paper
Freedman DM, Tangrea JA, Virtamo J, Albanes D. The effect of beta-carotene supplementation on serum Vitamin D metabolite concentrations. Cancer Epidemiology, Biomarkers & Prevention 8 (12):1115-6, 1999. | No outcomes of interest
Fronczak CM, Baron AE, Chase HP et al. In utero dietary exposures and risk of islet autoimmunity in children. Diabetes Care 26 (12):3237 -42, 2003. | Observational study estimated Vitamin D supplement doses
Galloe AM, Graudal N, Moller J, Bro H, Jorgensen M, Christensen HR. Effect of oral calcium supplementation on blood pressure in patients with previously untreated hypertension: a randomised, double-blind, placebo-controlled, crossover study. Journal of Human Hypertension 7 (1):43-5, 1993. | In systematic review
Gambacciani M, Ciaponi M, Cappagli B et al. Body weight, body fat distribution, and hormonal replacement therapy in early postmenopausal women.[erratum appears in J Clin Endocrinol Metab 1997 Dec;82(12):4074]. Journal of Clinical Endocrinology & Metabolism 82 (2):414-7, 1997. | No outcomes of interest
Garland CF, Garland FC. Do sunlight and Vitamin D reduce the likelihood of colon cancer? [reprint in Int J Epidemiol. 2006 Apr;35(2):217-20; PMID: 16303809]. International Journal of Epidemiology 9 (3):227-31, 1980. | Ecological study
Garland CF, Mohr SB, Gorham ED, Grant WB, Garland FC. Role of ultraviolet B irradiance and Vitamin D in prevention of ovarian cancer. American Journal of Preventive Medicine 2006; 31(6):512-514. | No 25(OH)D or dietary Ca
Genkinger JM, Hunter DJ, Spiegelman D et al. Dairy products and ovarian cancer: a pooled analysis of 12 cohort studies. Cancer Epidemiology, Biomarkers & Prevention 15 (2):364-72, 2006. | Pooled analysis
Gertner JM, Domenech M. 25-HydroxyVitamin D levels in patients treated with high-dosage ergo- and cholecalciferol. Journal of Clinical Pathology 30(2):144-50, 1977. | >=20% subjects with diseases
Gillies DR, Hay A, Sheltawy MJ, Congdon PJ. Effect of phototherapy on plasma 25(OH)-Vitamin D in neonates. Biology of the Neonate 1984; 45(5):225-227. | Not RCT arrow 4 study
Gillman MW, Oliveria SA, Moore LL, Ellison RC. Inverse association of dietary calcium with systolic blood pressure in young children. JAMA 267 (17):2340-3, 1992. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Gillman MW, Rifas-Shiman SL, Kleinman KP, Rich-Edwards JW, Lipshultz SE. Maternal calcium intake and offspring blood pressure. Circulation 110 (14):1990-5, 2004. | Relationship between maternal intake and offspring blood pressure
Giovannucci E, Liu Y, Rimm EB et al. Prospective study of predictors of Vitamin D status and cancer incidence and mortality in men.. Journal of the National Cancer Institute 98 (7):451-9, 2006. | Superseded by Giovannucci 2007
Giovannucci E, Rimm EB, Wolk A et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Research 58 (3):442-7, 1998. | Predictive model was used to predict 25(OH)D levels of whole cohort
Giovannucci E, Stampfer MJ, Colditz GA et al. MultiVitamin use, folate, and colon cancer in women in the Nurses' Health Study.. Annals of Internal Medicine 129 (7):517 -24, 1998. | No 25(OH)D or dietary Ca
Gonzalez AJ, White E, Kristal A, Littman AJ. Calcium intake and 10-year weight change in middle-aged adults. Journal of the American Dietetic Association 106 (7):1066-73 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Goswami R, Gupta N, Ray D, Singh N, Tomar N. Pattern of 25-hydroxy vitamin D response at short (2 month) and long (1 year) interval after 8 weeks of oral supplementation with cholecalciferol in Asian Indians with chronic hypovitaminosis D. British Journal of Nutrition 100 (3):526-9, 2008. | not RCT curve 4 study
Grady D, Halloran B, Cummings S et al. 1,25-DihydroxyVitamin D3 and muscle strength in the elderly: a randomized controlled trial. Journal of Clinical Endocrinology & Metabolism 73 (5):1111-7, 1991. | 1,25(OH)2D supplement
Grant WB. The likely role of Vitamin D from solar ultraviolet-B irradiance in increasing cancer survival. Anticancer Research 26 (4A ):2605-14, 2006. | Ecological study
Grau MV, Baron JA, Barry EL et al. Interaction of calcium supplementation and nonsteroidal anti-inflammatory drugs and the risk of colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 14(10):2353-8, 2005. | In Weigarten 2008 systematic review
Greene MF. Trial of calcium to prevent preeclampsia. Journal of Women's Health 6(4):485-6, 1997. | Commentary
Greer FR, Ho M, Dodson D, Tsang RC. Lack of 25-hydroxyVitamin D and 1,25-dihydroxyVitamin D in human milk. Journal of Pediatrics 99 (2):233-5, 1981. | No 25(OH)D or dietary Ca
Greer FR, Hollis BW, Cripps DJ, Tsang RC. Effects of maternal ultraviolet B irradiation on Vitamin D content of human milk. Journal of Pediatrics 105 (3):431-3, 1984. | No 25(OH)D or dietary Ca
Greer FR, Marshall S. Bone mineral content, serum Vitamin D metabolite concentrations, and ultraviolet B light exposure in infants fed human milk with and without Vitamin D2 supplements. Journal of Pediatrics 114 (2):204-12, 1989. | In Ottawa EPC report
Greer FR, Searcy JE, Levin RS, Steichen JJ, Asch PS, Tsang RC. Bone mineral content and serum 25-hydroxyVitamin D concentration in breast-fed infants with and without supplemental Vitamin D. Journal of Pediatrics 98 (5):696-701, 1981. | In Ottawa EPC report
Gruson M, Cancela L, Denne MA, Miravet L. Relationship between bone GLA-protein (BGP) and calcidiol (25-hydroxycalciferol) in serum of breast-fed infants. Endocrinologia Experimentalis. 20(2-3):329-34, 1986 Aug. | 25(OH)D supplement
Gunther CW, Legowski PA, Lyle RM et al. Dairy products do not lead to alterations in body weight or fat mass in young women in a 1-y intervention. American Journal of Clinical Nutrition 81 (4):751-6, 2005. | In systematic review
Gunther CW, Legowski PA, Lyle RM et al. Parathyroid hormone is associated with decreased fat mass in young healthy women. International Journal of Obesity 30 (1):94-9, 2006. | Ca intake and BW measured but not assessed ==> no relevant results reported
Haddad JG, Jr., Rojanasathit S. Acute administration of 25-hydroxycholecalciferol in man. Journal of Clinical Endocrinology & Metabolism 42 (2):284 -90, 1976. | Not RCT arrow 4 study
Hakala P, Karvetti RL. Weight reduction on lactovegetarian and mixed diets. Changes in weight, nutrient intake, skinfold thicknesses and blood pressure. European Journal of Clinical Nutrition 43 (6):421-30, 1989. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Halhali A, Villa AR, Madrazo E et al. Longitudinal changes in maternal serum 1,25-dihydroxyVitamin D and insulin like growth factor I levels in pregnant women who developed preeclampsia: comparison with normotensive pregnant women. Journal of Steroid Biochemistry & Molecular Biology 89 -90 (1-5):553-6, 2004. | No outcomes of interest
Hamet P, Mongeau E, Lambert J et al. Interactions among calcium, sodium, and alcohol intake as determinants of blood pressure. Hypertension 17(1 Suppl):I150-4, 1991. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hamid Z, Riggs A, Spencer T, Redman C, Bodenner D. Vitamin D deficiency in residents of academic long-term care facilities despite having been prescribed Vitamin D.. Journal of the American Medical Directors Association 2007; 8(2):71-75. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hansen KE, Jones AN, Lindstrom MJ, Davis LA, Engelke JA, Shafer MM. Vitamin D insufficiency: disease or no disease? Journal of Bone & Mineral Research 23(7):1052-60, 2008. | Not RCT arrow 4 study
Haub MD, Simons TR, Cook CM, Remig VM, Al-Tamimi EK, Holcomb CA. Calcium-fortified beverage supplementation on body composition in postmenopausal women. Nutrition Journal 4:21, 2005. | In systematic review
Heilbrun LK, Hankin JH, Nomura AM, Stemmermann GN. Colon cancer and dietary fat, phosphorus, and calcium in Hawaiian-Japanese men. American Journal of Clinical Nutrition 43 (2):306-9, 1986. | Letter to the editor
Heilbrun LK, Nomura A, Hankin JH, Stemmermann GN. Dietary Vitamin D and calcium and risk of colorectal cancer. Lancet 1985; 1(8434):925. | Superceded by Stemmermann, 1990 RefID 1691
Herrera JA, revalo-Herrera M, Herrera S. Prevention of preeclampsia by linoleic acid and calcium supplementation: a randomized controlled trial. Obstetrics & Gynecology 91 (4):585 -90, 1998. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Herrmann U, Schwille PO, Schmiedl A, Fan J, Manoharan M. Acute effects of calcium sodium citrate supplementation of a test meal on mineral homeostasis, oxalate, and calcium oxalate crystallization in the urine of healthy humans--preliminary results in patients with idiopathic calcium urolithiasis. Biomedicine & Pharmacotherapy 53 (5-6):264-73, 1999. | No UL outcomes: CaOx crystallization; saturation of CaOx
Hill KM, Braun M, Kern M et al. Predictors of calcium retention in adolescent boys. Journal of Clinical Endocrinology & Metabolism 93 (12 ):4743 -8, 2008. | no outcomes of interest
Hiller JE, Crowther CA, Moore VA, Willson K, Robinson JS. Calcium supplementation in pregnancy and its impact on blood pressure in children and women: follow up of a randomised controlled trial. Australian & New Zealand Journal of Obstetrics & Gynaecology 2007; 47(2):115-121. | No outcomes of interest
Hillman LS, Haddad JG. Perinatal Vitamin D metabolism. II. Serial 25-hydroxyVitamin D concentrations in sera of term and premature infants. Journal of Pediatrics 1975; 86(6):928-935. | No clear Vitamin D dose for term infants
Hillman LS, Johnson LS, Lee DZ, Vieira NE, Yergey AL. Measurement of true absorption, endogenous fecal excretion, urinary excretion, and retention of calcium in term infants by using a dual-tracer, stable-isotope method. Journal of Pediatrics 1993; 123(3):444-456. | All neonates included weighed < 1500 gm
Hintzpeter B, Mensink GB, Thierfelder W, Muller MJ, Scheidt-Nave C. Vitamin D status and health correlates among German adults. European Journal of Clinical Nutrition 62 (9 ):1079 -89, 2008. | cross-sectional or retrospective assessment of diet after disease diagnosis
Hofmeyr GJ, Mlokoti Z, Nikodem VC et al. Calcium supplementation during pregnancy for preventing hypertensive disorders is not associated with changes in platelet count, urate, and urinary protein: a randomized control trial. Hypertension in Pregnancy 27 (3):299 -304, 2008. | ancillary study (small sample) of WHO trial. The preeclampsia data of WHO trial was already included in the previous SR (Hofmeyer2007).
Hofstad B, Almendingen K, Vatn M et al. Growth and recurrence of colorectal polyps: a double-blind 3-year intervention with calcium and antioxidants. Digestion 59 (2):148-56, 1998. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Hofstad B, Vatn MH, Andersen SN, Owen RW, Larsen S, Osnes M. The relationship between faecal bile acid profile with or without supplementation with calcium and antioxidants on recurrence and growth of colorectal polyps. European Journal of Cancer Prevention 7 (4):287-94, 1998. | No independent Ca effect
Hollis BW, Wagner CL. Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypoVitaminosis D for both the mother and the nursing infant. Am J Clin Nutr 2004; 80(6 Suppl):1752S-1758S. | In Ottawa EPC report
Hollis JH, Mattes RD. Effect of increased dairy consumption on appetitive ratings and food intake. [erratum appears in Obesity (Silver Spring). 2007 Oct;15(10):2520]. Obesity 2007; 15(6):1520-1526. | No outcomes of interest
Holt PR, Atillasoy EO, Gilman J et al. Modulation of abnormal colonic epithelial cell proliferation and differentiation by low-fat dairy foods: a randomized controlled trial. JAMA 280 (12):1074-9, 1998. | No outcomes of interest
Holt PR, Bresalier RS, Ma CK et al. Calcium plus Vitamin D alters preneoplastic features of colorectal adenomas and rectal mucosa. Cancer 106 (2):287-96, 2006. | No outcomes of interest
Holt PR, Wolper C, Moss SF, Yang K, Lipkin M. Comparison of calcium supplementation or low-fat dairy foods on epithelial cell proliferation and differentiation. Nutrition & Cancer 41 (1-2):150-5, 2001. | No outcomes of interest
Hunt CD, Johnson LK. Calcium requirements: new estimations for men and women by cross-sectional statistical analyses of calcium balance data from metabolic studies. American Journal of Clinical Nutrition 2007; 86(4):1054-1063. | Arrow 4: calcium balance
Hvarfner A, Ljunghall S, Morlin C, Wide L. Calcium metabolism and arterial blood pressure in a healthy population sample and in hypertensive men. American Journal of Nephrology 6 Suppl 1:14-5, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Hyman J, Baron JA, Dain BJ et al. Dietary and supplemental calcium and the recurrence of colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 7 (4):291-5, 1998. | Multiple antioxidant trials analyses
Hypponen E, Hartikainen AL, Sovio U, Jarvelin MR, Pouta A. Does Vitamin D supplementation in infancy reduce the risk of pre-eclampsia? European Journal of Clinical Nutrition 2007; 61(9):1136-1139. | Observational study estimated Vitamin D supplement doses
Hypponen E, Laara E, Reunanen A, Jarvelin MR, Virtanen SM. Intake of Vitamin D and risk of type 1 diabetes: a birth-cohort study. Lancet 358 (9292):1500-3, 2001. | Observational study estimated Vitamin D supplement doses
Hypponen E, Sovio U, Wjst M et al. Infant Vitamin d supplementation and allergic conditions in adulthood: northern Finland birth cohort 1966. Annals of the New York Academy of Sciences 1037:84-95, 2004. | Observational study estimated Vitamin D supplement doses
Ilich-Ernst JZ, McKenna AA, Badenhop NE et al. Iron status, menarche, and calcium supplementation in adolescent girls.[erratum appears in Am J Clin Nutr 1999 Mar;69(3):577]. American Journal of Clinical Nutrition 68 (4):880-7, 1998. | Ca intake, BMI, LBM and BW measured, but the analyses on the relationship among these were not performed.
Ish-Shalom S, Segal E, Salganik T, Raz B, Bromberg IL, Vieth R. Comparison of daily, weekly, and monthly vitamin D3 in ethanol dosing protocols for two months in elderly hip fracture patients. Journal of Clinical Endocrinology & Metabolism 93 (9 ):3430 -5, 2008. | arrow 4 RCT but daily doses were the same in the comparison groups (comparison of daily, weekly versus monthly dose)
Ito M, Koyama H, Ohshige A, Maeda T, Yoshimura T, Okamura H. Prevention of preeclampsia with calcium supplementation and Vitamin D3 in an antenatal protocol. International Journal of Gynaecology & Obstetrics 47 (2):115 -20, 1994. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Jackson RD, Donepudi S, Mysiw WJ. Epidemiology of fracture risk in the Women's Health Initiative. Current Osteoporosis Reports 6 (4):155 -61, 2008. | review paper
Jackson RD, Lacroix AZ, Cauley JA, McGowan J. The Women's Health Initiative calcium-Vitamin D trial: overview and baseline characteristics of participants. Annals of Epidemiology 13(9 Suppl):S98-106, 2003. | Overview of trial participants
Jackson RD, Lacroix AZ, Gass M et al. Calcium plus Vitamin D supplementation and the risk of fractures.[erratum appears in N Engl J Med. 2006 Mar 9;354(10):1102]. New England Journal of Medicine 354 (7):669-83, 2006. | Same as Wactawski-Wende 2006 RefID 1967 in which longer f/up data reported
Jacobs D. Calcium and myocardial infarction. South African Medical Journal Suid -Afrikaanse Tydskrif Vir Geneeskunde 48 (13):523-7, 1974. | No 25(OH)D or dietary Ca
Jacobs ET, Alberts DS, Benuzillo J, Hollis BW, Thompson PA, Martinez ME. Serum 25(OH)D levels, dietary intake of Vitamin D, and colorectal adenoma recurrence. Journal of Steroid Biochemistry & Molecular Biology 2007; 103(3-5):752-756. | Analyses include 25(OH)D measurements taken after outcome (colorectal polyps) occurred.
Jacques PF, Felson DT, Tucker KL et al. Plasma 25-hydroxyVitamin D and its determinants in an elderly population sample. American Journal of Clinical Nutrition 66 (4):929-36, 1997. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Joffe GM, Esterlitz JR, Levine RJ et al. The relationship between abnormal glucose tolerance and hypertensive disorders of pregnancy in healthy nulliparous women. Calcium for Preeclampsia Prevention (CPEP) Study Group.. American Journal of Obstetrics & Gynecology 179 (4):1032-7, 1998. | No 25(OH)D or dietary Ca
John EM, Dreon DM, Koo J, Schwartz GG. Residential sunlight exposure is associated with a decreased risk of prostate cancer. Journal of Steroid Biochemistry & Molecular Biology 89 -90 (1-5):549 -52, 2004. | No 25(OH)D or dietary Ca
John WG, Noonan K, Mannan N, Boucher BJ. HypoVitaminosis D is associated with reductions in serum apolipoprotein A-I but not with fasting lipids in British Bangladeshis. American Journal of Clinical Nutrition 82 (3):517-22, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Johnson MA, Fischer JG, Park S. Vitamin D deficiency and insufficiency in the Georgia Older Americans Nutrition Program. Journal of Nutrition for the Elderly 27 (1-2):29 -46, 2008. | combination of vit D/Ca and other treatment w/o analysis of independent effect
Johnson NE, Smith EL, Freudenheim JL. Effects on blood pressure of calcium supplementation of women. American Journal of Clinical Nutrition 42 (1):12-7, 1985. | In systematic review
Jones G, Scott F. Low bone mass in premenopausal parous women: identification and the effect of an information and bone density feedback program. Journal of Clinical Densitometry 2(2):109-15, 1999. | No outcomes of interest
Jorde R, Bonaa KH. Calcium from dairy products, Vitamin D intake, and blood pressure: the Tromso Study.. American Journal of Clinical Nutrition 71 (6):1530-5, 2000. | No outcomes of interest
Kampman E, Giovannucci E, van ', V et al. Calcium, Vitamin D, dairy foods, and the occurrence of colorectal adenomas among men and women in two prospective studies. Am J Epidemiol 1994; 139(1):16-29. | Same cohorts as Wu 2002 RefID 529 (HPFS & NHS) and same exposure-outcome relationship but shorter follow-up
Karanja N, Morris CD, Illingworth DR, McCarron DA. Plasma lipids and hypertension: response to calcium supplementation. American Journal of Clinical Nutrition 45 (1):60-5, 1987. | No outcomes of interest
Karanja N, Morris CD, Rufolo P, Snyder G, Illingworth DR, McCarron DA. Impact of increasing calcium in the diet on nutrient consumption, plasma lipids, and lipoproteins in humans. American Journal of Clinical Nutrition 59 (4):900-7, 1994. | No outcomes of interest
Kawano Y. Role of blood pressure monitoring in non-pharmacological management of hypertension. Blood Pressure Monitoring 7 (1):51-4, 2002. | Review paper
Kearney J, Giovannucci E, Rimm EB et al. Calcium, Vitamin D, and dairy foods and the occurrence of colon cancer in men. American Journal of Epidemiology 143 (9):907-17, 1996. | Longer followup data were published in Wu 2002
Kemi VE, Karkkainen MU, Karp HJ, Laitinen KA, Lamberg-Allardt CJ. Increased calcium intake does not completely counteract the effects of increased phosphorus intake on bone: an acute dose-response study in healthy females. British Journal of Nutrition 99 (4):832-9, 2008. | No outcomes of interest
Kenny AM, Bellantonio S, Gruman CA, Acosta RD, Prestwood KM. Effects of transdermal testosterone on cognitive function and health perception in older men with low bioavailable testosterone levels. Journals of Gerontology Series A-Biological Sciences & Medical Sciences 57 (5):M321-5, 2002. | No 25(OH)D or dietary Ca
Kenny AM, Biskup B, Robbins B, Marcella G, Burleson JA. Effects of Vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. Journal of the American Geriatrics Society 51 (12):1762-7, 2003. | In Ottawa EPC report
Kesteloot H, Geboers J. Calcium and blood pressure. Lancet 1(8276):813 -5, 1982. | No 25(OH)D or dietary Ca
Khaw KT, Barrett-Connor E. Dietary potassium and stroke-associated mortality. A 12-year prospective population study. New England Journal of Medicine 316 (5):235-40, 1987. | Continuous Ca intake analysis only
Kigutha HN, van Staveren WA, Wijnhoven TM, Hautvast JG. Maternal nutritional status may be stressed by seasonal fluctuations in food availability: evidence from rural women in Kenya. International Journal of Food Sciences & Nutrition 46 (3):247-55, 1995. | Ca intake, BMI and BW measured, but analysis did not relate Ca intake to BMI/BW.
Knekt P, Laaksonen M, Mattila C et al. Serum Vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology. 19(5):666-71, 2008 Sep. | No outcomes of interest
Knight KB, Keith RE. Calcium supplementation on normotensive and hypertensive pregnant women. American Journal of Clinical Nutrition 55 (4):891-5, 1992. | No outcomes of interest
Knox EG. Ischaemic-heart-disease mortality and dietary intake of calcium. Lancet 1(7818):1465-7, 1973. | Analysis @ region level, not individual level
Kobayashi E, Okubo Y, Suwazono Y et al. Association between urinary calcium excretion level and mortality in inhabitants of the Jinzu River basin area of Japan. Biological Trace Element Research 89(2):145-53, 2002. | No 25(OH)D or dietary Ca
Koh-Banerjee PK, Ferreira MP, Greenwood M et al. Effects of calcium pyruvate supplementation during training on body composition, exercise capacity, and metabolic responses to exercise. Nutrition 21(3):312-9, 2005. | No 25(OH)D or dietary Ca
Kokot F, Pietrek J, Srokowska S et al. 25-hydroxyVitamin D in patients with essential hypertension. Clinical Nephrology 16 (4):188-92, 1981. | On drug Rx for hypertension
Koralek DO, Bertone-Johnson ER, Leitzmann MF et al. Relationship between calcium, lactose, Vitamin D, and dairy products and ovarian cancer. Nutrition & Cancer 2006; 56(1):22-30. | No outcomes of interest
Kristal AR, Chi C, Tangen CM, Goodman PJ, Etzioni R, Thompson IM. Associations of demographic and lifestyle characteristics with prostate-specific antigen (PSA) concentration and rate of PSA increase. Cancer 106 (2):320-8, 2006. | No outcomes of interest
Kromhout D, Bosschieter EB, Coulander CD. Potassium, calcium, alcohol intake and blood pressure: the Zutphen Study. American Journal of Clinical Nutrition 41 (6):1299-304, 1985. | No outcomes of interest
Kulier R, de OM, Gulmezoglu AM, Villar J. Nutritional interventions for the prevention of maternal morbidity. International Journal of Gynaecology & Obstetrics 63 (3):231-46, 1998. | SR of prevention of maternal morbidity
Kumar R, Cohen WR, Silva P, Epstein FH. Elevated 1,25-dihydroxyVitamin D plasma levels in normal human pregnancy and lactation. Journal of Clinical Investigation 63 (2):342-4, 1979. | No outcomes of interest
Kuroda T, Shiraki M, Tanaka S, Ohta H. Contributions of 25-hydroxyvitamin D, co-morbidities and bone mass to mortality in Japanese postmenopausal women. Bone 44 (1):168 -72, 2009. | >=20% subjects with diseases
Kynast-Gales SA, Massey LK. Effects of dietary calcium from dairy products on ambulatory blood pressure in hypertensive men.. Journal of the American Dietetic Association 92 (12):1497-501, 1992. | In systematic review
Laaksi I, Ruohola JP, Tuohimaa P et al. An association of serum Vitamin D concentrations < 40 nmol/L with acute respiratory tract infection in young Finnish men. American Journal of Clinical Nutrition 86 (3):714-7, 2007. | No outcomes of interest
Lakdawala DR, Widdowson EM. Vitamin-D in human milk. Lancet 1(8004):167-8, 1977. | No outcomes of interest
Lamberg-Allardt C, Larjosto M, Schultz E. 25-HydroxyVitamin D concentrations in maternal and cord blood at delivery and in maternal blood during lactation in Finland. Human Nutrition - Clinical Nutrition 38 (4):261-8, 1984. | Not RCT arrow 4 study
Lancia B, Tedesco M, Sergio G, Tenna M. Anthropometric and nutritional assessment in Italian elderly subjects. Journal of Nutrition, Health & Aging 1(3):174-80, 1997. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lappe JM, Davies KM, Travers-Gustafson D, Heaney RP. Vitamin D status in a rural postmenopausal female population. Journal of the American College of Nutrition 2006; 25(5):395-402. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Laraia BA, Bodnar LM, Siega-Riz AM. Pregravid body mass index is negatively associated with diet quality during pregnancy. Public Health Nutrition 2007; 10(9):920-926. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lasco A, Gaudio A, Morini E et al. Effect of long-term treatment with raloxifene on mammary density in postmenopausal women. Menopause 2006; 13(5):787-792. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Latham NK, Anderson CS, Lee A et al. A randomized, controlled trial of quadriceps resistance exercise and Vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). Journal of the American Geriatrics Society 51 (3):291-9, 2003. | In Ottawa EPC report
Le BN, Cancela L, Miravet L. Calcidiol in human milk. The effect of prohormone on Vitamin D status of breast fed unsupplemented infants. Endocrinologia Experimentalis. 20(2-3):325-8, 1986. | Correlation b/tw breastmilk 25(OH)D with infant's serum 25(OH)D
Lee DC, Lee GY. The use of pamidronate for hypercalcemia secondary to acute Vitamin D intoxication. Journal of Toxicology - Clinical Toxicology 36 (7):719-21, 1998. | Case report
Lee WT, Leung SS, Wang SH et al. Double-blind, controlled calcium supplementation and bone mineral accretion in children accustomed to a low-calcium diet.. American Journal of Clinical Nutrition 60 (5):744 -50, 1994. | In Winzenberg 2007 systematic review, no outcomes of interest
Levine AJ, Harper JM, Ervin CM et al. Serum 25-hydroxyVitamin D, dietary calcium intake, and distal colorectal adenoma risk. Nutrition & Cancer 2001; 39(1):35-41. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Levine RJ, Esterlitz JR, Raymond EG et al. Trial of Calcium for Preeclampsia Prevention (CPEP): rationale, design, and methods. Controlled Clinical Trials 17(5):442-69, 1996. | Methods for trial
Levine RJ, Hauth JC, Curet LB et al. Trial of calcium to prevent preeclampsia.. New England Journal of Medicine 337 (2):69-76, 1997. | In Hofmeyer 2007 systematic review
Lewandowski S, Rodgers AL. Renal response to lithogenic and anti-lithogenic supplement challenges in a stone-free population group. Journal of Renal Nutrition 14(3):170-9, 2004. | No UL outcomes: saturation of CaOx
Liebman M, Chopin LF, Carter E et al. Factors related to blood pressure in a biracial adolescent female population. Hypertension 8(10):843-50, 1986. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lin PH, Appel LJ, Funk K et al. The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. Journal of the American Dietetic Association 2007; 107(9):1541-1551. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Lin YC, Lyle RM, McCabe LD, McCabe GP, Weaver CM, Teegarden D. Dairy calcium is related to changes in body composition during a two-year exercise intervention in young women. Journal of the American College of Nutrition. 19(6):754-60, 2000 Nov-Dec. | No outcomes of interest
Lind L, Lithell H, Skarfors E, Wide L, Ljunghall S. Reduction of blood pressure by treatment with alphacalcidol. A double-blind, placebo-controlled study in subjects with impaired glucose tolerance. Acta Medica Scandinavica 223 (3):211-7, 1988. | >=20% subjects with diseases
Lipkin M, Friedman E, Winawer SJ, Newmark H. Colonic epithelial cell proliferation in responders and nonresponders to supplemental dietary calcium. Cancer Research 49 (1):248 -54, 1989. | >=20% subjects with diseases
Lipkin M, Newmark H. Effect of added dietary calcium on colonic epithelial-cell proliferation in subjects at high risk for familial colonic cancer. New England Journal of Medicine 313 (22):1381-4, 1985. | No outcomes of interest
Liu LS. Epidemiology of hypertension and cardiovascular disease--China experience. Clinical & Experimental Hypertension - Part A, Theory & Practice 12 (5):831-44, 1990. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Liu S, Choi HK, Ford E et al. A prospective study of dairy intake and the risk of type 2 diabetes in women. Diabetes Care 29 (7):1579-84, 2006. | No 25(OH)D or dietary Ca
Ljunghall S, Lind L, Lithell H et al. Treatment with one-alpha-hydroxycholecalciferol in middle-aged men with impaired glucose tolerance--a prospective randomized double-blind study. Acta Medica Scandinavica 222 (4):361-7, 1987. | >=20% subjects with diseases
Lonzer MD, Imrie R, Rogers D, Worley D, Licata A, Secic M. Effects of heredity, age, weight, puberty, actiVitaminy, and calcium intake on bone mineral density in children. Clinical Pediatrics 35 (4):185-9, 1996. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Lopez-Jaramillo P, Delgado F, Jacome P, Teran E, Ruano C, Rivera J. Calcium supplementation and the risk of preeclampsia in Ecuadorian pregnant teenagers. Obstetrics & Gynecology 90 (2):162-7, 1997. | In Hofmeyer 2007 systematic review
Lopez-Jaramillo P, Narvaez M, Weigel RM, Yepez R. Calcium supplementation reduces the risk of pregnancy-induced hypertension in an Andes population. British Journal of Obstetrics & Gynaecology 96 (6):648 -55, 1989. | In Hofmeyer 2007 systematic review
Luft FC, Aronoff GR, Sloan RS, Fineberg NS, Weinberger MH. Short-term augmented calcium intake has no effect on sodium homeostasis. Clinical Pharmacology & Therapeutics 39 (4):414-9, 1986. | No outcomes of interest
Lutter CK, Rodriguez A, Fuenmayor G, Avila L, Sempertegui F, Escobar J. Growth and micronutrient status in children receiving a fortified complementary food. Journal of Nutrition 138 (2):379-88, 2008. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Lyle RM. Does baseline serum total calcium level influence the blood pressure response to calcium supplementation? A double-blind study. Netherlands Journal of Medicine 41 (1-2):48-55, 1992. | In systematic review
Lynch MF, Griffin IJ, Hawthorne KM, Chen Z, Hamzo M, Abrams SA. Calcium balance in 1-4-y-old children. American Journal of Clinical Nutrition 2007; 85(3):750-754. | Arrow 4: calcium balance
Ma J, Stampfer MJ, Gann PH et al. Vitamin D receptor polymorphisms, circulating Vitamin D metabolites, and risk of prostate cancer in United States physicians. Cancer Epidemiology, Biomarkers & Prevention 7 (5):385-90, 1998. | Main results had been previous published (Gann 1996, RefID 3783), and no additional usable data
Macdonald HM, New SA, Campbell MK, Reid DM. Longitudinal changes in weight in perimenopausal and early postmenopausal women: effects of dietary energy intake, energy expenditure, dietary calcium intake and hormone replacement therapy. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 27 (6):669-76, 2003. | No outcomes of interest
Madore F, Stampfer MJ, Rimm EB, Curhan GC. Nephrolithiasis and risk of hypertension. American Journal of Hypertension 11(1 Pt 1):46-53, 1998. | No outcomes of interest
Malila N, Virtanen M, Pietinen P et al. A comparison of prospective and retrospective assessments of diet in a study of colorectal cancer. Nutrition & Cancer 32 (3):146 -53, 1998. | Superseded by Pietinen 1999
Mandic-Puljek M, Mandic ML, Perl A, Kenjeric D. Calcium intake, food sources and seasonal variations in eastern Croatia. Collegium Antropologicum 29 (2):503-7, 2005. | No outcomes of interest
Manios Y, Moschonis G, Grammatikaki E, Katsaroli I, Kanelou P, Tanagra S. Nutrition education in postmenopausal women: changes in dietary and cardiovascular indices. Maturitas 2006; 55(4):338-347. | Nutrition education intervention study
Marangella M, Vitaminale C, Petrarulo M, Rovera L, Dutto F. Effects of mineral composition of drinking water on risk for stone formation and bone metabolism in idiopathic calcium nephrolithiasis. Clinical Science 91 (3):313-8, 1996. | No UL outcomes: saturation of CaOx
Markestad T, Kolmannskog S, Arntzen E, Toftegaard L, Haneberg B, Aksnes L. Serum concentrations of Vitamin D metabolites in exclusively breast-fed infants at 70 degrees north. Acta Paediatrica Scandinavica 73 (1):29-32, 1984. | No relation with 25(OH)D to growth outcome
Markestad T. Effect of season and Vitamin D supplementation on plasma concentrations of 25-hydroxyVitamin D in Norwegian infants. Acta Paediatrica Scandinavica 72 (6):817-21, 1983. | Not RCT arrow 4 study
Markestad T. Plasma concentrations of Vitamin D metabolites in unsupplemented breast-fed infants. European Journal of Pediatrics 141 (2):77-80, 1983. | No outcomes of interest
Marniemi J, Jarvisalo J, Toikka T, Raiha I, Ahotupa M, Sourander L. Blood Vitamins, mineral elements and inflammation markers as risk factors of vascular and non-vascular disease mortality in an elderly population. International Journal of Epidemiology 27 (5):799-807, 1998. | No 25(OH)D or dietary Ca
Martinez ME, Giovannucci EL, Colditz GA et al. Calcium, Vitamin D, and the occurrence of colorectal cancer among women. Journal of the National Cancer Institute 88 (19):1375-82, 1996. | Longer followup data were published in Wu 2002
Marx SJ, Swart EG, Jr., Hamstra AJ, DeLuca HF. Normal intrauterine development of the fetus of a woman receiving extraordinarily high doses of 1,25-dihydroxyVitamin D3. Journal of Clinical Endocrinology & Metabolism 51 (5):1138 -42, 1980. | Case report
Masse PG, Tranchant CC, Jougleux JL, Coburn SP, Cole DE. Cardiovascular disease-risk factors in middle-aged osteopaenic women treated with calcium alone or combined to three nutrients essential to artery and bone collagen. Journal of Human Nutrition & Dietetics 21(2):117-28, 2008. | No outcomes of interest
Matheson NA. Letter: Multiple sclerosis and diet. Lancet 2 (7884):831, 1974. | Letter to the editor
Matsumoto T, Kubodera N. ED-71, a new active Vitamin D3, increases bone mineral density regardless of serum 25(OH)D levels in osteoporotic subjects. Journal of Steroid Biochemistry & Molecular Biology 2007; 103(3-5):584-586. | Vitamin D analog
Mawer EB, Berry JL, Sommer-Tsilenis E, Beykirch W, Kuhlwein A, Rohde BT. Ultraviolet irradiation increases serum 1,25-dihydroxyVitamin D in Vitamin-D-replete adults. Mineral & Electrolyte Metabolism 10(2):117-21, 1984. | Not RCT arrow 4 study
Mazess RB, Peppler WW, Chesnut CH, III, Nelp WB, Cohn SH, Zanzi I. Total body bone mineral and lean body mass by dual-photon absorptiometry. II. Comparison with total body calcium by neutron activation analysis. Calcified Tissue International 33 (4):361-3, 1981. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Mazess RB, Peppler WW, Harrison JE, McNeill KG. Total body bone mineral and lean body mass by dual-photon absorptiometry. III. Comparison with trunk calcium by neutron activation analysis. Calcified Tissue International 33 (4):365-8, 1981. | No 25(OH)D or dietary Ca
McCarron DA, Morris CD. Blood pressure response to oral calcium in persons with mild to moderate hypertension. A randomized, double-blind, placebo-controlled, crossover trial. Annals of Internal Medicine 103 (6 (Pt 1)):825 -31, 1985. | In systematic review
Merlino LA, Curtis J, Mikuls TR et al. Vitamin D intake is inversely associated with rheumatoid arthritis: results from the Iowa Women's Health Study.. Arthritis & Rheumatism 50(1):72-7, 2004. | Observational study estimated Vitamin D supplement doses
Methy N, Binquet C, Boutron-Ruault MC, Paillot B, Faivre J, Bonithon-Kopp C. Dietary fatty acids and recurrence of colorectal adenomas in a European intervention trial. Nutrition & Cancer 60 (5):560-7, 2008. | no 25(OH)D or dietary Ca
Michaud DS, Spiegelman D, Clinton SK, Rimm EB, Willett WC, Giovannucci E. Prospective study of dietary supplements, macronutrients, micronutrients, and risk of bladder cancer in US men. American Journal of Epidemiology 152 (12):1145-53, 2000. | No outcomes of interest
Misselwitz J, Hesse V, Markestad T. Nephrocalcinosis, hypercalciuria and elevated serum levels of 1,25-dihydroxyVitamin D in children. Possible link to Vitamin D toxicity. Acta Paediatrica Scandinavica 79 (6-7):637-43, 1990. | Case report
Moerman CJ, Smeets FW, Kromhout D. Dietary risk factors for clinically diagnosed gallstones in middle-aged men. A 25-year follow-up study (the Zutphen Study). Annals of Epidemiology 4(3):248-54, 1994. | No outcomes of interest
Mohr SB, Garland CF, Gorham ED, Garland FC. The association between ultraviolet B irradiance, vitamin D status and incidence rates of type 1 diabetes in 51 regions worldwide. Diabetologia 51 (8 ):1391-8, 2008. | ecological study
Moller UK, Ramlau-Hansen CH, Rejnmark L, Heickendorff L, Henriksen TB, Mosekilde L. Postpartum Vitamin D insufficiency and secondary hyperparathyroidism in healthy Danish women. European Journal of Clinical Nutrition 2006; 60(10):1214-1221. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Morley R, Carlin JB, Dwyer T. Maternal calcium supplementation and cardiovascular risk factors in twin offspring. International Journal of Epidemiology 33 (6):1304-9, 2004. | No 25(OH)D or dietary Ca
Morosetti M, Jankovic L, Palombo G et al. High-dose calcitriol therapy and progression of cardiac vascular calcifications. Journal of Nephrology 21(4):603 -8, 2008; Aug. | i.v. calcitriol
Morris CD, McCarron DA. Effect of calcium supplementation in an older population with mildly increased blood pressure. American Journal of Hypertension 5(4 Pt 1):230-7, 1992. | No outcomes of interest
Munger KL, Levin LI, Hollis BW, Howard NS, Ascherio A. Serum 25-hydroxyVitamin D levels and risk of multiple sclerosis. JAMA. 296(23):2832-8, 2006 Dec 20. | No outcomes of interest
Muray S, Marco MP, Craver L, Rue M, Valdivielso JM, Fernandez E. Influence of mineral metabolism parameters on pulse pressure in healthy subjects.. Clinical Nephrology 2006; 66(6):411-417. | No 25(OH)D or dietary Ca
Nakamura K, Nishiwaki T, Ueno K, Yamamoto M. Age-related decrease in serum 25-hydroxyVitamin D concentrations in the frail elderly: a longitudinal study. Journal of Bone & Mineral Metabolism 2007; 25(4):232-236. | Effect of aging on 25(OH) D
Nakamura R, Saruta T. Effect of calcium supplementation on blood pressure in essential hypertensive subjects. Japanese Journal of Medicine 26 (2):203-6, 1987. | No outcomes of interest
Nako Y, Fukushima N, Tomomasa T, Nagashima K, Kuroume T. HyperVitaminosis D after prolonged feeding with a premature formula. Pediatrics 1993; 92(6):862-864. | Case report
Narang NK, Gupta RC, Jain MK. Role of Vitamin D in pulmonary tuberculosis. Journal of the Association of Physicians of India 32 (2):185-8, 1984. | No outcomes of interest
Nayir A, Kadioglu A, Sirin A, Emre S, Tonguc E, Bilge I. Causes of increased renal medullary echogenicity in Turkish children. Pediatric Nephrology 9 (6):729-33, 1995. | Case report
Need AG, O'Loughlin PD, Horowitz M, Nordin BE. Relationship between fasting serum glucose, age, body mass index and serum 25 hydroxyVitamin D in postmenopausal women. Clinical Endocrinology 62 (6):738-41, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Nieves JW, Barrett-Connor E, Siris ES, Zion M, Barlas S, Chen YT. Calcium and vitamin D intake influence bone mass, but not short-term fracture risk, in Caucasian postmenopausal women from the National Osteoporosis Risk Assessment (NORA) study. Osteoporosis International 1919;673-9. | not RCT bone study (postmenopausal women)
Nilas L, Christiansen C. Treatment with Vitamin D or its analogues does not change body weight or blood glucose level in postmenopausal women. International Journal of Obesity 8(5):407-11, 1984. | Review paper
Niromanesh S, Laghaii S, Mosavi-Jarrahi A. Supplementary calcium in prevention of pre-eclampsia. International Journal of Gynaecology & Obstetrics 74 (1):17-21, 2001. | In Hofmeyer 2007 systematic review
Nishimura K, Shima M, Tsugawa N et al. Long-term hospitalization during pregnancy is a risk factor for Vitamin D deficiency in neonates.[erratum appears in J Bone Miner Metab. 2003;21(4):253]. Journal of Bone & Mineral Metabolism 21(2):103-8, 2003. | No outcomes of interest
Nishiyama T. Effects of calcium on muscular training. Journal of Nutritional Science & Vitaminology 31 Suppl: S45-7, 1985. | Calcium only and bone/muscle outcomes
Nowak A, Pachocka L, Targosz U, Klosiewicz-Latoszek L. Dietary calcium and obesity in men. Roczniki Panstwowego Zakladu Higieny 58 (1):301-5, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Nowson C, Morgan T. Effect of calcium carbonate on blood pressure in normotensive and hypertensive people. Hypertension 13(6 Pt 1):630-9, 1989. | In systematic review
Obarzanek E, Hunsberger SA, Van HL et al. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics 100 (1):51-9, 1997. | No outcomes of interest
Ochner CN, Lowe MR. Self-reported changes in dietary calcium and energy intake predict weight regain following a weight loss diet in obese women. Journal of Nutrition 2007; 137(10):2324-2328. | No outcomes of interest
Olafsdottir AS, Wagner KH, Thorsdottir I, Elmadfa I. Fat-soluble Vitamins in the maternal diet, influence of cod liver oil supplementation and impact of the maternal diet on human milk composition. Annals of Nutrition & Metabolism 45 (6):265-72, 2001. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Paganus A, Juntunen-Backman K, Savilahti E. Follow-up of nutritional status and dietary survey in children with cow's milk allergy. Acta Paediatrica 81 (6-7):518 -21, 1992. | >=20% subjects with diseases
Palacios C, Benedetti P, Fonseca S. Impact of calcium intake on body mass index in Venezuelan adolescents. Puerto Rico Health Sciences Journal 26 (3):199-204, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Park SB, Suh DH, Youn JI. A pilot study to assess the safety and efficacy of topical calcipotriol treatment in childhood psoriasis. Pediatric Dermatology 16 (4):321-5, 1999. | No 25(OH)D or dietary Ca
Pasch A, Frey FJ, Eisenberger U, Mohaupt MG, Bonny O. PTH and 1.25 vitamin D response to a low-calcium diet is associated with bone mineral density in renal stone formers. Nephrology Dialysis Transplantation 23(8 ):2563-70, 2008. | no outcomes of interest
Pehlivan I, Hatun S, Aydogan M, Babaoglu K, Gokalp AS. Maternal Vitamin D deficiency and Vitamin D supplementation in healthy infants. Turkish Journal of Pediatrics 45 (4):315-20, 2003;-Dec. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Peters U, Hayes RB, Chatterjee N et al. Circulating Vitamin D metabolites, polymorphism in Vitamin D receptor, and colorectal adenoma risk. Cancer Epidemiology, Biomarkers & Prevention 2004; 13(4):546-552. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Peters U, McGlynn KA, Chatterjee N et al. Vitamin D, calcium, and Vitamin D receptor polymorphism in colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention 2001; 10(12):1267-1274. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Pettifor JM, Bikle DD, Cavaleros M, Zachen D, Kamdar MC, Ross FP. Serum levels of free 1,25-dihydroxyVitamin D in Vitamin D toxicity. Annals of Internal Medicine 122 (7):511-3, 1995. | Case report
Phillips SM, Bandini LG, Cyr H, Colclough-Douglas S, Naumova E, Must A. Dairy food consumption and body weight and fatness studied longitudinally over the adolescent period. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity 27 (9):1106-13, 2003. | Not RCT growth study
Pilz S, Dobnig H, Fischer JE et al. Low Vitamin d levels predict stroke in patients referred to coronary angiography. Stroke 39 (9):2611-3, 2008. | >=20% subjects with diseases
Pilz S, Dobnig H, Winklhofer-Roob B et al. Low serum levels of 25-hydroxyVitamin D predict fatal cancer in patients referred to coronary angiography. Cancer Epidemiology, Biomarkers & Prevention 17(5):1228-33, 2008. | >=20% subjects with diseases
Pittard WB, III, Geddes KM, Hulsey TC, Hollis BW. How much Vitamin D for neonates? American Journal of Diseases of Children 145 (10):1147-9, 1991. | Not RCT arrow 4 study
Pittard WB, III, Geddes KM, Sutherland SE, Miller MC, Hollis BW. Longitudinal changes in the bone mineral content of term and premature infants. American Journal of Diseases of Children 1990; 144(1):36-40. | Changes in 25(OH)D status of term and premature infants
Pittas AG, Harris SS, Stark PC, wson-Hughes B. The effects of calcium and Vitamin D supplementation on blood glucose and markers of inflammation in nondiabetic adults.. Diabetes Care 2007; 30(4):980-986. | No outcomes of interest
Porojnicu AC, Robsahm TE, Dahlback A et al. Seasonal and geographical variations in lung cancer prognosis in Norway. Does Vitamin D from the sun play a role? Lung Cancer 2007; 55(3):263-270. | Ecological study
Prentice A, Ginty F, Stear SJ, Jones SC, Laskey MA, Cole TJ. Calcium supplementation increases stature and bone mineral mass of 16- to 18-year-old boys. Journal of Clinical Endocrinology & Metabolism 90 (6):3153-61, 2005. | In Winzenberg 2007 systematic review
Prineas RJ, Folsom AR, Zhang ZM, Sellers TA, Potter J. Nutrition and other risk factors for renal cell carcinoma in postmenopausal women. Epidemiology 8 (1):31-6, 1997. | No outcomes of interest
Purwar M, Kulkarni H, Motghare V, Dhole S. Calcium supplementation and prevention of pregnancy induced hypertension. Journal of Obstetrics & Gynaecology Research 22 (5):425-30, 1996. | In Hofmeyer 2007 systematic review
Rajalakshmi R, Sail SS, Shah DG, Ambady SK. The effects of supplements varying in carotene and calcium content on the physical, biochemical and skeletal status of preschool children. British Journal of Nutrition 30 (1):77-86, 1973. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Rajpathak SN, Rimm EB, Rosner B, Willett WC, Hu FB. Calcium and dairy intakes in relation to long-term weight gain in US men. American Journal of Clinical Nutrition 83 (3):559-66, 2006. | No outcomes of interest
Rees GA, Doyle W, Srivastava A, Brooke ZM, Crawford MA, Costeloe KL. The nutrient intakes of mothers of low birth weight babies - a comparison of ethnic groups in East London, UK. Maternal & Child Nutrition 1(2):91-9, 2005. | No outcomes of interest
Repke JT, Villar J, Anderson C, Pareja G, Dubin N, Belizan JM. Biochemical changes associated with blood pressure reduction induced by calcium supplementation during pregnancy. American Journal of Obstetrics & Gynecology 160 (3):684-90, 1989. | In Hofmeyer 2007 systematic review
Repke JT, Villar J. Pregnancy-induced hypertension and low birth weight: the role of calcium. American Journal of Clinical Nutrition 1991; 54(1:Suppl): Suppl-241S. | Review paper
Resnick LM, Oparil S, Chait A et al. Factors affecting blood pressure responses to diet: the Vanguard study. American Journal of Hypertension 13(9):956-65, 2000. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Reunanen A, Knekt P, Marniemi J, Maki J, Maatela J, Aromaa A. Serum calcium, magnesium, copper and zinc and risk of cardiovascular death. European Journal of Clinical Nutrition 50 (7):431-7, 1996. | No 25(OH)D or dietary Ca
Rich GM, McCullough M, Olmedo A, Malarick C, Moore TJ. Blood pressure and renal blood flow responses to dietary calcium and sodium intake in humans. American Journal of Hypertension 4(11):642S-645S, 1991. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Roberts CC, Chan GM, Folland D, Rayburn C, Jackson R. Adequate bone mineralization in breast-fed infants. Journal of Pediatrics 99 (2):192-6, 1981. | In Ottawa EPC report
Robien K, Cutler GJ, Lazovich D. Vitamin D intake and breast cancer risk in postmenopausal women: the Iowa Women's Health Study. Cancer Causes & Control 2007; 18(7):775-782. | Observational study estimated Vitamin D supplement doses
Rogers MS, Fung HY, Hung CY. Calcium and low-dose aspirin prophylaxis in women at high risk of pregnancy-induced hypertension. Hypertension in Pregnancy 18 (2):165-72, 1999. | In Hofmeyer 2007 systematic review
Roongpisuthipong C, Kantawan R, Roongpisuthipong W. Reduction of adipose tissue and body weight: effect of water soluble calcium hydroxycitrate in Garcinia atroviridis on the short term treatment of obese women in Thailand. Asia Pacific Journal of Clinical Nutrition 2007; 16(1):25-29. | No 25(OH)D or dietary Ca
Rosell M, Hakansson NN, Wolk A. Association between dairy food consumption and weight change over 9 y in 19,352 perimenopausal women. American Journal of Clinical Nutrition 2006; 84(6):1481-1488. | Ca intake and BW measured but not assessed ==> no relevant results reported
Rothberg AD, Pettifor JM, Cohen DF, Sonnendecker EW, Ross FP. Maternal-infant Vitamin D relationships during breast-feeding. Journal of Pediatrics 101 (4):500-3, 1982. | In Ottawa EPC report
Rourke KM, Brehm BJ, Cassell C, Sethuraman G. Effect of weight change on bone mass in female adolescents. Journal of the American Dietetic Association 103 (3):369-72, 2003. | No 25(OH)D or dietary Ca
Rozen P, Fireman Z, Fine N, Wax Y, Ron E. Oral calcium suppresses increased rectal epithelial proliferation of persons at risk of colorectal cancer. Gut 30(5):650-5, 1989. | No outcomes of interest
Rozen P, Lubin F, Papo N et al. Calcium supplements interact significantly with long-term diet while suppressing rectal epithelial proliferation of adenoma patients. Cancer 91 (4):833-40, 2001. | No outcomes of interest
Rumiris D, Purwosunu Y, Wibowo N, Farina A, Sekizawa A. Lower rate of preeclampsia after antioxidant supplementation in pregnant women with low antioxidant status. Hypertension in Pregnancy 2006; 25(3):241-253. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Rush D, Sloan NL, Leighton J et al. The National WIC Evaluation: evaluation of the Special Supplemental Food Program for Women, Infants, and Children. V. Longitudinal study of pregnant women. American Journal of Clinical Nutrition 48 (2 Suppl):439-83, 1988. | No exposure of interest
Saadi HF, Dawodu A, Afandi B et al. Effect of combined maternal and infant vitamin D supplementation on vitamin D status of exclusively breastfed infants. Maternal & Child Nutrition 5(1):25 -32, 2009. | arrow 4 RCT but daily doses were the same in the comparison groups (comparison of daily vs. monthly doses)
Sacks FM, Brown LE, Appel L, Borhani NO, Evans D, Whelton P. Combinations of potassium, calcium, and magnesium supplements in hypertension. Hypertension 26 (6 Pt 1):950-6, 1995. | Combinations of minerals
Sacks FM, Obarzanek E, Windhauser MM et al. Rationale and design of the Dietary Approaches to Stop Hypertension trial (DASH). A multicenter controlled-feeding study of dietary patterns to lower blood pressure. Annals of Epidemiology 5(2):108-18, 1995. | No outcomes of interest
Sacks FM, Willett WC, Smith A, Brown LE, Rosner B, Moore TJ. Effect on blood pressure of potassium, calcium, and magnesium in women with low habitual intake. Hypertension 31 (1):131-8, 1998. | In systematic review
Saito K, Sano H, Kawahara J, Yokoyama M. Calcium supplementation attenuates an enhanced platelet function in salt-loaded mildly hypertensive patients. Hypertension 26 (1):156-63, 1995. | Data too incomplete
Sakhaee K, Baker S, Zerwekh J, Poindexter J, Garcia-Hernandez PA, Pak CY. Limited risk of kidney stone formation during long-term calcium citrate supplementation in nonstone forming subjects. Journal of Urology 152 (2 Pt 1):324-7, 1994. | No UL outcomes
Sakhaee K, Poindexter JR, Griffith CS, Pak CY. Stone forming risk of calcium citrate supplementation in healthy postmenopausal women. Journal of Urology 172 (3):958-61, 2004. | No UL outcomes: saturation of CaOx
Salazar-Martinez E, Lazcano-Ponce E, Sanchez-Zamorano LM, Gonzalez-Lira G, Escudero-DE Los RP, Hernandez-Avila M. Dietary factors and endometrial cancer risk. Results of a case-control study in Mexico. International Journal of Gynecological Cancer 15 (5):938-45, 2005. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sampath V, Havel PJ, King JC. Calcium supplementation does not alter lipid oxidation or lipolysis in overweight/obese women. Obesity 16 (11):2400-4, 2008. | not RCT wt study
Sanchez-Ramos L, Adair CD, Kaunitz AM, Briones DK, Del Valle GO, Delke I. Calcium supplementation in mild preeclampsia remote from term: a randomized double-blind clinical trial. Obstetrics & Gynecology 85 (6):915-8, 1995. | 100% patients with already diagnosed “mild” preeclampsia
Sanchez-Ramos L, Briones DK, Kaunitz AM, Delvalle GO, Gaudier FL, Walker CD. Prevention of pregnancy-induced hypertension by calcium supplementation in angiotensin II-sensitive patients. Obstetrics & Gynecology 84 (3):349-53, 1994. | In Hofmeyer 2007 systematic review
Sanders TA, Purves R. An anthropometric and dietary assessment of the nutritional status of vegan preschool children. Journal of Human Nutrition 35 (5):349-57, 1981. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sato K, Emoto N, Toraya S et al. Progressively increased serum 1,25-dihydroxyVitamin D2 concentration in a hypoparathyroid patient with protracted hypercalcemia due to Vitamin D2 intoxication. Endocrine Journal 41 (4):329-37, 1994. | Case report
Satterfield S, Cutler JA, Langford HG et al. Trials of hypertension prevention. Phase I design. Annals of Epidemiology 1(5):455-71, 1991. | Shows research design, but no result
Schleithoff SS, Zittermann A, Tenderich G, Berthold HK, Stehle P, Koerfer R. Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial.[see comment]. American Journal of Clinical Nutrition 83 (4):754 -9, 2006. | >=20% subjects with diseases
Schumann SA, Ewigman B. Double-dose Vitamin D lowers cancer risk in women over 55. Journal of Family Practice 2007; 56(11):907-910. | Editorial-like brief review
Sellers TA, Bazyk AE, Bostick RM et al. Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes & Control 9(4):357-67, 1998. | Same cohort as Zheng 1998 (RefID 2924) only difference is that taking into consideration the family history of colon cancer in the analysis
Shahar DR, Abel R, Elhayany A, Vardi H, Fraser D. Does dairy calcium intake enhance weight loss among overweight diabetic patients? Diabetes Care 2007; 30(3):485-489. | >=20% subjects with diseases
Shapses SA, Heshka S, Heymsfield SB. Effect of calcium supplementation on weight and fat loss in women. Journal of Clinical Endocrinology & Metabolism 89 (2):632-7, 2004. | In systematic review
Sharkey JR, Giuliani C, Haines PS, Branch LG, Busby-Whitehead J, Zohoori N. Summary measure of dietary musculoskeletal nutrient (calcium, Vitamin D, magnesium, and phosphorus) intakes is associated with lower-extremity physical performance in homebound elderly men and women. American Journal of Clinical Nutrition 77 (4):847-56, 2003. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Shaunak S, Ang L, Colston K, Patel S, Bland M, Maxwell JD. Muscle strength in healthy white and Asian subjects: the relationship of quadriceps maximum voluntary contraction to age, sex, body build and Vitamin D. Clinical Science 73 (5):541-6, 1987. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Sibai BM, Ewell M, Levine RJ et al. Risk factors associated with preeclampsia in healthy nulliparous women. The Calcium for Preeclampsia Prevention (CPEP) Study Group. American Journal of Obstetrics & Gynecology 177 (5):1003-10, 1997. | No Ca dose
Sieg J, Sieg A, Dreyhaupt J, Schmidt-Gayk H. Insufficient Vitamin D supply as a possible co-factor in colorectal carcinogenesis. Anticancer Research 26 (4A):2729 -33, 2006. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Silverman SL, Delmas PD, Kulkarni PM, Stock JL, Wong M, Plouffe L, Jr. Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. Journal of the American Geriatrics Society 52 (9):1543-8, 2004. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Sita-Lumsden A, Lapthorn G, Swaminathan R, Milburn HJ. Reactivation of tuberculosis and Vitamin D deficiency: the contribution of diet and exposure to sunlight. Thorax 62 (11):1003-7, 2007. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Siwek RA, Burkinshaw L, Oxby CB, Robinson PA. Multi-element analysis of the obese subject by in vivo neutron activation analysis. Physics in Medicine & Biology 29 (6):687-701, 1984. | Not relevant
Skinner JD, Bounds W, Carruth BR, Ziegler P. Longitudinal calcium intake is negatively related to children's body fat indexes.. Journal of the American Dietetic Association 103 (12):1626-31, 2003. | Not RCT growth study
Slemenda CW, Reister TK, Hui SL, Miller JZ, Christian JC, Johnston CC, Jr. Influences on skeletal mineralization in children and adolescents: evidence for varying effects of sexual maturation and physical actiVitaminy. Journal of Pediatrics 125 (2):201-7, 1994. | No 25(OH)D or dietary Ca
Specker BL, Beck A, Kalkwarf H, Ho M. Randomized trial of varying mineral intake on total body bone mineral accretion during the first year of life. Pediatrics 99(6): E12, 1997. | No independent Ca effect
Specker BL, Tsang RC, Ho M, Miller D. Effect of vegetarian diet on serum 1,25-dihydroxyVitamin D concentrations during lactation. Obstetrics & Gynecology 70 (6):870-4, 1987. | No 25(OH)D or dietary Ca
Specker BL, Valanis B, Hertzberg V, Edwards N, Tsang RC. Sunshine exposure and serum 25-hydroxyVitamin D concentrations in exclusively breast-fed infants. Journal of Pediatrics 107 (3):372-6, 1985. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Stamler J, Liu K, Ruth KJ, Pryer J, Greenland P. Eight-year blood pressure change in middle-aged men: relationship to multiple nutrients. Hypertension 39 (5):1000-6, 2002. | No outcomes of interest
Stern HS, Gregoire RC, Kashtan H, Stadler J, Bruce RW. Long-term effects of dietary calcium on risk markers for colon cancer in patients with familial polyposis. Surgery 108 (3):528-33, 1990. | No outcomes of interest
Sugden JA, Davies JI, Witham MD, Morris AD, Struthers AD. Vitamin D improves endothelial function in patients with Type 2 diabetes mellitus and low vitamin D levels. Diabetic Medicine 2008;25:320-5. | >=20% subjects with diseases
Swanenburg J, de Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. Clinical Rehabilitation 2007; 21(6):523-534. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Takeuchi A, Okano T, Tsugawa N et al. Effects of ergocalciferol supplementation on the concentration of Vitamin D and its metabolites in human milk. Journal of Nutrition 119 (11):1639-46, 1989. | Not RCT arrow 4 study
Tanji JL, Lew EY, Wong GY, Treguboff C, Ward JA, Amsterdam EA. Dietary calcium supplementation as a treatment for mild hypertension.. Journal of the American Board of Family Practice 4(3):145-50, 1991. | In systematic review
Taylor EN, Stampfer MJ, Curhan GC. Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. Journal of the American Society of Nephrology 15 (12):3225-32, 2004. | No outcomes of interest
Teegarden D, White KM, Lyle RM et al. Calcium and dairy product modulation of lipid utilization and energy expenditure. Obesity 16 (7):1566-72, 2008. | No outcomes of interest
Thompson IM, Coltman CA, Jr., Crowley J. Chemoprevention of prostate cancer: the Prostate Cancer Prevention Trial. Prostate 33 (3):217-21, 1997. | Commentary
Thompson WG, Rostad HN, Janzow DJ, Slezak JM, Morris KL, Zemel MB. Effect of energy-reduced diets high in dairy products and fiber on weight loss in obese adults. Obesity Research 13(8):1344-53, 2005. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Thomson K, Morley R, Grover SR, Zacharin MR. Postnatal evaluation of Vitamin D and bone health in women who were Vitamin D-deficient in pregnancy, and in their infants.[erratum appears in Med J Aust. 2005 Jan 3;182(1):48 Note: Thompson, Katherine [corrected to Thomson, Katherine]]. Medical Journal of Australia 181 (9):486-8, 2004. | No analysis of association between 25(OH)D and outcomes
Tomoda S, Kitanaka T, Ogita S, Hidaka A. Prevention of pregnancy-induced hypertension by calcium dietary supplement: a preliminary report. Journal of Obstetrics & Gynaecology 21(3):281-8, 1995. | No outcomes of interest
Tretli S, Hernes E, Berg JP, Hestvik UE, Robsahm TE. Association between serum 25(OH)D and death from prostate cancer. British Journal of Cancer 100 (3):450 -4, 2009. | >=20% subjects with diseases
Tsang RC, Gigger M, Oh W, Brown DR. Studies in calcium metabolism in infants with intrauterine growth retardation. Journal of Pediatrics 86 (6):936-41, 1975. | No 25(OH)D or dietary Ca
Tworoger SS, Lee IM, Buring JE, Rosner B, Hollis BW, Hankinson SE. Plasma 25-hydroxyVitamin D and 1,25-dihydroxyVitamin D and risk of incident ovarian cancer. Cancer Epidemiology, Biomarkers & Prevention 2007; 16(4):783-788. | No outcomes of interest
van Beresteijn EC, Riedstra M, van der WA, Schouten EG, Burema J, Kok FJ. Habitual dietary calcium intake and blood pressure change around the menopause: a longitudinal study. International Journal of Epidemiology 21(4):683-9, 1992. | No outcomes of interest
van Buul BJ, Steegers EA, Jongsma HW et al. Dietary sodium restriction in the prophylaxis of hypertensive disorders of pregnancy: effects on the intake of other nutrients. American Journal of Clinical Nutrition 62 (1):49-57, 1995. | Ca intake and BM (mothers and neonates) measured but not assessed ==> no relevant results reported
Vatanparast H, Baxter-Jones A, Faulkner RA, Bailey DA, Whiting SJ. Positive effects of vegetable and fruit consumption and calcium intake on bone mineral accrual in boys during growth from childhood to adolescence: the University of Saskatchewan Pediatric Bone Mineral Accrual Study. American Journal of Clinical Nutrition 82 (3):700-6, 2005. | No 25(OH)D or dietary Ca
Vergnaud AC, Peneau S, Chat-Yung S et al. Dairy consumption and 6-y changes in body weight and waist circumference in middle-aged French adults. American Journal of Clinical Nutrition 88 (5):1248 -55, 2008. | not RCT (weight outcome)
Verhaar HJ, Samson MM, Jansen PA, de Vreede PL, Manten JW, Duursma SA. Muscle strength, functional mobility and Vitamin D in older women.. Aging-Clinical & Experimental Research 12 (6):455-60, 2000. | In Ottawa EPC report
Verreault R, Semba RD, Volpato S, Ferrucci L, Fried LP, Guralnik JM. Low serum Vitamin d does not predict new disability or loss of muscle strength in older women. Journal of the American Geriatrics Society 50 (5):912-7, 2002. | In Ottawa EPC report
Verreault R, Semba RD, Volpato S, Ferrucci L, Fried LP, Guralnik JM. Low serum Vitamin d does not predict new disability or loss of muscle strength in older women. Journal of the American Geriatrics Society 50(5):912-7, 2002. | In Ottawa EPC report
Villar J, bdel-Aleem H, Merialdi M et al. World Health Organization randomized trial of calcium supplementation among low calcium intake pregnant women. American Journal of Obstetrics & Gynecology. 194(3):639-49, 2006 Mar. | In Hofmeyer 2007 systematic review, systematic review
Villar J, Gulmezoglu AM, de OM. Nutritional and antimicrobial interventions to prevent preterm birth: an overview of randomized controlled trials. Obstetrical & Gynecological Survey 53 (9):575-85, 1998 Sep. | Not relevant systematic review
Villar J, Repke JT. Calcium supplementation during pregnancy may reduce preterm delivery in high-risk populations. American Journal of Obstetrics & Gynecology 163 (4 Pt 1):1124-31, 1990. | In Hofmeyer 2007 systematic review
Visser M, Deeg DJ, Lips P, Longitudinal Aging SA. Low Vitamin D and high parathyroid hormone levels as determinants of loss of muscle strength and muscle mass (sarcopenia): the Longitudinal Aging Study Amsterdam. Journal of Clinical Endocrinology & Metabolism 88 (12):5766-72, 2003. | In Ottawa EPC report
von Hurst PR, Stonehouse W, Matthys C, Conlon C, Kruger MC, Coad J. Study protocol--metabolic syndrome, vitamin D and bone status in South Asian women living in Auckland, New Zealand: a randomised, placebo-controlled, double-blind vitamin D intervention. BMC Public Health 8 :267, 2008. | RCT protocol only
Wallace K, Baron JA, Cole BF et al. Effect of calcium supplementation on the risk of large bowel polyps.[see comment]. Journal of the National Cancer Institute 96 (12 ):921-5, 2004. | In Weigarten 2008 SR
Wallace K, Baron JA, Karagas MR et al. The association of physical actiVitaminy and body mass index with the risk of large bowel polyps. Cancer Epidemiology, Biomarkers & Prevention 14(9):2082-6, 2005. | No outcomes of interest
Waltman NL, Twiss JJ, Ott CD et al. Testing an intervention for preventing osteoporosis in postmenopausal breast cancer survivors. Journal of Nursing Scholarship 35 (4):333-8, 2003. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Wanchu M, Malhotra S, Khullar M. Calcium supplementation in pre-eclampsia. Journal of the Association of Physicians of India 49:795-8, 2001. | In Hofmeyer 2007 systematic review
Wang LD, Qiu SL, Yang GR, Lipkin M, Newmark HL, Yang CS. A randomized double-blind intervention study on the effect of calcium supplementation on esophageal precancerous lesions in a high-risk population in China. Cancer Epidemiology, Biomarkers & Prevention 2(1):71-8, 1993. | >=20% subjects with diseases
Wargovich MJ, Isbell G, Shabot M et al. Calcium supplementation decreases rectal epithelial cell proliferation in subjects with sporadic adenoma. Gastroenterology 103 (1):92-7, 1992. | No outcomes of interest
Webb AR, Pilbeam C, Hanafin N, Holick MF. An evaluation of the relative contributions of exposure to sunlight and of diet to the circulating concentrations of 25-hydroxyVitamin D in an elderly nursing home population in Boston. American Journal of Clinical Nutrition 51 (6):1075-81, 1990. | Not RCT arrow 4 study
Webber CE, Blake JM, Chambers LF, Roberts JG. Effects of 2 years of hormone replacement upon bone mass, serum lipids and lipoproteins. Maturitas. 19(1):13-23, 1994 May. | No 25(OH)D or dietary Ca
Wei EK, Giovannucci E, Fuchs CS, Willett WC, Mantzoros CS. Low plasma adiponectin levels and risk of colorectal cancer in men: a prospective study. Journal of the National Cancer Institute 97 (22):1688-94, 2005. | No 25(OH)D or dietary Ca
Weinberger MH, Wagner UL, Fineberg NS. The blood pressure effects of calcium supplementation in humans of known sodium responsiveness. American Journal of Hypertension 6 (9):799-805, 1993. | In systematic review
Weisgerber UM, Boeing H, Owen RW, Waldherr R, Raedsch R, Wahrendorf J. Effect of longterm placebo controlled calcium supplementation on sigmoidal cell proliferation in patients with sporadic adenomatous polyps. Gut 38 (3):396-402, 1996. | No outcomes of interest
Weisman Y, Bawnik JC, Eisenberg Z, Spirer Z. Vitamin D metabolites in human milk. Journal of Pediatrics 100 (5):745-8, 1982. | Cross-sectional or retrospective assessment of diet after disease diagnosis
Weston TL, Aronson KJ, Siemiatycki J, Howe GR, Nadon L. Cancer mortality among males in relation to exposures assessed through a job-exposure matrix. International Journal of Occupational & Environmental Health 6(3):194-202, 2000. | No 25(OH)D or dietary Ca
Widga AC, Lewis NM. Defined, in-home, prenatal nutrition intervention for low-income women. Journal of the American Dietetic Association 99(9):1058-62, 1999. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Willett WC, Stampfer MJ, Colditz GA, Rosner BA, Speizer FE. Relation of meat, fat, and fiber intake to the risk of colon cancer in a prospective study among women. N Engl J Med 1990; 323(24):1664-1672. | No 25(OH)D or dietary Ca
Williams CP, Child DF, Hudson PR et al. Why oral calcium supplements may reduce renal stone disease: report of a clinical pilot study. Journal of Clinical Pathology 54 (1):54-62, 2001. | No UL outcomes
Wimalawansa SJ. Antihypertensive effects of oral calcium supplementation may be mediated through the potent vasodilator CGRP. American Journal of Hypertension 6 (12):996-1002, 1993. | n=8, Ca to Rx HTN
Witteman JC, Willett WC, Stampfer MJ et al. A prospective study of nutritional factors and hypertension among US women. Circulation 80 (5):1320-7, 1989. | Superceded by Ascherio (4022)
Wortsman J, Matsuoka LY, Chen TC, Lu Z, Holick MF. Decreased bioavailability of Vitamin D in obesity. [erratum appears in Am J Clin Nutr. 2003 May;77(5):1342]. American Journal of Clinical Nutrition 72 (3):690-3, 2000. | Not RCT arrow 4 study
Wosje KS, Kalkwarf HJ. Lactation, weaning, and calcium supplementation: effects on body composition in postpartum women. American Journal of Clinical Nutrition 80 (2):423-9, 2004. | No outcomes of interest
Wyatt HR, Jortberg BT, Babbel C et al. Weight loss in a community initiative that promotes decreased energy intake and increased physical actiVitaminy and dairy consumption: Calcium Weighs-In. Journal of Physical ActiVitaminy & Health 5(1):28-44, 2008. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Yang YX, Han JH, Shao XP et al. Effect of micronutrient supplementation on the growth of preschool children in China. Biomedical & Environmental Sciences 15 (3):196-202, 2002. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Yesudian PD, Berry JL, Wiles S et al. The effect of ultraviolet B-induced Vitamin D levels on host resistance to Mycobacterium tuberculosis: a pilot study in immigrant Asian adults living in the United Kingdom. Photodermatology, Photoimmunology & Photomedicine 24 (2):97-8, 2008. | No outcomes of interest
Zemel MB, Richards J, Milstead A, Campbell P. Effects of calcium and dairy on body composition and weight loss in African-American adults. Obesity Research 13(7):1218-25, 2005. | In systematic review
Zemel MB, Thompson W, Milstead A, Morris K, Campbell P. Calcium and dairy acceleration of weight and fat loss during energy restriction in obese adults. Obesity Research 12 (4):582-90, 2004. | In systematic review
Zhang Y, Kiel DP, Ellison RC et al. Bone mass and the risk of prostate cancer: the Framingham Study. American Journal of Medicine 113 (9):734-9, 2002. | No 25(OH)D or dietary Ca
Zhou C, Fan S, Zhou L, Ni Y, Huang T, Shi Y. Clinical observation of treatment of hypertension with calcium. American Journal of Hypertension 7 (4 Pt 1):363-7, 1994. | In systematic review
Zofkova I, Hill M. Long-term 1,25(OH)2 Vitamin D therapy increases bone mineral density in osteopenic women. Comparison with the effect of plain Vitamin D. Aging-Clinical & Experimental Research. 19(6):472-7, 2007 Dec. | Combination of Vitamin D/Ca and other treatment w/o analysis of independent effect
Zorbas YG, Petrov KL, Kakurin VJ et al. Calcium supplementation effect on calcium balance in endurance-trained athletes during prolonged hypokinesia and ambulatory conditions. Biological Trace Element Research 73 (3):231-50, 2000. | Arrow 4: calcium balance

## Excluded Studies (From the Current Report)

### Rejected for Study Design—N=191

1 Abrams SA. (2011). Calcium and vitamin D requirements for optimal bone mass during adolescence. Current Opinion in Clinical Nutrition & Metabolic Care.
2 Adami S, Giannini S, Bianchi G, et al. (2009). Vitamin D status and response to treatment in post-menopausal osteoporosis. Osteoporosis International.
3 Adams SV, Newcomb PA, Burnett-Hartman AN, et al. (2011). Circulating 25-hydroxyvitamin-D and risk of colorectal adenomas and hyperplastic polyps. Nutrition & Cancer.
4 Ahn J, Albanes D, Berndt SI, et al. (2009). Vitamin D-related genes, serum vitamin D concentrations and prostate cancer risk. Carcinogenesis.
5 Allan K, Devereux G. (2011). Diet and asthma: nutrition implications from prevention to treatment. Journal of the American Dietetic Association.
6 Alvarez JA, Ashraf A. (2010). Role of vitamin d in insulin secretion and insulin sensitivity for glucose homeostasis. International Journal of Endocrinology Print.
7 Alzaim M, Wood RJ. (2013). Vitamin D and gestational diabetes mellitus. Nutrition Reviews.
8 Annweiler C, Rolland Y, Schott AM, et al. (2012). Higher vitamin D dietary intake is associated with lower risk of alzheimer's disease: a 7-year follow-up. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
9 Annweiler C, Schott AM, Montero-Odasso M, et al. (2010). Cross-sectional association between serum vitamin D concentration and walking speed measured at usual and fast pace among older women: the EPIDOS study. Journal of Bone & Mineral Research.
10 Assimos D. (2011). Re: Urinary tract stone occurrence in the Women's Health Initiative (WHI) randomized clinical trial of calcium and vitamin D supplements. Journal of Urology.
11 Attar SM. (2012). Vitamin D deficiency in rheumatoid arthritis. Prevalence and association with disease activity in Western Saudi Arabia. Saudi Medical Journal.
12 Barake R, Weiler H, Payette H, et al. (2010). Vitamin D supplement consumption is required to achieve a minimal target 25-hydroxyvitamin D concentration of > or = 75 nmol/L in older people. Journal of Nutrition.
13 Bischoff-Ferrari HA, Kiel DP, Dawson-Hughes B, et al. (2009). Dietary calcium and serum 25-hydroxyvitamin D status in relation to BMD among U.S. adults. Journal of Bone & Mineral Research.
14 Bischoff-Ferrari HA, Shao A, Dawson-Hughes B, et al. (2010). Benefit-risk assessment of vitamin D supplementation. Osteoporosis International.
15 Bolland MJ, Grey A, Avenell A, et al. (2011). Calcium supplements with or without vitamin D and risk of cardiovascular events: reanalysis of the Women's Health Initiative limited access dataset and meta-analysis. BMJ.
16 Boyce AM, Gafni RI. (2011). Approach to the child with fractures. Journal of Clinical Endocrinology & Metabolism.
17 Chaganti RK, Parimi N, Cawthon P, et al. (2010). Association of 25-hydroxyvitamin D with prevalent osteoarthritis of the hip in elderly men: the osteoporotic fractures in men study. Arthritis & Rheumatism.
18 Chai W, Maskarinec G, Cooney RV. (2010). Serum 25-hydroxyvitamin D levels and mammographic density among premenopausal women in a multiethnic population. European Journal of Clinical Nutrition.
19 Christenson ES, Jiang X, Kagan R, et al. (2012). Osteoporosis management in post-menopausal women. Minerva Ginecologica.
20 Coney P, Demers LM, Dodson WC, et al. (2012). Determination of vitamin D in relation to body mass index and race in a defined population of black and white women. International Journal of Gynaecology & Obstetrics.
21 Dasgupta A, Saikia U, Sarma D. (2012). Status of 25(OH)D levels in pregnancy: A study from the North Eastern part of India. Indian Journal of Endocrinology and Metabolism.
22 Davis LM, Chang SC, Mancini J, et al. (2010). Vitamin D insufficiency is prevalent among pregnant African American adolescents. Journal of Pediatric & Adolescent Gynecology.
23 Davis W, Rockway S, Kwasny M. (2009). Effect of a combined therapeutic approach of intensive lipid management, omega-3 fatty acid supplementation, and increased serum 25 (OH) vitamin D on coronary calcium scores in asymptomatic adults. American Journal of Therapeutics.
24 Dunlop AL, Taylor RN, Tangpricha V, et al. (2012). Maternal micronutrient status and preterm versus term birth for black and white US women. Reproductive Sciences.
25 El Hayek J, Egeland G, Weiler H. (2011). Older age and lower adiposity predict better 25-hydroxy vitamin D concentration in Inuit adults: International Polar Year Inuit Health Survey, 2007-2008. Archives of Osteoporosis.
26 Ertl R, Yu CKH, Samaha R, et al. (2012). Maternal serum vitamin D at 11-13 weeks in pregnancies delivering small for gestational age neonates. Fetal Diagnosis & Therapy.
27 Esteitie R, Naclerio RM, Baroody FM. (2010). Vitamin D levels in children undergoing adenotonsillectomies. International Journal of Pediatric Otorhinolaryngology.
28 Fairweather-Tait SJ, Skinner J, Guile GR, et al. (2011). Diet and bone mineral density study in postmenopausal women from the TwinsUK registry shows a negative association with a traditional English dietary pattern and a positive association with wine. American Journal of Clinical Nutrition.
29 Fall T, Shiue I, Bergea af Geijerstam P, et al. (2012). Relations of circulating vitamin D concentrations with left ventricular geometry and function. European Journal of Heart Failure.
30 Formiga F, Ferrer A, Almeda J, et al. (2011). Utility of geriatric assessment tools to identify 85-years old subjects with vitamin D deficiency. Journal of Nutrition, Health & Aging.
31 Gallicchio L, Helzlsouer KJ, Chow WH, et al. (2010). Circulating 25-hydroxyvitamin D and the risk of rarer cancers: Design and methods of the Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
32 Garg M, Lubel JS, Sparrow MP, et al. (2012). Review article: vitamin D and inflammatory bowel disease--established concepts and future directions. Alimentary Pharmacology & Therapeutics.
33 Garrett-Mayer E, Wagner CL, Hollis BW, et al. (2012). Vitamin D3 supplementation (4000 IU/d for 1 y) eliminates differences in circulating 25-hydroxyvitamin D between African American and white men. American Journal of Clinical Nutrition.
34 Geleijnse JM. (2011). Vitamin D and the prevention of hypertension and cardiovascular diseases: a review of the current evidence. American Journal of Hypertension.
35 Genuis SJ, Bouchard TP. (2012). Combination of Micronutrients for Bone (COMB) Study: bone density after micronutrient intervention. Journal Of Environmental & Public Health.
36 Gilbert R, Martin RM, Fraser WD, et al. (2012). Predictors of 25-hydroxyvitamin D and its association with risk factors for prostate cancer: evidence from the prostate testing for cancer and treatment study. Cancer Causes & Control.
37 Gilbert R, Metcalfe C, Fraser WD, et al. (2012). Associations of circulating retinol, vitamin E, and 1,25-dihydroxyvitamin D with prostate cancer diagnosis, stage, and grade. Cancer Causes & Control.
38 Gilbert R, Metcalfe C, Fraser WD, et al. (2012). Associations of circulating 25-hydroxyvitamin D with prostate cancer diagnosis, stage and grade. International Journal of Cancer.
39 Ginde AA, Camargo CA, Shapiro NI. (2011). Vitamin D insufficiency and sepsis severity in emergency department patients with suspected infection. Academic Emergency Medicine.
40 Goleva E, Searing DA, Jackson LP, et al. (2012). Steroid requirements and immune associations with vitamin D are stronger in children than adults with asthma. Journal of Allergy & Clinical Immunology.
41 Goltz L, Degenhardt G, Maywald U, et al. (2013). Evaluation of a program of integrated care to reduce recurrent osteoporotic fractures. Pharmacoepidemiology & Drug Safety.
42 Gominak SC, Stumpf WE. (2012). The world epidemic of sleep disorders is linked to vitamin D deficiency. Medical Hypotheses.
43 Gonzalez CA, Riboli E. (2010). Diet and cancer prevention: Contributions from the European Prospective Investigation into Cancer and Nutrition (EPIC) study. European Journal of Cancer.
44 Grant WB, Schwalfenberg GK, Genuis SJ, et al. (2010). An estimate of the economic burden and premature deaths due to vitamin D deficiency in Canada. Molecular Nutrition & Food Research.
45 Grant WB, Tangpricha V. (2012). Vitamin D: Its role in disease prevention. Dermato-endocrinology.
46 Guerrieri-Gonzaga A, Gandini S. (2013). Vitamin D and overall mortality. Pigment Cell & Melanoma Research.
47 Hansen KE. (2011). High-dose vitamin D: helpful or harmful?. Current Rheumatology Reports.
48 Harvey NC, Javaid K, Bishop N, et al. (2012). MAVIDOS Maternal Vitamin D Osteoporosis Study: study protocol for a randomized controlled trial. The MAVIDOS Study Group. Trials.
49 Holmes VA, Barnes MS, Alexander HD, et al. (2009). Vitamin D deficiency and insufficiency in pregnant women: a longitudinal study. British Journal of Nutrition.
50 Hronek M, Doubkova P, Hrnciarikova D, et al. (2013). Dietary intake of energy and nutrients in relation to resting energy expenditure and anthropometric parameters of Czech pregnant women. European Journal of Nutrition.
51 Huang W, Shah S, Long Q, et al. (2013). Improvement of pain, sleep, and quality of life in chronic pain patients with vitamin d supplementation. Clinical Journal of Pain.
52 Jin SE, Park JS, Kim CK. (2009). Pharmacokinetics of oral calcitriol in healthy human based on the analysis with an enzyme immunoassay. Pharmacological Research.
53 Jyvakorpi SK, Puranen T, Pitkala KH, et al. (2012). Nutritional treatment of aged individuals with Alzheimer disease living at home with their spouses: study protocol for a randomized controlled trial. Trials.
54 Kalava UR, Cha SS, Takahashi PY. (2011). Association between vitamin D and pressure ulcers in older ambulatory adults: results of a matched case-control study. Clinical Interventions In Aging.
55 Karatekin G, Kaya A, Salihoglu O, et al. (2009). Association of subclinical vitamin D deficiency in newborns with acute lower respiratory infection and their mothers. European Journal of Clinical Nutrition.
56 Kaukonen JP, Luthje P, Nurmi-Luthje I, et al. (2011). Second hip fracture and patients' medication after the first hip fracture: a follow-up of 221 hip fracture patients in Finland. Archives of Gerontology & Geriatrics.
57 Kawase T, Matsuo K, Suzuki T, et al. (2010). Association between vitamin D and calcium intake and breast cancer risk according to menopausal status and receptor status in Japan. Cancer Science.
58 Khader YS, Batieha A, Jaddou H, et al. (2011). Relationship between 25-hydroxyvitamin D and metabolic syndrome among Jordanian adults. Nutrition Research & Practice.
59 Kluczynski MA, Lamonte MJ, Mares JA, et al. (2011). Duration of physical activity and serum 25-hydroxyvitamin D status of postmenopausal women. Annals of Epidemiology.
60 Koul PA, Ahmad SH, Ahmad F, et al. (2011). Vitamin d toxicity in adults: a case series from an area with endemic hypovitaminosis d. Oman Medical Journal.
61 Kuchuk NO, van Schoor NM, Pluijm SM, et al. (2009). Vitamin D status, parathyroid function, bone turnover, and BMD in postmenopausal women with osteoporosis: global perspective. Journal of Bone & Mineral Research.
62 Lamendola CA, Ariel D, Feldman D, et al. (2012). Relations between obesity, insulin resistance, and 25-hydroxyvitamin D. American Journal of Clinical Nutrition.
63 Lee P, Greenfield JR, Seibel MJ, et al. (2009). Adequacy of vitamin D replacement in severe deficiency is dependent on body mass index. American Journal of Medicine.
64 Li B, Byrjalsen I, Glendenning P, et al. (2009). Selective monitoring of vitamin D2 and D3 supplementation with a highly specific 25-hydroxyvitamin D3 immunoassay with negligible cross-reactivity to 25-hydroxyvitamin D2. Clinica Chimica Acta.
65 Liang L, Chantry C, Styne DM, et al. (2010). Prevalence and risk factors for vitamin D deficiency among healthy infants and young children in Sacramento, California. European Journal of Pediatrics.
66 Lim S, Shin H, Kim MJ, et al. (2012). Vitamin D inadequacy is associated with significant coronary artery stenosis in a community-based elderly cohort: the Korean Longitudinal Study on Health and Aging. Journal of Clinical Endocrinology & Metabolism.
67 Linday LA. (2010). Cod liver oil, young children, and upper respiratory tract infections. Journal of the American College of Nutrition.
68 Litonjua AA. (2012). Vitamin D deficiency as a risk factor for childhood allergic disease and asthma. Current Opinion in Allergy & Clinical Immunology.
69 Liu K, Meng H, Tang X, et al. (2009). Elevated plasma calcifediol is associated with aggressive periodontitis. Journal of Periodontology.
70 Lopez-Torres Hidalgo J, Group A. (2011). Prevention of falls and fractures in old people by administration of calcium and vitamin D, randomized clinical trial. BMC Public Health.
71 Luzzi R, Belcaro G, Cornelli U, et al. (2011). Osteoporosis of the jaw. Product evaluation: mf Odontovis Calcium. Panminerva Medica.
72 Mahdy S, Al-Emadi SA, Khanjar IA, et al. (2010). Vitamin D status in health care professionals in Qatar. Saudi Medical Journal.
73 Maji D. (2012). Vitamin D toxicity. Indian Journal of Endocrinology and Metabolism.
74 Makariou S, Liberopoulos E, Florentin M, et al. (2012). The relationship of vitamin D with non-traditional risk factors for cardiovascular disease in subjects with metabolic syndrome. Archives of Medical Science.
75 Makgoba M, Nelson SM, Savvidou M, et al. (2011). First-trimester circulating 25-hydroxyvitamin D levels and development of gestational diabetes mellitus. Diabetes Care.
76 Manickam B, Washington T, Villagrana NE, et al. (2012). Determinants of circulating 25-hydroxyvitamin D and bone mineral density in young physicians. Endocrine Practice.
77 Manson JE, Bassuk SS, Lee IM, et al. (2012). The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemporary Clinical Trials.
78 Mark S, Lambert M, Delvin EE, et al. (2011). Higher vitamin D intake is needed to achieve serum 25(OH)D levels greater than 50 nmol/l in Quebec youth at high risk of obesity. European Journal of Clinical Nutrition.
79 Marwaha RK, Puri S, Tandon N, et al. (2011). Effects of sports training & nutrition on bone mineral density in young Indian healthy females. Indian Journal of Medical Research.
80 Mathei C, Van Pottelbergh G, Vaes B, et al. (2013). No relation between vitamin D status and physical performance in the oldest old: results from the Belfrail study. Age & Ageing.
81 Miettinen ME, Reinert L, Kinnunen L, et al. (2012). Serum 25-hydroxyvitamin D level during early pregnancy and type 1 diabetes risk in the offspring. Diabetologia.
82 Mohr SB, Gorham ED, Alcaraz JE, et al. (2013). Serum 25-hydroxyvitamin D and breast cancer in the military: a case-control study utilizing pre-diagnostic serum. Cancer Causes & Control.
83 Mondul AM, Weinstein SJ, Horst RL, et al. (2012). Serum vitamin D and risk of bladder cancer in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening trial. Cancer Epidemiology, Biomarkers & Prevention.
84 Moore WC, Pascual RM. (2010). Update in asthma 2009. American Journal of Respiratory & Critical Care Medicine.
85 Moser AM, Salzer HJF, Krause R. (2011). Immunoplasticity--triggers of regulatory function. Medical Hypotheses.
86 Mowry DA, Costello MM, Heelan KA. (2009). Association among cardiorespiratory fitness, body fat, and bone marker measurements in healthy young females. Journal of the American Osteopathic Association.
87 Mullins RJ, Clark S, Wiley V, et al. (2012). Neonatal vitamin D status and childhood peanut allergy: a pilot study. Annals of Allergy, Asthma, & Immunology.
88 Munns CF, Simm PJ, Rodda CP, et al. (2012). Incidence of vitamin D deficiency rickets among Australian children: an Australian Paediatric Surveillance Unit study. Medical Journal of Australia.
89 Mutlu A, Mutlu GY, Ozsu E, et al. (2011). Vitamin D deficiency in children and adolescents with type 1 diabetes. Journal of clinical research in pediatric endocrinology.
90 Nakano T, Tsugawa N, Kuwabara A, et al. (2011). High prevalence of hypovitaminosis D and K in patients with hip fracture. Asia Pacific Journal of Clinical Nutrition.
91 Pandita KK, Razdan S, Kudyar RP, et al. (2012). “Excess gooD can be Dangerous”. A case series of iatrogenic symptomatic hypercalcemia due to hypervitaminosis D. Clinical Cases in Mineral & Bone Metabolism”.
92 Perez-Rossello JM, Feldman HA, Kleinman PK, et al. (2012). Rachitic changes, demineralization, and fracture risk in healthy infants and toddlers with vitamin D deficiency. Radiology.
93 Peters S, Adams A. (2010). Vitamin D supplementation to reduce the risk of falls and fractures: the dosing dilemma. Orthopedics.
94 Pilz S, Henry RMA, Snijder MB, et al. (2010). Vitamin D deficiency and myocardial structure and function in older men and women: the Hoorn study. Journal of Endocrinological Investigation.
95 Ponda MP, Huang X, Odeh MA, et al. (2012). Vitamin D may not improve lipid levels: a serial clinical laboratory data study. Circulation.
96 Rajakumar K, de las Heras J, Lee S, et al. (2012). 25-hydroxyvitamin D concentrations and in vivo insulin sensitivity and cell function relative to insulin sensitivity in black and white youth. Diabetes Care.
97 Richart T, Thijs L, Nawrot T, et al. (2011). The metabolic syndrome and carotid intima-media thickness in relation to the parathyroid hormone to 25-OH-D(3) ratio in a general population. American Journal of Hypertension.
98 Ring SM, Dannecker EA, Peterson CA. (2010). Vitamin d status is not associated with outcomes of experimentally-induced muscle weakness and pain in young, healthy volunteers. Journal of Nutrition and Metabolism.
99 Rooze S, Dramaix-Wilmet M, Mathieu F, et al. (2012). Growth, nutritional status, and signs of rickets in 0-5-year-old children in a Kashin-Beck disease endemic area of Central Tibet. European Journal of Pediatrics.
100 Rubin CD. (2012). Evaluation and management of hip fracture risk in the aged. American Journal of the Medical Sciences.
101 Sanford M, McCormack PL. (2012). Spotlight on eldecalcitol in osteoporosis.[Reprint of Drugs. 2011 Sep 10;71(13):1755-70; PMID: 21902297]. Drugs & Aging.
102 Schmitz KJ, Skinner HG, Bautista LE, et al. (2009). Association of 25-hydroxyvitamin D with blood pressure in predominantly 25-hydroxyvitamin D deficient Hispanic and African Americans. American Journal of Hypertension.
103 Shin M, Minden C. (2011). Evaluation of the effectiveness of cholecalciferol in long-term care elderly patients with hypovitaminosis d. Consultant Pharmacist.
104 Skinner HG, Litzelman K, Schwartz GG. (2010). Recent clinical trials of vitamin D3 supplementation and serum calcium levels in humans: Implications for vitamin D-based chemoprevention. Current Opinion in Investigational Drugs.
105 Speroff L. (2011). Research in a community hospital: some lessons from the Clarkson-Schnatz mentor-mentee pair in The North American Menopause Society Mentorship Program. Menopause.
106 Stewart JW, Alekel DL, Ritland LM, et al. (2009). Serum 25-hydroxyvitamin D is related to indicators of overall physical fitness in healthy postmenopausal women. Menopause.
107 Sun Z, Wang PP, Roebothan B, et al. (2011). Calcium and vitamin D and risk of colorectal cancer: results from a large population-based case-control study in Newfoundland and Labrador and Ontario. Canadian Journal of Public Health. Revue Canadienne de Sante Publique.
108 Takahashi R, Mizoue T, Otake T, et al. (2010). Circulating vitamin D and colorectal adenomas in Japanese men. Cancer Science.
109 Tarcin O, Yavuz DG, Ozben B, et al. (2009). Effect of vitamin D deficiency and replacement on endothelial function in asymptomatic subjects. Journal of Clinical Endocrinology & Metabolism.
110 Tran B, Armstrong BK, Carlin JB, et al. (2012). Recruitment and results of a pilot trial of vitamin D supplementation in the general population of Australia. Journal of Clinical Endocrinology & Metabolism.
111 Ubbenhorst A, Striebich S, Lang F, et al. (2011). Exploring the relationship between vitamin D and basic personality traits. Psychopharmacology.
112 Valtuena J, Gracia-Marco L, Vicente-Rodriguez G, et al. (2012). Vitamin D status and physical activity interact to improve bone mass in adolescents. The HELENA Study. Osteoporosis International.
113 Voloc A, Esterle L, Nguyen TM, et al. (2010). High prevalence of genu varum/valgum in European children with low vitamin D status and insufficient dairy products/calcium intakes. European Journal of Endocrinology.
114 Wu AC, Tantisira K, Li L, et al. (2012). Effect of vitamin D and inhaled corticosteroid treatment on lung function in children. American Journal of Respiratory & Critical Care Medicine.
115 Wu K, Feskanich D, Fuchs CS, et al. (2011). Interactions between plasma levels of 25-hydroxyvitamin D, insulin-like growth factor (IGF)-1 and C-peptide with risk of colorectal cancer. PLoS ONE.
116 Yamaji T, Iwasaki M, Sasazuki S, et al. (2012). Association between plasma 25-hydroxyvitamin D and colorectal adenoma according to dietary calcium intake and vitamin D receptor polymorphism. American Journal of Epidemiology.
117 Yao S, Zirpoli G, Bovbjerg DH, et al. (2012). Variants in the vitamin D pathway, serum levels of vitamin D, and estrogen receptor negative breast cancer among African-American women: a case-control study. Breast Cancer Research.
118 Yli-Kyyny T, Tamminen I, Syri J, et al. (2011). Bilateral hip pain. Lancet.
119 Zablotska LB, Gong Z, Wang F, et al. (2011). Vitamin D, calcium, and retinol intake, and pancreatic cancer in a population-based case-control study in the San Francisco Bay area. Cancer Causes & Control.
120 Zagura M, Serg M, Kampus P, et al. (2011). Aortic stiffness and vitamin D are independent markers of aortic calcification in patients with peripheral arterial disease and in healthy subjects. European Journal of Vascular & Endovascular Surgery.
121 Zhang X, Meng H, Sun X, et al. (2013). Elevation of vitamin D-binding protein levels in the plasma of patients with generalized aggressive periodontitis. Journal of Periodontal Research.
122 Zhao J, Xia W, Nie M, et al. (2011). The levels of bone turnover markers in Chinese postmenopausal women: Peking Vertebral Fracture study. Menopause.
123 Zittermann A, Prokop S, Gummert JF, et al. (2013). Safety issues of vitamin d supplementation. Current Medicinal Chemistry—Anti-Cancer Agents.
124 Wagner CL, Johnson D, Hulsey TC, et al. (2010). Vitamin D supplementation during pregnancy Part I NICHD/CTSA randomized clinical trial (RCT): safety consideration. Pediatric Academic Societies Annual Meeting.
125 Wagner CL, Johnson D, Hulsey TC, et al. (2010). Vitamin D supplementation during pregnancy part 2 NICHD/CTSA randomized clinical trial (RCT): outcomes. Pediatric Academic Societies' 2010 Annual Meeting.
126 Wagner CL, McNeil R, Hamilton SA, et al. (2010). Vitamin D (vitD) supplementation during pregnancy: Thrasher Research Fund RCT in SC community center networks. Pediatric Academic Societies' 2010 Annual Meeting.
127 Breitenbucher A, Voit U, Miedinger D, et al. Substitution of vitamin D in patients with moderate to severe persistent asthma: A randomized, placebo-controlled pilot study. European Respiratory Journal: European Respiratory Society Annual Congress.
128 Hurst PR, Stonehouse W, Matthys C, et al. (2008). Study protocol--metabolic syndrome, vitamin D and bone status in South Asian women living in Auckland, New Zealand: a randomised, placebo-controlled, double-blind vitamin D intervention. BMC public health.
129 Piura E, Chapman JW, Lipton A, et al. (2009). Serum 1-OH vitamin D (D) and prognosis of postmenopausal breast cancer (BC) patients: NCIC-CTG MA14 trial. Journal of Clinical Oncology.
130 Lewis E, Fernandez C, Nella AA, et al. (2011). The relationship of vitamin D and asthma in children. Journal of Allergy and Clinical Immunology.
131 Roth DE, A-M A, EA S, R R, B RE, B AH. (2011). Randomized Pilot Trial of Two Oral Vitamin D3 Supplementation Regimens during the Third Trimester of Pregnancy in Bangladeshi Women: Effects on Neonatal Vitamin D Status and Safety. Pediatric academic societies annual meeting.
132 Hanson CK, A L, L E, A-B A. (2011). Parathyroid Hormone Is Inversely Associated with Low 25(OH)D Levels in Late Preterm Infants at Discharge from the NICU. Pediatric academic societies annual meeting.
133 Ala-Houhala MJ, Vahavihu K, Kautiainen H, et al. (2011). Narrow-band ultraviolet b exposures and oral vitamin d substitution in the treatment of vitamin d insufficiency (Abstract 627). Conference: 41st Annual Meeting of the European Society for Dermatological Research, ESDR 2011 Barcelona Spain.
134 Jarvenpaa J, Schwab U, Lappalainen T, et al. (2008). Mineral water fortified with folic acid and vitamins B6, B12, D and calcium improves folate status and decreases plasma homocysteine concentration in pregnant women. 35th Nordic Congress of Obstetrics and Gynecology.
135 Raggi P, Guasch A. (2011). Mineral metabolism and vascular effects of Vitamin D therapy in kidney.
136 Litonjua AA, Hollis BW, Scheumann BK, et al. (2008). Low serum vitamin D levels are associated with increased asthma exacerbations among children using regular inhaled corticosteroids. Journal of Allergy and Clinical Immunology.
137 Christensen P, Riecke BF, Bliddal H, et al. (2010). Improved nutritional status after a weight loss formula diet: a cohort study exploring safety in a randomised controlled trial. Obesity Reviews.
138 Das V, Agarwal A, Bhatia V, et al. (2009). Evaluation of vitamin d status and need for supplementation in pregnant women of a rural area of North India. International Journal of Gynaecology and Obstetrics.
139 Bilenko N, Belmaker I, Vardi H, et al. (2010). Efficacy of multiple micronutrient supplementations on child health: study design and baseline characteristics. The Israel Medical Association journal : IMAJ.
140 Thijs W, Janssen K, Verhoosel RM, et al. Effect of vitamin D treatment on antimicrobial peptides in asthma patients and healthy controls. European Respiratory Society Annual Congress.
141 Koo W, Du W. (2009). Effect of Vitamin D Status on Bone Mass and Bone Biomarker in Preterm Infants. Pediatric Academic Societies Annual Meeting.
142 Astrup A, C P, F R, B H, R BF, B EM, H M, S TJ, G H, W K, Christensen R. (2012). Cardiovascular risk factor changes following three different maintenance programs in obese knee osteoarthritis patients after a major weight loss: A randomized controlled trial. Osteoarthritis and cartilage.
143 Sahota H. (2008). Association of vitamin D related information from a telephone interview with 25-hydroxyvitamin D. Cancer epidemiology, biomarkers prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology.
144 Hansen AB, L T, M FH, Pedersen EB. (2012). Antihypertensive effect of cholecalciferol during winter months in patients with hypertension. Nephrology, dialysis, transplantation.
145 Abbas S, Linseisen J, Slanger T, et al. (2008). The Gc2 allele of the vitamin D binding protein is associated with a decreased postmenopausal breast cancer risk, independent of the vitamin D status. Cancer Epidemiology, Biomarkers & Prevention.
146 Abbas S, Nieters A, Linseisen J, et al. (2008). Vitamin D receptor gene polymorphisms and haplotypes and postmenopausal breast cancer risk. Breast Cancer Research.
147 Bener A, Alsaied A, Al-Ali M, et al. (2008). Impact of lifestyle and dietary habits on hypovitaminosis D in type 1 diabetes mellitus and healthy children from Qatar, a sun-rich country. Annals of Nutrition & Metabolism.
148 Bischoff-Ferrari HA, Can U, Staehelin HB, et al. (2008). Severe vitamin D deficiency in Swiss hip fracture patients. Bone.
149 Blackmore KM, Lesosky M, Barnett H, et al. (2008). Vitamin D from dietary intake and sunlight exposure and the risk of hormone-receptor-defined breast cancer. American Journal of Epidemiology.
150 Giovannucci E. (2008). Vitamin D status and cancer incidence and mortality. Advances in Experimental Medicine & Biology.
151 Granado-Lorencio F, Olmedilla-Alonso B, Herrero-Barbudo C, et al. (2008). Seasonal variation of serum alpha- and beta-cryptoxanthin and 25-OH-vitamin D(3) in women with osteoporosis. Osteoporosis International.
152 Harinarayan CV, Ramalakshmi T, Prasad UV, et al. (2008). Vitamin D status in Andhra Pradesh: a population based study. Indian Journal of Medical Research.
153 Lehtonen-Veromaa M, Mottonen T, Leino A, et al. (2008). Prospective study on food fortification with vitamin D among adolescent females in Finland: minor effects. British Journal of Nutrition.
154 Makitie O, Toiviainen-Salo S, Marttinen E, et al. (2008). Metabolic control and growth during exclusive growth hormone treatment in X-linked hypophosphatemic rickets. Hormone Research.
155 Mizoue T, Kimura Y, Toyomura K, et al. (2008). Calcium, dairy foods, vitamin D, and colorectal cancer risk: the Fukuoka Colorectal Cancer Study. Cancer Epidemiology, Biomarkers & Prevention.
156 O'Riordan MN, Kiely M, Higgins JR, et al. (2008). Prevalence of suboptimal vitamin D status during pregnancy. Irish Medical Journal.
157 Schwalfenberg G. (2008). Vitamin D and diabetes: improvement of glycemic control with vitamin D3 repletion. Canadian Family Physician.
158 Warner AE, Arnspiger SA. (2008). Diffuse musculoskeletal pain is not associated with low vitamin D levels or improved by treatment with vitamin D. JCR: Journal of Clinical Rheumatology.
159 Leu JP, Weiner A, Barzel US. (2008). Vitamin D toxicity: caveat emptor. Endocrine Practice.
160 Taskapan H, Vieth R, Oreopoulos DG. (2008). Unusually prolonged vitamin D intoxication after discontinuation of vitamin D: possible role of primary hyperparathyroidism. International Urology & Nephrology.
161 Abbas S, Linseisen J, Slanger T, et al. (2008). Serum 25-hydroxyvitamin D and risk of post-menopausal breast cancer--results of a large case-control study. Carcinogenesis.
162 Bjelakovic G, Gluud Lise L, Nikolova D, et al. (2008). Vitamin D supplementation for prevention of cancer in adults. Cochrane Database of Systematic Reviews.
163 Das Jai K, Salam Rehana A, Lassi Zohra S, et al. (2012). Food fortification with calcium and vitamin D: impact on health outcomes. Cochrane Database of Systematic Reviews.
164 Scragg Robert KR, Kenealy T, Bryant Linda Julia M, et al. (2013). Vitamin D for preventing cardiovascular disease. Cochrane Database of Systematic Reviews.
165 Yakoob Mohammad Y, Bhutta Zulfiqar A. (2010). Vitamin D supplementation for preventing infections in children less than five years of age. Cochrane Database of Systematic Reviews.
166 Steer PJ. (2013). Is vitamin D supplementation in pregnancy advisable?. Lancet.
167 Demir M, Uyan U, Melek M. (2014). The effects of vitamin d deficiency on atrial fibrillation. Clinical & Applied Thrombosis/Hemostasis.
168 Zheng XE, Lipka S, Li T, et al. (2013). The relationship of vitamin D status, smoking, and colorectal adenoma: a retrospective study in an ethnically diverse community. Journal of Steroid Biochemistry & Molecular Biology.
169 Yousef FM, Jacobs ET, Kang PT, et al. (2013). Vitamin D status and breast cancer in Saudi Arabian women: case-control study. American Journal of Clinical Nutrition.
170 Wong YY, Flicker L, Yeap BB, et al. (2013). Is hypovitaminosis D associated with abdominal aortic aneurysm, and is there a dose-response relationship?. European Journal of Vascular & Endovascular Surgery.
171 Wang LF, Lee CH, Chien CY, et al. (2013). Serum 25-hydroxyvitamin D levels are lower in chronic rhinosinusitis with nasal polyposis and are correlated with disease severity in Taiwanese patients. American Journal of Rhinology & Allergy.
172 Vatanparast H, Nisbet C, Gushulak B. (2013). Vitamin D insufficiency and bone mineral status in a population of newcomer children in Canada. Nutrients.
173 Ullah MI, Koch CA, Tamanna S, et al. (2013). Vitamin d deficiency and the risk of preeclampsia and eclampsia in bangladesh. Hormone & Metabolic Research.
174 Sy AM, Bautista JE. (2013). Association between serum vitamin D levels and colonic carcinomatous polyps. Journal of Gastrointestinal Cancer.
175 Samochocki Z, Bogaczewicz J, Jeziorkowska R, et al. (2013). Vitamin D effects in atopic dermatitis. Journal of the American Academy of Dermatology.
176 Remmelts HH, Spoorenberg SM, Oosterheert JJ, et al. (2013). The role of vitamin D supplementation in the risk of developing pneumonia: three independent case-control studies. Thorax.
177 Ramly M, Moy FM, Pendek R, et al. (2013). Study protocol: the effect of vitamin D supplements on cardiometabolic risk factors among urban premenopausal women in a tropical country—a randomized controlled trial. BMC Public Health.
178 Quraishi SA, Bittner EA, Christopher KB, et al. (2013). Vitamin d status and community-acquired pneumonia: results from the third national health and nutrition examination survey. PLoS ONE.
179 Pludowski P, Holick MF, Pilz S, et al. (2013). Vitamin D effects on musculoskeletal health, immunity, autoimmunity, cardiovascular disease, cancer, fertility, pregnancy, dementia and mortality-a review of recent evidence. Autoimmunity Reviews.
180 O'Connell K, Kelly S, Kinsella K, et al. (2013). Dose-related effects of vitamin D on immune responses in patients with clinically isolated syndrome and healthy control participants: study protocol for an exploratory randomized double- blind placebo-controlled trial. Trials.
181 Malafarina V, Uriz-Otano F, Gil-Guerrero L, et al. (2013). Study protocol: High-protein nutritional intervention based on beta-hydroxy-beta-methylbutirate, vitamin D3 and calcium on obese and lean aged patients with hip fractures and sarcopenia. The HIPERPROT-GER study. Maturitas.
182 Lumachi F, Camozzi V, Doretto P, et al. (2013). Circulating PTH, Vitamin D and IGF-I levels in relation to bone mineral density in elderly women. Vivo.
183 Jelsma JG, van Poppel MN, Galjaard S, et al. (2013). DALI: Vitamin D and lifestyle intervention for gestational diabetes mellitus (GDM) prevention: an European multicentre, randomised trial—study protocol. BMC Pregnancy & Childbirth.
184 Jacobsen R, Abrahamsen B, Bauerek M, et al. (2013). The influence of early exposure to vitamin D for development of diseases later in life. BMC Public Health.
185 Gergen PJ, Teach SJ, Mitchell HE, et al. (2013). Lack of a relation between serum 25-hydroxyvitamin D concentrations and asthma in adolescents. American Journal of Clinical Nutrition.
186 Cunningham E. (2013). Are there evidence-based dietary interventions for multiple sclerosis?. Journal of the Academy of Nutrition & Dietetics.
187 Cashman KD, Kiely M. (2013). EURRECA-Estimating vitamin D requirements for deriving dietary reference values. Critical Reviews in Food Science & Nutrition.
188 Brondum-Jacobsen P, Benn M, Tybjaerg-Hansen A, et al. (2013). 25-Hydroxyvitamin D concentrations and risk of venous thromboembolism in the general population with 18,791 participants. Journal of Thrombosis & Haemostasis.
189 Barker T, Henriksen VT, Martins TB, et al. (2013). Higher serum 25-hydroxyvitamin D concentrations associate with a faster recovery of skeletal muscle strength after muscular injury. Nutrients.
190 Aronsson CA, Vehik K, Yang J, et al. (2013). Use of dietary supplements in pregnant women in relation to sociodemographic factors—a report from The Environmental Determinants of Diabetes in the Young (TEDDY) study. Public Health Nutrition.
191 Chao YS, Brunel L, Faris P, et al. (2013). The importance of dose, frequency and duration of vitamin D supplementation for plasma 25-hydroxyvitamin D. Nutrients.

### Co-morbidities Not of Interest—N=116

1 Agborsangaya CB, Lehtinen T, Toriola AT, et al. (2011). Association between Epstein-Barr virus infection and risk for development of pregnancy-associated breast cancer: joint effect with vitamin D?. European Journal of Cancer.
2 Agborsangaya CB, Surcel HM, Toriola AT, et al. (2010). Serum 25-hydroxyvitamin D at pregnancy and risk of breast cancer in a prospective study. European Journal of Cancer.
3 Aivo J, Lindsrom BM, Soilu-Hanninen M. (2012). A Randomised, Double-Blind, Placebo-Controlled Trial with Vitamin D3 in MS: Subgroup Analysis of Patients with Baseline Disease Activity Despite Interferon Treatment. Multiple Sclerosis International.
4 Amestejani M, Salehi BS, Vasigh M, et al. (2012). Vitamin D supplementation in the treatment of atopic dermatitis: a clinical trial study. Journal of Drugs in Dermatology: JDD.
5 Amir E, Cecchini RS, Ganz PA, et al. (2012). 25-Hydroxy vitamin-D, obesity, and associated variables as predictors of breast cancer risk and tamoxifen benefit in NSABP-P1. Breast Cancer Research & Treatment.
6 Bacon CJ, Gamble GD, Horne AM, et al. (2009). High-dose oral vitamin D3 supplementation in the elderly. Osteoporosis International.
7 Banajeh SM. (2009). Nutritional rickets and vitamin D deficiency—association with the outcomes of childhood very severe pneumonia: a prospective cohort study. Pediatric Pulmonology.
8 Batchelor F, Hill K, Mackintosh S, et al. (2010). What works in falls prevention after stroke?: a systematic review and meta-analysis. Stroke.
9 Center JR, Bliuc D, Nguyen ND, et al. (2011). Osteoporosis medication and reduced mortality risk in elderly women and men. Journal of Clinical Endocrinology & Metabolism.
10 Davison BJ, Wiens K, Cushing M. (2012). Promoting calcium and vitamin D intake to reduce the risk of osteoporosis in men on androgen deprivation therapy for recurrent prostate cancer. Supportive Care in Cancer.
11 Dukas L, Schacht E, Runge M, et al. (2010). Effect of a six-month therapy with alfacalcidol on muscle power and balance and the number of fallers and falls. Arzneimittel-Forschung.
12 Eftekhari MH, Akbarzadeh M, Dabbaghmanesh MH, et al. (2011). Impact of treatment with oral calcitriol on glucose indices in type 2 diabetes mellitus patients. Asia Pacific Journal of Clinical Nutrition.
13 Gaal J, Lakos G, Szodoray P, et al. (2009). Immunological and clinical effects of alphacalcidol in patients with psoriatic arthropathy: results of an open, follow-up pilot study. Acta Dermato-Venereologica.
14 Gabbay MAL, Sato MN, Finazzo C, et al. (2012). Effect of cholecalciferol as adjunctive therapy with insulin on protective immunologic profile and decline of residual-cell function in new-onset type 1 diabetes mellitus. Archives of Pediatrics & Adolescent Medicine.
15 Garcia MN, Hildebolt CF, Miley DD, et al. (2011). One-year effects of vitamin D and calcium supplementation on chronic periodontitis. Journal of Periodontology.
16 Gugatschka M, Kiesler K, Obermayer-Pietsch B, et al. (2011). Vitamin D status is associated with disease-free survival and overall survival time in patients with squamous cell carcinoma of the upper aerodigestive tract. European Archives of Oto-Rhino-Laryngology.
17 Hanson C, Armas L, Lyden E, et al. (2011). Vitamin D status and associations in newborn formula-fed infants during initial hospitalization. Journal of the American Dietetic Association.
18 Hara S, Kishimoto KN, Okuno H, et al. (2013). Effects of alfacalcidol on back extensor strength gained through back extensor exercise in postmenopausal women with osteoporosis. American Journal of Physical Medicine & Rehabilitation.
19 Harris SS, Pittas AG, Palermo NJ. (2012). A randomized, placebo-controlled trial of vitamin D supplementation to improve glycaemia in overweight and obese African Americans. Diabetes, Obesity & Metabolism.
20 Helou J, Moutran R, Maatouk I, et al. (2013). Raynaud's phenomenon and vitamin D. Rheumatology International.
21 Hiremath VP, Rao CB, Naik V, et al. (2013). Anti-inflammatory Effect of Vitamin D on Gingivitis: A Dose-Response Randomised Control Trial. Oral Health & Preventive Dentistry.
22 Hoeck HC, Li B, Qvist P. (2009). Changes in 25-Hydroxyvitamin D3 to oral treatment with vitamin D3 in postmenopausal females with osteoporosis. Osteoporosis International.
23 Houston DK, Neiberg RH, Tooze JA, et al. (2013). Low 25-hydroxyvitamin D predicts the onset of mobility limitation and disability in community-dwelling older adults: the Health ABC Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
24 Houston DK, Tooze JA, Hausman DB, et al. (2011). Change in 25-hydroxyvitamin D and physical performance in older adults. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
25 Ishijima M, Sakamoto Y, Yamanaka M, et al. (2009). Minimum required vitamin D level for optimal increase in bone mineral density with alendronate treatment in osteoporotic women. Calcified Tissue International.
26 Ito M, Nakamura T, Fukunaga M, et al. (2011). Effect of eldecalcitol, an active vitamin D analog, on hip structure and biomechanical properties: 3D assessment by clinical CT. Bone.
27 Iwamoto J, Sato Y, Uzawa M, et al. (2009). Comparison of the effects of alendronate and alfacalcidol on hip bone mineral density and bone turnover in Japanese men having osteoporosis or osteopenia with clinical risk factors for fractures. Yonsei Medical Journal.
28 Iwamoto N, Inaba Y, Kobayashi N, et al. (2011). A comparison of the effects of alendronate and alfacalcidol on bone mineral density around the femoral implant and in the lumbar spine after total hip arthroplasty. Journal of Bone & Joint Surgery—American Volume.
29 Janssen HCJP, Samson MM, Verhaar HJJ. (2010). Muscle strength and mobility in vitamin D-insufficient female geriatric patients: a randomized controlled trial on vitamin D and calcium supplementation. Aging-Clinical & Experimental Research.
30 Javanbakht MH, Keshavarz SA, Djalali M, et al. (2011). Randomized controlled trial using vitamins E and D supplementation in atopic dermatitis. Journal of Dermatological Treatment.
31 Joergensen C, Hovind P, Schmedes A, et al. (2011). Vitamin D levels, microvascular complications, and mortality in type 1 diabetes. Diabetes Care.
32 Judd SE, Raiser SN, Kumari M, et al. (2010). 1,25-dihydroxyvitamin D3 reduces systolic blood pressure in hypertensive adults: a pilot feasibility study. Journal of Steroid Biochemistry & Molecular Biology.
33 Karaplis AC, Chouha F, Djandji M, et al. (2011). Vitamin D status and response to daily 400 IU vitamin D3 and weekly alendronate 70 mg in men and women with osteoporosis. Annals of Pharmacotherapy.
34 Kluczynski MA, Wactawski-Wende J, Platek ME, et al. (2012). Changes in vitamin D supplement use and baseline plasma 25-hydroxyvitamin D concentration predict 5-y change in concentration in postmenopausal women. Journal of Nutrition.
35 Langdahl B, Binkley N, Bone H, et al. (2012). Odanacatib in the treatment of postmenopausal women with low bone mineral density: five years of continued therapy in a phase 2 study. Journal of Bone & Mineral Research.
36 Larsen T, Mose FH, Bech JN, et al. (2012). Effect of cholecalciferol supplementation during winter months in patients with hypertension: a randomized, placebo-controlled trial. American Journal of Hypertension.
37 Lasky-Su J, Lange N, Brehm JM, et al. (2012). Genome-wide association analysis of circulating vitamin D levels in children with asthma. Human Genetics.
38 Lerchbaum E, Pilz S, Boehm BO, et al. (2012). Combination of low free testosterone and low vitamin D predicts mortality in older men referred for coronary angiography. Clinical Endocrinology.
39 Li M, Xing Xp, Zhang Zl, et al. (2010). Infusion of ibandronate once every 3 months effectively decreases bone resorption markers and increases bone mineral density in Chinese postmenopausal osteoporotic women: a 1-year study. Journal of Bone & Mineral Metabolism.
40 Li X, Liao L, Yan X, et al. (2009). Protective effects of 1-alpha-hydroxyvitamin D3 on residual beta-cell function in patients with adult-onset latent autoimmune diabetes (LADA). Diabetes/Metabolism Research Reviews.
41 Lloyd BD, Williamson DA, Singh NA, et al. (2009). Recurrent and injurious falls in the year following hip fracture: a prospective study of incidence and risk factors from the Sarcopenia and Hip Fracture study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
42 Majima T, Shimatsu A, Komatsu Y, et al. (2009). Effects of risedronate or alfacalcidol on bone mineral density, bone turnover, back pain, and fractures in Japanese men with primary osteoporosis: results of a two-year strict observational study. Journal of Bone & Mineral Metabolism.
43 Matsumoto T, Ito M, Hayashi Y, et al. (2011). A new active vitamin D3 analog, eldecalcitol, prevents the risk of osteoporotic fractures--a randomized, active comparator, double-blind study. Bone.
44 Mesliniene S, Ramrattan L, Giddings S, et al. (2013). Role of vitamin D in the onset, progression, and severity of multiple sclerosis. Endocrine Practice.
45 Nagahama K, Kanayama M, Togawa D, et al. (2011). Does alendronate disturb the healing process of posterior lumbar interbody fusion? A prospective randomized trial. Journal of Neurosurgery Spine.
46 Napoli N, Strollo R, Pitocco D, et al. (2013). Effect of calcitriol on bone turnover and osteocalcin in recent-onset type 1 diabetes. PLoS ONE.
47 Nazarian S, St Peter JV, Boston RC, et al. (2011). Vitamin D3 supplementation improves insulin sensitivity in subjects with impaired fasting glucose. Translational Research: The Journal Of Laboratory & Clinical Medicine.
48 Neelemaat F, Bosmans JE, Thijs A, et al. (2012). Oral nutritional support in malnourished elderly decreases functional limitations with no extra costs. Clinical Nutrition.
49 Neelemaat F, Lips P, Bosmans JE, et al. (2012). Short-term oral nutritional intervention with protein and vitamin D decreases falls in malnourished older adults. Journal of the American Geriatrics Society.
50 Newton-Bishop JA, Beswick S, Randerson-Moor J, et al. (2009). Serum 25-hydroxyvitamin D3 levels are associated with breslow thickness at presentation and survival from melanoma. Journal of Clinical Oncology.
51 Neyens JC, van Haastregt JC, Dijcks BP, et al. (2011). Effectiveness and implementation aspects of interventions for preventing falls in elderly people in long-term care facilities: a systematic review of RCTs. Journal of the American Medical Directors Association.
52 Nikooyeh B, Neyestani TR, Farvid M, et al. (2011). Daily consumption of vitamin D- or vitamin D + calcium-fortified yogurt drink improved glycemic control in patients with type 2 diabetes: a randomized clinical trial. American Journal of Clinical Nutrition.
53 Orimo H, Nakamura T, Fukunaga M, et al. (2011). Effects of alendronate plus alfacalcidol in osteoporosis patients with a high risk of fracture: the Japanese Osteoporosis Intervention Trial (JOINT)—02. Current Medical Research & Opinion.
54 Parikh S, Avorn J, Solomon DH. (2009). Pharmacological management of osteoporosis in nursing home populations: a systematic review. Journal of the American Geriatrics Society.
55 Pfleiderer AG, Ahmad N, Draper MR, et al. (2009). The timing of calcium measurements in helping to predict temporary and permanent hypocalcaemia in patients having completion and total thyroidectomies. Annals of the Royal College of Surgeons of England.
56 Pignotti GAP, Genaro PS, Pinheiro MM, et al. (2010). Is a lower dose of vitamin D supplementation enough to increase 25(OH)D status in a sunny country?. European Journal of Nutrition.
57 Pilz S, Dobnig H, Tomaschitz A, et al. (2012). Low 25-hydroxyvitamin D is associated with increased mortality in female nursing home residents. Journal of Clinical Endocrinology & Metabolism.
58 Premaor MO, Scalco R, da Silva MJS, et al. (2009). Secondary hyperparathyroidism is associated with increased risk of hospitalization or death in elderly adults living in a geriatric institution. Gerontology.
59 Prieto-Alhambra D, Javaid MK, Servitja S, et al. (2011). Vitamin D threshold to prevent aromatase inhibitor-induced arthralgia: a prospective cohort study. Breast Cancer Research & Treatment.
60 Punthakee Z, Bosch J, Dagenais G, et al. (2012). Design, history and results of the Thiazolidinedione Intervention with vitamin D Evaluation (TIDE) randomised controlled trial. Diabetologia.
61 Quesada-Gomez JM, Muschitz C, Gomez-Reino J, et al. (2011). The effect of PTH(1-84) or strontium ranelate on bone formation markers in postmenopausal women with primary osteoporosis: results of a randomized, open-label clinical trial. Osteoporosis International.
62 Ralston SH, Binkley N, Boonen S, et al. (2011). Randomized trial of alendronate plus vitamin D3 versus standard care in osteoporotic postmenopausal women with vitamin D insufficiency. Calcified Tissue International.
63 Rejnmark L, Vestergaard P, Brot C, et al. (2011). Increased fracture risk in normocalcemic postmenopausal women with high parathyroid hormone levels: a 16-year follow-up study. Calcified Tissue International.
64 Ringe JD, Farahmand P, Faber H, et al. (2009). Sustained efficacy of risedronate in men with primary and secondary osteoporosis: results of a 2-year study. Rheumatology International.
65 Ringe JD, Farahmand P, Schacht E. (2013). Alfacalcidol in men with osteoporosis: a prospective, observational, 2-year trial on 214 patients. Rheumatology International.
66 Roschger P, Manjubala I, Zoeger N, et al. (2010). Bone material quality in transiliac bone biopsies of postmenopausal osteoporotic women after 3 years of strontium ranelate treatment. Journal of Bone & Mineral Research.
67 Sahni S, Hannan MT, Blumberg J, et al. (2009). Protective effect of total carotenoid and lycopene intake on the risk of hip fracture: a 17-year follow-up from the Framingham Osteoporosis Study. Journal of Bone & Mineral Research.
68 Sanders KM, Stuart AL, Williamson EJ, et al. (2010). Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA.
69 Sato Y, Iwamoto J, Honda Y. (2011). An open-label trial comparing alendronate and alphacalcidol in reducing falls and hip fractures in disabled stroke patients. Journal of Stroke & Cerebrovascular Diseases.
70 Schacht E, Ringe JD. (2012). Alfacalcidol improves muscle power, muscle function and balance in elderly patients with reduced bone mass. Rheumatology International.
71 Schwartz JB. (2009). Effects of vitamin D supplementation in atorvastatin-treated patients: a new drug interaction with an unexpected consequence. Clinical Pharmacology & Therapeutics.
72 Semba RD, Houston DK, Ferrucci L, et al. (2009). Low serum 25-hydroxyvitamin D concentrations are associated with greater all-cause mortality in older community-dwelling women. Nutrition Research.
73 Shanafelt TD, Drake MT, Maurer MJ, et al. (2011). Vitamin D insufficiency and prognosis in chronic lymphocytic leukemia. Blood.
74 Shapses SA, Kendler DL, Robson R, et al. (2011). Effect of alendronate and vitamin D3 on fractional calcium absorption in a double-blind, randomized, placebo-controlled trial in postmenopausal osteoporotic women. Journal of Bone & Mineral Research.
75 Shiraki M, Saito H, Matsumoto T. (2012). Eldecalcitol normalizes bone turnover markers regardless of their pre-treatment levels. Current Medical Research & Opinion.
76 Sontag A, Krege JH. (2010). First fractures among postmenopausal women with osteoporosis. Journal of Bone & Mineral Metabolism.
77 Soric MM, Renner ET, Smith SR. (2012). Effect of daily vitamin D supplementation on HbA1c in patients with uncontrolled type 2 diabetes mellitus: a pilot study. Journal Of Diabetes.
78 Sridharan M, Cheung J, Moore AE, et al. (2010). Circulating fibroblast growth factor-23 increases following intermittent parathyroid hormone (1-34) in postmenopausal osteoporosis: association with biomarker of bone formation. Calcified Tissue International.
79 Srinivas S, Feldman D. (2009). A phase II trial of calcitriol and naproxen in recurrent prostate cancer. Anticancer Research.
80 Tellioglu A, Basaran S, Guzel R, et al. (2012). Efficacy and safety of high dose intramuscular or oral cholecalciferol in vitamin D deficient/insufficient elderly. Maturitas.
81 Tsai CL, Delclos GL, Huang JS, et al. (2013). Age-related differences in asthma outcomes in the United States, 1988-2006. Annals of Allergy, Asthma, & Immunology.
82 Tse SM, Kelly HW, Litonjua AA, et al. (2012). Corticosteroid use and bone mineral accretion in children with asthma: effect modification by vitamin D. Journal of Allergy & Clinical Immunology.
83 Turner C, Dalton N, Inaoui R, et al. (2013). Effect of a 300 000-IU loading dose of ergocalciferol (Vitamin D2) on circulating 1,25(OH)2-vitamin D and fibroblast growth factor-23 (FGF-23) in vitamin D insufficiency. Journal of Clinical Endocrinology & Metabolism.
84 Urashima M, Segawa T, Okazaki M, et al. (2010). Randomized trial of vitamin D supplementation to prevent seasonal influenza A in schoolchildren. American Journal of Clinical Nutrition.
85 Vacek JL, Vanga SR, Good M, et al. (2012). Vitamin D deficiency and supplementation and relation to cardiovascular health. American Journal of Cardiology.
86 Vaidya A, Sun B, Larson C, et al. (2012). Vitamin D3 therapy corrects the tissue sensitivity to angiotensin ii akin to the action of a converting enzyme inhibitor in obese hypertensives: an interventional study. Journal of Clinical Endocrinology & Metabolism.
87 Walter M, Kaupper T, Adler K, et al. (2010). No effect of the 1alpha,25-dihydroxyvitamin D3 on beta-cell residual function and insulin requirement in adults with new-onset type 1 diabetes. Diabetes Care.
88 Waltman NL, Twiss JJ, Ott CD, et al. (2010). The effect of weight training on bone mineral density and bone turnover in postmenopausal breast cancer survivors with bone loss: a 24-month randomized controlled trial. Osteoporosis International.
89 Xia Wb, Zhang Zl, Wang Hf, et al. (2009). The efficacy and safety of calcitriol and/or Caltrate D in elderly Chinese women with low bone mass. Zhongguo Yao Li Xue Bao/Acta Pharmacologica Sinica.
90 Majak P, Olszowiec-Chlebna M, Smejda K, et al. (2011). Vitamin D supplementation in children may prevent asthma exacerbation triggered by acute respiratory infection. The Journal of allergy and clinical immunology.
91 Sidbury R, Sullivan AF, Thadhani RI, et al. (2008). Randomized controlled trial of vitamin D supplementation for winter-related atopic dermatitis in Boston: a pilot study. The British journal of dermatology.
92 Avenell A, MacLennan GS, Jenkinson DJ, et al. (2012). Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). The Journal of clinical endocrinology and metabolism.
93 Zhang X, Li SW, Wu JF, et al. (2010). Effects of ipriflavone on postmenopausal syndrome and osteoporosis. Gynecological Endocrinology.
94 Adami S, Isaia G, Luisetto G, et al. (2008). Osteoporosis treatment and fracture incidence: the ICARO longitudinal study. Osteoporosis International.
95 Buduneli N, Saygan BH, Karaduman U, et al. (2008). Calcium, vitamin D supplements with or without alendronate and supragingival calculus formation in osteoporotic women: a preliminary study. Expert Opinion on Pharmacotherapy.
96 Chen JS, Sambrook PN, March L, et al. (2008). Hypovitaminosis D and parathyroid hormone response in the elderly: effects on bone turnover and mortality. Clinical Endocrinology.
97 Dobnig H, Pilz S, Scharnagl H, et al. (2008). Independent association of low serum 25-hydroxyvitamin d and 1,25-dihydroxyvitamin d levels with all-cause and cardiovascular mortality. Archives of Internal Medicine.
98 Geller JL, Hu B, Reed S, et al. (2008). Increase in bone mass after correction of vitamin D insufficiency in bisphosphonate-treated patients. Endocrine Practice.
99 Majima T, Komatsu Y, Shimatsu A, et al. (2008). Efficacy of combined treatment with raloxifene and alfacalcidol on bone density and biochemical markers of bone turnover in postmenopausal osteoporosis. Endocrine Journal.
100 Pilz S, Dobnig H, Fischer JE, et al. (2008). Low vitamin d levels predict stroke in patients referred to coronary angiography. Stroke.
101 Pilz S, Dobnig H, Winklhofer-Roob B, et al. (2008). Low serum levels of 25-hydroxyvitamin D predict fatal cancer in patients referred to coronary angiography. Cancer Epidemiology, Biomarkers & Prevention.
102 Thornton J, Ashcroft D, O'Neill T, et al. (2008). A systematic review of the effectiveness of strategies for reducing fracture risk in children with juvenile idiopathic arthritis with additional data on long-term risk of fracture and cost of disease management. Health Technology Assessment (Winchester, England).
103 Witham MD, Dove FJ, Khan F, et al. (2013). Effects of Vitamin D supplementation on markers of vascular function after myocardial infarction--a randomised controlled trial. International Journal of Cardiology.
104 Villasenor A, Ballard-Barbash R, Ambs A, et al. (2013). Associations of serum 25-hydroxyvitamin D with overall and breast cancer-specific mortality in a multiethnic cohort of breast cancer survivors. Cancer Causes & Control.
105 Tohidi M, Bozorgmanesh M, Mohebi R, et al. (2013). Non-linear association between 25-hydroxyvitamin D and the incidence of type 2 diabetes: a community-based nested case-control study. Diabetic Medicine.
106 Saliba W, Barnett-Griness O, Rennert G. (2013). The association between obesity and urinary tract infection. European Journal of Internal Medicine.
107 Rees JR, Hendricks K, Barry EL, et al. (2013). Vitamin D3 supplementation and upper respiratory tract infections in a randomized, controlled trial. Clinical Infectious Diseases.
108 Mocanu V, Vieth R. (2013). Three-year follow-up of serum 25-hydroxyvitamin D, parathyroid hormone, and bone mineral density in nursing home residents who had received 12months of daily bread fortification with 125mug of vitamin D3. Nutrition Journal.
109 Marchisio P, Consonni D, Baggi E, et al. (2013). Vitamin D supplementation reduces the risk of acute otitis media in otitis-prone children. Pediatric Infectious Disease Journal.
110 Lai L, Qian J, Yang Y, et al. (2013). Is the serum vitamin D level at the time of hospital-acquired acute kidney injury diagnosis associated with prognosis?. PLoS ONE.
111 Chai W, Cooney RV, Franke AA, et al. (2013). Effects of calcium and vitamin D supplementation on blood pressure and serum lipids and carotenoids: a randomized, double-blind, placebo-controlled, clinical trial. Annals of Epidemiology.
112 Carlson N, Mah R, Aburto M, et al. (2013). Hypovitaminosis d correction and high-sensitivity C-reactive protein levels in hypertensive adults. Permanente Journal.
113 Bhattoa HP, Onyeka U, Kalina E, et al. (2013). Bone metabolism and the 10-year probability of hip fracture and a major osteoporotic fracture using the country-specific FRAX algorithm in men over 50 years of age with type 2 diabetes mellitus: a case-control study. Clinical Rheumatology.
114 Aziz M, Livak B, Burke-Miller J, et al. (2013). Vitamin D insufficiency may impair CD4 recovery among Women's Interagency HIV Study participants with advanced disease on HAART. AIDS.
115 Amer M, Qayyum R. (2013). Relationship between 25-hydroxyvitamin D and all-cause and cardiovascular disease mortality. American Journal of Medicine.
116 Alele JD, Luttrell LM, Hollis BW, et al. (2013). Relationship between vitamin D status and incidence of vascular events in the Veterans Affairs Diabetes Trial. Atherosclerosis.

### Interventions/Exposures/Predictors Not of Interest—N=111

1 Abbas S, Linseisen J, Rohrmann S, et al. (2013). Dietary intake of vitamin D and calcium and breast cancer risk in the European Prospective Investigation into Cancer and Nutrition. Nutrition & Cancer.
2 Abbas S, Linseisen J, Rohrmann S, et al. (2013). Dietary intake of vitamin d and calcium and breast cancer risk in the European prospective investigation into cancer and nutrition. Nutrition & Cancer.
3 Agarwal R, Virmani D, Jaipal ML, et al. (2012). Vitamin d status of low birth weight infants in Delhi: a comparative study. Journal of Tropical Pediatrics.
4 Aggarwal V, Seth A, Marwaha RK, et al. (2013). Management of nutritional rickets in Indian children: a randomized controlled trial. Journal of Tropical Pediatrics.
5 Albanes D, Mondul AM, Yu K, et al. (2011). Serum 25-hydroxy vitamin D and prostate cancer risk in a large nested case-control study. Cancer Epidemiology, Biomarkers & Prevention.
6 Al-Daghri NM, Alkharfy KM, Al-Othman A, et al. (2013). Effect of non-pharmacologic vitamin D status correction on circulating bone markers in healthy overweight and obese Saudis. Molecules.
7 Alekel DL, Van Loan MD, Koehler KJ, et al. (2010). The soy isoflavones for reducing bone loss (SIRBL) study: a 3-y randomized controlled trial in postmenopausal women. American Journal of Clinical Nutrition.
8 Ananthakrishnan AN, Khalili H, Higuchi LM, et al. (2012). Higher predicted vitamin D status is associated with reduced risk of Crohn's disease. Gastroenterology.
9 Antoniucci DM, Vittinghoff E, Palermo L, et al. (2009). Vitamin D insufficiency does not affect response of bone mineral density to alendronate. Osteoporosis International.
10 Avenell A, MacLennan GS, Jenkinson DJ, et al. (2012). Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). Journal of Clinical Endocrinology & Metabolism.
11 Bao Y, Ng K, Wolpin BM, et al. (2010). Predicted vitamin D status and pancreatic cancer risk in two prospective cohort studies. British Journal of Cancer.
12 Benetou V, Orfanos P, Zylis D, et al. (2011). Diet and hip fractures among elderly Europeans in the EPIC cohort. European Journal of Clinical Nutrition.
13 Berggren M, Stenvall M, Olofsson B, et al. (2008). Evaluation of a fall-prevention program in older people after femoral neck fracture: a one-year follow-up. Osteoporosis International.
14 Bischoff-Ferrari HA, Orav EJ, Dawson-Hughes B. (2008). Additive benefit of higher testosterone levels and vitamin D plus calcium supplementation in regard to fall risk reduction among older men and women. Osteoporosis International.
15 Cauley JA, Chlebowski RT, Wactawski-Wende J, et al. (2013). Calcium plus vitamin D supplementation and health outcomes five years after active intervention ended: the Women's Health Initiative. Journal of Women's Health.
16 Costenbader KH, Feskanich D, Holmes M, et al. (2008). Vitamin D intake and risks of systemic lupus erythematosus and rheumatoid arthritis in women. Annals of the Rheumatic Diseases.
17 Davidson MB, Duran P, Lee ML, et al. (2013). High-dose vitamin D supplementation in people with prediabetes and hypovitaminosis D. Diabetes Care.
18 Edvardsen K, Veierod MB, Brustad M, et al. (2011). Vitamin D-effective solar UV radiation, dietary vitamin D and breast cancer risk. International Journal of Cancer.
19 Engel P, Fagherazzi G, Mesrine S, et al. (2011). Joint effects of dietary vitamin D and sun exposure on breast cancer risk: results from the French E3N cohort. Cancer Epidemiology, Biomarkers & Prevention.
20 Erkkola M, Kaila M, Nwaru BI, et al. (2009). Maternal vitamin D intake during pregnancy is inversely associated with asthma and allergic rhinitis in 5-year-old children. Clinical & Experimental Allergy.
21 Evans RK, Antczak AJ, Lester M, et al. (2008). Effects of a 4-month recruit training program on markers of bone metabolism. Medicine & Science in Sports & Exercise.
22 Fan C, Nieto FJ, Bautista LE, et al. (2012). Vitamin D intake and cardiovascular mortality in the NHANES I epidemiological follow-up study cohort. Journal of Dietary Supplements.
23 Farhanghi MA, Mahboob S, Ostadrahimi A. (2009). Obesity induced magnesium deficiency can be treated by vitamin D supplementation. JPMA—Journal of the Pakistan Medical Association.
24 Felsenberg D, Bock O, Borst H, et al. (2011). Additive impact of alfacalcidol on bone mineral density and bone strength in alendronate treated postmenopausal women with reduced bone mass. Journal of Musculoskeletal Neuronal Interactions.
25 Fonollá J, López-Huertas E, Machado FJ, et al. (2009). Milk enriched with “healthy fatty acids” improves cardiovascular risk markers and nutritional status in human volunteers. Nutrition (Burbank, Los Angeles County, Calif.).
26 Gaal J, Bender T, Varga J, et al. (2009). Overcoming resistance to bisphosphonates through the administration of alfacalcidol: results of a 1-year, open follow-up study. Rheumatology International.
27 Ganry O, Lapotre-Ledoux B, Fardellone P, et al. (2008). Bone mass density, subsequent risk of colon cancer and survival in postmenopausal women. European Journal of Epidemiology.
28 Gilbert R, Metcalfe C, Oliver SE, et al. (2009). Life course sun exposure and risk of prostate cancer: population-based nested case-control study and meta-analysis. International Journal of Cancer.
29 Gonzalez CA, Travier N, Lujan-Barroso L, et al. (2011). Dietary factors and in situ and invasive cervical cancer risk in the European prospective investigation into cancer and nutrition study. International Journal of Cancer.
30 Gutin B, Stallmann-Jorgensen IS, Le AH, et al. (2011). Relations of diet and physical activity to bone mass and height in black and white adolescents. Pediatric Reports.
31 Hagstrom E, Ingelsson E, Sundstrom J, et al. (2010). Plasma parathyroid hormone and risk of congestive heart failure in the community. European Journal of Heart Failure.
32 Harris HR, Chavarro JE, Malspeis S, et al. (2013). Dairy-food, calcium, magnesium, and vitamin D intake and endometriosis: a prospective cohort study. American Journal of Epidemiology.
33 Haugen M, Brantsaeter AL, Trogstad L, et al. (2009). Vitamin D supplementation and reduced risk of preeclampsia in nulliparous women. Epidemiology.
34 Hettiarachchi M, Lekamwasam S, Liyanage C. (2010). Long-term cereal-based nutritional supplementation improved the total spine bone mineral density amongst Sri Lankan preschool children: a randomized controlled study. Journal of Pediatric Endocrinology.
35 Hinton PS, Rector RS, Donnelly JE, et al. (2010). Total body bone mineral content and density during weight loss and maintenance on a low- or recommended-dairy weight-maintenance diet in obese men and women. European Journal of Clinical Nutrition.
36 Hiraki LT, Munger KL, Costenbader KH, et al. (2012). Dietary intake of vitamin D during adolescence and risk of adult-onset systemic lupus erythematosus and rheumatoid arthritis. Arthritis care & research.
37 Holecki M, Zahorska-Markiewicz B, Wiecek A, et al. (2008). Influence of calcium and vitamin D supplementation on weight and fat loss in obese women. Obesity facts.
38 Holm L, Olesen JL, Matsumoto K, et al. (2008). Protein-containing nutrient supplementation following strength training enhances the effect on muscle mass, strength, and bone formation in postmenopausal women. Journal of Applied Physiology.
39 Horn LV, Tian L, Neuhouser ML, et al. (2012). Dietary patterns are associated with disease risk among participants in the Women's Health Initiative Observational Study. Journal of Nutrition.
40 Hypponen E, Fararouei M, Sovio U, et al. (2011). High-dose vitamin D supplements are not associated with linear growth in a large Finnish cohort. Journal of Nutrition.
41 Ishihara J, Inoue M, Iwasaki M, et al. (2008). Dietary calcium, vitamin D, and the risk of colorectal cancer. American Journal of Clinical Nutrition.
42 Itariu BK, Zeyda M, Leitner L, et al. (2013). Treatment with n-3 polyunsaturated fatty acids overcomes the inverse association of vitamin D deficiency with inflammation in severely obese patients: a randomized controlled trial. PLoS ONE.
43 Jacobs ET, Hibler EA, Lance P, et al. (2013). Association between circulating concentrations of 25(OH)D and colorectal adenoma: a pooled analysis. International Journal of Cancer.
44 Jeon H, Lee S, Kim TE, et al. (2011). Pharmacokinetics and tolerability of probucol after multiple oral administrations in healthy volunteers. International journal of clinical pharmacology and therapeutics.
45 Karami S, Andreotti G, Koutros S, et al. (2013). Pesticide exposure and inherited variants in vitamin d pathway genes in relation to prostate cancer. Cancer Epidemiology, Biomarkers & Prevention.
46 Kiehn KA, Mahoney J, Jones AN, et al. (2009). Vitamin D supplement intake in elderly fallers. Journal of the American Geriatrics Society.
47 Kim MJ, Na B, No SJ, et al. (2010). Nutritional status of vitamin D and the effect of vitamin D supplementation in Korean breast-fed infants. Journal of Korean Medical Science.
48 Kirii K, Mizoue T, Iso H, et al. (2009). Calcium, vitamin D and dairy intake in relation to type 2 diabetes risk in a Japanese cohort. Diabetologia.
49 Kojima G, Bell C, Abbott RD, et al. (2012). Low dietary vitamin D predicts 34-year incident stroke: the Honolulu Heart Program. Stroke.
50 Kota BP, Abdul MIM, Allen JD, et al. (2012). Effect of vitamin D3 supplementation on the pharmacokinetics of digoxin--a pilot study. Fundamental & Clinical Pharmacology.
51 Kristal AR, Arnold KB, Schenk JM, et al. (2008). Dietary patterns, supplement use, and the risk of symptomatic benign prostatic hyperplasia: results from the prostate cancer prevention trial. American Journal of Epidemiology.
52 Kruger MC, Schollum LM, Kuhn-Sherlock B, et al. (2010). The effect of a fortified milk drink on vitamin D status and bone turnover in post-menopausal women from South East Asia. Bone.
53 Kuper H, Yang L, Sandin S, et al. (2009). Prospective study of solar exposure, dietary vitamin D intake, and risk of breast cancer among middle-aged women. Cancer Epidemiology, Biomarkers & Prevention.
54 Lappe J, Kunz I, Bendik I, et al. (2013). Effect of a combination of genistein, polyunsaturated fatty acids and vitamins D3 and K1 on bone mineral density in postmenopausal women: a randomized, placebo-controlled, double-blind pilot study. European Journal of Nutrition.
55 Leventis P, Kiely PDW. (2009). The tolerability and biochemical effects of high-dose bolus vitamin D2 and D3 supplementation in patients with vitamin D insufficiency. Scandinavian Journal of Rheumatology.
56 Lindelof B, Krynitz B, Ayoubi S, et al. (2012). Previous extensive sun exposure and subsequent vitamin D production in patients with basal cell carcinoma of the skin, has no protective effect on internal cancers. European Journal of Cancer.
57 Liu E, McKeown NM, Pittas AG, et al. (2012). Predicted 25-hydroxyvitamin D score and change in fasting plasma glucose in the Framingham offspring study. European Journal of Clinical Nutrition.
58 Liu JJ, Bertrand KA, Karageorgi S, et al. (2013). Prospective analysis of vitamin D and endometrial cancer risk. Annals of Oncology.
59 Lucey AJ, Paschos GK, Cashman KD, et al. (2008). Influence of moderate energy restriction and seafood consumption on bone turnover in overweight young adults. The American journal of clinical nutrition.
60 Maki KC, Rubin MR, Wong LG, et al. (2011). Effects of vitamin D supplementation on 25-hydroxyvitamin D, high-density lipoprotein cholesterol, and other cardiovascular disease risk markers in subjects with elevated waist circumference. International Journal of Food Sciences & Nutrition.
61 Martin-Bautista E, Muñoz-Torres M, Fonolla J, et al. (2010). Improvement of bone formation biomarkers after 1-year consumption with milk fortified with eicosapentaenoic acid, docosahexaenoic acid, oleic acid, and selected vitamins. Nutrition research (New York, N.Y.).
62 Mason C, Xiao L, Imayama I, et al. (2011). Effects of weight loss on serum vitamin D in postmenopausal women. The American journal of clinical nutrition.
63 Mason C, Xiao L, Imayama I, et al. (2013). Influence of diet, exercise, and serum vitamin d on sarcopenia in postmenopausal women. Medicine & Science in Sports & Exercise.
64 Matsumoto T, Takano T, Yamakido S, et al. (2010). Comparison of the effects of eldecalcitol and alfacalcidol on bone and calcium metabolism. Journal of Steroid Biochemistry & Molecular Biology.
65 McLean RR, Jacques PF, Selhub J, et al. (2008). Plasma B vitamins, homocysteine, and their relation with bone loss and hip fracture in elderly men and women. Journal of Clinical Endocrinology & Metabolism.
66 Merlino LA, Curtis J, Mikuls TR, et al. (2004). Vitamin D intake is inversely associated with rheumatoid arthritis: results from the Iowa Women's Health Study. Arthritis Rheum.
67 Moran DS, Heled Y, Arbel Y, et al. (2012). Dietary intake and stress fractures among elite male combat recruits. Journal of the International Society of Sports Nutrition.
68 Munger KL, Chitnis T, Frazier AL, et al. (2011). Dietary intake of vitamin D during adolescence and risk of multiple sclerosis. Journal of Neurology.
69 Munger KL, Levin LI, O'Reilly EJ, et al. (2011). Anti-Epstein-Barr virus antibodies as serological markers of multiple sclerosis: a prospective study among United States military personnel. Multiple Sclerosis.
70 Neelemaat F, Bosmans JE, Thijs A, et al. (2011). Post-discharge nutritional support in malnourished elderly individuals improves functional limitations. Journal of the American Medical Directors Association.
71 Neuhouser ML, Wassertheil-Smoller S, Thomson C, et al. (2009). Multivitamin use and risk of cancer and cardiovascular disease in the Women's Health Initiative cohorts. Archives of Internal Medicine.
72 Nieves JW, Melsop K, Curtis M, et al. (2010). Nutritional factors that influence change in bone density and stress fracture risk among young female cross-country runners. Pm & R.
73 O'Connor DL, Khan S, Weishuhn K, et al. (2008). Growth and nutrient intakes of human milk-fed preterm infants provided with extra energy and nutrients after hospital discharge. Pediatrics.
74 Palacios S, Rojo IA, Cancelo MJ, et al. (2008). Women's perception of the efficacy of a soy extract with probiotic: the M3 study. Gynecological Endocrinology.
75 Palvanen M, Kannus P, Piirtola M, et al. (2014). Effectiveness of the Chaos Falls Clinic in preventing falls and injuries of home-dwelling older adults: A randomised controlled trial. Injury.
76 Pentti K, Tuppurainen MT, Honkanen R, et al. (2009). Use of calcium supplements and the risk of coronary heart disease in 52-62-year-old women: The Kuopio Osteoporosis Risk Factor and Prevention Study. Maturitas.
77 Porojnicu AC, Bruland OS, Aksnes L, et al. (2008). Sun beds and cod liver oil as vitamin D sources. Journal of photochemistry and photobiology. B, Biology.
78 Prelack K, Dwyer J, Ziegler P, et al. (2012). Bone mineral density in elite adolescent female figure skaters. Journal of the International Society of Sports Nutrition.
79 Prescott J, Bertrand KA, Poole EM, et al. (2013). Surrogates of long-term vitamin d exposure and ovarian cancer risk in two prospective cohort studies. Cancer.
80 Puri S, Marwaha RK, Agarwal N, et al. (2008). Vitamin D status of apparently healthy schoolgirls from two different socioeconomic strata in Delhi: relation to nutrition and lifestyle. British Journal of Nutrition.
81 Rajakumar K, Fernstrom JD, Holick MF, et al. (2008). Vitamin D status and response to Vitamin D(3) in obese vs. non-obese African American children. Obesity.
82 Rautiainen S, Akesson A, Levitan EB, et al. (2010). Multivitamin use and the risk of myocardial infarction: a population-based cohort of Swedish women. American Journal of Clinical Nutrition.
83 Rejnmark L, Vestergaard P, Heickendorff L, et al. (2010). Simvastatin does not affect vitamin d status, but low vitamin d levels are associated with dyslipidemia: results from a randomised, controlled trial. International Journal of Endocrinology Print.
84 Rohan TE, Negassa A, Caan B, et al. (2008). Low-fat dietary pattern and risk of benign proliferative breast disease: a randomized, controlled dietary modification trial. Cancer Prevention Research.
85 Romeo J, Wärnberg J, García-Mármol E, et al. (2011). Daily consumption of milk enriched with fish oil, oleic acid, minerals and vitamins reduces cell adhesion molecules in healthy children. Nutrition, metabolism, and cardiovascular diseases : NMCD.
86 Sai AJ, Gallagher JC, Smith LM, et al. (2010). Fall predictors in the community dwelling elderly: a cross sectional and prospective cohort study. Journal of Musculoskeletal Neuronal Interactions.
87 Samelson EJ, Booth SL, Fox CS, et al. (2012). Calcium intake is not associated with increased coronary artery calcification: the Framingham Study. American Journal of Clinical Nutrition.
88 Scheinfeld NS. (2011). Calcipotriene 0.005% and betamethasone dipropionate 0.064% combination topical suspension (Taclonex Scalp). SKINmed.
89 Scholl TO, Chen X. (2009). Vitamin D intake during pregnancy: association with maternal characteristics and infant birth weight. Early Human Development.
90 Soares PAO, Kovacs C, Moreira P, et al. (2012). Is intake of vitamin D and calcium important for cardiovascular health in elderly obese patients?. Obesity Surgery.
91 Songpatanasilp T, Chailurkit LO, Nichachotsalid A, et al. (2009). Combination of alfacalcidol with calcium can improve quadriceps muscle strength in elderly ambulatory Thai women who have hypovitaminosis D: a randomized controlled trial. Journal of the Medical Association of Thailand.
92 Sonneville KR, Gordon CM, Kocher MS, et al. (2012). Vitamin d, calcium, and dairy intakes and stress fractures among female adolescents. Archives of Pediatrics & Adolescent Medicine.
93 Spector TD, Calomme MR, Anderson SH, et al. (2008). Choline-stabilized orthosilicic acid supplementation as an adjunct to calcium/vitamin D3 stimulates markers of bone formation in osteopenic females: a randomized, placebo-controlled trial. BMC musculoskeletal disorders.
94 Stenova E, Steno B, Killinger Z, et al. (2011). Effect of long-term oral anticoagulant therapy on bone mineral density and bone turnover markers: a prospective 12 month study. Bratislavske Lekarske Listy.
95 Su X, Colditz GA, Collins LC, et al. (2012). Adolescent intakes of vitamin D and calcium and incidence of proliferative benign breast disease. Breast Cancer Research & Treatment.
96 Sun Q, Shi L, Rimm EB, et al. (2011). Vitamin D intake and risk of cardiovascular disease in US men and women. American Journal of Clinical Nutrition.
97 Sverdlov AL, Ngo DTM, Chan WPA, et al. (2012). Determinants of aortic sclerosis progression: implications regarding impairment of nitric oxide signalling and potential therapeutics. European Heart Journal.
98 Takata Y, Shu XO, Yang G, et al. (2013). Calcium intake and lung cancer risk among female nonsmokers: a report from the Shanghai Women's Health Study. Cancer Epidemiology, Biomarkers & Prevention.
99 Tenta R, Moschonis G, Koutsilieris M, et al. (2011). Calcium and vitamin D supplementation through fortified dairy products counterbalances seasonal variations of bone metabolism indices: the Postmenopausal Health Study. European Journal of Nutrition.
100 Thorp JM, Camargo CA, McGee PL, et al. (2012). Vitamin D status and recurrent preterm birth: a nested case-control study in high-risk women. BJOG: An International Journal of Obstetrics & Gynaecology.
101 van de Lagemaat M, Rotteveel J, Schaafsma A, et al. (2013). Higher vitamin D intake in preterm infants fed an isocaloric, protein- and mineral-enriched postdischarge formula is associated with increased bone accretion. Journal of Nutrition.
102 Vande Griend JP, Linnebur SA, Ruscin JM, et al. (2008). Vitamin D intervention by pharmacists in geriatric outpatients. Journal of the American Pharmacists Association: JAPhA.
103 Vinceti M, Malagoli C, Fiorentini C, et al. (2011). Inverse association between dietary vitamin D and risk of cutaneous melanoma in a northern Italy population. Nutrition & Cancer.
104 Watson PE, McDonald BW. (2010). The association of maternal diet and dietary supplement intake in pregnant New Zealand women with infant birthweight. European Journal of Clinical Nutrition.
105 Weinstein SJ, Stolzenberg-Solomon RZ, Kopp W, et al. (2012). Impact of circulating vitamin D binding protein levels on the association between 25-hydroxyvitamin D and pancreatic cancer risk: a nested case-control study. Cancer Research.
106 Weinstein SJ, Yu K, Horst RL, et al. (2011). Serum 25-hydroxyvitamin D and risks of colon and rectal cancer in Finnish men. American Journal of Epidemiology.
107 White KM, Bauer SJ, Hartz KK, et al. (2009). Changes in body composition with yogurt consumption during resistance training in women. International Journal of Sport Nutrition & Exercise Metabolism.
108 Wilson RT, Wang J, Chinchilli V, et al. (2009). Fish, vitamin D, and flavonoids in relation to renal cell cancer among smokers. American Journal of Epidemiology.
109 Zabihiyeganeh M, Jahed A, Nojomi M. (2013). Treatment of hypovitaminosis D with pharmacologic doses of cholecalciferol, oral vs intramuscular; an open labeled RCT. Clinical Endocrinology.
110 Zhou W, Langsetmo L, Berger C, et al. (2013). Longitudinal changes in calcium and vitamin D intakes and relationship to bone mineral density in a prospective population-based study: the Canadian Multicentre Osteoporosis Study (CaMos). Journal of Musculoskeletal Neuronal Interactions.
111 Zittermann A, Frisch S, Berthold HK, et al. (2009). Vitamin D supplementation enhances the beneficial effects of weight loss on cardiovascular disease risk markers. American Journal of Clinical Nutrition.

### Comparator/Placebo Not of Interest—N=36

1 Aguirre Castaneda R, Nader N, Weaver A, et al. (2012). Response to vitamin D3 supplementation in obese and non-obese Caucasian adolescents. Hormone research in pdiatrics.
2 Allen AC, Kelly S, Basdeo SA, et al. (2012). A pilot study of the immunological effects of high-dose vitamin D in healthy volunteers. Multiple Sclerosis.
3 Back O, Blomquist HKS, Hernell O, et al. (2009). Does vitamin D intake during infancy promote the development of atopic allergy?. Acta Dermato-Venereologica.
4 Bischoff-Ferrari HA, Dawson-Hughes B, Stocklin E, et al. (2012). Oral supplementation with 25(OH)D3 versus vitamin D3: effects on 25(OH)D levels, lower extremity function, blood pressure, and markers of innate immunity. Journal of Bone & Mineral Research.
5 Cipriani C, Romagnoli E, Scillitani A, et al. (2010). Effect of a single oral dose of 600,000 IU of cholecalciferol on serum calciotropic hormones in young subjects with vitamin D deficiency: a prospective intervention study. Journal of Clinical Endocrinology & Metabolism.
6 Coelho IMG, Andrade LDd, Saldanha L, et al. (2010). Bioavailability of vitamin D3 in non-oily capsules: the role of formulated compounds and implications for intermittent replacement. Arquivos Brasileiros de Endocrinologia e Metabologia.
7 Colacurci N, De Franciscis P, Atlante M, et al. (2013). Endometrial, breast and liver safety of soy isoflavones plus Lactobacillus sporogenes in post-menopausal women. Gynecological Endocrinology.
8 Colon-Emeric CS, Lyles KW, Su G, et al. (2011). Clinical risk factors for recurrent fracture after hip fracture: a prospective study. Calcified Tissue International.
9 Dinizulu T, Griffin D, Carey J, et al. (2011). Vitamin D supplementation versus combined calcium and vitamin D in older female patients—an observational study. Journal of Nutrition, Health & Aging.
10 Ekbote VH, Khadilkar AV, Chiplonkar SA, et al. (2011). A pilot randomized controlled trial of oral calcium and vitamin D supplementation using fortified laddoos in underprivileged Indian toddlers. European Journal of Clinical Nutrition.
11 Gallo S, Phan A, Vanstone CA, et al. (2013). The change in plasma 25-hydroxyvitamin D did not differ between breast-fed infants that received a daily supplement of ergocalciferol or cholecalciferol for 3 months. Journal of Nutrition.
12 Heaney RP, Recker RR, Grote J, et al. (2011). Vitamin D(3) is more potent than vitamin D(2) in humans. Journal of Clinical Endocrinology & Metabolism.
13 Herrmann W, Kirsch SH, Kruse V, et al. (2013). One year B and D vitamins supplementation improves metabolic bone markers. Clinical Chemistry & Laboratory Medicine.
14 Holvik K, Madar AA, Meyer HE, et al. (2012). Changes in the vitamin D endocrine system and bone turnover after oral vitamin D3 supplementation in healthy adults: results of a randomised trial. BMC Endocrine Disorders.
15 Husemoen LLN, Thuesen BH, Fenger M, et al. (2012). Serum 25(OH)D and type 2 diabetes association in a general population: a prospective study. Diabetes Care.
16 Kanellakis S, Moschonis G, Tenta R, et al. (2012). Changes in parameters of bone metabolism in postmenopausal women following a 12-month intervention period using dairy products enriched with calcium, vitamin D, and phylloquinone (vitamin K(1)) or menaquinone-7 (vitamin K (2)): the Postmenopausal Health Study II. Calcified Tissue International.
17 Leaf DE, Korets R, Taylor EN, et al. (2012). Effect of vitamin D repletion on urinary calcium excretion among kidney stone formers. Clinical Journal of The American Society of Nephrology: CJASN.
18 Logan VF, Gray AR, Peddie MC, et al. (2013). Long-term vitamin D3 supplementation is more effective than vitamin D2 in maintaining serum 25-hydroxyvitamin D status over the winter months. British Journal of Nutrition.
19 Marwaha RK, Tandon N, Agarwal N, et al. (2010). Impact of two regimens of vitamin D supplementation on calcium—vitamin D—PTH axis of schoolgirls of Delhi. Indian Pediatrics.
20 Park CY, Hill KM, Elble AE, et al. (2010). Daily supplementation with 25 ug cholecalciferol does not increase calcium absorption or skeletal retention in adolescent girls with low serum 25-hydroxyvitamin D. Journal of Nutrition.
21 Pekkarinen T, Valimaki VV, Aarum S, et al. (2010). The same annual dose of 292000 IU of vitamin D (cholecalciferol) on either daily or four monthly basis for elderly women: 1-year comparative study of the effects on serum 25(OH)D concentrations and renal function. Clinical Endocrinology.
22 Pierce D, Hossack S, Poole L, et al. (2011). The effect of sevelamer carbonate and lanthanum carbonate on the pharmacokinetics of oral calcitriol. Nephrology Dialysis Transplantation.
23 Prietl B, Pilz S, Wolf M, et al. (2010). Vitamin D supplementation and regulatory T cells in apparently healthy subjects: vitamin D treatment for autoimmune diseases?. Israel Medical Association Journal: Imaj.
24 Raimundo FV, Faulhaber GAM, Menegatti PK, et al. (2011). Effect of High- versus Low-Fat Meal on Serum 25-Hydroxyvitamin D Levels after a Single Oral Dose of Vitamin D: A Single-Blind, Parallel, Randomized Trial. International Journal of Endocrinology Print.
25 Roth DE, Al Mahmud A, Raqib R, et al. (2012). Pharmacokinetics of a single oral dose of vitamin D3 (70,000 IU) in pregnant and non-pregnant women. Nutrition Journal.
26 Roth DE, Mahmud AA, Raqib R, et al. (2013). Pharmacokinetics of High-Dose Weekly Oral Vitamin D3 Supplementation during the Third Trimester of Pregnancy in Dhaka, Bangladesh. Nutrients.
27 Russo S, Carlucci L, Cipriani C, et al. (2011). Metabolic changes following 500 ug monthly administration of calcidiol: a study in normal females. Calcified Tissue International.
28 Steinberg FM, Murray MJ, Lewis RD, et al. (2011). Clinical outcomes of a 2-y soy isoflavone supplementation in menopausal women. American Journal of Clinical Nutrition.
29 Thacher TD, Aliu O, Griffin IJ, et al. (2009). Meals and dephytinization affect calcium and zinc absorption in Nigerian children with rickets. Journal of Nutrition.
30 Thacher TD, Fischer PR, Obadofin MO, et al. (2010). Comparison of metabolism of vitamins D2 and D3 in children with nutritional rickets. Journal of Bone & Mineral Research.
31 Thomas SDC, Need AG, Nordin BEC. (2010). Suppression of C-terminal telopeptide in hypovitaminosis D requires calcium as well as vitamin D. Calcified Tissue International.
32 Wicherts IS, Boeke AJP, van der Meer IM, et al. (2011). Sunlight exposure or vitamin D supplementation for vitamin D-deficient non-western immigrants: a randomized clinical trial. Osteoporosis International.
33 Valimaki MJ, Pekkarinen T, Velimaki VV, et al. (2010). The same annual dose of 292000 IU of vitamin D3 (cholecalciferol) on either daily or four monthly basis for elderly women: 1-year comparative study of the effects on serum 25(OH)D3 concentrations and renal function. Clinical Endocrinology.
34 V Eckardstein A, B-F HA, D-H B, S E, S E, W WC, E JO, S HB, W S, J A, S J, H J, Egli A. (2012). Oral supplementation with 25(OH)D3 versus vitamin D3: Effects on 25(OH)D levels, lower extremity function, blood pressure, and markers of innate immunity. Journal of Bone and Mineral Research.
35 Golombick T, Diamond T. (2008). The effect of a combined oral calcium and vitamin D supplement for treating mild to moderate vitamin D deficiency in postmenopausal women. Clinical Interventions In Aging.
36 Cipriani C, Romagnoli E, Pepe J, et al. (2013). Long-term bioavailability after a single oral or intramuscular administration of 600,000 IU of ergocalciferol or cholecalciferol: implications for treatment and prophylaxis. Journal of Clinical Endocrinology & Metabolism.

### No Outcomes of Interest—N=306

1 Abnet CC, Chen Y, Chow WH, et al. (2010). Circulating 25-hydroxyvitamin D and risk of esophageal and gastric cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
2 Abrams SA, Hawthorne KM, Chen Z. (2013). Supplementation with 1000 IU vitamin D/d leads to parathyroid hormone suppression, but not increased fractional calcium absorption, in 4-8-y-old children: a double-blind randomized controlled trial. American Journal of Clinical Nutrition.
3 Afzal S, Bojesen SE, Nordestgaard BG. (2013). Low 25-hydroxyvitamin D and risk of type 2 diabetes: a prospective cohort study and metaanalysis. Clinical Chemistry.
4 Afzal S, Nordestgaard BG, Bojesen SE. (2013). Plasma 25-hydroxyvitamin D and risk of non-melanoma and melanoma skin cancer: a prospective cohort study. Journal of Investigative Dermatology.
5 Agarwal N, Faridi MMA, Aggarwal A, et al. (2010). Vitamin D Status of term exclusively breastfed infants and their mothers from India. Acta Paediatrica.
6 Agarwal N, Mithal A, Dhingra V, et al. (2013). Effect of two different doses of oral cholecalciferol supplementation on serum 25-hydroxy-vitamin D levels in healthy Indian postmenopausal women: A randomized controlled trial. Indian Journal of Endocrinology and Metabolism.
7 Ahearn TU, McCullough ML, Flanders WD, et al. (2011). A randomized clinical trial of the effects of supplemental calcium and vitamin D3 on markers of their metabolism in normal mucosa of colorectal adenoma patients. Cancer Research.
8 Ahearn TU, Shaukat A, Flanders WD, et al. (2012). A randomized clinical trial of the effects of supplemental calcium and vitamin D3 on the APC/-catenin pathway in the normal mucosa of colorectal adenoma patients. Cancer Prevention Research.
9 Al-Daghri NM, Alkharfy KM, Al-Saleh Y, et al. (2012). Modest reversal of metabolic syndrome manifestations with vitamin D status correction: a 12-month prospective study. Metabolism: Clinical & Experimental.
10 Aloia J, Bojadzievski T, Yusupov E, et al. (2010). The relative influence of calcium intake and vitamin D status on serum parathyroid hormone and bone turnover biomarkers in a double-blind, placebo-controlled parallel group, longitudinal factorial design. Journal of Clinical Endocrinology & Metabolism.
11 Aloia JF, Dhaliwal R, Shieh A, et al. (2013). Calcium and vitamin d supplementation in postmenopausal women. Journal of Clinical Endocrinology & Metabolism.
12 Aloia JF, Patel M, Dimaano R, et al. (2008). Vitamin D intake to attain a desired serum 25-hydroxyvitamin D concentration. American Journal of Clinical Nutrition.
13 Alonso A, Rodriguez J, Carvajal I, et al. (2011). Prophylactic vitamin D in healthy infants: assessing the need. Metabolism: Clinical & Experimental.
14 Aluisio AR, Maroof Z, Chandramohan D, et al. (2013). Vitamin D3supplementation and childhood diarrhea: a randomized controlled trial. Pediatrics.
15 Amirbaigloo A, Hosseinpanah F, Sarvghadi F, et al. (2013). Absence of association between vitamin d deficiency and incident metabolic syndrome: tehran lipid and glucose study. Metabolic Syndrome & Related Disorders.
16 Andersen R, Brot C, Mejborn H, et al. (2009). Vitamin D supplementation does not affect serum lipids and lipoproteins in Pakistani immigrants. European Journal of Clinical Nutrition.
17 Anderson JL, Vanwoerkom RC, Horne BD, et al. (2011). Parathyroid hormone, vitamin D, renal dysfunction, and cardiovascular disease: dependent or independent risk factors?. American Heart Journal.
18 Annweiler C, Rolland Y, Schott AM, et al. (2011). Serum vitamin D deficiency as a predictor of incident non-Alzheimer dementias: a 7-year longitudinal study. Dementia & Geriatric Cognitive Disorders.
19 Arabi A, Baddoura R, El-Rassi R, et al. (2012). PTH level but not 25 (OH) vitamin D level predicts bone loss rates in the elderly. Osteoporosis International.
20 Arabi A, Zahed L, Mahfoud Z, et al. (2009). Vitamin D receptor gene polymorphisms modulate the skeletal response to vitamin D supplementation in healthy girls. Bone.
21 Arem H, Weinstein SJ, Horst RL, et al. (2011). Serum 25-hydroxyvitamin D and risk of oropharynx and larynx cancers in Finnish men. Cancer Epidemiology, Biomarkers & Prevention.
22 Arslan AA, Clendenen TV, Koenig KL, et al. (2009). Circulating vitamin d and risk of epithelial ovarian cancer. Journal of Oncology Print.
23 Arvold DS, Odean MJ, Dornfeld MP, et al. (2009). Correlation of symptoms with vitamin D deficiency and symptom response to cholecalciferol treatment: a randomized controlled trial. Endocrine Practice.
24 Arvold DS, Odean MJ, Dornfeld MP, et al. (2009). Correlation of symptoms with vitamin D deficiency and symptom response to cholecalciferol treatment: a randomized controlled trial. Endocrine Practice.
25 Asemi Z, Samimi M, Tabassi Z, et al. (2013). Vitamin D supplementation affects serum high-sensitivity C-reactive protein, insulin resistance, and biomarkers of oxidative stress in pregnant women. Journal of Nutrition.
26 Asgari MM, Tang J, Warton ME, et al. (2010). Association of prediagnostic serum vitamin D levels with the development of basal cell carcinoma. Journal of Investigative Dermatology.
27 Atas E, Karademir F, Ersen A, et al. (2013). Comparison between daily supplementation doses of 200 versus 400 IU of vitamin D in infants. European Journal of Pediatrics.
28 Avenell A, Cook JA, MacLennan GS, et al. (2009). Vitamin D supplementation and type 2 diabetes: a substudy of a randomised placebo-controlled trial in older people (RECORD trial, ISRCTN 51647438). Age & Ageing.
29 Baker AM, Haeri S, Camargo CA, et al. (2012). First-trimester maternal vitamin D status and risk for gestational diabetes (GDM) a nested case-control study. Diabetes/Metabolism Research Reviews.
30 Beilfuss J, Berg V, Sneve M, et al. (2012). Effects of a 1-year supplementation with cholecalciferol on interleukin-6, tumor necrosis factor-alpha and insulin resistance in overweight and obese subjects. Cytokine.
31 Belenchia AM, Tosh AK, Hillman LS, et al. (2013). Correcting vitamin D insufficiency improves insulin sensitivity in obese adolescents: a randomized controlled trial. American Journal of Clinical Nutrition.
32 Benjamin A, Moriakova A, Akhter N, et al. (2009). Determinants of 25-hydroxyvitamin D levels in African-American and Caucasian male veterans. Osteoporosis International.
33 Bergink AP, Uitterlinden AG, Van Leeuwen JPTM, et al. (2009). Vitamin D status, bone mineral density, and the development of radiographic osteoarthritis of the knee: The Rotterdam Study. JCR: Journal of Clinical Rheumatology.
34 Bertone-Johnson ER, Powers SI, Spangler L, et al. (2012). Vitamin D supplementation and depression in the women's health initiative calcium and vitamin D trial. American Journal of Epidemiology.
35 Biancuzzo RM, Clarke N, Reitz RE, et al. (2013). Serum concentrations of 1,25-dihydroxyvitamin d2 and 1,25-dihydroxyvitamin d3 in response to vitamin d2 and vitamin d3 supplementation. Journal of Clinical Endocrinology & Metabolism.
36 Biancuzzo RM, Young A, Bibuld D, et al. (2010). Fortification of orange juice with vitamin D(2) or vitamin D(3) is as effective as an oral supplement in maintaining vitamin D status in adults. American Journal of Clinical Nutrition.
37 Binkley N, Gemar D, Engelke J, et al. (2011). Evaluation of ergocalciferol or cholecalciferol dosing, 1,600 IU daily or 50,000 IU monthly in older adults. Journal of Clinical Endocrinology & Metabolism.
38 Binkley N, Ringe JD, Reed JI, et al. (2009). Alendronate/vitamin D3 70 mg/2800 IU with and without additional 2800 IU vitamin D3 for osteoporosis: results from the 24-week extension of a 15-week randomized, controlled trial. Bone.
39 Bischoff-Ferrari HA, Dawson-Hughes B, Platz A, et al. (2010). Effect of high-dosage cholecalciferol and extended physiotherapy on complications after hip fracture: a randomized controlled trial. Archives of Internal Medicine.
40 Boer IH, Tinker LF, Connelly S, et al. (2008). Calcium plus vitamin D supplementation and the risk of incident diabetes in the women's health initiative. Diabetes Care.
41 Bonjour JP, Benoit V, Rousseau B, et al. (2012). Consumption of vitamin D-and calcium-fortified soft white cheese lowers the biochemical marker of bone resorption TRAP 5b in postmenopausal women at moderate risk of osteoporosis fracture. Journal of Nutrition.
42 Breen ME, Laing EM, Hall DB, et al. (2011). 25-hydroxyvitamin D, insulin-like growth factor-I, and bone mineral accrual during growth. Journal of Clinical Endocrinology & Metabolism.
43 Breitling LP, Perna L, Muller H, et al. (2012). Vitamin D and cognitive functioning in the elderly population in Germany. Experimental Gerontology.
44 Brunel E, Schnitzler M, Foidart-Dessalle M, et al. (2013). A Double-Blind, Placebo Controlled, Randomized Trial to Assess the Impact of a Monthly Administration of 50,000 IU of Vitamin D3 for 6 Months on Serum Levels of 25-Hydroxyvitamin D in Healthy Young Adults. International Journal of Endocrinology Print.
45 Burnett-Bowie SAM, Leder BZ, Henao MP, et al. (2012). Randomized trial assessing the effects of ergocalciferol administration on circulating FGF23. Clinical Journal of The American Society of Nephrology: CJASN.
46 Candido FG, Silva Ton WT, Goncalves Alfenas Rde C. (2013). Dairy products consumption versus type 2 diabetes prevention and treatment; a review of recent findings from human studies. Nutricion Hospitalaria.
47 Carnes J, Quinn S, Nelson M, et al. (2012). Intermittent high-dose vitamin D corrects vitamin D deficiency in adolescents: a pilot study. European Journal of Clinical Nutrition.
48 Carter GD, Jones JC. (2009). Use of a common standard improves the performance of liquid chromatography-tandem mass spectrometry methods for serum 25-hydroxyvitamin-D. Annals of Clinical Biochemistry.
49 Cashman KD, FitzGerald AP, Viljakainen HT, et al. (2011). Estimation of the dietary requirement for vitamin D in healthy adolescent white girls. American Journal of Clinical Nutrition.
50 Cashman KD, Hill TR, Lucey AJ, et al. (2008). Estimation of the dietary requirement for vitamin D in healthy adults. The American journal of clinical nutrition.
51 Cashman KD, Seamans KM, Lucey AJ, et al. (2012). Relative effectiveness of oral 25-hydroxyvitamin D3 and vitamin D3 in raising wintertime serum 25-hydroxyvitamin D in older adults. American Journal of Clinical Nutrition.
52 Cashman KD, Wallace JM, Horigan G, et al. (2009). Estimation of the dietary requirement for vitamin D in free-living adults >=64 y of age. American Journal of Clinical Nutrition.
53 Cavalier E, Fache W, Souberbielle JC. (2013). A Randomised, Double-Blinded, Placebo-Controlled, Parallel Study of Vitamin D3 Supplementation with Different Schemes Based on Multiples of 25,000IU Doses. International Journal of Endocrinology Print.
54 Cavalli L, Cavalli T, Marcucci G, et al. (2009). Biological effects of various regimes of 25-hydroxyvitamin D3 (calcidiol) administration on bone mineral metabolism in postmenopausal women. Clinical Cases in Mineral & Bone Metabolism.
55 Cherniack EP, Florez HJ, Hollis BW, et al. (2011). The response of elderly veterans to daily vitamin D3 supplementation of 2,000 IU: a pilot efficacy study. Journal of the American Geriatrics Society.
56 Chung HY, Chin SO, Kang MIL, et al. (2011). Efficacy of risedronate with cholecalciferol on 25-hydroxyvitamin D level and bone turnover in Korean patients with osteoporosis. Clinical Endocrinology.
57 Close GL, Russell J, Cobley JN, et al. (2013). Assessment of vitamin D concentration in non-supplemented professional athletes and healthy adults during the winter months in the UK: implications for skeletal muscle function. Journal of Sports Sciences.
58 Cremers E, Thijs C, Penders J, et al. (2011). Maternal and child's vitamin D supplement use and vitamin D level in relation to childhood lung function: the KOALA Birth Cohort Study. Thorax.
59 Crozier SR, Harvey NC, Inskip HM, et al. (2012). Maternal vitamin D status in pregnancy is associated with adiposity in the offspring: findings from the Southampton Women's Survey. American Journal of Clinical Nutrition.
60 Curtis JR, Ewing SK, Bauer DC, et al. (2012). Association of intact parathyroid hormone levels with subsequent hip BMD loss: the Osteoporotic Fractures in Men (MrOS) Study. Journal of Clinical Endocrinology & Metabolism.
61 Daly RM, Petrass N, Bass S, et al. (2008). The skeletal benefits of calcium- and vitamin D3-fortified milk are sustained in older men after withdrawal of supplementation: an 18-mo follow-up study. American Journal of Clinical Nutrition.
62 Darling AL, Hart KH, Macdonald HM, et al. (2013). Vitamin D deficiency in UK South Asian Women of childbearing age: a comparative longitudinal investigation with UK Caucasian women. Osteoporosis International.
63 Dean AJ, Bellgrove MA, Hall T, et al. (2011). Effects of vitamin D supplementation on cognitive and emotional functioning in young adults--a randomised controlled trial. PLoS ONE.
64 Deleskog A, Hilding A, Brismar K, et al. (2012). Low serum 25-hydroxyvitamin D level predicts progression to type 2 diabetes in individuals with prediabetes but not with normal glucose tolerance. Diabetologia.
65 Deng X, Song Y, Manson JE, et al. (2013). Magnesium, vitamin D status and mortality: results from US National Health and Nutrition Examination Survey (NHANES) 2001 to 2006 and NHANES III. BMC Medicine.
66 Dennis NA, Houghton LA, Jones GT, et al. (2012). The level of serum anti-Mullerian hormone correlates with vitamin D status in men and women but not in boys. Journal of Clinical Endocrinology & Metabolism.
67 Diamond T, Wong YK, Golombick T. (2013). Effect of oral cholecalciferol 2,000 versus 5,000 IU on serum vitamin D, PTH, bone and muscle strength in patients with vitamin D deficiency. Osteoporosis International.
68 Ding C, Parameswaran V, Blizzard L, et al. (2010). Not a simple fat-soluble vitamin: Changes in serum 25-(OH)D levels are predicted by adiposity and adipocytokines in older adults. Journal of Internal Medicine.
69 Dong Y, Stallmann-Jorgensen IS, Pollock NK, et al. (2010). A 16-week randomized clinical trial of 2000 international units daily vitamin D3 supplementation in black youth: 25-hydroxyvitamin D, adiposity, and arterial stiffness. Journal of Clinical Endocrinology & Metabolism.
70 Dror Y, Giveon SM, Hoshen M, et al. (2013). Vitamin D levels for preventing acute coronary syndrome and mortality: evidence of a nonlinear association. Journal of Clinical Endocrinology & Metabolism.
71 Eide MJ, Johnson DA, Jacobsen GR, et al. (2011). Vitamin D and nonmelanoma skin cancer in a health maintenance organization cohort. Archives of Dermatology.
72 Emel T, Dogan DA, Erdem G, et al. (2012). Therapy strategies in vitamin D deficiency with or without rickets: efficiency of low-dose stoss therapy. Journal of Pediatric Endocrinology.
73 Ensrud KE, Blackwell TL, Cauley JA, et al. (2011). Circulating 25-hydroxyvitamin D levels and frailty in older men: the osteoporotic fractures in men study. Journal of the American Geriatrics Society.
74 Ensrud KE, Ewing SK, Fredman L, et al. (2010). Circulating 25-hydroxyvitamin D levels and frailty status in older women. Journal of Clinical Endocrinology & Metabolism.
75 Ensrud KE, Taylor BC, Paudel ML, et al. (2009). Serum 25-hydroxyvitamin D levels and rate of hip bone loss in older men. Journal of Clinical Endocrinology & Metabolism.
76 Farid K, Volpe-Gillot L, Petras S, et al. (2012). Correlation between serum 25-hydroxyvitamin D concentrations and regional cerebral blood flow in degenerative dementia. Nuclear Medicine Communications.
77 Fedirko V, Bostick RM, Flanders WD, et al. (2009). Effects of vitamin D and calcium supplementation on markers of apoptosis in normal colon mucosa: a randomized, double-blind, placebo-controlled clinical trial. Cancer Prevention Research.
78 Fedirko V, Bostick RM, Flanders WD, et al. (2009). Effects of vitamin d and calcium on proliferation and differentiation in normal colon mucosa: a randomized clinical trial. Cancer Epidemiology, Biomarkers & Prevention.
79 Forouhi NG, Luan Ja, Cooper A, et al. (2008). Baseline serum 25-hydroxy vitamin d is predictive of future glycemic status and insulin resistance: the Medical Research Council Ely Prospective Study 1990-2000. Diabetes.
80 Forsythe LK, Livingstone MBE, Barnes MS, et al. (2012). Effect of adiposity on vitamin D status and the 25-hydroxycholecalciferol response to supplementation in healthy young and older Irish adults. British Journal of Nutrition.
81 Gagnon C, Lu ZX, Magliano DJ, et al. (2012). Low serum 25-hydroxyvitamin D is associated with increased risk of the development of the metabolic syndrome at five years: results from a national, population-based prospective study (The Australian Diabetes, Obesity and Lifestyle Study: AusDiab). Journal of Clinical Endocrinology & Metabolism.
82 Gagnon C, Lu ZX, Magliano DJ, et al. (2011). Serum 25-hydroxyvitamin D, calcium intake, and risk of type 2 diabetes after 5 years: results from a national, population-based prospective study (the Australian Diabetes, Obesity and Lifestyle study). Diabetes Care.
83 Gallagher JC, Jindal PS, Smith LM. (2014). Vitamin d supplementation in young white and african american women. Journal of Bone & Mineral Research.
84 Gallagher JC, Peacock M, Yalamanchili V, et al. (2013). Effects of vitamin d supplementation in older african american women. Journal of Clinical Endocrinology & Metabolism.
85 Gallagher JC, Sai A, Templin T, et al. (2012). Dose response to vitamin D supplementation in postmenopausal women: a randomized trial. Annals of internal medicine.
86 Gallagher JC, Yalamanchili V, Smith LM. (2012). The effect of vitamin D on calcium absorption in older women. Journal of Clinical Endocrinology & Metabolism.
87 Gallicchio L, Moore LE, Stevens VL, et al. (2010). Circulating 25-hydroxyvitamin D and risk of kidney cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
88 Genazzani AR, Stomati M, Valentino V, et al. (2011). Effect of 1-year, low-dose DHEA therapy on climacteric symptoms and female sexuality. Climacteric.
89 Gernand AD, Bodnar LM, Klebanoff MA, et al. (2013). Maternal serum 25-hydroxyvitamin D and placental vascular pathology in a multicenter US cohort. American Journal of Clinical Nutrition.
90 Ghazi AA, Hosseinpanah F, M Ardakani E, et al. (2010). Effects of different doses of oral cholecalciferol on serum 25(OH)D, PTH, calcium and bone markers during fall and winter in schoolchildren. European Journal of Clinical Nutrition.
91 Giapros VI, Schiza V, Challa AS, et al. (2012). Vitamin D and parathormone levels of late-preterm formula fed infants during the first year of life. European Journal of Clinical Nutrition.
92 Glendenning P, Zhu K, Inderjeeth C, et al. (2012). Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. Journal of Bone & Mineral Research.
93 Gonzalez-Molero I, Rojo-Martinez G, Morcillo S, et al. (2012). Vitamin D and incidence of diabetes: a prospective cohort study. Clinical Nutrition.
94 Gorai I, Hattori S, Tanaka Y, et al. (2012). Alfacalcidol-supplemented raloxifene therapy has greater bone-sparing effect than raloxifene-alone therapy in postmenopausal Japanese women with osteoporosis or osteopenia. Journal of Bone & Mineral Metabolism.
95 Gordon CM, Williams AL, Feldman HA, et al. (2008). Treatment of hypovitaminosis D in infants and toddlers. Journal of Clinical Endocrinology & Metabolism.
96 Gorham ED, Garland CF, Burgi AA, et al. (2012). Lower prediagnostic serum 25-hydroxyvitamin D concentration is associated with higher risk of insulin-requiring diabetes: a nested case-control study. Diabetologia.
97 Goswami R, Gupta N, Ray D, et al. (2008). Pattern of 25-hydroxy vitamin D response at short (2 month) and long (1 year) interval after 8 weeks of oral supplementation with cholecalciferol in Asian Indians with chronic hypovitaminosis D. British Journal of Nutrition.
98 Goswami R, Vatsa M, Sreenivas V, et al. (2012). Skeletal muscle strength in young Asian Indian females after vitamin D and calcium supplementation: a double-blind randomized controlled clinical trial. Journal of Clinical Endocrinology & Metabolism.
99 Green TJ, Skeaff CM, Rockell JE. (2010). Milk fortified with the current adequate intake for vitamin D (5 microg) increases serum 25-hydroxyvitamin D compared to control milk but is not sufficient to prevent a seasonal decline in young women. Asia Pacific journal of clinical nutrition.
100 Greene DA, Naughton GA. (2011). Calcium and vitamin-D supplementation on bone structural properties in peripubertal female identical twins: a randomised controlled trial. Osteoporosis International.
101 Griffin FC, Gadegbeku CA, Sowers MR. (2011). Vitamin D and subsequent systolic hypertension among women. American Journal of Hypertension.
102 Grimnes G, Figenschau Y, Almas B, et al. (2011). Vitamin D, insulin secretion, sensitivity, and lipids: results from a case-control study and a randomized controlled trial using hyperglycemic clamp technique. Diabetes.
103 Gupta R, Sharma U, Gupta N, et al. (2010). Effect of cholecalciferol and calcium supplementation on muscle strength and energy metabolism in vitamin D-deficient Asian Indians: a randomized, controlled trial. Clinical Endocrinology.
104 Haliloglu B, Ilter E, Aksungar FB, et al. (2011). Bone turnover and maternal 25(OH) vitamin D3 levels during pregnancy and the postpartum period: should routine vitamin D supplementation be increased in pregnant women?. European Journal of Obstetrics, Gynecology, & Reproductive Biology.
105 Harris RA, Pedersen-White J, Guo DH, et al. (2011). Vitamin D3 supplementation for 16 weeks improves flow-mediated dilation in overweight African-American adults. American Journal of Hypertension.
106 Heine G, Drozdenko G, Lahl A, et al. (2011). Efficient tetanus toxoid immunization on vitamin D supplementation. European Journal of Clinical Nutrition.
107 Hettiarachchi M, Liyanage C. (2010). Efficacy of ‘Thriposha’ supplementation in improving the micronutrient status of preschool children. Ceylon Medical Journal.
108 Hirschler V, Maccallini G, Sanchez MS, et al. (2013). Improvement in high-density lipoprotein cholesterol levels in argentine Indian school children after vitamin d supplementation. Hormone research in pdiatrics.
109 Holecki M, Zahorska-Markiewicz B, Chudek J, et al. (2010). Changes in bone mineral density and bone turnover markers in obese women after short-term weight loss therapy during a 5-year follow-up. Polskie Archiwum Medycyny Wewnetrznej.
110 Holick MF, Biancuzzo RM, Chen TC, et al. (2008). Vitamin D2 is as effective as vitamin D3 in maintaining circulating concentrations of 25-hydroxyvitamin D. Journal of Clinical Endocrinology & Metabolism.
111 Holick MF, Lamb JJ, Lerman RH, et al. (2010). Hop rho iso-alpha acids, berberine, vitamin D3 and vitamin K1 favorably impact biomarkers of bone turnover in postmenopausal women in a 14-week trial. Journal of Bone & Mineral Metabolism.
112 Hoogendijk WJG, Lips P, Dik MG, et al. (2008). Depression is associated with decreased 25-hydroxyvitamin D and increased parathyroid hormone levels in older adults. Archives of General Psychiatry.
113 Houghton LA, Gray AR, Szymlek-Gay EA, et al. (2011). Vitamin D-fortified milk achieves the targeted serum 25-hydroxyvitamin D concentration without affecting that of parathyroid hormone in New Zealand toddlers. The Journal of nutrition.
114 Ilahi M, Armas LA, Heaney RP. (2008). Pharmacokinetics of a single, large dose of cholecalciferol. The American journal of clinical nutrition.
115 Ioannou C, Javaid MK, Mahon P, et al. (2012). The effect of maternal vitamin D concentration on fetal bone. Journal of Clinical Endocrinology & Metabolism.
116 Jorde R, Figenschau Y, Emaus N, et al. (2010). Serum 25-hydroxyvitamin D levels are strongly related to systolic blood pressure but do not predict future hypertension. Hypertension.
117 Jorde R, Sneve M, Emaus N, et al. (2010). Cross-sectional and longitudinal relation between serum 25-hydroxyvitamin D and body mass index: the Tromso study. European Journal of Nutrition.
118 Jorde R, Sneve M, Figenschau Y, et al. (2008). Effects of vitamin D supplementation on symptoms of depression in overweight and obese subjects: randomized double blind trial. Journal of Internal Medicine.
119 Jorde R, Sneve M, Hutchinson M, et al. (2010). Tracking of serum 25-hydroxyvitamin D levels during 14 years in a population-based study and during 12 months in an intervention study. American Journal of Epidemiology.
120 Jorde R, Sneve M, Torjesen P, et al. (2010). Parameters of the thrombogram are associated with serum 25-hydroxyvitamin D levels at baseline, but not affected during supplementation with vitamin D. Thrombosis Research.
121 Jorde R, Sneve M, Torjesen PA, et al. (2010). No effect of supplementation with cholecalciferol on cytokines and markers of inflammation in overweight and obese subjects. Cytokine.
122 Jorde R, Strand Hutchinson M, Kjaergaard M, et al. (2013). Supplementation with High Doses of Vitamin D to Subjects without Vitamin D Deficiency May Have Negative Effects: Pooled Data from Four Intervention Trials in Tromso. Isrn Endocrinology Print.
123 Kaats GR, Preuss HG, Croft HA, et al. (2011). A comparative effectiveness study of bone density changes in women over 40 following three bone health plans containing variations of the same novel plant-sourced calcium. International Journal of Medical Sciences.
124 Kabadi SM, Liu L, Auchincloss AH, et al. (2013). Multivariate path analysis of serum 25-hydroxyvitamin D concentration, inflammation, and risk of type 2 diabetes mellitus. Disease Markers.
125 Kamycheva E, Berg V, Jorde R. (2013). Insulin-like growth factor I, growth hormone, and insulin sensitivity: the effects of a one-year cholecalciferol supplementation in middle-aged overweight and obese subjects. Endocrine.
126 Kayaniyil S, Retnakaran R, Harris SB, et al. (2011). Prospective associations of vitamin D with -cell function and glycemia: the PROspective Metabolism and ISlet cell Evaluation (PROMISE) cohort study. Diabetes.
127 Khajehei M, Abdali K, Parsanezhad ME, et al. (2009). Effect of treatment with dydrogesterone or calcium plus vitamin D on the severity of premenstrual syndrome. International Journal of Gynaecology & Obstetrics.
128 Khajehei M, Abdali K, Tabatabaee HR. (2010). A comparison between the efficacy of dydrogesterone and calcium plus vitamin D in improving women's general health. African Journal of Psychiatry.
129 Khoraminya N, Tehrani-Doost M, Jazayeri S, et al. (2013). Therapeutic effects of vitamin D as adjunctive therapy to fluoxetine in patients with major depressive disorder. Australian & New Zealand Journal of Psychiatry.
130 Kilkkinen A, Knekt P, Heliovaara M, et al. (2008). Vitamin D status and the risk of lung cancer: a cohort study in Finland. Cancer Epidemiology, Biomarkers & Prevention.
131 Kislal FM, Dilmen U. (2008). Effect of different doses of vitamin D on osteocalcin and deoxypyridinoline in preterm infants. Pediatrics International.
132 Kjaergaard M, Waterloo K, Wang CEA, et al. (2012). Effect of vitamin D supplement on depression scores in people with low levels of serum 25-hydroxyvitamin D: nested case-control study and randomised clinical trial. British Journal of Psychiatry.
133 Knekt P, Laaksonen M, Mattila C, et al. (2008). Serum vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology.
134 Knight JA, Wong J, Blackmore KM, et al. (2010). Vitamin D association with estradiol and progesterone in young women. Cancer Causes & Control.
135 Kull M, Kallikorm R, Tamm A, et al. (2009). Seasonal variance of 25-(OH) vitamin D in the general population of Estonia, a Northern European country. BMC Public Health.
136 Kumar GT, Sachdev HS, Chellani H, et al. (2011). Effect of weekly vitamin D supplements on mortality, morbidity, and growth of low birthweight term infants in India up to age 6 months: randomised controlled trial. BMJ.
137 Lagari VS, Gomez-Marin O, Levis S. (2012). Differences in vitamin D3 dosing regimens in a geriatric community-dwelling population. Endocrine Practice.
138 Lalla RV, Choquette LE, Feinn RS, et al. (2012). Multivitamin therapy for recurrent aphthous stomatitis: a randomized, double-masked, placebo-controlled trial. Journal of the American Dental Association.
139 Lalor MK, Floyd S, Gorak-Stolinska P, et al. (2011). BCG vaccination: a role for vitamin D?. PLoS ONE.
140 Lamb JJ, Holick MF, Lerman RH, et al. (2011). Nutritional supplementation of hop rho iso-alpha acids, berberine, vitamin D3, and vitamin K1 produces a favorable bone biomarker profile supporting healthy bone metabolism in postmenopausal women with metabolic syndrome. Nutrition Research.
141 Lasco A, Catalano A, Benvenga S. (2012). Improvement of primary dysmenorrhea caused by a single oral dose of vitamin D: Results of a randomized, double-blind, placebo-controlled study. Archives of internal medicine.
142 Lawlor DA, Wills AK, Fraser A, et al. (2013). Association of maternal vitamin D status during pregnancy with bone-mineral content in offspring: a prospective cohort study. Lancet.
143 LeBlanc ES, Rizzo JH, Pedula KL, et al. (2012). Associations between 25-hydroxyvitamin D and weight gain in elderly women. Journal of Women's Health.
144 Leidig-Bruckner G, Roth HJ, Bruckner T, et al. (2011). Are commonly recommended dosages for vitamin D supplementation too low? Vitamin D status and effects of supplementation on serum 25-hydroxyvitamin D levels--an observational study during clinical practice conditions. Osteoporosis International.
145 Lewis RM, Redzic M, Thomas DT. (2013). The effects of season-long vitamin d supplementation on collegiate swimmers and divers. International Journal of Sport Nutrition & Exercise Metabolism.
146 Liang G, Nan H, Qureshi AA, et al. (2012). Pre-diagnostic plasma 25-hydroxyvitamin D levels and risk of non-melanoma skin cancer in women. PLoS ONE.
147 Lim S, Kim MJ, Choi SH, et al. (2013). Association of vitamin D deficiency with incidence of type 2 diabetes in high-risk Asian subjects. American Journal of Clinical Nutrition.
148 Lim U, Freedman DM, Hollis BW, et al. (2009). A prospective investigation of serum 25-hydroxyvitamin D and risk of lymphoid cancers. International Journal of Cancer.
149 Llewellyn DJ, Lang IA, Langa KM, et al. (2010). Vitamin D and risk of cognitive decline in elderly persons. Archives of Internal Medicine.
150 Lutz LJ, Karl JP, Rood JC, et al. (2012). Vitamin D status, dietary intake, and bone turnover in female Soldiers during military training: a longitudinal study. Journal of the International Society of Sports Nutrition.
151 Maalouf J, Nabulsi M, Vieth R, et al. (2008). Short- and long-term safety of weekly high-dose vitamin D3 supplementation in school children. Journal of Clinical Endocrinology & Metabolism.
152 Madar AA, Klepp KI, Meyer HE. (2009). Effect of free vitamin D(2) drops on serum 25-hydroxyvitamin D in infants with immigrant origin: a cluster randomized controlled trial. European Journal of Clinical Nutrition.
153 Mahon P, Harvey N, Crozier S, et al. (2010). Low maternal vitamin D status and fetal bone development: cohort study. Journal of Bone & Mineral Research.
154 Mai XM, Chen Y, Camargo CA, et al. (2012). Cross-sectional and prospective cohort study of serum 25-hydroxyvitamin D level and obesity in adults: the HUNT study. American Journal of Epidemiology.
155 Major GC, Alarie FP, Dore J, et al. (2009). Calcium plus vitamin D supplementation and fat mass loss in female very low-calcium consumers: potential link with a calcium-specific appetite control. British Journal of Nutrition.
156 Major JM, Graubard BI, Dodd KW, et al. (2013). Variability and reproducibility of circulating vitamin D in a nationwide U.S. population. Journal of Clinical Endocrinology & Metabolism.
157 Major JM, Kiruthu C, Weinstein SJ, et al. (2012). Pre-diagnostic circulating vitamin D and risk of melanoma in men. PLoS ONE.
158 Malhotra N, Mithal A, Gupta S, et al. (2009). Effect of vitamin D supplementation on bone health parameters of healthy young Indian women. Archives of Osteoporosis.
159 Manios Y, Moschonis G, Koutsikas K, et al. (2009). Changes in body composition following a dietary and lifestyle intervention trial: the postmenopausal health study. Maturitas.
160 Manios Y, Moschonis G, Lyritis GP. (2011). Seasonal variations of vitamin D status in Greek postmenopausal women receiving enriched dairy products for 30 months: the Postmenopausal Health Study. European Journal of Clinical Nutrition.
161 Manios Y, Moschonis G, Panagiotakos DB, et al. (2009). Changes in biochemical indices of bone metabolism in post-menopausal women following a dietary intervention with fortified dairy products. Journal of Human Nutrition & Dietetics.
162 Manson JE, Allison MA, Carr JJ, et al. (2010). Calcium/vitamin D supplementation and coronary artery calcification in the Women's Health Initiative. Menopause.
163 Margolis KL, Martin LW, Ray RM, et al. (2012). A prospective study of serum 25-hydroxyvitamin D levels, blood pressure, and incident hypertension in postmenopausal women. American Journal of Epidemiology.
164 McAlindon T, LaValley M, Schneider E, et al. (2013). Effect of vitamin D supplementation on progression of knee pain and cartilage volume loss in patients with symptomatic osteoarthritis: a randomized controlled trial. JAMA.
165 McCullough ML, Bandera EV, Moore DF, et al. (2008). Vitamin D and calcium intake in relation to risk of endometrial cancer: a systematic review of the literature. Preventive Medicine.
166 McCullough ML, Bostick RM, Daniel CR, et al. (2009). Vitamin D status and impact of vitamin D3 and/or calcium supplementation in a randomized pilot study in the Southeastern United States. Journal of the American College of Nutrition.
167 McGrath JJ, Eyles DW, Pedersen CB, et al. (2010). Neonatal vitamin D status and risk of schizophrenia: a population-based case-control study. Archives of General Psychiatry.
168 Meng JE, Hovey KM, Wactawski-Wende J, et al. (2012). Intraindividual variation in plasma 25-hydroxyvitamin D measures 5 years apart among postmenopausal women. Cancer Epidemiology, Biomarkers & Prevention.
169 Merewood A, Mehta SD, Grossman X, et al. (2012). Vitamin D status among 4-month-old infants in New England: a prospective cohort study. Journal of Human Lactation.
170 Milaneschi Y, Shardell M, Corsi AM, et al. (2010). Serum 25-hydroxyvitamin D and depressive symptoms in older women and men. Journal of Clinical Endocrinology & Metabolism.
171 Millen AE, Wactawski-Wende J, Pettinger M, et al. (2010). Predictors of serum 25-hydroxyvitamin D concentrations among postmenopausal women: the Women's Health Initiative Calcium plus Vitamin D clinical trial. American Journal of Clinical Nutrition.
172 Miricescu D, Totan A, Calenic B, et al. (2014). Salivary biomarkers: Relationship between oxidative stress and alveolar bone loss in chronic periodontitis. Acta Odontologica Scandinavica.
173 Mitri J, Dawson-Hughes B, Hu FB, et al. (2011). Effects of vitamin D and calcium supplementation on pancreatic cell function, insulin sensitivity, and glycemia in adults at high risk of diabetes: the Calcium and Vitamin D for Diabetes Mellitus (CaDDM) randomized controlled trial. American Journal of Clinical Nutrition.
174 Mohamed WA, Al-Shehri MA. (2013). Cord blood 25-hydroxyvitamin D levels and the risk of acute lower respiratory tract infection in early childhood. Journal of Tropical Pediatrics.
175 Moller UK, Streym S, Heickendorff L, et al. (2012). Effects of 25OHD concentrations on chances of pregnancy and pregnancy outcomes: a cohort study in healthy Danish women. European Journal of Clinical Nutrition.
176 Mondul AM, Weinstein SJ, Mannisto S, et al. (2010). Serum vitamin D and risk of bladder cancer. Cancer Research.
177 Mondul AM, Weinstein SJ, Virtamo J, et al. (2012). Influence of vitamin D binding protein on the association between circulating vitamin D and risk of bladder cancer. British Journal of Cancer.
178 Morales E, Guxens M, Llop S, et al. (2012). Circulating 25-hydroxyvitamin D3 in pregnancy and infant neuropsychological development. Pediatrics.
179 Mueller EA, Seiberling M, Kirch W, et al. (2011). Pharmacokinetics and pharmacodynamics of calcium-vitamin D(3) chewable tablets: a single-blind, multiple-dose study in postmenopausal women. Expert Opinion On Drug Metabolism & Toxicology.
180 Muldowney S, Lucey AJ, Hill TR, et al. (2012). Incremental cholecalciferol supplementation up to 15 ug/d throughout winter at 51-55 N has no effect on biomarkers of cardiovascular risk in healthy young and older adults. Journal of Nutrition.
181 Mulligan GB, Licata A. (2010). Taking vitamin D with the largest meal improves absorption and results in higher serum levels of 25-hydroxyvitamin D. Journal of Bone & Mineral Research.
182 Naharci I, Bozoglu E, Kocak N, et al. (2012). Effect of vitamin D on insulin sensitivity in elderly patients with impaired fasting glucose. Geriatrics & gerontology international.
183 Nakamura K, Oyama M, Saito T, et al. (2012). Nutritional and biochemical parameters associated with 6-year change in bone mineral density in community-dwelling Japanese women aged 69 years and older: The Muramatsu Study. Nutrition.
184 Naves-Diaz M, Cabezas-Rodriguez I, Barrio-Vazquez S, et al. (2012). Low calcidiol levels and risk of progression of aortic calcification. Osteoporosis International.
185 Oberhelman SS, Meekins ME, Fischer PR, et al. (2013). Maternal Vitamin D Supplementation to Improve the Vitamin D Status of Breast-fed Infants: A Randomized Controlled Trial. Mayo Clinic Proceedings.
186 Ojaimi S, Skinner NA, Strauss BJ, et al. (2013). Vitamin D deficiency impacts on expression of toll-like receptor-2 and cytokine profile: a pilot study. Journal of Translational Medicine.
187 Okazaki R, Sugimoto T, Kaji H, et al. (2011). Vitamin D insufficiency defined by serum 25-hydroxyvitamin D and parathyroid hormone before and after oral vitamin D3 load in Japanese subjects. Journal of Bone & Mineral Metabolism.
188 Ortega RM, Aparicio A, Rodríguez-Rodríguez E, et al. (2008). Preliminary data about the influence of vitamin D status on the loss of body fat in young overweight/obese women following two types of hypocaloric diet. The British journal of nutrition.
189 Ortega RM, Lopez-Sobaler AM, Aparicio A, et al. (2009). Vitamin D status modification by two slightly hypocaloric diets in young overweight/obese women. International Journal for Vitamin & Nutrition Research.
190 Ostertag A, Cohen-Solal M, Madec Y, et al. (2011). Bone changes in spouses having shared lifestyle for 40 years. Joint, Bone, Spine: Revue du Rhumatisme.
191 O'Sullivan A, Gibney MJ, Connor AO, et al. (2011). Biochemical and metabolomic phenotyping in the identification of a vitamin D responsive metabotype for markers of the metabolic syndrome. Molecular Nutrition & Food Research.
192 Parlea L, Bromberg IL, Feig DS, et al. (2012). Association between serum 25-hydroxyvitamin D in early pregnancy and risk of gestational diabetes mellitus. Diabetic Medicine.
193 Pedone C, Napoli N, Pozzilli P, et al. (2010). Quality of diet and potential renal acid load as risk factors for reduced bone density in elderly women. Bone.
194 Pekkarinen T, Turpeinen U, Hamalainen E, et al. (2010). Serum 25(OH)D3 vitamin status of elderly Finnish women is suboptimal even after summer sunshine but is not associated with bone density or turnover. European Journal of Endocrinology.
195 Peterson CA, Heffernan ME. (2008). Serum tumor necrosis factor-alpha concentrations are negatively correlated with serum 25(OH)D concentrations in healthy women. Journal of Inflammation.
196 Pilz S, Frisch S, Koertke H, et al. (2011). Effect of vitamin D supplementation on testosterone levels in men. Hormone & Metabolic Research.
197 Pilz S, van den Hurk K, Nijpels G, et al. (2012). Vitamin D status, incident diabetes and prospective changes in glucose metabolism in older subjects: the Hoorn study. Nutrition Metabolism & Cardiovascular Diseases.
198 Pittas AG, Nelson J, Mitri J, et al. (2012). Plasma 25-hydroxyvitamin D and progression to diabetes in patients at risk for diabetes: an ancillary analysis in the Diabetes Prevention Program. Diabetes Care.
199 Pittas AG, Sun Q, Manson JE, et al. (2010). Plasma 25-hydroxyvitamin D concentration and risk of incident type 2 diabetes in women. Diabetes Care.
200 Plawecki K, Chapman-Novakofski K. (2013). Effectiveness of community intervention in improving bone health behaviors in older adults. Journal of Nutrition in Gerontology & Geriatrics.
201 Pludowski P, Socha P, Karczmarewicz E, et al. (2011). Vitamin D supplementation and status in infants: a prospective cohort observational study. Journal of Pediatric Gastroenterology & Nutrition.
202 Ponda MP, Dowd K, Finkielstein D, et al. (2012). The short-term effects of vitamin D repletion on cholesterol: a randomized, placebo-controlled trial. Arteriosclerosis, Thrombosis & Vascular Biology.
203 Ponnapakkam T, Bradford E, Gensure R. (2010). A treatment trial of vitamin D supplementation in breast-fed infants: universal supplementation is not necessary for rickets prevention in Southern Louisiana. Clinical Pediatrics.
204 Porojnicu AC, Moroti-Constantinescu R, Laslau A, et al. (2012). Vitamin D status in healthy Romanian caregivers and risk of respiratory infections. Public Health Nutrition.
205 Prentice A, Jarjou LMA, Goldberg GR, et al. (2009). Maternal plasma 25-hydroxyvitamin D concentration and birthweight, growth and bone mineral accretion of Gambian infants. Acta Paediatrica.
206 Principi N, Marchisio P, Terranova L, et al. (2013). Impact of vitamin D administration on immunogenicity of trivalent inactivated influenza vaccine in previously unvaccinated children. Human vaccines & Immunotherapeutics.
207 Purdue MP, Freedman DM, Gapstur SM, et al. (2010). Circulating 25-hydroxyvitamin D and risk of non-hodgkin lymphoma: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
208 Putman MS, Pitts SA, Milliren CE, et al. (2013). A randomized clinical trial of vitamin D supplementation in healthy adolescents. Journal of Adolescent Health.
209 Radford LT, Bolland MJ, Gamble GD, et al. (2013). Subgroup analysis for the risk of cardiovascular disease with calcium supplements. BoneKEy Reports.
210 Rajpathak SN, Xue X, Wassertheil-Smoller S, et al. (2010). Effect of 5 y of calcium plus vitamin D supplementation on change in circulating lipids: results from the Women's Health Initiative. American Journal of Clinical Nutrition.
211 Rejnmark L, Amstrup AK, Mollerup CL, et al. (2013). Further insights into the pathogenesis of primary hyperparathyroidism: a nested case-control study. Journal of Clinical Endocrinology & Metabolism.
212 Rich-Edwards JW, Ganmaa D, Kleinman K, et al. (2011). Randomized trial of fortified milk and supplements to raise 25-hydroxyvitamin D concentrations in schoolchildren in Mongolia. The American journal of clinical nutrition.
213 Robinson JG, Manson JE, Larson J, et al. (2011). Lack of association between 25(OH)D levels and incident type 2 diabetes in older women. Diabetes Care.
214 Rochat MK, Ege MJ, Plabst D, et al. (2010). Maternal vitamin D intake during pregnancy increases gene expression of ILT3 and ILT4 in cord blood. Clinical & Experimental Allergy.
215 Rohan TE, Negassa A, Chlebowski RT, et al. (2009). A randomized controlled trial of calcium plus vitamin D supplementation and risk of benign proliferative breast disease. Breast Cancer Research & Treatment.
216 Rosenblum JL, Castro VM, Moore CE, et al. (2012). Calcium and vitamin D supplementation is associated with decreased abdominal visceral adipose tissue in overweight and obese adults. American Journal of Clinical Nutrition.
217 Rossini M, Adami S, Viapiana O, et al. (2012). Dose-dependent short-term effects of single high doses of oral vitamin D(3) on bone turnover markers. Calcified Tissue International.
218 Rossini M, Gatti D, Viapiana O, et al. (2012). Short-term effects on bone turnover markers of a single high dose of oral vitamin D3. Journal of Clinical Endocrinology & Metabolism.
219 Rossom RC, Espeland MA, Manson JE, et al. (2012). Calcium and vitamin D supplementation and cognitive impairment in the women's health initiative. Journal of the American Geriatrics Society.
220 Roth DE, Perumal N, Al Mahmud A, et al. (2013). Maternal Vitamin D3 Supplementation during the Third Trimester ofPregnancy: Effects on Infant Growth in a Longitudinal Follow-Up StudyinBangladesh. Journal of Pediatrics.
221 Saadi HF, Dawodu A, Afandi B, et al. (2009). Effect of combined maternal and infant vitamin D supplementation on vitamin D status of exclusively breastfed infants. Maternal & Child Nutrition.
222 Sahu M, Das V, Aggarwal A, et al. (2009). Vitamin D replacement in pregnant women in rural north India: a pilot study. European Journal of Clinical Nutrition.
223 Sai AJ, Gallagher JC, Fang X. (2011). Effect of hormone therapy and calcitriol on serum lipid profile in postmenopausal older women: association with estrogen receptor- genotypes. Menopause.
224 Sakalli H, Arslan D, Yucel AE. (2012). The effect of oral and parenteral vitamin D supplementation in the elderly: a prospective, double-blinded, randomized, placebo-controlled study. Rheumatology International.
225 Salehpour A, Hosseinpanah F, Shidfar F, et al. (2012). A 12-week double-blind randomized clinical trial of vitamin D3 supplementation on body fat mass in healthy overweight and obese women. Nutrition Journal.
226 Sanders KM, Stuart AL, Merriman EN, et al. (2009). Trials and tribulations of recruiting 2,000 older women onto a clinical trial investigating falls and fractures: Vital D study. BMC Medical Research Methodology.
227 Sanders KM, Stuart AL, Williamson EJ, et al. (2011). Annual high-dose vitamin D3 and mental well-being: randomised controlled trial. British Journal of Psychiatry.
228 Sayers A, Fraser WD, Lawlor DA, et al. (2012). 25-Hydroxyvitamin-D3 levels are positively related to subsequent cortical bone development in childhood: findings from a large prospective cohort study. Osteoporosis International.
229 Scholl TO, Chen X, Stein P. (2012). Maternal vitamin D status and delivery by cesarean. Nutrients.
230 Schottker B, Herder C, Rothenbacher D, et al. (2013). Serum 25-hydroxyvitamin D levels and incident diabetes mellitus type 2: a competing risk analysis in a large population-based cohort of older adults. European Journal of Epidemiology.
231 Schreuder F, Bernsen RMD, van der Wouden JC. (2012). Vitamin D supplementation for nonspecific musculoskeletal pain in non-Western immigrants: a randomized controlled trial. Annals of Family Medicine.
232 Seamans KM, Hill TR, Wallace JMW, et al. (2010). Cholecalciferol supplementation throughout winter does not affect markers of bone turnover in healthy young and elderly adults. Journal of Nutrition.
233 Sergi G, Sarti S, Mosele M, et al. (2011). Changes in healthy elderly women's physical performance: a 3-year follow-up. Experimental Gerontology.
234 Shahar DR, Schwarzfuchs D, Fraser D, et al. (2010). Dairy calcium intake, serum vitamin D, and successful weight loss. American Journal of Clinical Nutrition.
235 Shakiba M, Ghadir M, Nafei Z, et al. (2011). Study to evaluate two dosage regimens of vitamin D through an academic year in middle school girls: a randomized trial. Acta Medica Iranica.
236 Shakiba M, Sadr S, Nefei Z, et al. (2010). Combination of bolus dose vitamin D with routine vaccination in infants: a randomised trial. Singapore Medical Journal.
237 Shapses SA, Sukumar D, Schneider SH, et al. (2013). Vitamin D supplementation and calcium absorption during caloric restriction: a randomized double-blind trial. American Journal of Clinical Nutrition.
238 Shardell M, D'Adamo C, Alley DE, et al. (2012). Serum 25-hydroxyvitamin D, transitions between frailty states, and mortality in older adults: the Invecchiare in Chianti Study. Journal of the American Geriatrics Society.
239 Shipowick CD, Moore CB, Corbett C, et al. (2009). Vitamin D and depressive symptoms in women during the winter: a pilot study. Applied Nursing Research.
240 Shui IM, Mucci LA, Wilson KM, et al. (2013). Common genetic variation of the calcium-sensing receptor and lethal prostate cancer risk. Cancer Epidemiology, Biomarkers & Prevention.
241 Siafarikas A, Piazena H, Feister U, et al. (2011). Randomised controlled trial analysing supplementation with 250 versus 500 units of vitamin D3, sun exposure and surrounding factors in breastfed infants. Archives of Disease in Childhood.
242 Simha V, Mahmood M, Ansari M, et al. (2012). Effect of vitamin D replacement on insulin sensitivity in subjects with vitamin D deficiency. Journal of Investigative Medicine.
243 Sinha A, Hollingsworth KG, Ball S, et al. (2013). Improving the vitamin d status of vitamin d deficient adults is associated with improved mitochondrial oxidative function in skeletal muscle. Journal of Clinical Endocrinology & Metabolism.
244 Skaaby T, Husemoen LL, Martinussen T, et al. (2013). Vitamin D status, filaggrin genotype, and cardiovascular risk factors: a Mendelian randomization approach. PLoS ONE.
245 Skaaby T, Husemoen LLN, Martinussen T, et al. (2013). Vitamin d status, filaggrin genotype, and cardiovascular risk factors: a mendelian randomization approach. PLoS ONE.
246 Skaaby T, Husemoen LLN, Pisinger C, et al. (2012). Vitamin D status and changes in cardiovascular risk factors: a prospective study of a general population. Cardiology.
247 Slinin Y, Paudel M, Taylor BC, et al. (2012). Association between serum 25(OH) vitamin D and the risk of cognitive decline in older women. Journals of Gerontology Series A-Biological Sciences & Medical Sciences.
248 Smith SM, Gardner KK, Locke J, et al. (2009). Vitamin D supplementation during Antarctic winter. American Journal of Clinical Nutrition.
249 Soares MJ, Chan She Ping-Delfos W. (2008). Second meal effects of dietary calcium and vitamin D. European Journal of Clinical Nutrition.
250 Soares MJ, Chan She Ping-Delfos W, Ghanbari MH. (2011). Calcium and vitamin D for obesity: a review of randomized controlled trials. European Journal of Clinical Nutrition.
251 Soheilykhah S, Mojibian M, Moghadam MJ, et al. (2013). The effect of different doses of vitamin D supplementation on insulin resistance during pregnancy. Gynecological Endocrinology.
252 Southard EB, Roff A, Fortugno T, et al. (2012). Lead, calcium uptake, and related genetic variants in association with renal cell carcinoma risk in a cohort of male Finnish smokers. Cancer Epidemiology, Biomarkers & Prevention.
253 Stein MS, Scherer SC, Ladd KS, et al. (2011). A randomized controlled trial of high-dose vitamin D2 followed by intranasal insulin in Alzheimer's disease. Journal of Alzheimer's Disease.
254 Stephensen CB, Zerofsky M, Burnett DJ, et al. (2012). Ergocalciferol from mushrooms or supplements consumed with a standard meal increases 25-hydroxyergocalciferol but decreases 25-hydroxycholecalciferol in the serum of healthy adults. Journal of Nutrition.
255 Sundaram ME, Talbot HK, Zhu Y, et al. (2013). Vitamin D is not associated with serologic response to influenza vaccine in adults over 50 years old. Vaccine.
256 Szulc P, Munoz F, Marchand F, et al. (2010). Rapid loss of appendicular skeletal muscle mass is associated with higher all-cause mortality in older men: the prospective MINOS study. American Journal of Clinical Nutrition.
257 Tang JY, Fu T, Leblanc E, et al. (2011). Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer: post hoc analyses of the women's health initiative randomized controlled trial. Journal of Clinical Oncology.
258 Tang JY, Parimi N, Wu A, et al. (2010). Inverse association between serum 25(OH) vitamin D levels and non-melanoma skin cancer in elderly men. Cancer Causes & Control.
259 Tolppanen AM, Sayers A, Fraser WD, et al. (2012). Association of serum 25-hydroxyvitamin D3 and D2 with academic performance in childhood: findings from a prospective birth cohort. Journal of Epidemiology & Community Health.
260 Tolppanen AM, Sayers A, Fraser WD, et al. (2012). The association of 25-hydroxyvitamin D3 and D2 with behavioural problems in childhood. PLoS ONE.
261 Tolppanen AM, Sayers A, Fraser WD, et al. (2012). The association of serum 25-hydroxyvitamin D3 and D2 with depressive symptoms in childhood--a prospective cohort study. Journal of Child Psychology & Psychiatry & Allied Disciplines.
262 Tolppanen AM, Sayers A, Fraser WD, et al. (2012). Serum 25-hydroxyvitamin D3 and D2 and non-clinical psychotic experiences in childhood. PLoS ONE.
263 Toriola AT, Surcel HM, Agborsangaya C, et al. (2010). Serum 25-hydroxyvitamin D and the risk of ovarian cancer. European Journal of Cancer.
264 Toriola AT, Surcel HM, Calypse A, et al. (2010). Independent and joint effects of serum 25-hydroxyvitamin D and calcium on ovarian cancer risk: a prospective nested case-control study. European Journal of Cancer.
265 Toss G, Magnusson P. (2012). Is a daily supplementation with 40 microgram vitamin D3 sufficient? A randomised controlled trial. European Journal of Nutrition.
266 Tran B, Armstrong BK, Ebeling PR, et al. (2014). Effect of vitamin D supplementation on antibiotic use: a randomized controlled trial. American Journal of Clinical Nutrition.
267 Trilok-Kumar G, Arora H, Rajput M, et al. (2012). Effect of vitamin D supplementation of low birth weight term Indian infants from birth on cytokine production at 6 months. European Journal of Clinical Nutrition.
268 Trummer O, Pilz S, Hoffmann MM, et al. (2013). Vitamin D and mortality: a Mendelian randomization study. Clinical Chemistry.
269 Tzotzas T, Papadopoulou FG, Tziomalos K, et al. (2010). Rising serum 25-hydroxy-vitamin D levels after weight loss in obese women correlate with improvement in insulin resistance. Journal of Clinical Endocrinology & Metabolism.
270 Umhau JC, George DT, Heaney RP, et al. (2013). Low vitamin D status and suicide: a case-control study of active duty military service members. PLoS ONE.
271 Urbain P, Singler F, Ihorst G, et al. (2011). Bioavailability of vitamin D2 from UV-B-irradiated button mushrooms in healthy adults deficient in serum 25-hydroxyvitamin D: a randomized controlled trial. European Journal of Clinical Nutrition.
272 van Ballegooijen AJ, Snijder MB, Visser M, et al. (2012). Vitamin D in relation to myocardial structure and function after eight years of follow-up: the Hoorn study. Annals of Nutrition & Metabolism.
273 van den Berg G, van Eijsden M, Vrijkotte TG, et al. (2013). Suboptimal maternal vitamin D status and low education level as determinants of small-for-gestational-age birth weight. European Journal of Nutrition.
274 van der Pols JC, Russell A, Bauer U, et al. (2013). Vitamin D status and skin cancer risk independent of time outdoors: 11-year prospective study in an Australian community. Journal of Investigative Dermatology.
275 Viljakainen HT, Korhonen T, Hytinantti T, et al. (2011). Maternal vitamin D status affects bone growth in early childhood--a prospective cohort study. Osteoporosis International.
276 Viljakainen HT, Vaisanen M, Kemi V, et al. (2009). Wintertime vitamin D supplementation inhibits seasonal variation of calcitropic hormones and maintains bone turnover in healthy men. Journal of Bone & Mineral Research.
277 Villamor E, Marin C, Mora-Plazas M, et al. (2011). Vitamin D deficiency and age at menarche: a prospective study. American Journal of Clinical Nutrition.
278 von Hurst PR, Stonehouse W, Coad J. (2010). Vitamin D supplementation reduces insulin resistance in South Asian women living in New Zealand who are insulin resistant and vitamin D deficient—a randomised, placebo-controlled trial. British Journal of Nutrition.
279 von Hurst PR, Stonehouse W, Kruger MC, et al. (2010). Vitamin D supplementation suppresses age-induced bone turnover in older women who are vitamin D deficient. Journal of Steroid Biochemistry & Molecular Biology.
280 Wagner CL, Howard C, Hulsey TC, et al. (2009). Circulating 25-Hydroxy-Vitamin D (25-OH-D) Levels in Fully Breastfed Infants on Oral Vitamin D (VitD) Supplementation. Pediatric Academic Societies Annual Meeting.
281 Wagner CL, Howard C, Hulsey TC, et al. (2010). Circulating 25-hydroxyvitamin d levels in fully breastfed infants on oral vitamin d supplementation. International Journal of Endocrinology Print.
282 Wagner CL, McNeil R, Hamilton SA, et al. (2013). A randomized trial of vitamin D supplementation in 2 community health center networks in South Carolina. American Journal of Obstetrics & Gynecology.
283 Wagner D, Sidhom G, Whiting SJ, et al. (2008). The bioavailability of vitamin D from fortified cheeses and supplements is equivalent in adults. Journal of Nutrition.
284 Walsh JM, Kilbane M, McGowan CA, et al. (2013). Pregnancy in dark winters: implications for fetal bone growth?. Fertility & Sterility.
285 Walsh JM, McGowan CA, Kilbane M, et al. (2013). The relationship between maternal and fetal vitamin D, insulin resistance, and fetal growth. Reproductive Sciences.
286 Wang JB, Abnet CC, Chen W, et al. (2013). Association between serum 25(OH) vitamin D, incident liver cancer and chronic liver disease mortality in the Linxian Nutrition Intervention Trials: a nested case-control study. British Journal of Cancer.
287 Wang O, Nie M, Hu YY, et al. (2012). Association between vitamin D insufficiency and the risk for gestational diabetes mellitus in pregnant Chinese women. Biomedical & Environmental Sciences.
288 Weinstein SJ, Mondul AM, Kopp W, et al. (2013). Circulating 25-hydroxyvitamin D, vitamin D-binding protein and risk of prostate cancer. International Journal of Cancer.
289 Weinstein SJ, Yu K, Horst RL, et al. (2011). Serum 25-hydroxyvitamin D and risk of lung cancer in male smokers: a nested case-control study. PLoS ONE.
290 Williams DM, Fraser A, Fraser WD, et al. (2013). Associations of maternal 25-hydroxyvitamin D in pregnancy with offspring cardiovascular risk factors in childhood and adolescence: findings from the Avon Longitudinal Study of Parents and Children. Heart.
291 Young BE, McNanley TJ, Cooper EM, et al. (2012). Maternal vitamin D status and calcium intake interact to affect fetal skeletal growth in utero in pregnant adolescents. American Journal of Clinical Nutrition.
292 Young KA, Engelman CD, Langefeld CD, et al. (2009). Association of plasma vitamin D levels with adiposity in Hispanic and African Americans. Journal of Clinical Endocrinology & Metabolism.
293 Yu CKH, Ertl R, Skyfta E, et al. (2013). Maternal serum vitamin D levels at 11-13 weeks of gestation in preeclampsia. Journal of Human Hypertension.
294 Yu CKH, Sykes L, Sethi M, et al. (2009). Vitamin D deficiency and supplementation during pregnancy. Clinical Endocrinology.
295 Yusupov E, Li-Ng M, Pollack S, et al. (2010). Vitamin d and serum cytokines in a randomized clinical trial. International Journal of Endocrinology Print.
296 Zeleniuch-Jacquotte A, Gallicchio L, Hartmuller V, et al. (2010). Circulating 25-hydroxyvitamin D and risk of endometrial cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
297 Zgaga L, Agakov F, Theodoratou E, et al. (2013). Model selection approach suggests causal association between 25-hydroxyvitamin D and colorectal cancer. PLoS ONE.
298 Zhang C, Qiu C, Hu FB, et al. (2008). Maternal plasma 25-hydroxyvitamin D concentrations and the risk for gestational diabetes mellitus. PLoS ONE.
299 Zhang LR, Sawka AM, Adams L, et al. (2013). Vitamin and mineral supplements and thyroid cancer: a systematic review. European Journal of Cancer Prevention.
300 Zhao LJ, Zhou Y, Bu F, et al. (2012). Factors predicting vitamin D response variation in non-Hispanic white postmenopausal women. Journal of Clinical Endocrinology & Metabolism.
301 Zheng W, Danforth KN, Tworoger SS, et al. (2010). Circulating 25-hydroxyvitamin D and risk of epithelial ovarian cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
302 Zhou J, Zhao LJ, Watson P, et al. (2010). The effect of calcium and vitamin D supplementation on obesity in postmenopausal women: secondary analysis for a large-scale, placebo controlled, double-blind, 4-year longitudinal clinical trial. Nutrition & Metabolism.
303 Zhou JC, Zhu YM, Guo P, et al. (2013). Serum 25(OH)D and Lipid Levels in Chinese Obese and Normal Weight Males before and after Oral Vitamin D Supplementation. Biomedical & Environmental Sciences.
304 Zhu H, Guo D, Li K, et al. (2012). Increased telomerase activity and vitamin D supplementation in overweight African Americans. International Journal of Obesity.
305 Zittermann A, von Helden R, Grant W, et al. (2009). An estimate of the survival benefit of improving vitamin D status in the adult german population. Dermato-endocrinology.
306 Zwart SR, Parsons H, Kimlin M, et al. (2013). A 250mug/week dose of vitamin D was as effective as a 50mug/d dose in healthy adults, but a regimen of four weekly followed by monthly doses of 1250mug raised the risk of hypercalciuria. British Journal of Nutrition.

### Duration Not of Interest—N=10

1 Abrams SA, Hawthorne KM, Rogers SP, et al. (2012). Effects of ethnicity and vitamin D supplementation on vitamin D status and changes in bone mineral content in infants. BMC Pediatrics.
2 Barker T, Martins TB, Hill HR, et al. (2012). Different doses of supplemental vitamin D maintain interleukin-5 without altering skeletal muscle strength: a randomized, double-blind, placebo-controlled study in vitamin D sufficient adults. Nutrition & Metabolism.
3 Carrillo AE, Flynn MG, Pinkston C, et al. (2013). Impact of vitamin D supplementation during a resistance training intervention onbody composition, muscle function, and glucose tolerance in overweight andobese adults. Clinical Nutrition.
4 Close GL, Leckey J, Patterson M, et al. (2013). The effects of vitamin D(3) supplementation on serum total 25[OH]D concentration and physical performance: a randomised dose-response study. British Journal of Sports Medicine.
5 Diogenes ME, Bezerra FF, Rezende EP, et al. (2013). Effect of calcium plus vitamin D supplementation during pregnancy in Brazilian adolescent mothers: a randomized, placebo-controlled trial. American Journal of Clinical Nutrition.
6 Gallo S, Comeau K, Vanstone C, et al. (2013). Effect of different dosages of oral vitamin D supplementation on vitamin D status in healthy, breastfed infants: a randomized trial. JAMA.
7 Lagari V, Gomez-Marin O, Levis S. (2013). The role of vitamin D in improving physical performance in the elderly. Journal of Bone & Mineral Research.
8 Nieman DC, Gillitt ND, Shanely RA, et al. (2013). Vitamin D2 Supplementation Amplifies Eccentric Exercise-Induced Muscle Damage in NASCAR Pit Crew Athletes. Nutrients.
9 Wamberg L, Pedersen SB, Richelsen B, et al. (2013). The effect of high-dose vitamin d supplementation on calciotropic hormones and bone mineral density in obese subjects with low levels of circulating 25-hydroxyvitamin d: results from a randomized controlled study. Calcified Tissue International.
10 Wyon MA, Koutedakis Y, Wolman R, et al. (2014). The influence of winter vitamin D supplementation on muscle function and injury occurrence in elite ballet dancers: A controlled study. Journal of Science & Medicine in Sport.

### Duplicate Data—N=2

1 Al-Shaar L, Nabulsi M, Maalouf J, et al. (2013). Effect of vitamin D replacement on hip structural geometry in adolescents: a randomized controlled trial. Bone.
2 Kukuljan S, Nowson CA, Bass SL, et al. (2009). Effects of a multi-component exercise program and calcium-vitamin-D3-fortified milk on bone mineral density in older men: a randomised controlled trial. Osteoporosis international.

### Systematic Review Excludes- N=169

1 Aghajafari F, Nagulesapillai T, Ronksley PE, et al. (2013). Association between maternal serum 25-hydroxyvitamin D level and pregnancy and neonatal outcomes: systematic review and meta-analysis of observational studies. BMJ.
2 Aghajafari F, Nagulesapillai T, Ronksley PE, et al. (2013). Association between maternal serum 25-hydroxyvitamin D level and pregnancy and neonatal outcomes: systematic review and meta-analysis of observational studies (Provisional abstract). Bmj.
3 Anglin RES, Samaan Z, Walter SD, et al. (2013). Vitamin D deficiency and depression in adults: systematic review and meta-analysis. British Journal of Psychiatry.
4 Annweiler C, Allali G, Allain P, et al. (2009). Vitamin D and cognitive performance in adults: a systematic review. European Journal of Neurology.
5 Annweiler C, Llewellyn DJ, Beauchet O. (2013). Low serum vitamin D concentrations in Alzheimer's disease: a systematic review and meta-analysis. Journal of Alzheimer's Disease.
6 Annweiler C, Schott AM, Berrut G, et al. (2009). Vitamin D-related changes in physical performance: a systematic review. Journal of Nutrition, Health & Aging.
7 Antico A, Tampoia M, Tozzoli R, et al. (2012). Can supplementation with vitamin D reduce the risk or modify the course of autoimmune diseases? A systematic review of the literature. Autoimmunity Reviews.
8 Autier P, Boniol M, Pizot C, et al. (2014). Vitamin D status and ill health: a systematic review. Lancet Diabetes Endocrinol.
9 Avenell A, Gillespie WJ, Gillespie LD, et al. (2009). Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database of Systematic Reviews.
10 Bagnoli F, Casucci M, Toti S, et al. (2013). Is vitamin D supplementation necessary in healthy full-term breastfed infants? A follow-up study of bone mineralization in healthy full-term infants with and without supplemental vitamin D. Minerva Pediatrica.
11 Bailey EE, Ference EH, Alikhan A, et al. (2012). Combination treatments for psoriasis: a systematic review and meta-analysis. Archives of Dermatology.
12 Balion C, Griffith LE, Strifler L, et al. (2012). Vitamin D, cognition, and dementia: a systematic review and meta-analysis. Neurology.
13 Balzer K, Bremer M, Schramm S, et al. (2012). Falls prevention for the elderly. GMS Health Technology Assessment.
14 Barengolts E. (2010). Vitamin D role and use in prediabetes. Endocrine Practice.
15 Bassil D, Rahme M, Hoteit M, et al. (2013). Hypovitaminosis D in the Middle East and North Africa: Prevalence, risk factors and impact on outcomes. Dermato-endocrinology.
16 Bauer SR, Hankinson SE, Bertone-Johnson ER, et al. (2013). Plasma vitamin D levels, menopause, and risk of breast cancer: dose-response meta-analysis of prospective studies. Medicine.
17 Bergman GJD, Fan T, McFetridge JT, et al. (2010). Efficacy of vitamin D3 supplementation in preventing fractures in elderly women: a meta-analysis. Current Medical Research & Opinion.
18 Bergman P, Lindh AU, Bjorkhem-Bergman L, et al. (2013). Vitamin D and respiratory tract infections: a systematic review and meta-analysis of randomized controlled trials (Provisional abstract). Database of Abstracts of Reviews of Effects.
19 Bischoff-Ferrari HA, Dawson-Hughes B, Staehelin HB, et al. (2009). Fall prevention with supplemental and active forms of vitamin D: a meta-analysis of randomised controlled trials. BMJ.
20 Bischoff-Ferrari HA, Willett WC, Orav EJ, et al. (2012). A pooled analysis of vitamin D dose requirements for fracture prevention. New England Journal of Medicine.
21 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. (2009). Prevention of nonvertebral fractures with oral vitamin D and dose dependency: a meta-analysis of randomized controlled trials. Archives of Internal Medicine.
22 Bjelakovic G, Gluud LL, Nikolova D, et al. (2011). Vitamin D supplementation for prevention of mortality in adults. Cochrane Database of Systematic Reviews.
23 Black LJ, Seamans KM, Cashman KD, et al. (2012). An updated systematic review and meta-analysis of the efficacy of vitamin D food fortification. Journal of Nutrition.
24 Bouillon R, Van Schoor NM, Gielen E, et al. (2013). Optimal vitamin D status: a critical analysis on the basis of evidence-based medicine. Journal of Clinical Endocrinology & Metabolism.
25 Brandao CMR, Lima MG, Silva ALd, et al. (2008). Treatment of postmenopausal osteoporosis in women: a systematic review. Cadernos de Saude Publica.
26 Burgaz A, Orsini N, Larsson SC, et al. (2011). Blood 25-hydroxyvitamin D concentration and hypertension: a meta-analysis. Journal of Hypertension.
27 Cameron ID, Gillespie LD, Robertson MC, et al. (2012). Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database of Systematic Reviews.
28 Cameron ID, Murray GR, Gillespie LD, et al. (2010). Interventions for preventing falls in older people in nursing care facilities and hospitals. Cochrane Database of Systematic Reviews.
29 Cao Y, Winzenberg T, Nguo K, et al. (2013). Association between serum levels of 25-hydroxyvitamin D and osteoarthritis: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects.
30 Cao Y, Winzenberg T, Nguo K, et al. (2013). Association between serum levels of 25-hydroxyvitamin D and osteoarthritis: a systematic review. Rheumatology.
31 Carroll C, Cooper K, Papaioannou D, et al. (2010). Supplemental calcium in the chemoprevention of colorectal cancer: a systematic review and meta-analysis. Clinical Therapeutics.
32 Cashman KD, Fitzgerald AP, Kiely M, et al. (2011). A systematic review and meta-regression analysis of the vitamin D intake-serum 25-hydroxyvitamin D relationship to inform European recommendations. British Journal of Nutrition.
33 Charan J, Goyal JP, Saxena D, et al. (2012). Vitamin D for prevention of respiratory tract infections: A systematic review and meta-analysis. Journal of Pharmacology & Pharmacotherapeutics.
34 Chowdhury R, Stevens S, Ward H, et al. (2012). Circulating vitamin D, calcium and risk of cerebrovascular disease: a systematic review and meta-analysis. European Journal of Epidemiology.
35 Christesen HT, Elvander C, Lamont RF, et al. (2012). The impact of vitamin D in pregnancy on extraskeletal health in children: a systematic review. Acta Obstetricia et Gynecologica Scandinavica.
36 Christesen HT, Falkenberg T, Lamont RF, et al. (2012). The impact of vitamin D on pregnancy: a systematic review. Acta Obstetricia et Gynecologica Scandinavica.
37 Chua GT, Wong RY. (2011). Association Between Vitamin D Dosing Regimen and Fall Prevention in Long-term Care Seniors. Canadian Geriatrics Journal CGJ.
38 Chung M, Balk EM, Brendel M, et al. (2009). Vitamin D and calcium: a systematic review of health outcomes. Evidence Report/Technology Assessment.
39 Chung M, Lee J, Terasawa T, et al. (2011). Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Annals of Internal Medicine.
40 Church J, Goodall S, Norman R, et al. (2011). An economic evaluation of community and residential aged care falls prevention strategies in NSW. New South Wales Public Health Bulletin.
41 Cook LS, Neilson HK, Lorenzetti DL, et al. (2010). A systematic literature review of vitamin D and ovarian cancer. American Journal of Obstetrics & Gynecology.
42 Cooper C, Reginster JY, Cortet B, et al. (2012). Long-term treatment of osteoporosis in postmenopausal women: a review from the European Society for Clinical and Economic Aspects of Osteoporosis and Osteoarthritis (ESCEO) and the International Osteoporosis Foundation (IOF). Current Medical Research & Opinion.
43 Cooper K, Squires H, Carroll C, et al. (2010). Chemoprevention of colorectal cancer: systematic review and economic evaluation. Health Technology Assessment (Winchester, England).
44 De-Regil LM, Palacios C, Ansary A, et al. (2012). Vitamin D supplementation for women during pregnancy. Cochrane Database of Systematic Reviews.
45 Dolinsky DH, Armstrong S, Mangarelli C, et al. (2013). The association between vitamin d and cardiometabolic risk factors in children: a systematic review. Clinical Pediatrics.
46 Dong JY, Zhang WG, Chen JJ, et al. (2013). Vitamin D intake and risk of type 1 diabetes: a meta-analysis of observational studies. Nutrients.
47 Elamin MB, Abu Elnour NO, Elamin KB, et al. (2011). Vitamin D and cardiovascular outcomes: a systematic review and meta-analysis. Journal of Clinical Endocrinology & Metabolism.
48 Etgen T, Sander D, Bickel H, et al. (2011). Mild cognitive impairment and dementia: the importance of modifiable risk factors. Deutsches Arzteblatt International.
49 Etgen T, Sander D, Bickel H, et al. (2012). Vitamin D deficiency, cognitive impairment and dementia: a systematic review and meta-analysis. Dementia & Geriatric Cognitive Disorders.
50 Feneis JF, Arora RR. (2010). Role of vitamin D in blood pressure homeostasis. American Journal of Therapeutics.
51 Forte A, De Sanctis R, Leonetti G, et al. (2008). Dietary chemoprevention of colorectal cancer. Annali Italiani di Chirurgia.
52 Fosnight SM, Zafirau WJ, Hazelett SE. (2008). Vitamin D supplementation to prevent falls in the elderly: evidence and practical considerations. Pharmacotherapy:The Journal of Human Pharmacology & Drug Therapy.
53 Gandini S, Boniol M, Haukka J, et al. (2011). Meta-analysis of observational studies of serum 25-hydroxyvitamin D levels and colorectal, breast and prostate cancer and colorectal adenoma. International Journal of Cancer.
54 Gates BJ, Sonnett TE, Duvall CAK, et al. (2009). Review of osteoporosis pharmacotherapy for geriatric patients. American Journal of Geriatric Pharmacotherapy.
55 George PS, Pearson ER, Witham MD. (2012). Effect of vitamin D supplementation on glycaemic control and insulin resistance: a systematic review and meta-analysis. Diabetic Medicine.
56 Gilbert R, Martin RM, Beynon R, et al. (2011). Associations of circulating and dietary vitamin D with prostate cancer risk: a systematic review and dose-response meta-analysis. Cancer Causes & Control.
57 Gillespie LD, Gillespie WJ, Robertson MC, et al. (2009). WITHDRAWN: Interventions for preventing falls in elderly people. Cochrane Database of Systematic Reviews.
58 Gillespie LD, Robertson MC, Gillespie WJ, et al. (2009). Interventions for preventing falls in older people living in the community. Cochrane Database of Systematic Reviews.
59 Gillespie LD, Robertson MC, Gillespie WJ, et al. (2012). Interventions for preventing falls in older people living in the community. Cochrane Database of Systematic Reviews.
60 Gissel T, Rejnmark L, Mosekilde L, et al. (2008). Intake of vitamin D and risk of breast cancer--a meta-analysis. Journal of Steroid Biochemistry & Molecular Biology.
61 Grandi NC, Breitling LP, Brenner H. (2010). Vitamin D and cardiovascular disease: systematic review and meta-analysis of prospective studies. Preventive Medicine.
62 Grant WB. (2010). Relation between prediagnostic serum 25-hydroxyvitamin D level and incidence of breast, colorectal, and other cancers. Journal of Photochemistry & Photobiology. B—Biology.
63 Group D. (2010). Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. BMJ.
64 Gustafson CJ, Watkins C, Hix E, et al. (2013). Combination therapy in psoriasis: an evidence-based review. American Journal of Clinical Dermatology.
65 Haentjens P, Vanderschueren D, Lips P, et al. (2009). Need for additional calcium to reduce the risk of hip or any nonvertebral fracture with vitamin D supplementation: evidence from a comparative meta-analysis of randomized controlled trials. The Journal of Bone and Joint Surgery (Proceedings).
66 Health Quality O. (2008). Prevention of falls and fall-related injuries in community-dwelling seniors: an evidence-based analysis. Ontario Health Technology Assessment Series.
67 Helzlsouer KJ, Committee VS. (2010). Overview of the Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. American Journal of Epidemiology.
68 Hossein-nezhad A, Holick MF. (2013). Vitamin D for health: a global perspective. Mayo Clinic Proceedings.
69 Hujoel PP. (2013). Vitamin D and dental caries in controlled clinical trials: systematic review and meta-analysis. Nutrition Reviews.
70 Hujoel PP. (2013). Vitamin D and dental caries in controlled clinical trials: systematic review and meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects.
71 Huncharek M, Muscat J, Kupelnick B. (2008). Impact of dairy products and dietary calcium on bone-mineral content in children: results of a meta-analysis. Bone.
72 Huncharek M, Muscat J, Kupelnick B. (2008). Dairy products, dietary calcium and vitamin D intake as risk factors for prostate cancer: a meta-analysis of 26,769 cases from 45 observational studies. Nutrition & Cancer.
73 Ingraham BA, Bragdon B, Nohe A. (2008). Molecular basis of the potential of vitamin D to prevent cancer. Current Medical Research & Opinion.
74 Jolliffe DA, Griffiths CJ, Martineau AR. (2013). Vitamin D in the prevention of acute respiratory infection: systematic review of clinical studies. Journal of Steroid Biochemistry & Molecular Biology.
75 Ju SY, Lee YJ, Jeong SN. (2013). Serum 25-hydroxyvitamin D levels and the risk of depression: a systematic review and meta-analysis. Journal of Nutrition, Health & Aging.
76 Kalyani RR, Stein B, Valiyil R, et al. (2010). Vitamin D treatment for the prevention of falls in older adults: systematic review and meta-analysis. Journal of the American Geriatrics Society.
77 Khan H, Kunutsor S, Franco OH, et al. (2013). Vitamin D, type 2 diabetes and other metabolic outcomes: a systematic review and meta-analysis of prospective studies. Proceedings of the Nutrition Society.
78 Kunutsor SK, Apekey TA, Steur M. (2013). Vitamin D and risk of future hypertension: meta-analysis of 283,537 participants. European Journal of Epidemiology.
79 Kunutsor SK, Apekey TA, Steur M. (2013). Vitamin D and risk of future hypertension: meta-analysis of 283,537 participants (Provisional abstract). Database of Abstracts of Reviews of Effects.
80 Lai JKC, Lucas RM, Clements MS, et al. (2010). Hip fracture risk in relation to vitamin D supplementation and serum 25-hydroxyvitamin D levels: a systematic review and meta-analysis of randomised controlled trials and observational studies. BMC Public Health.
81 Lamberg-Allardt C, Brustad M, Meyer HE, et al. (2013). Vitamin D—a systematic literature review for the 5th edition of the Nordic Nutrition Recommendations. Food &Nutrition Research.
82 Lazzeroni M, Serrano D, Pilz S, et al. (2013). Vitamin d supplementation and cancer: review of randomized controlled trials. Current Medicinal Chemistry—Anti-Cancer Agents.
83 Lee JE. (2011). Circulating levels of vitamin D, vitamin D receptor polymorphisms, and colorectal adenoma: a meta-analysis. Nutrition Research & Practice.
84 Liu SL, Zhao YP, Dai MH, et al. (2013). Vitamin D status and the risk of pancreatic cancer: a meta-analysis. Chinese Medical Journal.
85 Liu ZM, Woo J, Wu SH, et al. (2013). The role of vitamin D in blood pressure, endothelial and renal function in postmenopausal women. Nutrients.
86 Ma Y, Zhang P, Wang F, et al. (2011). Association between vitamin D and risk of colorectal cancer: a systematic review of prospective studies. Journal of Clinical Oncology.
87 MacLean C, Newberry S, Maglione M, et al. (2008). Systematic review: comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis. Annals of Internal Medicine.
88 Mahomed K, Gulmezoglu AM. (2011). WITHDRAWN: Vitamin D supplementation in pregnancy. Cochrane Database of Systematic Reviews.
89 Mao PJ, Zhang C, Tang L, et al. (2013). Effect of calcium or vitamin D supplementation on vascular outcomes: A meta-analysis of randomized controlled trials. International Journal of Cardiology.
90 Mao S, Huang S. (2013). Vitamin D supplementation and risk of respiratory tract infections: a meta-analysis of randomized controlled trials. Scandinavian Journal of Infectious Diseases.
91 Marik PE, Flemmer M. (2012). Do dietary supplements have beneficial health effects in industrialized nations: what is the evidence?. Jpen: Journal of Parenteral & Enteral Nutrition.
92 Melek J, Sakuraba A. (2014). Efficacy and Safety of Medical Therapy for Low Bone Mineral Density in Patients With Inflammatory Bowel Disease: A Meta-analysis and Systematic Review. Clinical Gastroenterology & Hepatology.
93 Michael YL, Whitlock EP, Lin JS, et al. (2010). Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Annals of Internal Medicine.
94 Miller PD. (2011). Vitamin D, calcium, and cardiovascular mortality: a perspective from a plenary lecture given at the annual meeting of the American Association of Clinical Endocrinologists. Endocrine Practice.
95 Mitri J, Muraru MD, Pittas AG. (2011). Vitamin D and type 2 diabetes: a systematic review. European Journal of Clinical Nutrition.
96 Mohr SB, Gorham ED, Alcaraz JE, et al. (2011). Serum 25-hydroxyvitamin D and prevention of breast cancer: pooled analysis. Anticancer Research.
97 Morse NL. (2012). Benefits of docosahexaenoic acid, folic acid, vitamin D and iodine on foetal and infant brain development and function following maternal supplementation during pregnancy and lactation. Nutrients.
98 Mouli VP, Ananthakrishnan AN. (2014). Review article: vitamin D and inflammatory bowel diseases. Alimentary Pharmacology & Therapeutics.
99 Muir SW, Montero-Odasso M. (2011). Effect of vitamin D supplementation on muscle strength, gait and balance in older adults: a systematic review and meta-analysis. Journal of the American Geriatrics Society.
100 Murad MH, Drake MT, Mullan RJ, et al. (2012). Clinical review. Comparative effectiveness of drug treatments to prevent fragility fractures: a systematic review and network meta-analysis. Journal of Clinical Endocrinology & Metabolism.
101 Murad MH, Elamin KB, Abu Elnour NO, et al. (2011). Clinical review: The effect of vitamin D on falls: a systematic review and meta-analysis. Journal of Clinical Endocrinology & Metabolism.
102 Murthy V, Chamberlain RS. (2012). Menopausal symptoms in young survivors of breast cancer: a growing problem without an ideal solution. Cancer Control.
103 Nahas R. (2008). Complementary and alternative medicine approaches to blood pressure reduction: An evidence-based review. Canadian Family Physician.
104 Nemerovski CW, Dorsch MP, Simpson RU, et al. (2009). Vitamin D and cardiovascular disease. Pharmacotherapy:The Journal of Human Pharmacology & Drug Therapy.
105 Nicholson I, Dalzell AM, El-Matary W. (2012). Vitamin D as a therapy for colitis: a systematic review. Journal of Crohn's & colitis.
106 Nnoaham KE, Clarke A. (2008). Low serum vitamin D levels and tuberculosis: a systematic review and meta-analysis. International Journal of Epidemiology.
107 Nurmatov U, Devereux G, Sheikh A. (2011). Nutrients and foods for the primary prevention of asthma and allergy: systematic review and meta-analysis. Journal of Allergy & Clinical Immunology.
108 O'Donnell S, Moher D, Thomas K, et al. (2008). Systematic review of the benefits and harms of calcitriol and alfacalcidol for fractures and falls. Journal of Bone & Mineral Metabolism.
109 Peppone LJ, Hebl S, Purnell JQ, et al. (2010). The efficacy of calcitriol therapy in the management of bone loss and fractures: a qualitative review. Osteoporosis International.
110 Pilz S, Kienreich K, Tomaschitz A, et al. (2013). Vitamin d and cancer mortality: systematic review of prospective epidemiological studies. Current Medicinal Chemistry—Anti-Cancer Agents.
111 Pittas AG, Chung M, Trikalinos T, et al. (2010). Systematic review: Vitamin D and cardiometabolic outcomes. Annals of Internal Medicine.
112 Poel YHM, Hummel P, Lips P, et al. (2012). Vitamin D and gestational diabetes: a systematic review and meta-analysis. European Journal of Internal Medicine.
113 Pogge E. (2010). Vitamin D and Alzheimer's disease: is there a link?. Consultant Pharmacist.
114 Posadzki P, Lee MS, Onakpoya I, et al. (2013). Dietary supplements and prostate cancer: a systematic review of double-blind, placebo-controlled randomised clinical trials. Maturitas.
115 Rabenda V, Bruyere O, Reginster JY. (2011). Relationship between bone mineral density changes and risk of fractures among patients receiving calcium with or without vitamin D supplementation: a meta-regression. Osteoporosis International.
116 Rathi N, Rathi A. (2011). Vitamin D and child health in the 21st century. Indian Pediatrics.
117 Redzic M, Lewis RM, Thomas DT. (2013). Relationship between 25-hydoxyvitamin D, muscle strength, and incidence of injury in healthy adults: a systematic review. Nutrition Research.
118 Reid IR, Bolland MJ, Grey A. (2014). Effects of vitamin D supplements on bone mineral density: a systematic review and meta-analysis. Lancet.
119 Rejnmark L. (2011). Effects of vitamin d on muscle function and performance: a review of evidence from randomized controlled trials. Therapeutic Advances in Chronic Disease.
120 Rejnmark L, Avenell A, Masud T, et al. (2012). Vitamin D with calcium reduces mortality: patient level pooled analysis of 70,528 patients from eight major vitamin D trials. Journal of Clinical Endocrinology & Metabolism.
121 Renzaho AMN, Halliday JA, Nowson C. (2011). Vitamin D, obesity, and obesity-related chronic disease among ethnic minorities: a systematic review. Nutrition.
122 Richy F, Dukas L, Schacht E. (2008). Differential effects of D-hormone analogs and native vitamin D on the risk of falls: a comparative meta-analysis. Calcified Tissue International.
123 Robien K, Oppeneer SJ, Kelly JA, et al. (2013). Drug-vitamin d interactions: a systematic review of the literature. Nutrition in Clinical Practice.
124 Rojas-Fernandez CH, Maclaughlin EJ, Dore NL, et al. (2012). Assessing the potential adverse consequences of supplemental calcium on cardiovascular outcomes: should we change our approach to bone health?. Annals of Pharmacotherapy.
125 Rush L, McCartney G, Walsh D, et al. (2013). Vitamin D and subsequent all-age and premature mortality: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects.
126 Schottker B, Ball D, Gellert C, et al. (2013). Serum 25-hydroxyvitamin D levels and overall mortality. A systematic review and meta-analysis of prospective cohort studies. Ageing Research Reviews.
127 Scragg R. (2011). Vitamin D and public health: an overview of recent research on common diseases and mortality in adulthood. Public Health Nutrition.
128 Seamans KM, Cashman KD. (2009). Existing and potentially novel functional markers of vitamin D status: a systematic review. American Journal of Clinical Nutrition.
129 Sokol SI, Tsang P, Aggarwal V, et al. (2011). Vitamin D status and risk of cardiovascular events: lessons learned via systematic review and meta-analysis. Cardiology in Review.
130 Song GG, Bae SC, Lee YH. (2012). Association between vitamin D intake and the risk of rheumatoid arthritis: a meta-analysis. Clinical Rheumatology.
131 Sperati F, Vici P, Maugeri-Sacca M, et al. (2013). Vitamin d supplementation and breast cancer prevention: a systematic review and meta-analysis of randomized clinical trials. PLoS ONE.
132 Sperati F, Vici P, Maugeri-Sacca M, et al. (2013). Vitamin d supplementation and breast cancer prevention: a systematic review and meta-analysis of randomized clinical trials (Provisional abstract). Database of Abstracts of Reviews of Effects.
133 Stockton KA, Mengersen K, Paratz JD, et al. (2011). Effect of vitamin D supplementation on muscle strength: a systematic review and meta-analysis. Osteoporosis International.
134 Tabesh M, Salehi-Abargouei A, Tabesh M, et al. (2013). Maternal vitamin D status and risk of pre-eclampsia: a systematic review and meta-analysis. Journal of Clinical Endocrinology & Metabolism.
135 Thiele DK, Senti JL, Anderson CM. (2013). Maternal vitamin D supplementation to meet the needs of the breastfed infant: a systematic review. Journal of Human Lactation.
136 Thomas GN, Scragg R, Jiang CQ, et al. (2012). Hyperglycaemia and vitamin D: a systematic overview. Current Diabetes Reviews.
137 Thorne-Lyman A, Fawzi WW. (2012). Vitamin D during pregnancy and maternal, neonatal and infant health outcomes: a systematic review and meta-analysis. Paediatric and Perinatal Epidemiology.
138 Touvier M, Chan DSM, Lau R, et al. (2011). Meta-analyses of vitamin D intake, 25-hydroxyvitamin D status, vitamin D receptor polymorphisms, and colorectal cancer risk. Cancer Epidemiology, Biomarkers & Prevention.
139 Tripkovic L, Lambert H, Hart K, et al. (2012). Comparison of vitamin D2 and vitamin D3 supplementation in raising serum 25-hydroxyvitamin D status: a systematic review and meta-analysis. American Journal of Clinical Nutrition.
140 Urrutia RP, Thorp JM. (2012). Vitamin D in pregnancy: current concepts. Current Opinion in Obstetrics & Gynecology.
141 Uusi-Rasi K, Karkkainen MU, Lamberg-Allardt CJ. (2013). Calcium intake in health maintenance—a systematic review. Food &Nutrition Research.
142 van der Putten GJ, Vanobbergen J, De Visschere L, et al. (2009). Association of some specific nutrient deficiencies with periodontal disease in elderly people: A systematic literature review. Nutrition.
143 van der Rhee H, Coebergh JW, de Vries E. (2009). Sunlight, vitamin D and the prevention of cancer: a systematic review of epidemiological studies. European Journal of Cancer Prevention.
144 van der Rhee H, Coebergh JW, de Vries E. (2013). Is prevention of cancer by sun exposure more than just the effect of vitamin D? A systematic review of epidemiological studies. European Journal of Cancer.
145 van der Schaft J, Koek HL, Dijkstra E, et al. (2013). The association between vitamin D and cognition: A systematic review. Ageing Research Reviews.
146 van Holten TC, Waanders LF, de Groot PG, et al. (2013). Circulating biomarkers for predicting cardiovascular disease risk; a systematic review and comprehensive overview of meta-analyses. PLoS ONE.
147 Verheyden GS, Weerdesteyn V, Pickering RM, et al. (2013). Interventions for preventing falls in people after stroke. Cochrane Database of Systematic Reviews.
148 Villar LM, Del Campo JA, Ranchal I, et al. (2013). Association between vitamin D and hepatitis C virus infection: a meta-analysis. World Journal of Gastroenterology.
149 Wang D, Velez de-la-Paz OI, Zhai JX, et al. (2013). Serum 25-hydroxyvitamin D and breast cancer risk: a meta-analysis of prospective studies (Provisional abstract). Database of Abstracts of Reviews of Effects.
150 Wang D, Velez de-la-Paz OI, Zhai JX, et al. (2013). Serum 25-hydroxyvitamin D and breast cancer risk: a meta-analysis of prospective studies. Tumour Biology.
151 Wang H, Xia N, Yang Y, et al. (2012). Influence of vitamin D supplementation on plasma lipid profiles: a meta-analysis of randomized controlled trials. Lipids in Health & Disease.
152 Wang L, Manson JE, Song Y, et al. (2010). Systematic review: Vitamin D and calcium supplementation in prevention of cardiovascular events. Annals of Internal Medicine.
153 Wei MY, Garland CF, Gorham ED, et al. (2008). Vitamin D and prevention of colorectal adenoma: a meta-analysis. Cancer Epidemiology, Biomarkers & Prevention.
154 Wheless L, Black J, Alberg AJ. (2010). Nonmelanoma skin cancer and the risk of second primary cancers: a systematic review. Cancer Epidemiology, Biomarkers & Prevention.
155 Winzenberg T, Powell S, Shaw KA, et al. (2011). Effects of vitamin D supplementation on bone density in healthy children: systematic review and meta-analysis. BMJ.
156 Winzenberg TM, Powell S, Shaw KA, et al. (2010). Vitamin D supplementation for improving bone mineral density in children. Cochrane Database of Systematic Reviews.
157 Witham MD, Nadir MA, Struthers AD. (2009). Effect of vitamin D on blood pressure: a systematic review and meta-analysis. Journal of Hypertension.
158 Wolpin BM, Ng K, Bao Y, et al. (2012). Plasma 25-hydroxyvitamin D and risk of pancreatic cancer. Cancer Epidemiology, Biomarkers & Prevention.
159 Wu SH, Ho SC, Zhong L. (2010). Effects of vitamin D supplementation on blood pressure. Southern Medical Journal.
160 Yamshchikov AV, Desai NS, Blumberg HM, et al. (2009). Vitamin D for treatment and prevention of infectious diseases: a systematic review of randomized controlled trials. Endocrine Practice.
161 Yin L, Grandi N, Raum E, et al. (2009). Meta-analysis: longitudinal studies of serum vitamin D and colorectal cancer risk. Alimentary Pharmacology & Therapeutics.
162 Yin L, Grandi N, Raum E, et al. (2010). Meta-analysis: serum vitamin D and breast cancer risk. European Journal of Cancer.
163 Yin L, Grandi N, Raum E, et al. (2011). Meta-analysis: Circulating vitamin D and ovarian cancer risk. Gynecologic Oncology.
164 Yin L, Ordonez-Mena JM, Chen T, et al. (2013). Circulating 25-hydroxyvitamin D serum concentration and total cancer incidence and mortality: A systematic review and meta-analysis. Preventive Medicine.
165 Yin L, Raum E, Haug U, et al. (2009). Meta-analysis of longitudinal studies: Serum vitamin D and prostate cancer risk. Cancer Epidemiology.
166 Zheng Y, Zhu J, Zhou M, et al. (2013). Meta-analysis of long-term vitamin d supplementation on overall mortality. PLoS ONE.
167 Zipitis CS, Akobeng AK. (2008). Vitamin D supplementation in early childhood and risk of type 1 diabetes: a systematic review and meta-analysis. Archives of Disease in Childhood.
168 Zittermann A, Gummert JF, Borgermann J. (2011). The role of vitamin D in dyslipidemia and cardiovascular disease. Current Pharmaceutical Design.
169 Zittermann A, Iodice S, Pilz S, et al. (2012). Vitamin D deficiency and mortality risk in the general population: a meta-analysis of prospective cohort studies. American Journal of Clinical Nutrition.

### Background Articles—N=10

1 (2008). Drugs for postmenopausal osteoporosis. Treatment Guidelines From the Medical Letter.
2 Bolland MJ, Grey A, Gamble GD, et al. (2011). Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women's Health Initiative (WHI) limited-access data set. American Journal of Clinical Nutrition.
3 Grant WB. (2011). Effect of interval between serum draw and follow-up period on relative risk of cancer incidence with respect to 25-hydroxyvitamin D level: Implications for meta-analyses and setting vitamin D guidelines. Dermato-endocrinology.
4 Grant WB. (2012). Effect of follow-up time on the relation between prediagnostic serum 25-hydroxyvitamin D and all-cause mortality rate. Dermato-endocrinology.
5 Hofmann JN, Yu K, Horst RL, et al. (2010). Long-term variation in serum 25-hydroxyvitamin D concentration among participants in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Cancer Epidemiology, Biomarkers & Prevention.
6 Niramitmahapanya S, Harris SS, Dawson-Hughes B. (2011). Type of dietary fat is associated with the 25-hydroxyvitamin D3 increment in response to vitamin D supplementation. Journal of Clinical Endocrinology & Metabolism.
7 O'Connor E, Molgaard C, Michaelsen KF, et al. (2010). Vitamin D-vitamin K interaction: effect of vitamin D supplementation on serum percentage undercarboxylated osteocalcin, a sensitive measure of vitamin K status, in Danish girls. British Journal of Nutrition.
8 Ross AC, Manson JE, Abrams SA, et al. (2011). The 2011 Dietary Reference Intakes for Calcium and Vitamin D: what dietetics practitioners need to know. Journal of the American Dietetic Association.
9 Vanstone MB, Oberfield SE, Shader L, et al. (2012). Hypercalcemia in children receiving pharmacologic doses of vitamin D. Pediatrics.
10 Wallace RB, Wactawski-Wende J, O'Sullivan MJ, et al. (2011). Urinary tract stone occurrence in the Women's Health Initiative (WHI) randomized clinical trial of calcium and vitamin D supplements. American Journal of Clinical Nutrition.