# Appendix E Blank Data Extraction Form and Quality Assessment Checklists

Blank Data Extraction Form and Quality Assessment Checklists (From the Original Report)

Blank Data Extraction Form and Quality Assessment Checklists (From the Current Report)