# Appendix D Evaluation of Existing Systematic Reviews and Evidence Tables of the Qualified Systematic Reviews

Evaluation of existing systematic reviews

Evidence table of systematic review of Vitamin D supplementation on serum 25(OH)D concentrations

Evidence table of systematic review of circulating 25(OH)D and Risk for Cardiovascular Disease

Evidence table of systematic review of the effect of vitamin D on bone health

Evidence table of systematic review on vitamin D supplementation and all-cause mortality

Evidence table of systematic review of calcium on growth in children

Evidence table of systematic reviews of calcium and blood pressure

Evidence table of systematic review of calcium on growth in children

Evidence table of systematic review on calcium intake and adenoma recurrence

List of Acronyms and Abbreviations
Acronym/Abbreviation: Term
BP: Blood pressure
Ca: Calcium
CRC: Colorectal cancer
DBP: Diastolic blood pressure
HTN: Hypertension
im: intramuscular
NTN: Normotensive
OR: Odds ratio
RCT: Randomized controlled trial
SBP: Systolic blood pressure
SE: Standard error