# Appendix C Evidence Tables for the Current Report

Vitamin D Update Evidence Table

List of Abbreviations and Acronyms Included in Evidence Tables
Abbreviation: Term
ACS: Aortic calcification score
ADL: Activities of Daily Living
BMC: Bone mineral content
BMD: Bone mineral density
BMI: Body mass index
BP: Blood pressure
CHS: Cardiovascular Health Study
CKD: Chronic kidney disease
CRC: Colorectal cancer
CRP: C-reactive protein
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
eGFR: Estimated glomerular filtration rate
EPIC: European Prospective Investigation into Cancer and Nutrition
ESTHER: EStrogen and THromboEmbolism Risk Study
GFR: Glomerular filtration rate
HDL: High-density lipoprotein
HLA: Human leukocyte antigen
HPFS: Health Professionals Follow-Up Study
HR: Hazard ratio
InChianti: Invecchiare nel Chianti
INTAPP: International Trial of Antioxidants in the Prevention of Pre-eclampsia
InChianti: Invecchiare nel Chianti
KORA: Cooperative Health Research in the Region Augsburg
InChianti: Invecchiare nel Chianti
LDL: Low-density lipoprotein
MEC: Mobile Examination Center
MESA: Multi-ethnic Study of Atherosclerosis
MI: Myocardial infarction
MONICA: Multinational MONItoring of trends and determinants in CArdiovascular disease Study
MONICA: Multinational MONItoring of trends and determinants in CArdiovascular disease Study
NSAIDS: Non-steroidal anti-inflammatories
NHANES: National Health and Nutrition Examination Survey
OR: Odds ratio
PASE: Physical Activity Score For The Elderly
PTH: Parathyroid hormone
Q: Quartile
RR: Relative risk
SC: Size-corrected
SD: Standard deviation
SBP: Systolic blood pressure
SES: Socioeconomic status
SPPB: Secondary-Short Physical Performance Battery
TUAG: Timed Up and Go
VTE: Venous thromboembolism
YRS: Years