# Abbreviations

1,25(OH)_2_D: Calcitriol
25(OH)D: 25-hydroxyvitamin D
AHRQ: Agency for Healthcare Research and Quality
AMSTAR: Assessment of multiple systematic reviews
Anthrop: Anthropometric measures
ASA: Acetyl-salicylic acid (aspirin)
ATBC: Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study
BCDDP: Breast Cancer Detection Demonstration Project
BMC: Bone mineral content
BMD: Bone mineral density
BMI: Body mass index
Ca: Calcium
CABG: Coronary artery bypass graft
CeVD: Cerebrovascular disease
CHD: Coronary heart disease
CI: Confidence Interval
CIFOS: Calcium Intake Fracture Outcome Study
CONSORT: Consolidated Standards of Reporting Trials
CPBA: Competitive protein binding assay
CPEP: Calcium for Prevention of Preeclampsia Trial
CPP: Calcium Polyp Prevention Study
CPS: Cancer Prevention Study
CRC: Colorectal cancer
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
Demograph: Demographics
Dx: Diagnosis
DM: Diabetes Mellitus
DRI: Dietary Reference Intake
Dx: Diagnosis
EAR: Estimated average requirement
EPC: Evidence-based Practice Center
FFQ: Food frequency questionnaire
FNB: Food and Nutrition Board
FOS: Framingham Offspring Study
FREE: Fracture Risk Epidemiology in the Elderly
HAH: Harvard Alumni Health Study
HbC: Hemoglobin C disease
HPFS: Health Professionals Followup Study
HPLC: High pressure liquid chromatography
HR: Hazard ratio
ht: Height
HT: Hormone (replacement) therapy
HTN: Hypertension
IA: Islet Autoimmune
IHD: Ischemic heart disease
IOM: Institute of Medicine
Iowa WHS: Iowa Women's Health Study
IQR: Interquartile range
IU: International unit
Japan CC: Japan Collaborative Cohort
Japan PHC: Japan Public Health Center study
Kupio ORFPS: Kupio Osteoporosis Risk Factor and Prevention Study
MCS: Multiethnic Cohort Study, Hawaii, California
MI: Myocardial infarction
mil: Million
mo: Months(s)
MS: Multiple sclerosis
N: Number of subjects
n: Number of subjects had event(s)
NA: Not applicable
nd: No data
NHANES: National Health and Nutrition Examination Survey
NHEFS: NHANES I Epidemiologic Followup Study
NHS: Nurses' Health Study
NIH: National Institutes of Health
NIH-AARP: National Institutes of Health—American Association of Retired Persons
NPC: Nutrition Prevention of Cancer trial
NS: Not significant
ODS: Office of Dietary Supplements
OR: Odds Ratio
OS: Observational Study
PAHSG: Princess Anne Hospital Study Group, U.K.
PCI: Percutaneous coronary intervention
PHS: Physicians' Health Study
PI(E)CO: Population, Intervention (or Exposure), Comparison and Outcome
PLCO: Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial
PMID: PubMed (unique) identifier
PSA: Prostate specific antigen
PTH: Parathyroid hormone
RA: Rheumatoid arthritis
RCT: Randomized-controlled trial
RDA: Recommended dietary allowance
RIA: Radioimmunoassay
RR: Relative risk
SBP: Systolic blood pressure
SD: Standard deviation
SE: Standard error
SGA: Small-for-gestational-age
STROBE: STrengthening the Reporting of OBservational studies in Epidemiology
Subgp: Subgroup
Suppl: Supplement(s)
TEP: Technical Expert Panel
TIA: Transient ischemic attack
TOHP: Trials of Hypertension Prevention
TOO: Task order officer
UK: United Kingdom
UL: Tolerable upper intake levels
U.S.: United States
USDA: United States Department of Agriculture
UV: Ultraviolet rays
Vit: Vitamin
WCC: Washington County Cohort
WHI: Women's Health Initiative
WHS: Women's Health Study
wk: week(s)
WMD: Weighted mean difference
wt: Weight
y: Year(s)