# Results

## Introduction

We begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question. A list of abbreviations and acronyms is provided at the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process.43 Searches of Ovid MEDLINE^®^, CDSR^®^, CCRCT^®^, CINAHL^®^, Scopus^®^ and PsycINFO^®^ yielded 3,405 citations. Manual searching and peer review identified 53 additional citations, but searches of ClinicalTrials.gov did not reveal relevant completed or on-going studies. We received scientific information packets from Jazz Pharmaceuticals, Forest Pharmaceuticals, Inc., and Sanofi Aventis, U.S. Based on all these sources, a total of 3,458 abstracts were screened, of which 319 articles were retrieved and assessed for eligibility. Of those, 130 unique studies were included in this report.55-193 No systematic reviews were found to be eligible for evidence synthesis. The majority of the evidence is from observational studies with 130 articles describing 124 unique studies. Very few trials met inclusion criteria for this report; we included nine articles describing six unique trials. Appendix B provides a listing of all included studies and Appendix C provides a complete list of articles excluded at full text, along with the reasons for exclusion.

Figure 2 Literature flow diagrama

^a^ This is a modified PRISMA flow diagram.43,194

Figure 2 is the Literature Flow Diagram which depicts the flow of articles through the literature search and screening process. A total of 3405 citations were identified through searches of Ovid MEDLINE®, CDSR®, CCRCT®, CINAHL®, SCOPUS® and PsycINFO®. Manual searching identified 53 additional citations. Of the 3458 citations that were screened, 3139 were excluded at the abstract level as they were obviously irrelevant to the Key Questions. Full text articles of the remaining 319 potentially relevant citations were retrieved and further assessed for eligibility. Of those, 131 unique studies and 9 companion publications met inclusion criteria and are included in this report. The majority of the evidence is from observational studies with 130 articles describing 124 unique studies. Very few trials met inclusion criteria for this report with 10 articles describing 7 unique trials.

Few studies included only pregnant women with depression—most compared pregnant women who received an antidepressant drug for any reason (i.e., maternal exposure) with pregnant women who did not receive an antidepressant drug during pregnancy (i.e., maternal nonexposure). There were no studies comparing an antidepressant drug with a nonpharmacological treatment, and only a few studies in which nonpharmacological treatment was used as an add-on to drug therapy. Using a “best evidence” approach, we focused our findings and conclusions on evidence in pregnant women with depression. We included 6 RCTs and 15 observational studies that focused on women with depression. To address gaps in the direct evidence, we included indirect evidence from an additional 109 observational studies of women receiving antidepressant drugs for mixed or unknown reasons compared with pregnant or postpartum women not taking an antidepressant. Findings from these studies were reported only for important outcomes when there was no better evidence, particularly for serious harms for which even such indirect evidence may be useful in guiding clinical decisions.

## Description of Included Studies

Of the 130 studies that were included, one-third were conducted in the United States. Four additional studies were conducted in multiple countries, and included sites in the United States and Canada. The remainder were conducted outside the United States.

Of the 124 included observational studies, 39 (30 percent) were rated high risk of bias,64,68,72,75,78,84,85,88-92,94,98,101,111,112,114,123,126-128,134,137,139,140,144-146,153-155,164,173,174,177,180,185 were rated low risk of bias (9 percent),74,82,93,104,105,110,125,136,161,169,171,192 and the rest of the observational studies were rated medium risk of bias.55-57,59-63,66,67,69-71,73,76,77,79-81,83,86,87,95-97,99,100,102,103,106-109,113,115,117-120,122,124,129-131,133,135,138,141-143,147-152,156-160,162,163,165-168,172,175,176,178,179,181,182,184,186,187,189,190,193 For two high risk of bias studies,98,140 we found secondary publications that we rated medium risk of bias for the specific additional outcomes reported.120,141 High risk of bias studies suffered from potentially biased selection of patients, lack of assessment of comparability of subjects at baseline, uncertain accuracy of exposure or outcome ascertainment, and lack of appropriate statistical analysis, including controlling for potential confounding. These observational studies largely examined outcomes and associations of exposures during pregnancy, with few evaluating treatment in the postpartum period. The designs of the studies included cohort and case control, with large, linked databases providing data for most of the larger studies, including several population-based cohort studies from Nordic countries. Prospective cohort studies, including data collected by teratology information services around the world, constituted a smaller set of studies with smaller sample sizes. The control groups in most of these observational studies were pregnant women without exposure to an antidepressant drug. The indication for treatment with an antidepressant drug was reported infrequently. In a few studies, depression in either intervention or control groups was controlled for in a way that allowed comparison of treatment groups or examination of the effect on outcomes of treatment. See Appendix E, Evidence Table 2 for individual study risk of bias ratings.

All six of the included RCTs examined women in the postpartum period. Three of these RCTs were rated medium risk of bias,58,65,132 while three were considered high risk of bias due to problems with uncertain randomization, allocation concealment, or blinding methods combined with lack of an intention-to-treat analysis and/or a high rate of missing data.170,188,191 None of the trials were rated as having a low risk of bias. Further details on studies are provided below. See Appendix E, Evidence Table 4 for individual study risk of bias ratings.

## Key Question 1 What are the comparative benefits of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

### Summary

We found no clinical trials to provide direct evidence on the comparative benefit or harms of antidepressant drugs used to treat depression in pregnancy. Direct evidence was limited to 16 observational studies of pharmacological treatments given at unknown dosages. Indirect evidence consisted of studies of women taking an antidepressant during pregnancy for any reason compared with women who did not take an antidepressant during pregnancy, with unknown depression status in either group.

- Direct evidence was sparse on the maternal and infant/child benefits associated with pharmacological and nonpharmacological treatment for depression during pregnancy and the postpartum period, and it was insufficient to support conclusions due to methodological limitations, unknown consistency and imprecision. Types of direct evidence available were:
  ○ Maternal depression symptomatology
    ■ One small observational study with high risk of bias (n=46) compared mean Center for Epidemiologic Studies Depression Scale (CES-D) scores between depressed pregnant women treated with fluoxetine and untreated depressed pregnant women.
    ■ One small RCT with high risk of bias (n=109) compared response and remission rates between sertraline and nortriptyline in postpartum women with depression.
    ■ Two small, medium risk of bias RCTs and one small, high risk of bias observational study (n=150) compared the effects of combining pharmacologic treatments with nonpharmacological treatments versus nonpharmacological treatments alone on depression symptomatology when used to treat depression in postpartum women.
    ■ One small, medium risk of bias RCTs and one small, high risk of bias observational study (n=58) compared the effects of combining pharmacologic treatments with nonpharmacological treatments versus pharmacological treatments alone on depression symptomatology when used to treat depression in postpartum women.
  ○ Maternal functional capacity:
    ■ One small observational study with medium risk of bias (n=62) compared mean Medical Outcomes Survey 12-Item Short Form (SF-12) mental component scores between depressed pregnant women treated with SSRIs and untreated depressed pregnant women.
  ○ Breastfeeding
    ■ One small observational study with medium risk of bias compared the effects of SSRI treatment during pregnancy on the proportions of women breastfeeding 6 weeks after birth.
    ■ One small RCT with high risk of bias (n=70) compared the effects on breastfeeding rates of taking sertraline versus nortriptyline for depression during the postpartum period.
  ○ Preterm birth
    ■ Low strength evidence from two medium risk of bias (n=266) studies suggested no difference in risk with use of SSRIs compared with no treatment for depression during pregnancy.
  ○ Infant/child development
    ■ One small observational study with medium risk of bias (n=49) compared mean scores on the Brazelton Neonatal Behavioral Assessment Scale between depressed pregnant women treated with SSRIs and untreated depressed pregnant women.
    ■ One small observational study with medium risk of bias (n=44) compared the effects of SSRIs plus psychotherapy versus psychotherapy alone during pregnancy on the Bayley Mental Development Index and Psychomotor Development Index and Behavioral Rating Scale.

### Detailed Assessment of the Evidence

#### Key Question 1 What are the comparative benefits of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

There were no clinical trials of pharmacologic treatment during pregnancy to inform the question of the comparative benefits of treatment. Evidence was limited to observational studies (cohort and case control designs). Most of these studies provide only indirect evidence, comparing women treated with antidepressants during pregnancy for any reason to pregnant women who were not treated. The diagnosis for treatment in the treated group was most often not reported, or it was reported as a baseline characteristic but with no subgroup analysis based on diagnosis. The rates of depression in the control groups were rarely reported. However, some studies controlled for depression in statistical analyses. We found both RCTs and observational studies of depression treatment in the postpartum period.

The evidence below is organized first by the subquestions of Key Question 1, then by pregnancy status at the time of exposure—during pregnancy or postpartum. Within those categories we present the evidence by pharmacological class with all outcomes for a given class presented together. Direct evidence was the primary focus, with indirect evidence reported only for important outcomes for which evidence in pregnant women with depression did not exist or was sparse, particularly for serious harms for which even such indirect evidence may be useful in guiding clinical decisions. Outcomes for which no evidence was found are not itemized below.

#### Key Question 1a How do pharmacological treatments affect maternal and child outcomes when compared with placebo or no active treatment or usual care?

##### Antidepressant Exposure During Pregnancy

###### Selective Serotonin Reuptake Inhibitors

###### Maternal Outcomes

Twenty-five observational studies reported maternal health outcomes for active SSRI treatment (as a class or as an individual drug),66,69,71,76,77,80,82,99,115,122,129,131,143,145,146,150,152,165,166,169,177,181,184,189 with only three40, 69,177 explicitly including women with depression during pregnancy in both the intervention and control groups (i.e., direct evidence). Two were methodologically weak with high risk of bias, due primarily to potentially biased selection of patients, unclear completeness of data, and lack of appropriate statistical analysis, including failure to control for potential confounding.145,177

Depression symptomatology. Associations of treatment effect require study populations that include depressed pregnant women with and without treatment, and ideally the study would include an assessment prior to initiation of treatment in the treated group. Six reports of five observational studies69,131,145,146,150,177 reported some feature of mood or depression symptoms with SSRI use; only two69,177 provide direct comparative evidence on depression symptomatology among depressed pregnant women with and without pharmacological treatment. These studies are small, totaling 106 women (59 treated, 31 depressed without pharmacologic treatment, and 16 without depression and no treatment). The smallest, totaling 44 depressed pregnant women,69 31 of whom were taking SSRIs, showed no significant difference between treated and untreated in change in symptoms across pregnancy. The larger study of 62 women177 focused exclusively on fluoxetine treatment and found significant improvement in depression symptoms as measured by CES-D score with treatment; the women's symptoms improved with each trimester. By the third trimester the mean CES-D score for depressed women on fluoxetine was 14.33±12.02 compared with 25.93±4.91 for those not treated with fluoxetine (p=0.0010). However, it is important to note both that these two studies differed in the scales they used to measure depression and that all studies used measures not commonly used in studies of depression in the general population. The four other studies provided only indirect evidence because the untreated group included a mixture of women with and without depression or other mood disorders.

Anxiety symptoms. No direct evidence was found; no studies examined anxiety symptom change in depressed pregnant women with and without treatment or comparing treatments. Indirect evidence comes from two studies with medium131 and high risk of bias145 that monitored anxiety and depression symptoms in depressed women taking SSRIs or SNRIs and made comparisons to women with and without mood disorders not taking antidepressants. Both studies used the Hamilton Rating Scale for Anxiety (HAM-A), as well as additional scales to measure anxiety. Anxiety scores were higher among women taking antidepressants compared with women not taking antidepressants. While there was a trend toward declining anxiety scores postpartum, it is unclear whether the declines were statistically significant.

Functional capacity. Only one medium risk of bias study122,189 provided direct evidence on functional capacity in pregnant women with depression with and without SSRI use. Women who were depressed continually throughout pregnancy and treated with an SSRI continuously throughout pregnancy had better functional capacity as measured by the mental component of the SF-12 compared with those that were depressed throughout pregnancy but untreated (45.2 +/- 13.7 compared with 35.3 +/- 11.4).189 Women treated with SSRIs for only part of their pregnancy had a mean score of 44.6, and those with depression in only part of their pregnancy but who received no SSRI had a mean score of 40.5 (on a scale of 1 to 100). A control group with no depression and no SSRI treatment had a mean score of 55.7. While the p-value across all groups was statistically significant (p<0.001), pairwise comparisons were not undertaken. Additionally, the specific timing of the SF-12 scores was not clear from the study report.

Pregnancy weight gain. We found no direct evidence on the effect of different treatments for depression on weight gain in pregnant women with depression. In a 1990 report,195 the Institute of Medicine recommended a maternal weight gain of 25 to 35 pounds for women with normal weight for height. Weight gain is associated both with the use of antidepressant drugs and with some forms of depression, and it can have a significant effect on maternal health; even so, there were only two medium risk of bias studies that addressed these associations. Both studies were indirect evidence because they included women treated with an SSRI for any reason and made comparisons to women who did not receive an SSRI (unknown depression status). Therefore, the strength of evidence was considered insufficient (see Appendix E, Table 2). A study of 5961 women reported mean weight gain during pregnancy, which was 33.4 pounds for non-SSRI users, 34.0 pounds for women who discontinued SSRIs two months before pregnancy, and 37.0 pounds for women who continued SSRIs through the first trimester. Although the group who continued SSRIs through the first trimester is the only group to have a mean weight gain in excess of the 1990 Institute of Medicine guidelines, the statistical significance of this difference is unknown.181 Another small study found that women in treated with fluoxetine gained an average of 37 +/- 15.4 pounds, which exceeds recommendations, but no data were available for the control group.71

Breastfeeding. No direct evidence was found on the effect of SSRIs used during pregnancy on breastfeeding outcomes postpartum.

Indirect evidence consisted of four prospective observational studies ranging in size from 44 to 466 women. These studies reported on breastfeeding rates among women taking SSRIs compared with the rates among women not taking SSRIs (depression status unknown in either group).66,69,99,115,166 All four studies had medium risk of bias due to potentially biased selection of patients and lack of controlling for potential confounding (e.g., not controlling for parity or prior experience breastfeeding). The best indirect evidence on breastfeeding came from a study of 168 pregnant women enrolled by 20 weeks gestation and assessed for breastfeeding intention, initiation, and breastfeeding up to 12 weeks postpartum.66 This study assessed depression symptoms at weeks 20, 30 and 36. The analysis controlled for depression symptoms and presence of a diagnosis of major depressive disorder, as well as parity and prior experience breastfeeding (factors known to be strongly associated with future breastfeeding). Intention to exclusively breastfeed was the most significant factor associated with breastfeeding initiation and duration. Neither depression symptoms nor symptom severity was associated with intention to breastfeed; however, there was a significant and negative association between SSRI use (for any reason) and intention to breastfeed compared with no antidepressant use in women with and without depression (relative risk reduction[RRR] 12.31; 95% CI 2.50-60.66) for intention to formula feed). There was also no association between diagnosis of major depressive disorder or depressive symptoms and initiation of breastfeeding. Furthermore, even though SSRI use at 2 weeks postpartum was associated with lower depression symptom scores, women taking SSRIs at 2 weeks postpartum were more likely to stop breastfeeding by 12 weeks (RRR 12.0; 95% CI 1.64-88.3) compared with women not taking SSRIs. This evidence was insufficient strength to draw conclusions for the questions posed in this report.

###### Infant/Child Outcomes: Birth Parameters

Preterm birth. Direct evidence on the risk of preterm birth was limited to two small observational studies (n=266 total) that provided low strength evidence that SSRIs had no statistically significant effect on rates of preterm birth (Figure 3).187,192 Both medium risk of bias studies reported preterm birth rates for depressed women treated with an SSRI during pregnancy compared with those who were depressed but did not receive an SSRI. In both studies, preterm birth was defined as delivery prior to the 37th week of gestation, and gestational age was based on ultrasound when available in one (proportion with ultrasound validation available not reported) 192 and no method reported in the other study.187,189 Pooled analysis resulted in an odds ratio of 1.87 (95% CI 0.89 to 3.89, Cochran Q = 0.089 p=0.77). The larger study (n=77 with depression) attempted to assess early preterm birth (delivery prior to 34 weeks gestation), but no births met this criterion for the group of women with depression and treated with an SSRI. 192

Figure 3 Risk of preterm birth (< 37 weeks gestation) with selective serotonin reuptake inhibitors compared with nonexposure

Figure 3 is a forest plot depicting the individual and pooled adjusted odds ratios and 95% confidence intervals fixed effects model) from two observational studies for risk ofpreterm birth with selective serotonin reuptake inhibitors taken during pregnancy compared with depressed women who did not take an antidepressant during pregnancy. Odds ratios were (95% confidence interval 0.63 to 3.40) for Yonkers 2012, and 2.21 (95% confidence interval 0.49 to 13.71 for Wisner 2013. The pooled estimate is not statistically significant; odds ratio 1.87 (95% confidence interval 0.89 to 3.89). There was no statistical heterogeneity in this meta-analysis (chi square for homogeneity P = 0.77).

There was a large volume of indirect evidence on the risk of preterm birth. Based on 11 observational studies, there was evidence of an increased risk of preterm birth (< 37 weeks gestation) birth with use of SSRIs during pregnancy in women with unknown depression status.81,95,100,107,117,118,138,167,180,184,189,192 The magnitude of risk may have varied by timing of exposure, but evidence was inadequate to establish reliable estimates. The most relevant of these studies was a medium risk of bias study that reported a statistically significant increased risk of preterm birth with SSRI use during pregnancy for any reason, compared with pregnant women with a documented psychiatric illness who did not receive an SSRI (or other antidepressant or antipsychotic drug) during pregnancy (adjusted odds ratio [OR] 2.68; 95% CI 1.83 to 3.93).100 While this study did not limit the diagnoses to depression, gestational age was determined by ultrasound. This study adjusted for several key factors, including history of prior preterm birth, but it did not adjust for severity or type of psychiatric illness.

Four studies provided some information on the effect of timing of exposure to an SSRI during pregnancy.100,117,118,138 These studies performed ultrasound verification of gestational age, defined preterm birth as delivery at less than 37 weeks gestation, and found an increased risk of preterm birth. A single study found the risk with early exposure to be extremely increased (adjusted OR 11.7; 95% CI 2.20 to 60.70); a second study found increased risk with late exposure (adjusted OR 2.48; 95% CI 1.75 to 3.50). Pooling the two studies reporting exposure at any time during pregnancy also resulted in a statistically significant, but lower, increase in risk (pooled adjusted OR 1.24; 95% CI 1.12 to1.38).

Evidence on the risk of preterm birth with individual SSRIs was very limited, with few studies for each drug. None of these studies made comparisons of pregnant women with depression and therefore only provide indirect evidence for the risk in such women. The estimate of risk was highest with citalopram and escitalopram,76,111,172,173 with non-statistically significant increase in risk with fluoxetine,71,76,84,153 sertraline76,172 and paroxetine71,76,84,107,111,153,172,173 but all of the estimates are likely to shift with additional studies, particularly those that control for potential confounders.

Growth for gestational age. Evidence on the risk for an infant to be small for gestational age at birth following maternal treatment for depression with an SSRI during pregnancy was insufficient because there was no direct evidence available. To determine whether SSRIs influence infant growth, it is necessary to understand whether depression in pregnancy itself influences infant growth parameters.

The best indirect evidence came from two of the five studies using ultrasound confirmation of gestational age.93,100 A study from Denmark identified three groups of women, those with depressive symptoms but who received no pharmacological treatment, women who took SSRIs (indication for the SSRI not recorded), and a control group of pregnant women not depressed and not taking an SSRI.93,100 This study did not report the outcome of small for gestational age for the group with depression, but it did report the outcome of head circumference at birth. This study found no statistically significant difference in head circumference between the depressed, untreated group and controls, but it did find a difference when comparing the group taking an SSRI for any reason with controls (−5.88 millimeters; 95% CI −11.45 to −0.30). A study that included women with a psychiatric illness who did not receive an antidepressant or an antipsychotic treatment during pregnancy compared with a group of similar women who were taking an SSRI did not find an increased risk with use of SSRIs late in pregnancy (adjusted OR 1.13; 95% CI 0.65 to 1.94). This study did not adjust for severity or type of mental illness.

Eleven other medium and high risk of bias observational studies reported on infants small for gestational age; these studies compared women taking an SSRI during pregnancy for unknown reasons with pregnant women not taking an SSRI (depression status unknown) .93,95,100,107,110,118,142,145,162,181,193 Only five of these studies used ultrasound to determine gestational age,93,95,100,110,118 and four reported odds ratios adjusted for confounding factors. ,93,95,100,110,118 These studies did not find an increased risk of an infant being small for gestational age (adjusted pooled OR of 1.04; 95% CI 0.64 to 1.69; I^2^=30%) with SSRI use during pregnancy.

###### Infant/Child Development

Bayley development assessments. Direct evidence from a very small (n=44) medium risk of bias study of children of women who were depressed during pregnancy and were treated with an SSRI or taking no antidepressant provided insufficient evidence on neonatal development. Both groups received “supportive psychotherapy” (no further details reported), and Beck Depression Inventory maximum scores were 24.0 in the untreated group and 21.3 in the treated group (on a scale of 0 to 63), p=0.58 at baseline.69,178 At 6–40 months of age, Bayley Scales for Infant Development, 2^nd^ Edition, scores were not statistically significantly different between groups on the mental development index (MDI) or the behavioral rating scale (BRS) portions of the Bayley after adjusting for APGAR scores. Ratings on the psychomotor development index (PDI) portion of the Bayley indicated lower scores in the SSRI-exposed group compared with the group whose mothers were depressed but not treated with an SSRI (90.0 versus 98.2, p=0.02). Examining the BRS factor scales found the motor quality factor to be lower in the SSRI-exposed group (68.6 versus 88.8, p=0.05).

We found indirect evidence from a small medium risk of bias study (n=84) of children at 10 months of age who had been exposed to SSRIs compared with those who were not exposed in-utero; this study reported that after adjusting for depression, scores on the gross motor, social-emotional and adaptive behavior subscales were significantly lower in the exposed children.102 The absolute differences were small and clinical relevance was not clear (e.g. gross motor scores 9.5 versus 8.3). Depression scores in the women who did not receive antidepressants were significantly lower than scores in the treated group. The study also analyzed outcomes for children whose mothers were depressed compared with those who were not and found no difference between groups. In contrast, two other studies found no difference between groups, but they did not control for depression among mothers during or after pregnancy.^62Reebye, 2002 #3454164^ Another study assessed development of children born preterm (< 37 weeks),using the Bayley scale at 36 months of age; the study compared those exposed to SSRIs during pregnancy to children whose mothers did not take an SSRI (depression status unknown).62 This medium risk of bias study (n=38) did not find differences between groups on the MDI or PDI. The other study was a small medium risk of bias study (n=61) of children, 24 of whom were exposed to SSRIs prenatally compared with 23 children born to mothers with unknown depression status who did not receive an SSRI during pregnancy and 14 whose mothers took an SSRI plus another psychoactive drug.166 This study found no difference in the MDI or PDI scores across groups.

Brazelton Neonatal Behavioral Assessment Scale (BNBAS) assessments. Direct evidence from a single small study of neurobehavioral outcomes in infants was insufficient to draw conclusions. Using the Brazelton Neonatal Behavioral Assessment Scale (BNBAS), neurobehavioral assessments for young infants exposed to SSRIs during at least second and third trimester (n=33) were recorded at 1 week and again at 6-8 weeks by blinded trained raters.178 Differences were not seen in children exposed to SSRIs compared with children of depressed mothers without antidepressant exposure (no antidepressants, discontinued antidepressants in first trimester, or <10 days, n=16).

Language development. The best indirect evidence on language development came from a medium risk of bias study in which children 15–71 months who were exposed prenatally to TCAs (n=45) or fluoxetine (n=38) were compared with children of nondepressed women (n=34), using the Reynell Verbal and Expressive Language Scales.141 Scores for all three groups were within the normal range, but children in the TCA group scored higher than those in the fluoxetine or nonexposed group on Reynell Developmental Language Scales. This study measured McCarthy cognitive development scores but missing data made this outcome high risk of bias.

Developmental milestones. The best indirect evidence on achievement of developmental milestones at 6 months was available from a medium risk of bias study that compared children exposed in utero to antidepressants (n=415; 81%=SSRIs, 3%=TCAs) with children of mothers with untreated depression during pregnancy (n=489) and children of women not receiving an antidepressant during pregnancy and not identified as being depressed by study methods.158 This study used maternal interviews at 6 months and 19 months after delivery to obtain assessments of milestone achievement, and information about depression was obtained from two prenatal interviews. At 6 months, children with antidepressant exposure at any time during pregnancy had greater risk of not achieving milestones compared with children of mothers with untreated depression during pregnancy (OR 1.5; 95% CI 1.1-2.0)]. A similar increase in risk was found for those with exposure in the second or second and third trimesters compared with untreated depression (OR 2.6; 95% CI 1.2-5.8)], while exposure only in the first trimester was not statistically significant (OR 1.1; 95% CI 0.6-2.1). At 19 months, there was no difference between the groups in the risk of not meeting one or more milestones. Analysis of the effect of specific types of antidepressants found no differences at 6 months, but on retrospective recall at 19 months, the group exposed to SSRIs in utero was found to have longer days to sitting or walking unassisted; however, the reported days to sit and/or walk for all groups were within the normal range of development.

Motor and speech delays. In a medium risk of bias retrospective study, motor and speech delays in children exposed to antidepressants in utero were compared with children of women who did not take antidepressants during pregnancy (depression status of mothers in either group unknown).171 Delays were identified by blinded chart review and required physician diagnosis confirmed by a formal developmental evaluation in the course of routine clinical care. No statistically significant differences were found in motor delays or speech delays and SSRI exposure (OR 3.07; 95% CI 0.61-15.40 and OR 1.0; 95% CI 0.14-7.18), respectively). Another study providing indirect evidence examined neonates neurological functioning by assessing the quality of an infant's general movements (Precht method), finding more “abnormal movements” in the SSRI group at 1 week of age (3.0; 95% CI 1.3 to 6.9) after controlling for maternal depression. Depression scores in the third trimester were significantly lower in the non-SSRI group. It does not appear that outcome assessment was conducted with blinding to SSRI exposure.

Early childhood behavioral outcomes. In a medium risk of bias follow-up study of a cohort of children exposed to antidepressants during gestation (n=127) and children whose mothers had depression during pregnancy but no antidepressant exposure (n=98), the Strengths and Difficulties Questionnaire (SDQ) was used to assess behavior at age 4 to 5 years. 157 No difference was found on the overall scores between treated and untreated groups, (any antidepressant compared with untreated depression OR 1.3; 95% CI 0.3 to 6.0). Results are reported to be similar for SSRIs, odds ratio not reported.

Autism spectrum disorders. No direct evidence on the risk of different treatments for depression during pregnancy on development of autism spectrum disorders in the child was found.

We found indirect evidence in two large case-control studies (n=1,805; n=47,656, respectively), which reported the risk of ASD in offspring of mothers who used SSRIs during pregnancy.79,161 Both used health system databases, one in the United States79 and the other in Sweden.161 The Swedish study161 was rated low risk of bias and the U.S. study79 was rated moderate risk of bias. Both studies adjusted for maternal age and mental health disorders and the Swedish study additionally adjusted for paternal age.161 Only the U.S. study adjusted for child's sex.79 Neither adjusted for family history of ASD or prematurity, both factors known to be strongly associated with ASD. These studies find that maternal SSRI use at any time during pregnancy is statistically significantly associated with an increased risk of autism spectrum disorder in offspring (pooled adjusted OR 1.82; 95% CI 1.14 to 2.91). The U.S. study additionally evaluated whether risk of ASD varied based on exposure period and found that the risk only reached statistical significance during the first trimester (adjusted OR 3.5; 95% CI 1.5 to 7.9), and not during the preconception period (adjusted OR 1.9; 95% CI 0.9 to 4.2), the second trimester (adjusted OR 1.5; 95% CI 0.5 to 5.0) or the third trimester (adjusted OR 2.2; 95% CI 0.7 to 6.9).79

In one of these studies, results of subgroup analyses suggested that depression itself may contribute to ASD diagnosis. Compared with the risk for ASD in children of pregnant women without depression or antidepressant use, the risk for ASD in the children of pregnant women with depression and antidepressant use was statistically significantly elevated (OR 3.34; 95% CI 1.50 to 7.47). In contrast, the risk in pregnant women taking an antidepressant for another indication was lower than the risk in children of pregnant women without depression or antidepressant use and not statistically significant (OR 1.61; 95% CI 0.85 to 3.06).

###### Education and Learning

We found no evidence on school performance or educational outcomes. Observational studies were found comparing maternal antidepressant exposure compared with nonexposure and risk of lowered intelligence testing results in their children. Indirect evidence on SSRIs and intelligence testing is based on two observational studies that assessed childhood intelligence by performance on standardized testing and compared exposure to antidepressants compared with nonexposure.139,146 Both were high risk of bias observational studies.

###### Illness Outcomes

We did not find evidence on the risk of stress related chronic disease in children associated with maternal SSRI use during pregnancy. We found evidence on the risk of developing ADHD or having internalizing or externalizing behaviors, reported below.

Attention deficit hyperactivity disorder (ADHD). No direct evidence on the risk of different treatments for depression during pregnancy on development of ADHD in the child was found. One retrospective cohort study with medium risk of bias assessed ADHD diagnoses by age 5 years using a large national claims-based dataset from self-insured employers,96 providing indirect evidence as a mental health diagnosis was identified in only 33 percent of women, including 10 percent with a depressive disorder and 5 percent with an anxiety disorder. After multiple logistic regression analysis, risk of diagnosis with ADHD in children born to women who used bupropion, SSRIs, or any other antidepressant during or after pregnancy was compared with women not exposed during pregnancy. SSRI use at any time during pregnancy was not associated with increased risk of ADHD in offspring (OR 0.91; 95% CI 0.51 to 1.60), but use after pregnancy (up to four years post-delivery) was associated with increased risk of ADHD diagnosis (OR 2.04; 95% CI 1.43 to 2.91). No breastfeeding data were provided to determine whether direct exposure may have occurred. Children of mothers with depressive disorders had statistically significantly higher risk of ADHD at age 5 than those without (OR 2.58; 95% CI 2.02 to 3.29).

We identified two additional high risk of bias studies that reported on ADHD symptoms.139,146 Neither study found an association between exposure to SSRIs in utero (n=22) and ADHD symptoms in offspring compared with nonexposed, presumed nondepressed groups.

Internalizing behaviors. No direct evidence on the risk of internalizing behaviors in the child with different treatments for depression during pregnancy was found. Internalizing behaviors are described as behaviors directed internally or “within the self”. They include emotional reactivity, depression, anxiety, irritability and withdrawal.

Three observational studies provide indirect evidence. One of medium risk of bias133 and two of high risk of bias139,145 reported on outcomes of children exposed to SSRIs and venlafaxine in utero. Levels of internalizing behaviors were assessed by maternal and teacher/caregiver reports in 36 children aged 4 to 5 years exposed to SSRIs and/or clonazepam prenatally.133 Mothers rated their children on the Child Behavior Checklist (CBCL) and teachers/caregivers rated children using the Child-Teacher Report Form (C-TRF). Maternal mood and anxiety was assessed by the Hamilton Rating Scale for Depression (HAM-D) and HAM-A. No statistically significant differences in internalizing behaviors were found in maternal or caregiver/teacher ratings of children at 4-5 years exposed to SSRIs during pregnancy compared with nonexposed controls [OR (95% CI) HAM-D 1.53 (0.24-9.85);HAM-A 2.89 (0.29-28.90)]. This remained true when controlled for maternal depression [OR (95% CI) HAM-D 0.99 (0.13-7.88); HAM-A 2.85 (0.26-31.20)]. However, increased maternal but not teacher reports of internalizing behaviors were associated with maternal depression (p<0.05) and anxiety (p<0.05).

Both high risk of bias studies found increased risk of internalizing behaviors associated with SSRI use during pregnancy compared with general nonexposed populations, but both also found that the increase was correlated with maternal depression.139,145

Externalizing behaviors. We found no direct evidence on the risk of externalizing behaviors in the child with different treatments for depression during pregnancy. Externalizing behaviors (noncompliance, verbal/physical aggression, disruptive acts, and emotional outbursts) are described as behaviors which are “directed outward”. The presence of these behaviors may herald a diagnosis of externalizing disorders such as ADHD, oppositional defiant disorder (ODD) and/or conduct disorder (CD). Indirect evidence comes from three observational studies, but all are high risk of bias, and are not described further.139,145,146

###### Health Care Utilization

We found no direct evidence on health care utilization among children born to mothers with depression during pregnancy, comparing those treated with antidepressants to those not treated, or comparing antidepressants. Indirect evidence, based on one medium risk of bias observational study (n=38,602), suggests that antidepressant use (primarily SSRIs, 71%) is associated with increased health care utilization among children born to women who were prescribed SSRIs during pregnancy compared with nonexposed children (Table 3).182 The depression status of mothers was not reported. For continuous SSRIs exposure during pregnancy the risk was increased for several markers of resource utilization both during the first two weeks and the first year of life, including a two-fold increase in the utilization of physiotherapy. Intermittent use of SSRIs during pregnancy was also associated with increased risk for some measures, primarily in the first year of life and the risk for those who discontinued an antidepressant during pregnancy; only risks for increased risk during the first two weeks of life were statistically significant.

Table 3 Association between antidepressant use during pregnancy and general practitioner visits and hospital admissions; unadjusted relative risk (95% confidence interval)182,*

N = 38,602 | First 2 Weeks After Birth | | | First Year After Birth
Antidepressant Use | Continuous | Intermittent | Discontinued | Continuous | Irregular
≥ 1 GP visits | NS | NS | 1.3 (1.2 to 1.5) | -- | --
>2 GP visits | -- | -- | -- | 1.5 (1.3 to 1.8) | 1.2 (1.1 to 1.4)
1 hospital admission | NS | NS | 1.3 (1.1 to 1.7) | NS | NS
≥ 2 Hospitalizations | 2.4 (1.8 to 3.1) | 1.4 (1.1 to 1.8) | 1.4 (1.1 to 1.9) | NS | 1.5 (1.1 to 2.1)
1 specialist visit | 1.3 (1.1 to 1.5) | 1.2 (1.0 to 1.3) | | 1.4 (1.1 to 1.8) | NS
>2 specialist visits | 2.4 (1.7 to 3.3) | NS | 1.2 (1.1 to 1.4) | 1.5 (1.2 to 1.9) | 1.4 (1.2 to 1.6)
1 specialist procedure | 1.5 (1.2 to 1.8) | 1.1 (1.0 to 1.3) | | 1.6 (1.3 to 2.0) | NS
>2 specialist procedures | 1.7 (1.1 to 2.6) | NS | | NS | 1.3 (1.1 to 1.5)
2 diagnostic tests | 1.9 (1.4 to 2.5) | NS | | NS | NS
Physiotherapy | -- | -- | -- | 2.0 (1.5 to 2.6) | 1.3 (1.1 to 1.7)

GP = general practitioner; NS = not significant

* Results are in bold type where they are statistically significant

###### Tricyclic Antidepressants

###### Maternal Outcomes

We found no evidence for maternal outcomes with the use of TCAs during pregnancy.

###### Infant/Child Outcomes

Preterm birth. No direct evidence on the effect of different treatments for depression on preterm birth in women with depression during pregnancy was found.

Indirect evidence based on two observational studies indicates an increased risk of preterm birth with exposure to TCAs during pregnancy for any reason, compared with pregnant women who were not treated with TCAs (depression status unknown for both groups).81,167

Growth for gestational age. We found no direct evidence on the effect of different treatments for depression on fetal growth in women with depression during pregnancy.

Indirect evidence indicated no increased risk for the infant to be small for gestational age at birth with exposure to TCAs for any reason compared with pregnant women who were not treated with TCAs (depression status unknown for both groups), based on two medium risk of bias studies.107,162 The pooled adjusted OR for exposure at any time point during pregnancy is 0.97 (95% CI 0.64 to 1.46), with no statistical heterogeneity. One of the studies reported the rates of a depression diagnosis in the treated and untreated group (46% and 36%, respectively). This study also evaluated the result by timing of exposure (first, second or third trimester) and found no statistically significant increase in risk for any of these time points.

###### Child Development

We found no direct evidence on the effect of maternal treatment with TCAs for depression during pregnancy on infant and child development. Indirect evidence was limited to three observational studies reporting on comparisons of children whose mothers took TCAs during pregnancy for any reason, compared with children whose mothers did not take TCAs; depression status was unknown for both groups.141,158,171

The best indirect evidence on developmental milestones came from a medium risk of bias study (described above regarding SSRI use).158 Adjusted odds ratios (days) were calculated for maternal report of sitting without support (at 6 months interview) for TCA exposure at any point during pregnancy. No statistically significant differences were found for exposure to TCAs (OR 2.9; 95% CI 0.89-9.51) at any point in pregnancy, nor were there differences with 1st or 2nd/3rd trimester exposure. On retrospective recall at 19 months, statistically significant delays with TCA exposure were also not found. The best evidence on motor and speech delays comes from a medium risk of bias retrospective study of children exposed to antidepressants in utero who were compared with children of women who did not take antidepressants during pregnancy (depression status of mothers in either group unknown).171 Delays were identified by blinded chart review and required physician diagnosis confirmed by a formal developmental evaluation in the course of routine clinical care. No statistically significant differences were found with motor or speech delays and TCA exposure (OR 1.0; 95% CI 0.14-7.17) Another study of language development used the Reynell Verbal and Expressive Language Scales.141 Scores for children 15-71 months exposed prenatally to TCAs (n=45) or fluoxetine (n=38) were compared with children of nondepressed comparison women (n=34). All three groups scored within the normal range. Children in the TCA group scored higher than those in the fluoxetine or nonexposed group on Reynell Developmental Language Scales.

Autism spectrum disorder. We found no direct evidence on the risk of different treatments for depression during pregnancy on development of autism spectrum disorders in the child.

Indirect evidence was found in two large case-control studies (n=1,805; n=47,656, respectively) reported the risk of ASD in offspring of mothers who used antidepressants, including TCAs, described in detail in the section on SSRIs, above.79,161 These studies included subgroups of women exposed to either TCAs or TCAs/SNRIs (as a group). In the study examining TCAs as a group (n=6 cases, n=20 controls), there is indirect evidence that maternal use of TCAs during pregnancy is statistically significantly associated with an increased risk of autism spectrum disorder in offspring (adjusted OR 2.69; 95% CI 1.04 to 6.96).161 This study was rated low risk of bias and adjusted for any maternal psychiatric disorder, maternal age, paternal age, parental income, education, occupation, maternal country of birth, and birth parity. It did not adjust for family history of ASD or prematurity, both factors known to be strongly associated with ASD.

The other study included SNRIs with their analysis of TCAs (n=5 cases, n=16 controls).79 Adding SNRIs to the group resulted in a nonstatistically significant associated increase in risk of ASD (adjusted OR 1.6; 95% CI 0.5 to 4.5). This study was rated moderate risk of bias and provides indirect evidence for this outcome, adjusting for maternal age, race/ethnicity, maternal education, birth weight, sex, birth year of child and birth facility, but not family history of ASD or prematurity, both factors known to be strongly associated with ASD.

###### Selective Norepinephrine Reuptake Inhibitors and Norepinephrine Reuptake Inhibitors

###### Maternal Outcomes

We found no evidence for maternal outcomes with the use of SNRIs/NRIs during pregnancy.

###### Child Outcomes

Preterm birth. We found no direct evidence on the effect of different treatments for depression on preterm birth in women with depression during pregnancy.

Indirect evidence, based on two medium-risk of bias observational studies, indicates an increased risk of preterm birth associated with use of an SNRI/NRI (including bupropion for one study) during pregnancy for any reason (adjusted OR 1.79, 95% CI 1.46 - 2.19).118,167 These studies compared birth outcomes of women treated with an SNRI or NRI during pregnancy to pregnant women who were not treated with an SNRI or NRI; depression status of either group was not analyzed.

Growth for gestational age. We found no direct evidence on the effect of SNRIs or NRIs for depression on having an infant that is small for gestational age in women with depression during pregnancy. Indirect evidence was limited to two studies, one of venlafaxine162 and the other including any SNRI or NRI, both with comparison with infants of mothers not receiving an SNRI or NRI during pregnancy but with no known depression.118 These studies had results in opposite directions. The reason for the discrepancy may simply be inadequate sample sizes – the larger study, the analysis of SNRI or NRI included only 27 exposures,118 and the smaller study included only five exposures to venlafaxine.162

Education and learning. No direct evidence on the effect of SNRI/NRIs for depression on education or learning outcomes in children of women with depression during pregnancy was found. Indirect evidence regarding prenatal SNRI exposure and subsequent intelligence testing in offspring is limited to one high risk of bias observational study, described in detail above (under SSRIs).139

###### Illness Outcomes

We did not find evidence on the risk of stress related chronic disease in children associated with maternal SNRI use during pregnancy. We found evidence on the risk of developing ADHD, internalizing or externalizing behaviors, or mental illness, reported below.

Internalizing behaviors. No direct evidence on the risk of internalizing behaviors and exposure to an SNRI/NRI during pregnancy was found. Indirect evidence was found to determine an effect of SNRI exposure during pregnancy on internalizing or externalizing behaviors in offspring compared with nonexposed children. Increased internalizing behaviors reported by mothers using the CBCL (n=178) correlated with severity of maternal depression during pregnancy and at time of testing, not maternal venlafaxine treatment in pregnancy. Depression in pregnancy and at time of testing, not exposure to venlafaxine, predicted externalizing behaviors as reported by mothers on the CBCL.139

###### Other Antidepressants: Bupropion

###### Infant/Child Outcomes

Attention deficit hyperactivity disorder. We found no direct evidence on the effect of bupropion for depression on the risk of children of women with depression during pregnancy developing ADHD. One retrospective cohort study with medium risk of bias provides indirect evidence on the risk of ADHD in children of women exposed to bupropion during pregnancy. This study assessed ADHD diagnoses by age 5 years using a large national claims-based dataset.96 A mental health diagnosis was identified in only 33 percent of women, including 10 percent with a depressive disorder. After multiple logistic regression analysis, risk of diagnosis with ADHD in children born to women who used bupropion, SSRIs, or any other antidepressant during or after pregnancy was compared with children of women who did not take any antidepressant during pregnancy. Exposure to bupropion at any time during pregnancy was associated with increased risk of ADHD diagnosis in children (OR 3.63; 95% CI 1.20 to 11.04), in particular for exposure during the second trimester (OR 14.66; 95% CI 3.27 to 65.73), but not first or third trimesters (OR 2.06; 95% CI 0.35 to 12.16; OR=<0.01, <0.01 to >99.9, respectively).

##### Postpartum Exposure

###### Selective Serotonin Reuptake Inhibitors

###### Maternal Outcomes

We found one high risk of bias placebo-controlled RCT of paroxetine in women who were depressed in the postpartum period.191 The trial was small (70 women enrolled and 31 completed) and short-term (8 weeks). This is the only direct evidence for maternal outcomes of treatment for depression in the postpartum period. Additionally, there was indirect evidence from a medium risk of bias observational study that compared treatment with citalopram during pregnancy and up to 2 months postpartum with pregnant and postpartum women who did not receive an SSRI (depression status unknown).103

Danger to self or infant. Evidence on the risk of danger to self or infant while being treated for depression with an SSRI is insufficient. The small, high risk of bias RCT reported zero such events.191

Depression symptomatology. Evidence on the effect of SSRIs on depressive symptoms in the postpartum period is insufficient to draw conclusions. Only one RCT with high risk of bias compared depression symptom improvement during the postpartum period, between paroxetine and placebo.191 Response at week 8 was defined as a Clinical Global Impression-Improvement (CGI-I) of 1 or 2 with 43 percent (n=15/35) of the paroxetine group achieving response as compared with 32 percent (n=11/35) of the placebo group (OR 1.31; 95% CI 0.50 to 3.41). Remission by week 8 as defined as a rating of <8 on the 17 Item Hamilton rating Scale for Depression (HAM-D-17) was significantly improved for women taking paroxetine with 37 percent achieving remission in the paroxetine group and 14 percent in the placebo group (OR 3.54; 95% CI 1.10 to 11.41).

###### Delivery and Postpartum Parameters

Breastfeeding. Evidence on the effect of SSRI treatment for depression during the postpartum period on breastfeeding outcomes is insufficient as there is no direct evidence available. Indirect evidence from one very small observational study (n=21) comparing women who took citalopram to during pregnancy and in the postpartum period (for any reason) to women who did not (depression status not reported) reported equal numbers of mothers breastfeeding in both groups (n=9) and so there is no significant difference between groups (OR 0.91; 95% CI 0.26 to 3.20).103

#### Key Question 1b How do pharmacological treatments affect maternal and child outcomes when compared with each other (drug A vs. drug B)?

##### Pregnancy Exposure

###### Maternal Outcomes

We found no evidence for maternal outcomes comparing antidepressants to each other for depression during pregnancy.

###### Child Outcomes

Preterm birth. No direct evidence was available comparing one antidepressant to another in women with depression during pregnancy. Three studies provide indirect evidence for risk of preterm birth in women taking specific SSRIs compared with other SSRIs in women taking the drugs during pregnancy. A single high risk of bias study (n = 809) provides opportunity to compare paroxetine and fluoxetine, where no difference between the drugs was found.84 Additionally, two studies compared citalopram or escitalopram with “other SSRIs”; the unadjusted pooled estimate from these studies is 1.26 (95% CI 0.54 to 2.96).172,173 These are small studies, one high risk of bias and one medium.

Growth for gestational age. No direct evidence was available comparing one antidepressant with another in women with depression during pregnancy. Indirect evidence was limited to one medium risk of bias study reporting the risk of having an infant that is small for gestational age at birth for any specific drug compared with other drugs.107 The risk with paroxetine treatment during pregnancy compared with other SSRIs was an adjusted odds ratio of 0.9 (95% CI 0.09 to 4.34).

##### Postpartum Exposure

###### Maternal Outcomes

The evidence comparing one antidepressant with another in women with depression during the postpartum period is insufficient to draw conclusions for maternal outcomes. We found one small RCT (n=109) that compared sertraline with nortriptyline in treating depression in postpartum women.188 Additionally, there are two publications of post-hoc analyses using data from this trial.116,121 The study was high risk of bias, due to unclear allocation concealment, dissimilarity of groups at baseline and high levels of overall attrition. See Appendix D for strength of evidence ratings for selected outcomes. There was also no difference between the groups in response or remission rates; by week 8 the proportions with either response or remission were 69 percent in the sertraline group, and 73 percent in the nortriptyline group. In a post-hoc analysis using a subset of the data (n=70), no difference in breastfeeding rates between the sertraline and nortriptyline was found (OR 2.78; 95% CI 0.86-8.94).116 No information in intention to breastfeed or baseline breastfeeding status is presented.

#### Key Question 1c How do pharmacological treatments affect outcomes when compared with active nonpharmacological treatments?

No evidence was found for this question in either pregnant or postpartum women.

#### Key Question 1d How does combination therapy affect maternal and child outcomes?

##### 1 Using a Second Drug To Augment the Effects of the Primary Drug and Comparing This Treatment With Monotherapy With a Single Drug

###### Pregnancy Exposure

###### Maternal Outcomes

No evidence was found for maternal outcomes for this question.

###### Child Outcomes

We found no direct comparative evidence on the benefits to children of combination pharmacological treatment for maternal depression during pregnancy. Indirect evidence from observational studies comparing results for children of women taking combination antidepressant therapy during pregnancy for any reason with women who did not take an antidepressant during pregnancy, but with unknown depression status was found.

The best indirect evidence on the risk of preterm birth with combination therapy with an antidepressant during pregnancy comes from a single observational study that reported a non-statistically significant unadjusted odds ratio of 1.3 (95% CI 0.5 to 3.33) for comparison of using two drugs (one SSRI and a second antidepressant from a different class) with use of a single SSRI. 92

Indirect evidence on combination antidepressant therapy during pregnancy and having an infant that is small for gestational age is limited to a single observational study.162 Although this study was medium risk of bias, it is important for this outcome that the method used to determine gestational age was not reported. Seventy percent were taking an SSRI in combination with a non-SSRI drug. In women who took two antidepressants in the second trimester, there was an increased risk of having a small for gestational age infant compared with women who did not take an antidepressant during pregnancy (ARR = 3.48; 95% CI 1.56 to 7.75).

##### 2 Combining Pharmacological Treatments With Nonpharmacological Treatments and Comparing Them With Nonpharmacological Treatments Alone

###### Postpartum Exposure

###### Maternal Outcomes

Direct evidence on maternal outcomes with combination pharmacological and nonpharmacological treatments for depression during the postpartum period compared with nonpharmacological treatments alone is insufficient to draw conclusions due to limited, inconsistent evidence. We found three small RCTs,58,65,69 rated medium risk of bias, and one small observational study,155 rated high risk of bias, that compared combining pharmacologic treatments with nonpharmacological treatments and comparing them with nonpharmacological treatments alone. All of the studies focused on the postpartum period only and reported on depression symptoms. See Appendix D for strength of evidence ratings.

Depression symptomatology. Two RCTs compared a nonpharmacological treatment combined with an SSRI with the nonpharmacological intervention alone. A medium risk of bias RCT (n=40)65 compared sertraline and brief psychodynamic psychotherapy with psychotherapy alone, finding no statistical differences in the rate of response (>50% reduction in either the Montgomery Asberg Depression Rating Scale [MADRS] or Edinburgh Postnatal Depression Scale [EPDS] scores) over 8 weeks of treatment (70% in the combination group and 50 percent psychotherapy only group, OR 1.91; 95% CI 0.52 to 7.00). Similarly, there was no statistically significant difference in remission (defined as final score on the MADRS of <10 or the EPDS <7) at week 8 (combination group 65T and psychotherapy only group 50%, OR 3.09; 95% CI 0.78 to 12.14). At week 12, the combination group had a remission rate of 94 percent and the psychotherapy only group had a rate of 82 percent (OR 3.64; 95% CI 0.34 to 39.02).

The other small (n=86) trial randomized women with depression six to eight weeks after delivery to fluoxetine plus cognitive behavioral counseling (one or six sessions) compared with counseling alone (one or six sessions). 58 Scores > 12 on the Revised Clinical Interview Scale (CIS-R) and the EPDS were considered clinically important morbidity and ‘mild depression’ was defined as a score of 8-17 on the HAM-D. Analysis based on study completers, few differences were found between groups with all but the single counseling session reducing symptoms. However, because the drop-out rate was high, 30 percent, the results based on intention to treat analysis are different - only the fluoxetine plus one or six counseling sessions had CIS-R scores less than 12 at week 12. The two counseling alone groups did not have scores less than 12 at any time point. This pattern held true for the analysis of EPDS scores. For the HAM-D at week 12, only the single session of counseling did not have a mean score less than 8.

Breastfeeding. Direct evidence on the effect of different treatments for depression used in combination with nonpharmacological treatments compared with nonpharmacological treatments alone on breastfeeding outcomes in women with depression during pregnancy comes from a single observational study and is insufficient to draw conclusions.69 In this very small (n=44) medium risk of bias study women with major depressive disorder (based on DSM-IV criteria) were enrolled and two groups were identified: those taking an SSRI during pregnancy and those who were not taking a pharmacologic treatment. Both groups received what is described only as “supportive psychotherapy” with no further details reported. No details on the psychotherapy received were reported. The duration of breastfeeding was two months longer in the untreated group (8.5 months) compared with the group treated with an SSRI (6.4 months, p = 0.4), but the difference was not statistically significant.

A high risk of bias observational study155 compared sertraline plus interpersonal psychotherapy (IPT) with IPT alone in postpartum women, which also included a third sertraline only group. This was a small observational study (n=23) with high loss to followup and high risk of bias.

##### 3 Comparing Pharmacological Treatments Alone With Pharmacological Treatments Used in Combination With Nonpharmacological Treatments

###### Postpartum Exposure

###### Maternal Outcomes

Direct evidence was insufficient to draw conclusions, based only on one small medium risk of bias RCT132 and one small high risk of bias observational study155 that compared SSRI treatment (as a class or as an individual drug) with pharmacological treatments used in combination with nonpharmacological treatments. The observational study was high risk of bias due to high overall and differential loss to followup and potentially inadequate handling of confounders.155 Both of the studies focused on the postpartum period only and both concluded that all treatment groups produced reduction in depression symptomatology compared with baseline. Please see Appendix D for strength of evidence ratings for selected outcomes. The RCT132 compared 16 postpartum women on paroxetine with 19 on paroxetine plus cognitive behavioral therapy. It was a small study with high loss to followup. There was no difference in response between the two groups on either the HAM-D (OR 1.87; 95% CI 0.29 to 11.84) or on the EPDS (OR 1.71; 95% CI 0.36 to 8.16). The response rate at the last visit on the HAM-D was 87.5 percent in the paroxetine only group verses 78.9 percent in the combination group and on the EPDS it was 50 percent compared with 58.3 percent. With anxiety symptoms, there was no difference in response between the two groups on either the HAM-A (OR 1.12; 95% CI 0.16 to 7.82) or on the YBOCS (OR 0.72; 95% CI 0.19 to 2.77).

The high risk of bias observational study155 comparing sertraline with sertraline plus interpersonal psychotherapy (IPT) in postpartum women. This was a small observational study (n=23) with high loss to followup and high risk of bias. Those who completed the study experienced significant overall improvement and in an analysis of covariance comparing outcomes on the HAM-D, Beck Depression Inventory, and EPDS, controlling for pretreatment depression, no differences in outcome were identified between the IPT and IPT plus sertraline.

## Key Question 2 What are the comparative harms of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

### Summary

- Direct evidence was sparse on the maternal and infant/child harms associated with pharmacological and nonpharmacological treatment for depression during pregnancy and the postpartum period.
  ○ Direct evidence provided sufficient data to draw the following low-strength conclusions:
    ■ Results from one observational study with medium risk of bias (n=107,877) suggest that infants of depressed mothers treated with SSRIs during pregnancy do not have a statistically significantly higher risk of convulsions than those of depressed mothers not treated with medication (0.14% compared with 0.11%; risk difference 0.0005; 95% CI −0.0015 to 0.0025).
    ■ Consistent results from three medium risk of bias observational studies (n=15,793) suggest that, compared with untreated maternal depression during pregnancy, SSRI treatment is associated with a statistically significant increase in risk of respiratory distress in infants (pooled unadjusted OR 1.91; 95% CI 1.63 to 2.24; I^2^ = 0%).
  ○ Direct evidence provided insufficient data to support conclusions on the following additional harms due to methodological limitations, unknown consistency and imprecision:
    ■ Major malformations:
      - One small medium risk of bias observational study (n=62) compared the effects of SSRIs with no treatment of depression during pregnancy.
      - One small medium risk of bias observational study (n=44) compared the effects of SSRIs plus psychotherapy with psychotherapy alone for depression during pregnancy.
    ■ Respiratory distress: One small medium risk of bias observational study (n=21) compared the effects of SSRIs with TCAs when used to treat depression during pregnancy.
    ■ Overall adverse events and withdrawals due to adverse events in babies of breastfeeding mothers:
      - One RCT with high risk of bias (n=109) compared risk between women taking either sertraline or nortriptyline for postpartum depression.
      - One small observational study with high risk of bias (n=23) compared risk between women treated with either sertraline or interpersonal psychotherapy for postpartum depression.

### Detailed Assessment of the Evidence

#### Key Question 2 What are the comparative harms of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

There were no RCTs of antidepressant drugs used to treat depression in pregnancy to provide direct evidence on the comparative harms. Direct evidence was limited to 16 observational studies of pharmacological treatments given at unknown dosages. Indirect evidence consists of studies of women taking an antidepressant during pregnancy for any reason compared with women who did not take an antidepressant during pregnancy, with unknown depression status in either group. Both RCTs and observational studies were found for comparative harms of pharmacologic treatment in the postpartum period.

We found no direct evidence on maternal harms of pharmacologic treatments for depression during pregnancy, primarily because for this population there is only observational evidence and the harms outcomes for this report, for example, rates of specific adverse effects (e.g., suicidal ideation, hepatoxicity, and loss of libido) are not reported. The risk of mortality may have been reported sporadically, but most of these retrospective observational studies would have excluded women who died during pregnancy, and the remaining studies did not have explicit methodology to ascertain this and other serious harms.

#### How do pharmacological treatments affect child outcomes when compared with active nonpharmacological treatments?

##### Antidepressant Exposure During Pregnancy

###### Selective Serotonin Reuptake Inhibitors

###### Infant/Child Outcomes

All-cause mortality. No direct evidence was available assessing comparative harms of pharmacologic treatment for depression during pregnancy.

Indirect evidence for this important outcome is available from one Danish cohort study with low risk of bias105 and four cohort studies with medium risk of bias.77,106,118,175 This evidence suggested an increased risk of neonatal/postneonatal death over the first year following maternal use of SSRIs during pregnancy, but not when we examined early and late deaths separately. None accounted for depression in analysis and only one small retrospective cohort study (n=105) reported the proportions of women diagnosed with depression, with 65 percent in the SSRI group and 46 percent in the nonexposed group; there were no neonatal deaths in either group.106

The remaining four studies did not have data on treatment indication or proportions of women with depression in groups.77,105,118,175 A population-based cohort study (n=98,365) found a statistically significant increase in risk of neonatal death at any time during the first year of life for SSRIs as a group, paroxetine, escitalopram, and fluvoxamine, but not for other individual SSRIs (Table 4).77 The remaining studies separately evaluated early and late death. Based on a study of all Nordic countries, maternal use of SSRIs as a group during pregnancy is not statistically significantly associated with a higher risk of early or late neonatal death (Table 4).175 A Danish study additionally evaluated individual SSRIs and found that citalopram, but not fluoxetine, escitalopram, paroxetine, or sertraline was associated with a statistically significant increase in risk of early death.

Table 4 Risk of neonatal/postneonatal death for maternal use of a selective serotonin reuptake inhibitor in pregnancy^*^

Author Year Country Sample Size | Results
First year as a whole
Colvin 2012^77^ Western Australia n=98,325 | Adjusted OR for deaths during first year of life (95% CI): SSRIs grouped: 1.81 (1.26, 2.60) Citalopram: 1.28 (0.61, 2.72) Escitalopram: 3.52 (1.30, 9.49) Fluoxetine: 2.30 (0.85, 6.19) Fluvoxamine: 4.52 (1.44, 14.24) Paroxetine: 2.18 (1.03, 4.61) Sertraline: 1.40 (0.72, 2.72)
Early death
Jimenez-Solem 2013^105^ Denmark n=920,620 | Adjusted OR for death within 28 days of birth (95% CI): Any SSRI: 1.27 (0.82 to 1.99) Citalopram: 2.49 (1.33 to 4.65) Escitalopram: 2.07 (0.29 to 14.85) Fluoxetine: 0.63 (0.24 to 1.69) Paroxetine: 1.95 (0.73 to 5.23) Sertraline: 0.26 (0.04 to 1.81)
Stephansson 2013^175^ Nordic countries n=1,633,877 | Adjusted OR (95% CI) for any SSRI Neonatal death (0-27 days): 1.23 (0.96 to 1.57)
Lennestal 2007^118^ Sweden n=860,947 | Adjusted RR (95% CI) for any SSRI compared with expected: Early: 0.8 (0.6 to 1.2)
Jordan 2008^106^ n=105 | No neonatal deaths
Late Death
Stephansson 2013^175^ Nordic countries n=1,633,877 | Adjusted OR (95% CI) for any SSRI Postneonatal death (28-364 days): 1.34 (0.97 to 1.86)
Lennestal 2007^118^ Sweden n=860,947 | Adjusted RR (95% CI) for any SSRI compared with expected: Late: 1.2 (0.7 to 2.0)

CI = confidence interval; OR = odds ratio; RR = relative risk; SSRI = selective serotonin reuptake inhibitor

* Results are in bold type where they are statistically significant

###### Congenital Anomalies

Major malformations. Only three studies provide direct evidence of the comparative risk of major malformations for the comparison of antidepressant-treated and untreated treated depressed pregnant women.69,72,189 The studies were small (n=44, n=136, and n=238) and reported one or zero major malformations.

In addition to these studies, indirect evidence was available from 26 other observational studies that report on the risk of major malformations in women taking an antidepressant during pregnancy for any reason compared with women who did not take an antidepressant during pregnancy – with depression status unknown for both groups.56,60,63,76,78,84,88,95,104,109,111,113-115,123,125-127,130,140,149,153,160,163,173,185,190 Two of these studies reported that all included women in the antidepressant groups were depressed, with control groups of women who did not take an antidepressant during pregnancy but whose depression status was unknown.88,153 Eight studies reported rates of depression in the exposed group; they reported widely varying numbers, from 26 percent95 to 77 percent.127 These studies did not report data in a way that allowed clear analysis of the effect of depression on the outcomes in the exposed or nonexposed groups. Several studies explicitly used a comparison group exposed to drugs known to be nonteratogenic.72,84,88,115,127,140,153,173

Selective serotonin reuptake inhibitors as a group. Direct evidence on the risk of major congenital malformations associated with the use of any SSRI or specific SSRIs for depression during pregnancy is limited to only two small, medium risk of bias observational studies.69 ,189 These studies were small; one reported no major malformations, and the other study reported one malformation in the group of women who were depressed but did not receive an SSRI.

A substantial amount of indirect evidence was available from 15 cohort studies that reported the incidence of major congenital malformations associated with the use of any SSRI, or specific SSRIs, during pregnancy, compared with the children of women who did not receive an SSRI and were not known to be depressed.76,80,104,109,113-115,125,126,138,142,159,167,171,184 Two of the studies were methodologically strong, rated low risk of bias,104,125 and two were methodologically weak, rated high risk of bias, due primarily to potentially biased selection of patients, lack of assessment of comparability of subjects at baseline, and lack of appropriate statistical analysis, including controlling for potential confounding.114,126 Major malformations are a fairly rare and serious adverse event; therefore, a signal from indirect evidence may be important.

Specific malformations that were classified as major varied across these studies, with most studies using ICD-9 codes196 to identify infants with malformations and some using additional methods to exclude more minor malformations. Other methods used to identify malformations were the EUROCAT197 classification system, and the approach identified by Holmes et al.198,199 This variability in what was categorized as “major” may result in heterogeneity in the data set; based on information presented, we were not able to refine this analysis further. As such, we focus our analysis on the best evidence – six studies that were methodologically stronger (medium or low risk of bias), used a formal system to identify and classify malformations (e.g., EUROCAT, Holmes, ICD), and controlled for at least three of the four types of potential confounders we had identified as critical, a priori (age, race, parity, and other relevant exposures such as smoking and drug use).104,109,125,138,167,184 None of the studies adjusted for race, and none reported on race characteristics of their study populations. None of these studies were conducted in the United States; all were conducted in Nordic countries. This evidence, based six studies of over 2.4 million pregnancies, suggests no increased risk of major malformations with exposure during pregnancy to SSRIs (as a group) compared with not being exposed (pooled adjusted OR 1.08; 95% CI 0.95 to 1.22) (Table 5). However, the I^2^ value of 67 percent suggests the presence of moderate heterogeneity. To explore potential sources of heterogeneity, we conducted exploratory subgroup analyses based on exposure timing, timing of diagnosis, and methods used to identify malformations. Exposure timing in these studies varied from first trimester to “any” time point in the 10 studies that reported adjusted odds ratios; limiting the best evidence analysis to only exposures in the first trimester resulted in a similar estimate (pooled adjusted OR 1.11; 95% CI 0.97 to 1.28). The studies varied in the timing of diagnosis of the malformation in that two allowed diagnosis up to 1 year, one was unclear, and three included malformations diagnosed soon after birth (e.g., within 7 days or during the initial hospitalization). Limiting to these early diagnosis studies resulted in a pooled adjusted odds ratio of 0.99 (95% CI 0.85 to 1.16), again not changing the estimate in a meaningful way. Limiting the analysis to those studies that used ICD coding resulted in an odds ratio of 0.99 (95% CI 0.85 to 1.15) while limiting to studies that used EUROCAT coding resulted in a slightly higher risk estimate, although still not statistically significant (OR 1.19; 95% CI 0.97 to 1.47). None of these sensitivity analyses reduced the heterogeneity to below 30 percent.

Table 5 Best evidence estimates of risk for major malformations with use of selective serotonin reuptake inhibitors during pregnancy^*^

SSRI | Number of Studies Sample Size | Pooled Adjusted OR (95% CI) | Heterogeneity (I^2^)
Any SSRI | 6 ; 2,421,444 | 1.08 (0.95 to 1.22) | 67%
Any SSRI during pregnancy vs. prior use of an SSRI | 8 | 1.07 (0.78 to 1.47) | Not estimable Cochran Q 0.29, P = 0.59
Citalopram/escitalopram | 8; 4,091,225 | 1.06 (0.97 to 1.16) | 0%
Fluoxetine | 7; 3,397,479 | 1.14 (1.01 to 1.30) | 0%
Paroxetine | 11; 4,192,613 | 1.17 (1.02 to 1.35) | 0%
Sertraline | 7; 4,020,791 | 0.98 (0.85 to 1.13) | 23%
Fluvoxamine | 2; 1,492,881 | 0.76 (0.38 to 1.50) | Not estimable (Cochran Q = 0.17; P = 0.68)

CI = confidence interval; OR = odds ratio; SSRI = selective serotonin reuptake inhibitor

* Results are in bold type where they are statistically significant

Compared with the results of our pooled analysis above the pooled estimate based on unadjusted rates from all studies, regardless of methods, showed a larger and statistically significant increased risk (OR 1.19; 95% CI 1.02 to 1.40). Heterogeneity was even higher in this analysis, with an inconsistency estimate (I^2^) of 78 percent.

Citalopram and/or escitalopram. Twelve studies reported indirect evidence on the risk of malformations with citalopram and/or escitalopram for any reason.56,76,90,109,111,113,125,138,149,159,167,173 One of the studies was methodologically strong, with low risk of bias,125 and three were methodologically weak, high risk of bias, due primarily to potentially biased selection of patients, lack of assessment of comparability of subjects at baseline, and lack of appropriate statistical analysis, including controlling for potential confounding.90,111,173

Based on eight medium and low risk of bias studies (seven cohort and one case control) reporting adjusted odds ratios, there was evidence that there is no increased risk of major malformations associated with use of either citalopram or escitalopram for any reason compared with women who did not take an antidepressant during pregnancy (depression status unknown) (Table 5). Using unadjusted rates for all 12 studies, regardless of methods, the pooled OR was slightly greater, although not statistically significant (1.12; 95% CI 0.91 to 1.38), but statistical heterogeneity was present (I^2^=64%). Because there was no heterogeneity in the adjusted analysis, we did not pursue subgroup analyses.

Fluoxetine. Thirteen observational studies provided indirect evidence on major malformations associated with fluoxetine use during pregnancy for any reason.56,71,76,84,90,109,113,125,140,149,153,159,167 Of these again one was low risk of bias125 and five were high risk of bias.71,84,90,140,153 We focused our analysis on the seven studies that were medium to low risk of bias and that reported adjusted odds ratios.56,76,109,113,125,159,167 Based on these studies, there was evidence that fluoxetine use during pregnancy for any reason is statistically significantly associated with an increased risk of major malformations compared with women who did not take an antidepressant (depression status unknown) (Table 5). Sensitivity analysis removing the only study that did not use a recognized classification system did not alter these results in a meaningful way (pooled adjusted OR 1.15; 95% CI 1.00 to 1.31; p=0.045).56,76,109,113,125,159,167

Paroxetine. Eleven observational studies56,76,84,90,109,113,125,138 ,149,159,167 provided indirect evidence on major malformation rates associated with paroxetine use during pregnancy for any reason compared with women who did not take an antidepressant during pregnancy (depression status unknown), of which two were high risk of bias.84,90 Based on analysis of the eight medium and low risk of bias studies that adjusted for potential confounders and reported odds ratios,56,76,109,113,125,138 ,159,167 we found an increased risk of major malformations (Table 5). Sensitivity analysis removing the two studies that did not adjust for at least three of four key confounding factors resulted in a similar estimate (pooled adjusted OR 1.20; 95% CI 1.03 to 1.41).

Sertraline. Nine medium and low risk of bias observational studies provided indirect evidence on rates of major malformations associated with sertraline use during pregnancy for any reason compared with women who were not treated with an antidepressant (depression status unknown).56,76,90,109,113,125,149 ,159,167 Analysis based on the seven studies that reported adjusted odds ratios indicates no increased risk for major malformations (Table 5).56,76,109,113,125,159,167 Sensitivity analysis removing studies that did not adjust for at least three of the four key confounding factors identified for this review left four studies and resulted in a more precise estimate (pooled adjusted OR 0.92; 95% CI 0.80 to 1.05).56,109,125,167

Fluvoxamine. Three medium and low risk of bias observational studies provided indirect evidence of the risk of major malformations with fluvoxamine use during pregnancy for any reason compared with women who did not use an antidepressant (depression status unknown), although the numbers of women using this SSRI were smaller than the others above.109,125,149 The pooled estimate from two studies reporting adjusted odds ratios indicated no increased risk (Table 5),109,125 nor did the third study that reported adjusted mean differences.149

Cardiac malformations. In addition to major malformations, we examined cardiac malformations as a separate category, in part because there is uncertainty in the ascertainment definitions and methods identifying major malformations, but also because although not all cardiac malformations are major, even those that are minor, if diagnosed, result in resource utilization and stress for families. No direct evidence was available on the risk of cardiac malformations following fetal exposure to SSRIs to treat maternal depression during pregnancy.

Ten observational studies provided indirect evidence on the risk of SSRIs as a group for cardiac malformations, compared with nonexposure.104,109,113,123,125,138,142,159,167,185 Two of the studies were methodologically strong, with low risk of bias,104,125 and one was methodologically weak, with high risk of bias, due primarily to potentially biased selection of patients, lack of assessment of comparability of subjects at baseline, and lack of appropriate statistical analysis, including controlling for potential confounding.185 Similar to identification of major malformations, above, we had concerns over the accuracy of ascertainment of serious cardiovascular anomalies in these studies, as they depended on ICD coding to identify a defect, with some studies applying additional criteria to categorize the type of anomaly according to developmental groupings. As a result there may have been heterogeneity in what was recorded as a major cardiac malformation across these studies. Because of this we focused our analysis on the best evidence—five studies that were methodologically stronger (medium or low risk of bias), used a formal system to identify and classify malformations (e.g., EUROCAT), and controlled for at least three of the four types of potential confounders we had identified as critical, a priori (age, race, parity, and other relevant exposures such as smoking and drug use).104,123,125,138,167 These studies provided evidence that there is no increased risk of cardiac malformations with SSRI use during pregnancy for any reason; however, there was statistically significant heterogeneity present in the analysis. In order to address this heterogeneity, we conducted a sensitivity analysis removing the studies that did not use an additional method to classify the type of cardiovascular defect, leaving three studies with a pooled adjusted odds ratio of 1.07 (95% CI 0.94 to 1.2), with no heterogeneity present.123,125,167

Citalopram and/or escitalopram. Eight studies reported indirect evidence on the risk of malformations with citalopram and/or escitalopram.113,123,125,130,138,149,159,167 One of the studies was methodologically strong, with low risk of bias,125 and one was methodologically weak, high risk of bias, due primarily to potentially biased selection of patients, uncertain accuracy of outcome ascertainment, and lack of appropriate statistical analysis, including controlling for potential confounding.130

Based on six medium and low risk of bias studies reporting adjusted odds ratios,113,123 ,125,138,159,167 there was evidence of no increased risk of cardiac malformations associated with use of either citalopram or escitalopram for any reason during pregnancy compared with women who did not take an antidepressant during pregnancy (depression status unknown) (Table 6). Because there was very little heterogeneity in the adjusted analysis, we did not pursue subgroup analyses. Analysis of unadjusted risk of a cardiac malformation in women taking citalopram or escitalopram during pregnancy compared with those who discontinued an SSRI prior to pregnancy resulted in a nonstatistically significant difference (OR 1.86; 95% CI 0.31 to 8.21).138

Table 6 Best evidence on risk of cardiac malformations with selective serotonin reuptake inhibitors compared with nonexposure^*^

SSRI (N = 15, 709) | Pooled Adjusted OR (95% CI) | Heterogeneity (I^2^)
Any SSRI | 1.29 (0.96 to 1.72) | 84%
Sensitivity analysis | 1.07 (0.94 to 1.20) | 0%
Comparison to Prior SSRI use | Unadjusted OR 1.29 (0.77 to 2.18) | Cochran Q=0.71, p=0.40
Citalopram/escitalopram | 1.05 (0.84 to 1.39) | 5%
Fluoxetine | 1.31 (1.08 to 1.58) | 0%
Sensitivity analysis | 1.2 (0.99 to 1.51) | 0%
Paroxetine | 1.49 (1.20 to 1.85) | 0%
Sensitivity analysis | 1.45 (1.13 to 1.85) | 0%
Sertraline | 1.08 (0.70 to 1.65) | 68%
Sensitivity analysis | 0.76 (0.57 to 1.00) | 0%

CI = confidence interval; OR = odds ratio; SSRI = selective serotonin reuptake inhibitor

* Results are in bold type where they are statistically significant

Fluoxetine. Eleven observational studies provide indirect evidence on the risk of major malformations associated with fluoxetine use during pregnancy for any reason, compared with women who did not take an antidepressant (depression status unknown).56,76,84 ,109,113,125,149,159,167 Of these one was low risk of bias125 and one was high risk of bias.84 We focused our analysis on the eight studies that were medium to low risk of bias and that reported adjusted odds ratios.56,76,109,113,125,159,167 Based on these studies, there was evidence that fluoxetine is associated with an increased risk of cardiac malformations (Table 6), with no statistical heterogeneity. Sensitivity analysis removing the three studies that did not adjust for at least three of four key confounders resulted in a nonstatistically significant finding (pooled adjusted OR 1.2; 95% CI 0.99 to 1.51).56,109,125,167

Paroxetine. Ten observational studies provided indirect evidence on the risk of cardiac malformation rates associated with paroxetine use during pregnancy for any reason compared with women who did not use an antidepressant during pregnancy (depression status unknown), of which one was high risk of bias.56,60,84,109,113,123,125,149,159,167 Based on analysis of the six medium and low risk of bias studies that adjusted for potential confounders and reported odds ratios,56,60 ,109,123,125,167 we found an increased risk of cardiac malformations (Table 6). Sensitivity analysis removing one study that did not report additional methods of identifying serious cardiac malformations resulted in a similar estimate (pooled adjusted OR 1.45; 95% CI 1.13 to 1.85). Statistical heterogeneity was not present in any of these analyses.

Sertraline. Eight observational studies, all medium to low risk of bias, provide indirect evidence of the risk of cardiac malformations associated with sertraline use during pregnancy for any reason compared with women who did not use an antidepressant during pregnancy (depression status unknown).56,109,113,123,125,149,159,167 Pooled analysis of the seven studies that reported adjusted odds ratios resulted in no increased risk of cardiac malformations (Table 6) but with statistical heterogeneity. Sensitivity analysis, first removing two studies that did not adjust for at least three of the four potential confounding factors identified for this review, resulted in a pooled estimate suggesting a reduced risk of cardiac anomalies with sertraline (pooled adjusted OR 0.76; 95% CI 0.59 to 0.97), but further limiting to the four studies that also indicated efforts to identify serious cardiac malformations yielded a pooled estimate of 0.76 (95% CI 0.57 to 1.00; p=0.51).

Fluvoxamine. Three observational studies provide indirect evidence on the risk of cardiac malformations associated with use of fluvoxamine use during pregnancy for any reason compared with women who did not use an antidepressant during pregnancy (depression status unknown),125,140,149 one being low risk of bias,125 another being medium,149 and the last being high risk of bias.140 Collectively, these studies provided evidence of no increased risk of cardiac malformations with fluvoxamine. None reported adjusted results in a similar way across the studies, preventing a meta-analysis of adjusted odds. The best of these studies, which adjusted for three of four key confounding factors and used both ICD-9 and EUROCAT coding, reported an adjusted odds ratio of 0.56 (95% CI 0.14 to 2.25), and the medium risk of bias study reported am adjusted risk difference of -0.55 (95% CI -1.45 to 0.36). Pooling the crude rates from these studies resulted in an odds ratio of 0.67 (95% CI 0.19 to 2.34).

###### Other Specific Adverse Events

Withdrawal symptoms (neonatal abstinence symptoms). No direct evidence was available on the risk of withdrawal symptoms following fetal exposure to SSRIs to treat maternal depression during pregnancy. Five small cohort studies with medium risk of bias provide indirect evidence suggesting increased risk of neonatal withdrawal/abstinence syndrome symptoms following maternal use of SSRIs for any reason during pregnancy compared with infants of women who did not take an antidepressant (depression status unknown).71,95,106,119,165 Signs of neonatal withdrawal/abstinence syndrome were consistently more frequent in SSRI-exposed newborns (Table 7). In the largest studies that adjusted for multiple potential confounding factors, neonates exposed to fluoxetine during the first trimester had almost a nine-fold greater risk of poor neonatal adaptation71 and those exposed to an SSRI or venlafaxine in late pregnancy had three-fold higher odds of neonatal behavioral signs.95

Table 7 Risk of neonatal withdrawal/abstinence syndrome for maternal use of a selective serotonin reuptake inhibitor in pregnancy

Author Year Country Sample Size | Depression | Comparison | Results
SSRIs grouped
Jordan 2008^106^ US N = 108 | SRI: 65% Control: 46% | SSRI during pregnancy vs. nonexposed | NBS: Any component present: 28% vs. 17%; NSD
Levinson-Castiel, 2006^119^ Israel n=120 | NR | SSRI during entire pregnancy or at least during the third trimester vs. nonexposed | Finnegan severe score of ≥ 8: 13% vs. 0% Any symptoms: 30% vs. 0% p=NR
Individual SSRIs
Chambers 1996^71^ US n=482 | Fluoxetine: 76.9% Control: NR | Fluoxetine during first trimester vs. nonexposed | Poor neonatal adaptation: Adjusted RR, 8.7 (2.9 to 26.6)
SSRIs or SNRIs
Ferreira 2007^95^ USA n=166 | Exposed: 41% Control: NR | SSRI or venlafaxine during third trimester or at least two weeks prior to delivery vs. nonexposed | Neonatal behavioral signs: Adjusted OR, 3.1 (1.3–7.1)
Rampono, 2009^165^ Australia N=56 | NR | SSRI/SNRI during pregnancy vs. nonexposed | Maximum median NAS on day 1: SSRI/SNRI=2 vs. nonexposed=0; P<0.05 No other differences in NAS scores (days 1 to 3) Percent infants with NAS > 12 or 3 scores > 8: SSRI=4% vs. SNRI=9%, NSD

NAS = Finnegan neonatal abstinence scoring system; NBS = neonatal behavioral syndrome; NR = not reported; NSD = no significant difference' OR = odds ratio; RR = risk ratio; SNRI = serotonin norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor

Pulmonary hypertension. No direct evidence was available on the risk of withdrawal symptoms following fetal exposure to SSRIs to treat maternal depression during pregnancy. Indirect evidence indicates an increased risk of persistent pulmonary hypertension is associated with use of SSRIs for any reason during pregnancy compared with women who did not take an antidepressant (depression status unknown), based on eight observational studies.57,70,106,108,110,167,185,186 All but one of these studies were medium risk of bias, but only four reported odds ratios adjusted for potential confounding factors.70,108,110,167

Using a broad “any exposure” category, the pooled adjusted odds ratio is 2.41 (95% CI 1.47 to 3.95), with only 14 percent inconsistency.70,108,167 Exposure later in pregnancy (generally after week 20, excluding women who used SSRIs both early and late) was associated with a statistically significant increase in risk (pooled adjusted OR 2.72; 95% CI 1.63 to 4.54), based on three studies.70,110,167 However, this pooled analysis had moderate heterogeneity, I^2^=48%. While all three adjusted for multiple confounders, including three of the four key confounders identified for this review, the categorization of exposure timing (early) was described in a way that may not exclude overlap between the groups of early, late, or any exposure. Pooled analysis of “early” exposure, reported in four studies,70,108,110,167 produced concerning statistical heterogeneity, I^2^=69% (pooled adjusted OR 1.45; 95% CI 0.84 to 2.49), with three studies showing an increased risk and one showing a nonsignificant lower risk compared with nonexposure. In both analyses it appears that the earliest study estimates were outliers.70 This was a prospective study that identified infants with persistent pulmonary hypertension prospectively using patient charts and blinded review by a pediatric cardiologist. The other three studies relied on ICD-9 coding to identify cases. However, the prospective study used mother's recall of medications used to identify exposure, while the other studies used combinations of medical and pharmacy records. Thus, none of the studies is superior to the others and the heterogeneity cannot be fully explained.

Respiratory distress. Direct evidence was available from three medium risk of bias observational studies that directly compared the risk of respiratory distress in infants between SSRI-treatment of maternal depression during pregnancy and untreated maternal depression.69,147,189 Methods for measuring respiratory distress-related outcomes varied across studies, including use of ICD-9 codes,147 the Peripartum Events Scale (tachypnea, required oxygen, respiratory distress, acrocyanosis, and cyanosis),189 and admission to the neonatal intensive care unit due to respiratory distress.69 Based on these three studies, there is low-strength evidence that, compared with untreated maternal depression during pregnancy, SSRI treatment is associated with a statistically significant increase in risk of respiratory distress in infants (pooled unadjusted OR 1.91; 95% CI 1.63 to 2.24; I^2^ = 0%).

Seven observational studies with medium risk of bias provide additional indirect evidence on the risk of respiratory distress among infants following maternal use of SSRIs for any reason during pregnancy compared with women who did not use SSRIs (depression status unknown).77,81,95,106,107,118,142 Four of the studies used ICD codes to identify infants with respiratory distress and used multivariate regression analyses to control for at least one of key confounders identified for this review (n=748,658).77,81,107,118 Focusing our analysis on the best evidence from these studies, this indirect evidence supports the direct evidence that maternal exposure to SSRIs primarily in late pregnancy is associated with a statistically significant increased risk of respiratory distress in infants exposed to SSRIs during pregnancy compared with infants of nonexposed pregnant women (pooled adjusted OR 1.79; 95% CI 1.64 to 1.97; I^2^ = 0%).77,81,107,118

A medium risk of bias study of pharmacy dispensing data from the Netherlands suggested a small increase in risk of a child whose mother had taken an SSRI during pregnancy being prescribed a drug for a respiratory condition (incidence risk ratio 1.17; 95 % CI 1.16–1.18).179 Because ascertainment of exposure was not ideal, and control for confounding possibly not adequate (e.g., did not control for smoking status of mother), these findings should be interpreted with caution.

Neonatal convulsions. Eight observational studies with low to moderate risk of bias reported risk of neonatal convulsions/seizures following maternal use of SSRIs during pregnancy.80,95,106,107,115,119,147,171 Only one study (n=107,877) provides direct evidence by comparing outcomes from infants of depressed mothers treated with SSRIs with infants of depressed mothers not treated with medication and nondepressed mothers.147 Infants of depressed mothers treated with SSRIs (incidence 0.14%) did not have a statistically significantly higher risk of convulsions than those of depressed mothers not treated with medication (incidence=0.09%) or nondepressed mothers (incidence =0.11%; risk difference 0.0005; 95% CI −0.0015 to 0.0025).

Indirect evidence from the remaining studies suggests that maternal use of SSRIs during pregnancy for any indication is associated with a statistically significantly increased risk of convulsions compared with infants of nonexposed pregnant women (pooled unadjusted OR 4.11; 95% CI 1.78 to 9.48). These findings are in conflict with the direct evidence.

###### Tricyclic Antidepressants

###### Infant/Child Outcomes

Congenital anomalies. No direct evidence was available on the risk of congenital anomalies following fetal exposure to TCAs to treat maternal depression during pregnancy. We identified indirect evidence form five observational studies that reported rates of congenital malformations following exposure to TCAs for any indication during pregnancy compared with women not taking an antidepressant during pregnancy, who were not known to be depressed.68,140,153,167,171 Of these, one was methodologically strong, low risk of bias,171 one was medium,167 and three were methodologically weak, high risk of bias.68,140,153 These studies had less clear methods for obtaining an unbiased sample and ascertaining exposures and outcomes.

Major malformations. Limiting our analysis to two low and medium risk of bias studies,167,171 both of which adjusted for at least three of four key confounding factors, we found indirect evidence of an increased risk of major malformations associated with TCAs as a group compared with non-use (pooled adjusted OR 1.31; 95% CI 1.04 to 1.65). Evidence was not reported in a way that allowed investigation of specific drugs in this class.

Cardiac malformations. Based on two low and medium risk of bias studies,167,171 both of which adjusted for at least three of four key confounding factors, indirect evidence indicated a statistically significant increased risk of cardiovascular malformations associated with use of TCAs as a group for any indication during pregnancy compared with nonuse (pooled adjusted OR 1.58; 95% CI 1.10 to 2.29). Evidence was not reported in a way that allowed investigation of specific drugs in this class.

###### Other specific adverse events

Respiratory distress. No direct evidence was available on the risk of neonatal respiratory distress following fetal exposure to TCAs to treat maternal depression during pregnancy. Indirect evidence from two large observational studies with medium risk of bias reported risk of respiratory distress among infants exposed to TCAs during late pregnancy.81,107 The first evaluated 16,299 cases and 566,497 controls using data from the Swedish Medical Birth Registry.107 The second was a cohort study of 76,093 women from five health maintenance organizations (HMOs) participating in the HMO Research Network's Center for Education and Research on Therapeutics project.81 Neither study matched groups based on maternal depression and do not allow direct comparison of the risks of TCA-treated depression to untreated depression. Based on the results of these studies, there is evidence that exposure to TCAs during late pregnancy leads to a statistically significant increased risk of respiratory distress (pooled adjusted OR 2.11; 95% CI 1.57 to 2.83; Cochran Q=0.08, df=1, p=0.78).

Neonatal convulsions. We found no direct evidence on the risk of neonatal convulsions following fetal exposure to TCAs to treat maternal depression during pregnancy. Indirect evidence indicates a statistically significant increase in risk of convulsions in infants of mothers exposed to TCAs during pregnancy. Two observational studies with moderate risk of bias evaluated risk of neonatal convulsions/seizures following maternal use of TCAs during pregnancy.107,171 Neither accounted for depression exposure. The best evidence comes from the large Swedish population-based case-control study (cases n=1009; controls n=581,787) that provided indirect evidence that infants exposed to TCAs during pregnancy have almost a seven-fold higher risk of convulsions (adjusted RR 6.8; 95% CI 2.2 to 16.0).107 A much smaller study (n=418) using data from a health plan also found that more infants of mothers treated with TCAs during pregnancy (1.9%) had seizure disorder than nonexposed infants (0.0%).171 This study did not provide an adjusted odds ratio. When we combined data from both studies, the unadjusted pooled odds ratio indicated an even higher risk of convulsions/seizures than in the Swedish study alone (7.82; 95% CI 2.81 to 21.76).

###### Selective Norepinephrine Reuptake Inhibitors and Norepinephrine Reuptake Inhibitors

###### Infant/Child Outcomes

All-cause mortality. There was no direct evidence to draw conclusions about the risk for infant death associated with use of SNRIs or NRIs during pregnancy to treat depression. One Swedish cohort study with medium risk of bias reported neonatal/postneonatal deaths following maternal use of SNRIs or NRIs during pregnancy.118 There was no statistically significant increased risk of either early (RR 1.3; 95% CI 0.5 to 2.8) or late (RR 0.0; 95% CI 0.0 to 4.4) neonatal death with SNRIs or NRIs as a group.

Congenital anomalies. There was no direct evidence to draw conclusions about the risk for congenital anomalies associated with use of SNRIs or NRIs during pregnancy to treat depression. Indirect evidence on the risk of congenital malformations with an SNRI indicated no statically significant increase in risk compared with pregnant women who did not use an antidepressant and were not known to be depressed. Two studies reported on malformations with venlafaxine.90,149 One was medium risk of bias and adjusted for depression and other diseases among other confounders, but did not control for the four key confounders identified for this review.149 The other was high risk of bias and presented unadjusted rates.90 There was no increased risk compared with a nonexposed group based on the adjusted risk difference presented in the medium risk of bias study (-1.18; 95% CI -3.20 to 0.84) or the pooled unadjusted rates from both studies (OR 0.68; 95% CI 0.33 to 1.38). Evidence for NRIs (nefazodone or trazodone) was limited to two small, high risk of bias studies.88,90

###### Other Specific Adverse Events

Respiratory distress. There was no direct evidence to draw conclusions about the risk for neonatal respiratory distress associated with use of SNRIs or NRIs during pregnancy to treat depression. Indirect evidence was limited with one very small cohort study with medium risk of bias reported risk of respiratory distress among infants exposed to SNRIs or NRIs during pregnancy.118

###### Other Antidepressants: Bupropion

###### Infant Outcomes

Congenital malformations. Two observational studies reported on the risk of congenital malformations associated with use of bupropion during pregnancy.55,72 One was high risk of bias, but it was the only study provided direct evidence on major malformations.72 There were few malformations in any group and the p value for comparison across the groups was 0.51. The second, medium risk of bias study55 was a case control study (n=12,749) designed to examine the risk of cardiac malformations provides only indirect evidence. Compared with nonexposed controls, the adjusted odds ratio for any cardiac malformation was 1.4 (95% CI 0.8 to 2.5).

##### Postpartum Exposure

###### Selective Serotonin Reuptake Inhibitors

###### Child Outcomes

Overall adverse events. One observational study with high risk of bias provided direct evidence on the comparative risk of overall adverse events in babies of 20 women taking an SSRI or venlafaxine for postpartum depression compared with 68 babies of breastfeeding mothers not treated with any medication and of unspecified depression status.64 Total adverse event symptom score was 5.9 in the treatment group and 7.6 in the control group (p not reported). The proportion of withdrawals from study drug due to adverse events was not reported. Due to high methodological limitations, unknown consistency and imprecision, however, this observational study provides insufficient evidence to draw strong conclusions about comparative risk of overall adverse events in babies.

#### How do pharmacological treatments affect maternal outcomes when compared with each other (drug A compared with drug B)?

##### Antidepressant Exposure During Pregnancy

We found no direct evidence comparing antidepressants to each other in pregnant women with depression.

###### Class Compared With Class: Selective Serotonin Reuptake Inhibitors Compared With Tricyclic Antidepressants

###### Infant/Child Outcomes

Congenital malformations. Indirect evidence from two medium risk of bias studies reported major malformations and cardiac malformations associated with specific classes of antidepressant drugs.167,171 Both studies adjusted for at least three of four key confounding factors. Both studies provide adjusted odds ratios for TCAs and SSRIs (and one includes SNRIs) compared with pregnant women who did not receive antidepressants during pregnancy but were not known to be depressed. These studies do not make direct comparisons across classes. The adjusted odds ratios are presented in Table 8. Findings from these studies differ in that a statistically significant increase in risk of major and cardiac malformations was found with TCAs, but not SSRIs in the larger study that used ICD-9 codes to identify malformations,167 while the other smaller study that used an unblinded pediatric specialist review of patient records to identify malformations found a nonstatistically significant lower risk with TCAs, and a nonsignificant increase in risk with SSRIs.171 Pooling the unadjusted rates from these two studies, we find SSRIs to have a statistically significantly lower risk of major or cardiac malformations compared with TCAs (Table 8). The comparison of SSRIs and SNRIs comes from a single medium risk of bias study (Table 8), where similar odds were found for both classes and neither was statistically significant.

Table 8 Class compared with class: Risk of congenital malformations

Study | SSRIs (Adjusted OR [95% CI] Compared With Nonexposure) | TCAs (Adjusted OR [95% CI] Compared With Nonexposure) | SNRIs (Adjusted OR [95% CI] Compared With Nonexposure) | SSRIs vs. TCAs (Unadjusted Pooled Odds Ratio [Fixed Effect Model])
Major malformations
Reis 2010 Sweden n=17,425 exposed | 1.08 (0.97 to 1.21) | 1.39 (1.07 to 1.72) | 1.00 (0.73 to 1.37)
Simon 2002 US n=385 exposed | 1.36 (0.56 to 3.30) | 0.82 (0.35 to 1.95) | --
| | | | 0.77 (0.60 to 0.98)
Cardiac malformations
Reis 2010 Sweden n=14, 821 exposed | 0.99 (0.82 to 1.20) | 1.63 (1.12 to 2.36) | 1.33 (0.84 to 2.09)
Simon 2002 US n=385 exposed | Non-estimable (0 events in control group) | 0.5 (0.05 to 5.53) | --
| | | | 0.66 (0.44 to 0.99)

OR = odds ratio; SNRI = serotonin norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant

###### Other Specific Adverse Events

Withdrawal symptoms (neonatal abstinence symptoms). Indirect evidence comparing the risk of neonatal abstinence symptoms in infants of women treated for depression with SSRIs compared with SNRIs during pregnancy comes from only one small (n=56) prospective cohort study with medium risk of bias evaluated the comparative risks of neonatal abstinence syndrome between maternal use of SSRIs as a group and SNRIs as a group during pregnancy.165 Depression status of the women was not reported. Only one cohort study with medium risk of bias include both classes and made any comparison between them, finding no difference in the proportion of infants with neonatal abstinence symptoms scores greater than 12 (on the Finnegan scale, range of 0 to 21) or with 3 days of scores greater than 8 (SSRI=4%, SNRI=9%, p = NR).

Respiratory distress: SSRI compared with TCA. Indirect evidence comparing the risk of neonatal respiratory distress in infants of women treated for depression with SSRIs compared with TCAs during pregnancy comes from only one small study with medium risk of bias compared the risk of respiratory distress among infants between treatment of maternal depression during pregnancy with different SSRIs or nortriptyline.172 The study included 21 women from the Women's Behavioral HealthCARE Program at the University of Pittsburgh Medical Center's Western Psychiatric Institute and Clinic. Results from this study suggest that SSRIs and nortriptyline are associated with similar risks of respiratory distress in infants (10% vs. 0%; p=NR).

###### Bupropion Compared With Other Antidepressants

###### Infant/Child Outcomes

Congenital malformations. One high risk of bias, observational study reported no increase in risk of congenital malformations associated with the use of bupropion during pregnancy compared with other antidepressants as a group in women with depression during pregnancy.72 Indirect evidence came from a larger (n=7005), medium risk of bias study that also reported no statistically significant increase in risk with bupropion compared with other antidepressants and reported an adjusted odds ratio of 0.95 (95% CI 0.62 to 1.45).74 Depression status of women in either group was not known in this study.

###### Within Class Comparisons: Selective Serotonin Reuptake Inhibitors Compared With Selective Serotonin Reuptake Inhibitors

###### Congenital Anomalies

Indirect evidence based on nine observational studies76,84,90,109,125,138,149,159,167 suggested that that there is no difference in risk of major (unadjusted pooled OR 1.14; 95% CI 0.95 to 1.37) or cardiac (unadjusted pooled OR 1.10; 95% CI 0.85 to 1.43) malformations between paroxetine and fluoxetine used for any indication during pregnancy. The evidence was limited by a lack of adjusted analyses directly comparing the two drugs (these findings are based on unadjusted rates), and the methodological limitations of individual studies (range from high to low risk of bias), but is strengthened by the strong consistency across estimates.

Based on eight observational studies,76,90,109,125,138,149,159,167 we compared the risk of citalopram or escitalopram with that of fluoxetine or paroxetine. Using unadjusted rates, we found that the pooled odds of a major malformations is 0.94 (95% CI 0.82 to 1.07; I^2^=0%), suggesting no statistically significant difference between the drugs. Similarly, analysis of the unadjusted risk for cardiac malformations did not result in a statistically significant difference (OR 0.94; 95% CI 0.60 to 1.47). This analysis resulted in significant statistical heterogeneity (I^2^ = 49%), sensitivity analyses based on risk of bias did not reduce this heterogeneity. These findings compare to adjusted analyses reported for the individual drugs (above) where the confidence intervals overlap considerably.

These same eight studies indicated a lower risk of major malformations with sertraline compared with fluoxetine or paroxetine (pooled unadjusted OR 0.59; 95% CI 0.38 to 0.90; I^2^ = 0%). The risk for cardiac malformations is also lower, based on pooled unadjusted rates (OR 0.59; 95% CI 0.38 to 0.93) but statistically significant heterogeneity (I^2^ = 42%) suggested caution in interpreting these results. Sensitivity analysis removing a high risk of bias study did not alter these results.

###### Other Specific Adverse Events

Persistent pulmonary hypertension. Of the eight observational studies reporting persistent pulmonary hypertension rates with SSRIs, only one conducted an analysis by drug.110 Based on this medium risk of bias study, there was indirect evidence that only escitalopram did not have statistically significant increased risk when exposure occurs after 20 weeks gestation (Table 9). For early exposure (up to 8 weeks gestation), only citalopram was associated with a statistically significant increase in risk, while escitalopram had the lowest risk. No direct statistical comparisons across the drugs were made. While increased odds are similar for late exposure across the four drugs (citalopram, fluoxetine, paroxetine and sertraline), they are less similar for the early exposure comparison, and a study designed to directly compare the drugs may result in differences being found.

Table 9 Risk of persistent pulmonary hypertension with individual selective serotonin reuptake inhibitors110,*

N exposed = 30,115 N control = 1 588 140 | Adjusted OR | Lower Bound (95% CI) | Upper Bound (95% CI)
Late exposure (20 weeks or after)
Fluoxetine | 2.0 | 1.0 | 3.8
Citalopram | 2.3 | 1.2 | 4.1
Paroxetine | 2.8 | 1.2 | 6.7
Sertraline | 2.3 | 1.3 | 4.4
Escitalopram | 1.3 | 0.2 | 9.5
Early exposure (up to 8 weeks)
Fluoxetine | 1.3 | 0.6 | 2.8
Citalopram | 1.8 | 1.1 | 3.0
Paroxetine | 1.3 | 0.5 | 3.5
Sertraline | 1.9 | 1 | 3.6
Escitalopram | 0.3 | 0 | 2.2

CI = confidence interval, OR = odds ratio

* Results are in bold type where they are statistically significant

Respiratory distress. Indirect evidence comparing the risk of neonatal abstinence symptoms in infants of women treated for depression with SSRIs compared with each other during pregnancy comes from only one small study (n=20) with medium risk of bias that compared the risk of respiratory distress among infants between treatments of maternal depression during pregnancy with different SSRIs.172 Results from this study suggest that sertraline is not associated with a statistically significant increase in risk of respiratory distress compared with other SSRIs (22% vs. 0%; p=NR).

##### Postpartum Exposure

###### Class Compared With Class: Selective Serotonin Reuptake Inhibitors Compared With Tricyclic Antidepressants

###### Child Outcomes

Overall adverse events and withdrawals due to adverse events. One RCT with high risk of bias provided direct evidence on the comparative risk of overall adverse events in babies of 109 women taking either sertraline or nortriptyline for postpartum depression.188 There were no adverse events or withdrawals due to adverse events in the babies of the breastfeeding mothers. Due to high methodological limitations, unknown consistency and imprecision, however, this trial provided insufficient evidence to draw strong conclusions about comparative risk of overall adverse events in babies.

#### How do pharmacological treatments affect child outcomes when compared with active nonpharmacological treatments?

##### Antidepressant Exposure During Pregnancy

We found no evidence on the risk of serious adverse outcomes in the infant (e.g., mortality, malformations, and pulmonary hypertension) when comparing pharmacologic and nonpharmacologic treatments.

##### Postpartum Exposure: Selective Serotonin Reuptake Inhibitors

###### Overall Adverse Events and Withdrawals Due To Adverse Events

One observational study with high risk of bias provided evidence on the comparative risk of overall adverse events and withdrawal due to adverse events in babies of 23 women treated with either sertraline or interpersonal psychotherapy for postpartum depression.155 Breastfeeding women reported no adverse events in their babies and none withdrew from the study due to adverse events. Due to high methodological limitations, unknown consistency and imprecision, however, this study provides insufficient evidence to draw strong conclusions about comparative risk of overall adverse events in babies.

#### How does combination therapy affect maternal and child outcomes?

##### Using a Second Drug To Augment the Effects of the Primary Drug and Comparing This Treatment With Single Drug Monotherapy

###### Congenital Anomalies

We found no direct evidence on the risk of congenital anomalies with multiple antidepressants taken during pregnancy for depression compared with monotherapy. Indirect evidence comes from only two small studies specifically addressed this question.92,159 Both studies reported nonstatistically significant risks with wide confidence intervals for the comparison of multiple antidepressants to nonexposure, but the direction of the estimates were opposite. A medium risk of bias study that adjusted for age, calendar year, income, marriage and smoking status presented an adjusted odds ratio of 1.62 (95% CI 0.83 to 3.16),159 while a high risk of bias study that matched patients for age, smoking status, and alcohol use reported an odds ratio of 0.68 (95% CI 0.11 to 4.16).92 This study also reported the comparison to monotherapy, finding an odds ratio of 1.03 (95% CI 0.14 to 7.48). Pooling these data results in an odds ratio of 1.58 (95% CI 0.86 to 2.93), still an imprecise result.

A statistically significant increase in risk of cardiac malformations was found in the one study reporting this outcome, compared with nonexposure; adjusted odds ratio of 3.42 (95% CI 1.40 to 8.34) compared with nonexposure. Because the use of multiple antidepressants may indicate more severe or resistant depression, and since this study did not control for depression or severity of depression, we cannot determine the role of the antidepressants compared with the role of the disease in these findings.

##### Combining Pharmacological Treatments With Nonpharmacological Treatments and Comparing Them With Nonpharmacological Treatments Alone

###### Antidepressant Exposure During Pregnancy

We found no evidence on the risk of serious adverse outcomes in the infant (e.g., mortality, malformations, pulmonary hypertension) when comparing combination pharmacologic treatments with nonpharmacologic treatments.

###### Postpartum Exposure

###### Overall Adverse Events or Withdrawal Due to Adverse Events

One RCT with high risk of bias provided direct evidence on the comparative risk of overall adverse events in babies of 23 women treated with either sertraline plus interpersonal psychotherapy or sertraline alone for postpartum depression.155 Breastfeeding women reported no adverse events or withdrew from the study due to adverse events in their babies. Due to high methodological limitations, unknown consistency and imprecision, however, this trial provides insufficient evidence to draw strong conclusions about comparative risk of overall adverse events in babies.

##### Comparing Pharmacological Treatments Alone With Pharmacological Treatments Used in Combination With Nonpharmacological Treatments

###### Antidepressant Exposure During Pregnancy

No evidence on the risk of serious adverse outcomes in the infant (e.g., mortality, malformations, pulmonary hypertension) was found comparing pharmacologic treatments used alone with pharmacologic treatments combined with nonpharmacologic treatments.

#### Key Question 2e In babies born to women who become pregnant while taking medications to treat depression, what is the comparative risk of teratogenicity?

The evidence on the risk of exposure to an antidepressant drug during the conception period in women with depression was extremely limited, and it was insufficient to draw conclusions. The studies included in the sections above reporting on the risk of congenital malformations comprised the best evidence to answer this question, but even among those that specified exposure in the first trimester, there were few that specified exposure during conception and none that made direct comparisons with a control group of untreated depression. For example, of the studies that reported specifically on first trimester exposure to SSRIs, and met our criteria for risk of bias (controlled for three of four of our key confounders and used a recognized categorization system to identify malformations), only one reported exposure timeframes that required exposure in the conception period.104 Compared with the other three studies reporting major malformations following exposure in the first trimester, but without necessarily including the conception period, this study reported the highest odds (Figure 4). All of these studies made comparisons with nonexposed pregnant women, with unknown proportions in either group with depression, but the Jiminez-Salem study also reported on a small group of women who had taken an SSRI in the year prior to pregnancy but had discontinued it prior to conception. The risk in this group was similar to the exposed group, (OR 1.27; 95% CI 0.91 to 0.78) but not statistically significant. This study also examined the effect of dose, with the risk associated with low dose SSRIs (e.g., ≤ 20 mg fluoxetine daily) having an odds ratio of 1.26 (95% CI 1.05 to 1.51) compared with 1.44 (95% CI 1.15 to 1.79) for high doses. While the high dose risk was slightly higher, analysis comparing the odds ratios indicated no statistically significant difference, indicating no clear dose-response relationship. Because this was a single observational study using a control group of presumably mainly nondepressed women, with unknown consistency in findings and imprecise results, this evidence was insufficient to draw firm conclusions.

Figure 4 Risk of major malformations with selective serotonin reuptake inhibitors compared with nonexposure

Figure 4 is a forest plot depicting the individual and pooled adjusted odds ratios and 95% confidence intervals (random effects model) from four observational studies for risk of major malformations with selective serotonin reuptake inhibitors during pregnancy compared with nonexposure in babies born to women who did not take antidepressants during pregnancy (depression status unknown). These four studies are the only ones that reported specifically on first trimester exposure to SSRIs, and met our criteria for risk of bias, controlled for three of four of our key confounders and used a recognized categorization system to identify malformations. None of them directly compared medication treatment for depression to a control group of untreated depression. Adjusted odds ratios were inconsistent across studies, ranging from 0.89 (95% confidence interval 0.70 to 1.07) to 1.33 (95% confidence interval, 1.16 to 1.53). Only one study, Jimenez-Solom 2012, reported exposure timeframes that required exposure in the conception period. Compared with the other three studies reporting major malformations following exposure in the first trimester, but without necessarily including the conception period, the Jimenez-Solom 2012 study reported the highest odds of major malformations of 1.33 (95% confidence interval, 1.16 to 1.53) and was the only study with a difference that reached statistical significance.

Based on this single study, the risk of a cardiovascular malformation was also found to be significantly increased in exposed women compared with nonexposed pregnant women, (adjusted OR 2.01; 95% CI 1.60 to 2.53). In this case, the risk in women who stopped taking an SSRI prior to conception was also statistically significantly elevated, (adjusted OR 1.85; 95% CI 1.07 to 3.20). Dose again showed a small increase in risk with greater dose, but comparison of the odds ratios resulted in a p value of 0.41, indicating no clear dose-response relationship. Analysis of other specific malformations did not result in any statistically significant increased risk estimates.

While there were a few other studies that reported the risk of malformations after exposure during the conception period for individual or grouped SSRIs, SNRIs, and individual drugs,73,74,149,184 none controlled for more than two of the key confounders, and all suffered from inferior methods for ascertainment of exposure or outcomes.

Insufficient evidence was available to reliably assess the risk of autism spectrum disorder in children of women taking an antidepressant at the time of conception. A single observational study examined this group and found no statistically significant increase in risk compared with nonexposed pregnant women. 79

## Key Question 3 Is there evidence that the comparative effectiveness of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period varies based on characteristics such as interventions, populations, and providers?

### Summary

- Evidence in subgroups based on characteristics such as interventions, populations, and providers was insufficient to draw conclusions. Direct evidence was limited.

#### Exposure During Pregnancy

##### Duration of Treatment

- Compared with partial SSRI exposure during pregnancy, there was not a statistically significantly greater risk of preterm birth (< 37 weeks) associated with continuous exposure (unadjusted pooled OR 3.23; 95% CI 0.74 to 14.17).
- Evidence on the influence of antidepressant dose on adverse effects was insufficient.

#### Postpartum Exposure

##### Depression Severity Level

- In women with postpartum depression, symptom response to brief dynamic psychotherapy, with or without sertraline, did not vary based on depression severity level.

##### Duration of Treatment

- In women with postpartum depression, symptom improvement did not differ when fluoxetine was used in combination with either one or six sessions of cognitive-behavioral counseling.

##### Depression History

- Evidence was insufficient to allow analysis of the impact of history of major depressive disorder prior to pregnancy versus those with a first episode during pregnancy or the postpartum period.

##### Other

- Studies with definite depression in all comparison groups and that had medium to low risk of bias provided only insufficient evidence to draw conclusions about variation in treatment effects based on all other patient characteristics and comorbidities, intervention characteristics, co-administration of other drugs, medical provide characteristics, medical care environments, and characteristics of diagnosis.

### Detailed Assessment of the Evidence

There were six medium to low risk of bias observational studies of the comparative effectiveness of pharmacological and nonpharmacological treatments in women with depression during pregnancy69,147,152,172,189,192 and three RCTs of treatment during the postpartum period that met this best evidence criteria.58,65,132 Among those, only one RCT of women with postpartum depression evaluated the effects of depression severity65 and four studies evaluated the effects of treatment duration.58,152,189,192

#### Exposure During Pregnancy

##### Duration of Treatment

Preterm birth. Two prospective cohort studies conducted in the United States (n=95) provided evidence that, compared with partial SSRI exposure, there was not a statistically significantly greater risk of preterm birth (< 37 weeks) associated with continuous exposure (unadjusted pooled OR 3.23; 95% CI 0.74 to 14.17).189,192

#### Postpartum Exposure

##### Severity of Symptoms

One RCT of 40 women treated for postpartum depression for 8 weeks with brief dynamic psychotherapy, with or without sertraline add-on, evaluated the effects of baseline depression severity (above and below the median MADRS scores).65 The main analysis of all patients provided evidence of no statistically significant difference between add-on sertraline (70%) and placebo (55%) in response rates (>50% reduction in either the MADRS or EPDS scores). The post-hoc analysis of the high depression severity subgroup also found no statistically significant difference in response rate (p=0.31).

##### Duration of Treatment

One 12-week RCT of 87 women treated for postpartum depression with fluoxetine, cognitive-behavioral counseling or their combination evaluated the effects of treatment duration.58 Treatment groups that received fluoxetine plus either one or six session(s) had similar mean changes on the Edinburgh postnatal depression scale (-67% compared with -69%; p=not reported) and on the Hamilton Depression Scale (-78% compared with -79%; p=not reported).