# References

1 Blazer DG, Kessler RC, McGonagle KA, et al. (1994). The prevalence and distribution of major depression in a national community sample: the National Comorbidity Survey. Am J Psychiatry.
2 Le Strat Y, Dubertret C, Le Foll B. (2011). Prevalence and correlates of major depressive episode in pregnant and postpartum women in the United States. J Affect Disord.
3 Dietz PM, Williams SB, Callaghan WM, et al. (2007). Clinically identified maternal depression before, during, and after pregnancies ending in live births. Am J Psychiatry.
4 Halbreich U, Karkun S. (2006). Cross-cultural and social diversity of prevalence of postpartum depression and depressive symptoms. J Affect Disord.
5 Le Strat Y, Dubertret C, Le Foll B. (2011). Prevalence and correlates of major depressive episode in pregnant and postpartum women in the United States. J Affect Disord.
6 Norwitz ER, Lye SJ. (2009). Chapter 5: Biology of parturition. Creasy RK, Resnick R, Iams JD, editors. Creasy and Resnik's maternal-fetal medicine : principles and practice.
7 Hallberg P, Sjoblom V. (2005). The use of selective serotonin reuptake inhibitors during pregnancy and breast-feeding: a review and clinical aspects. J Clin Psychopharmacol.
8 Nonacs R, Cohen LS. (2003). Assessment and treatment of depression during pregnancy: an update. Psychiatr Clin North Am.
9 Alder J, Fink N, Bitzer J, et al. (2007). Depression and anxiety during pregnancy: a risk factor for obstetric, fetal and neonatal outcome? A critical review of the literature. J Matern Fetal Neonatal Med.
10 Henry AL, Beach AJ, Stowe ZN, et al. (2004). The fetus and maternal depression: implications for antenatal treatment guidelines. Clin Obstet Gynecol.
11 Grote NK, Bridge JA, Gavin AR, et al. (2010). A meta-analysis of depression during pregnancy and the risk of preterm birth, low birth weight, and intrauterine growth restriction. Arch Gen Psychiatry.
12 Murray L, Cooper PJ. (1997). Postpartum depression and child development. Psychol Med.
13 Ludermir AB, Lewis G, Valongueiro SA, et al. (2010). Violence against women by their intimate partner during pregnancy and postnatal depression: a prospective cohort study. Lancet.
14 Doucet S, Jones I, Letourneau N, et al. (2011). Interventions for the prevention and treatment of postpartum psychosis: a systematic review. Arch Womens Ment Health.
15 Halbreich U. (2004). Prevalence of mood symptoms and depressions during pregnancy: implications for clinical practice and research. CNS Spectr.
16 Myers E, Aubuchon-Endsley N, Bastian L, et al. (2013). Efficacy and Safety of Screening for Postpartum Depression. Comparative Effectiveness Review 106.
17 Hayes RM, Wu P, Shelton RC, et al. (2012). Maternal antidepressant use and adverse outcomes: a cohort study of 228,876 pregnancies. Am J Obstet Gynecol.
18 (2000). Diagnostic and statistical manual of mental disorders: DSM-IV-TR.
19 Gartlehner G, Hansen RA, Morgan LC, et al. (2011). Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review.
20 Gartlehner G, Hansen RA, Morgan LC, et al. (2011). Comparative benefits and harms of second-generation antidepressants for treating major depressive disorder: an updated meta-analysis. Ann Intern Med.
21 Hale TW. (2012). Medication and Mother's Milk 2012: A Manual of Lactational Pharmacology.
22 Lanza di Scalea T, Wisner KL. (2009). Antidepressant medication use during breastfeeding. Clin Obstet Gynecol.
23 Lawrence RA, Lawrence RM. (2011). Breastfeeding: A Guide for the Medical Profession.
24 Freeman MP, Fava M, Lake J, et al. (2010). Complementary and alternative medicine in major depressive disorder: the American Psychiatric Association Task Force report. J Clin Psychiatry.
25 Kayser S, Bewernick BH, Grubert C, et al. (2011). Antidepressant effects, of magnetic seizure therapy and electroconvulsive therapy, in treatment-resistant depression. J Psychiatr Res.
26 Cuijpers P, Geraedts AS, van Oppen P, et al. (2011). Interpersonal psychotherapy for depression: a meta-analysis. Am J Psychiatry.
27 Ishak WW, Ha K, Kapitanski N, et al. (2011). The impact of psychotherapy, pharmacotherapy, and their combination on quality of life in depression. Harv Rev Psychiatry.
28 Nieuwsma JA, Trivedi RB, McDuffie J, et al. (2012). Brief psychotherapy for depression: a systematic review and meta-analysis. Int J Psychiatry Med.
29 Ross EL, Grigoriadis S, Mamisashvili L. (2013). Selected pregnancy and delivery outcomes after exposure to antidepressant medication: A systematic review and meta-analysis. JAMA Psychiatry.
30 't Jong GW, Einarson T, Koren G, et al. (2012). Antidepressant use in pregnancy and persistent pulmonary hypertension of the newborn (PPHN): A systematic review. Reprod Toxicol.
31 Bromley RL, Wieck A, Makarova D, et al. (2012). Fetal effects of selective serotonin reuptake inhibitor treatment during pregnancy: Immediate and longer term child outcomes. Fetal Matern Med Rev.
32 Sockol LE, Epperson CN, Barber JP. (2011). A meta-analysis of treatments for perinatal depression. Clin Psychol Rev.
33 Gentile S. (2011). Neonatal withdrawal reactions following late in utero exposure to antidepressant medications. Curr Womens Health Rev.
34 Wurst KE, Poole C, Ephross SA, et al. (2010). First trimester paroxetine use and the prevalence of congenital, specifically cardiac, defects: a meta-analysis of epidemiological studies. Birth Defects Res Part A Clin Mol Teratol.
35 Ng RC, Hirata CK, Yeung W, et al. (2010). Pharmacologic treatment for postpartum depression: a systematic review. Pharmacotherapy.
36 Kendall-Tackett K, Hale TW. (2010). The use of antidepressants in pregnant and breastfeeding women: a review of recent studies. J Hum Lact.
37 Santone G, Ricchi G, Rocchetti D, et al. (2009). Is the exposure to antidepressant drugs in early pregnancy a risk factor for spontaneous abortion? A review of available evidences. Epidemiol Psichiatr Soc.
38 Myles N, Newall H, Ward H, et al. (2013). Systematic meta-analysis of individual selective serotonin reuptake inhibitor medications and congenital malformations. Aust N Z J Psychiatry.
39 Grigoriadis S, VonderPorten EH, Mamisashvili L. (2013). Antidepressant exposure during pregnancy and congenital malformations: is there an association? A systematic review and meta-analysis of the best evidence. J Clin Psychiatry.
40 Grigoriadis S, VonderPorten EH, Mamisashvili L. (2013). The effect of prenatal antidepressant exposure on neonatal adaptation: a systematic review and meta-analysis. J Clin Psychiatry.
41 Painuly N, Heun R, Painuly R, et al. (2013). Risk of cardiovascular malformations after exposure to paroxetine in pregnancy: meta-analysis. Psychiatrist.
42 (2012). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
43 Moher D, Liberati A, Tetzlaff J, et al. (2009). Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS medicine.
44 McDonagh MS, Jonas DE, Gartlehner G, et al. (2012). Methods for the Drug Effectiveness Review Project. BMC Med Res Methodol.
45 Whitlock EP, Lin JS, Chou R, et al. (2008). Using existing systematic reviews in complex systematic reviews. Ann Intern Med.
46 (2001). Center for Reviews and Dissemination. Undertaking Systematic Reviews of Research on Effectiveness: CRD's Guidance for Those Carrying Out or Commissioning Reviews. CRD Report Number.
47 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med.
48 Fu R, Gartlehner G, Grant M, et al. (2011). Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
49 Guyatt GH, Norris SL, Schulman S, et al. (2012). Methodology for the development of antithrombotic therapy and prevention of thrombosis guidelines. Chest.
50 Sutton AJ, Abrams KR, Jones DR, et al. (2000). Methods for Meta-Analysis in Medical Research.
51 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
52 Higgins JPT, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
53 Owens D, Lohr K, Atkins D, et al. (2012). Chapter 10. Grading the Strength of a Body of Evidence When Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
54 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol.
55 Alwan S, Reefhuis J, Botto LD, et al. (2010). Maternal use of bupropion and risk for congenital heart defects. Am J Obstet Gynecol.
56 Alwan S, Reefhuis J, Rasmussen SA, et al. (2007). Use of selective serotonin-reuptake inhibitors in pregnancy and the risk of birth defects. N Engl J Med.
57 Andrade SE, McPhillips H, Loren D, et al. (2009). Antidepressant medication use and risk of persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf.
58 Appleby L, Warner R, Whitton A, et al. (1997). A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ.
59 Bakker MK, De Walle HEK, Wilffert B, et al. (2010). Fluoxetine and infantile hypertrophic pylorus stenosis: a signal from a birth defects-drug exposure surveillance study. Pharmacoepidemiol Drug Saf.
60 Bakker MK, Kerstjens-Frederikse WS, Buys CHCM, et al. (2010). First-trimester use of paroxetine and congenital heart defects: a population-based case-control study. Birth Defects Res Part A Clin Mol Teratol.
61 Ban L, Tata LJ, West J, et al. (2012). Live and non-live pregnancy outcomes among women with depression and anxiety: A population-based study. PLoS ONE.
62 Batton B, Batton E, Weigler K, et al. (2013). In utero antidepressant exposure and neurodevelopment in preterm infants. Am J Perinatol.
63 Bérard A, Ramos É, Rey É, et al. (2007). First trimester exposure to paroxetine and risk of cardiac malformations in infants: The importance of dosage. Birth Defects Res B Dev Reprod Toxicol.
64 Berle JO, Steen VM, Aamo TO, et al. (2004). Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry.
65 Bloch M, Meiboom H, Lorberblatt M, et al. (2012). The effect of sertraline add-on to brief dynamic psychotherapy for the treatment of postpartum depression: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry.
66 Bogen DL, Hanusa BH, Moses-Kolko E, et al. (2010). Are maternal depression or symptom severity associated with breastfeeding intention or outcomes?. J Clin Psychiatry.
67 Boucher N, Bairam A, Beaulac-Baillargeon L. (2008). A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol.
68 Bracken MB, Holford TR. (1981). Exposure to prescribed drugs in pregnancy and association with congenital malformations. Obstet Gynecol.
69 Casper RC, Fleisher BE, Lee-Ancajas JC, et al. (2003). Follow-up of children of depressed mothers exposed or not exposed to antidepressant drugs during pregnancy. J Pediatr.
70 Chambers CD, Hernandez-Diaz S, Van Marter LJ, et al. (2006). Selective serotonin-reuptake inhibitors and risk of persistent pulmonary hypertension of the newborn. N Engl J Med.
71 Chambers CD, Johnson KA, Dick LM, et al. (1996). Birth outcomes in pregnant women taking fluoxetine. N Engl J Med.
72 Chun-Fai-Chan B, Koren G, Fayez I, et al. (2005). Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol.
73 Cole JA, Ephross SA, Cosmatos IS, et al. (2007). Paroxetine in the first trimester and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf.
74 Cole JA, Modell JG, Haight BR, et al. (2007). Bupropion in pregnancy and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf.
75 Colvin L, Slack-Smith L, Stanley FJ, et al. (2010). Linking a pharmaceutical claims database with a birth defects registry to investigate birth defect rates of suspected teratogens. Pharmacoepidemiol Drug Saf.
76 Colvin L, Slack-Smith L, Stanley FJ, et al. (2011). Dispensing patterns and pregnancy outcomes for women dispensed selective serotonin reuptake inhibitors in pregnancy. Birth Defects Res Part A Clin Mol Teratol.
77 Colvin L, Slack-Smith L, Stanley FJ, et al. (2012). Early morbidity and mortality following in utero exposure to selective serotonin reuptake inhibitors: a population-based study in Western Australia. CNS Drugs.
78 Costei AM, Kozer E, Ho T, et al. (2002). Perinatal outcome following third trimester exposure to paroxetine. Arch Pediatr Adolesc Med.
79 Croen LA, Grether JK, Yoshida CK, et al. (2011). Antidepressant use during pregnancy and childhood autism spectrum disorders. Arch Gen Psychiatry.
80 Davidson S, Prokonov D, Taler M, et al. (2009). Effect of exposure to selective serotonin reuptake inhibitors in utero on fetal growth: potential role for the IGF-I and HPA axes. Pediatr Res.
81 Davis RL, Rubanowice D, McPhillips H, et al. (2007). Risks of congenital malformations and perinatal events among infants exposed to antidepressant medications during pregnancy. Pharmacoepidemiol Drug Saf.
82 De Vera MA, Bérard A. (2012). Antidepressant use during pregnancy and the risk of pregnancy-induced hypertension. Br J Clin Pharmacol.
83 de Vries NKS, van der Veere CN, Reijneveld SA, et al. (2013). Early Neurological Outcome of Young Infants Exposed to Selective Serotonin Reuptake Inhibitors during Pregnancy: Results from the Observational SMOK Study. PLoS ONE.
84 Diav-Citrin O, Shechtman S, Weinbaum D, et al. (2008). Paroxetine and fluoxetine in pregnancy: a prospective, multicentre, controlled, observational study. Br J Clin Pharmacol.
85 Djulus J, Koren G, Einarson TR, et al. (2006). Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry.
86 Dubnov-Raz G, Hemila H, Vurembrand Y, et al. (2012). Maternal use of selective serotonin reuptake inhibitors during pregnancy and neonatal bone density. Early Hum Dev.
87 Dubnov-Raz G, Juurlink DN, Fogelman R, et al. (2008). Antenatal use of selective serotonin-reuptake inhibitors and QT interval prolongation in newborns. Pediatrics.
88 Einarson A, Bonari L, Voyer-Lavigne S, et al. (2003). A multicentre prospective controlled study to determine the safety of trazodone and nefazodone use during pregnancy. Can J Psychiatry.
89 Einarson A, Choi J, Einarson TR, et al. (2009). Rates of spontaneous and therapeutic abortions following use of antidepressants in pregnancy: results from a large prospective database. J Obstet Gynaecol Can.
90 Einarson A, Choi J, Einarson TR, et al. (2009). Incidence of major malformations in infants following antidepressant exposure in pregnancy: results of a large prospective cohort study. Can J Psychiatry.
91 Einarson A, Choi J, Einarson TR, et al. (2010). Adverse effects of antidepressant use in pregnancy: an evaluation of fetal growth and preterm birth. Depress Anxiety.
92 Einarson A, Choi J, Koren G, et al. (2011). Outcomes of infants exposed to multiple antidepressants during pregnancy: results of a cohort study. J Popul Ther Clin Pharmacol.
93 El Marroun H, Jaddoe VWV, Hudziak JJ, et al. (2012). Maternal use of selective serotonin reuptake inhibitors, fetal growth, and risk of adverse birth outcomes. Arch Gen Psychiatry.
94 Ericson A, Kallen B, Wiholm B. (1999). Delivery outcome after the use of antidepressants in early pregnancy. Eur J Clin Pharmacol.
95 Ferreira E, Carceller AM, Agogue C, et al. (2007). Effects of selective serotonin reuptake inhibitors and venlafaxine during pregnancy in term and preterm neonates. Pediatrics.
96 Figueroa R. (2010). Use of antidepressants during pregnancy and risk of attention-deficit/hyperactivity disorder in the offspring. J Dev Behav Pediatr.
97 Galbally M, Lewis AJ, Buist A. (2011). Developmental outcomes of children exposed to antidepressants in pregnancy. Aust N Z J Psychiatry.
98 Galbally M, Lewis AJ, Lum J, et al. (2009). Serotonin discontinuation syndrome following in utero exposure to antidepressant medication: prospective controlled study. Aust N Z J Psychiatry.
99 Gorman JR, Kao K, Chambers CD. (2012). Breastfeeding among women exposed to antidepressants during pregnancy. J Hum Lact.
100 Grzeskowiak LE, Gilbert AL, Morrison JL. (2012). Neonatal outcomes after late-gestation exposure to selective serotonin reuptake inhibitors. J Clin Psychopharmacol.
101 Hale TW, Kendall-Tackett K, Cong Z, et al. (2010). Discontinuation syndrome in newborns whose mothers took antidepressants while pregnant or breastfeeding. Breastfeed Med.
102 Hanley GE, Brain U, Oberlander TF. (2013). Infant developmental outcomes following prenatal exposure to antidepressants, and maternal depressed mood and positive affect. Early Hum Dev.
103 Heikkinen T, Ekblad U, Kero P, et al. (2002). Citalopram in pregnancy and lactation. Clin Pharmacol Ther.
104 Jimenez-Solem E, Andersen JT, Petersen M, et al. (2012). Exposure to selective serotonin reuptake inhibitors and the risk of congenital malformations: A nationwide cohort study. BMJ Open.
105 Jimenez-Solem E, Andersen JT, Petersen M, et al. (2013). SSRI Use During Pregnancy and Risk of Stillbirth and Neonatal Mortality. Am J Psychiatry.
106 Jordan AE, Jackson GL, Deardorff D, et al. (2008). Serotonin reuptake inhibitor use in pregnancy and the neonatal behavioral syndrome. J Matern Fetal Neonatal Med.
107 Kallen B. (2004). Neonate characteristics after maternal use of antidepressants in late pregnancy. Arch Pediatr Adolesc Med.
108 Kallen B, Olausson PO. (2008). Maternal use of selective serotonin re-uptake inhibitors and persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf.
109 Kallen BAJ, Otterblad Olausson P. (2007). Maternal use of selective serotonin re-uptake inhibitors in early pregnancy and infant congenital malformations. Birth Defects Res Part A Clin Mol Teratol.
110 Kieler H, Artama M, Engeland A, et al. (2012). Selective serotonin reuptake inhibitors during pregnancy and risk of persistent pulmonary hypertension in the newborn: population based cohort study from the five Nordic countries. BMJ.
111 Klieger-Grossmann C, Weitzner B, Panchaud A, et al. (2012). Pregnancy outcomes following use of escitalopram: a prospective comparative cohort study. J Clin Pharmacol.
112 Klinger G, Frankenthal D, Merlob P, et al. (2011). Long-term outcome following selective serotonin reuptake inhibitor induced neonatal abstinence syndrome. J Perinatol.
113 Kornum JB. (2010). Use of selective serotonin-reuptake inhibitors during early pregnancy and risk of congenital malformations: updated analysis. Clin Epidemiol.
114 Kulin NA, Pastuszak A, Sage SR, et al. (1998). Pregnancy outcome following maternal use of the new selective serotonin reuptake inhibitors: a prospective controlled multicenter study. JAMA.
115 Laine K, Heikkinen T, Ekblad U, et al. (2003). Effects of exposure to selective serotonin reuptake inhibitors during pregnancy on serotonergic symptoms in newborns and cord blood monoamine and prolactin concentrations. Arch Gen Psychiatry.
116 Lanza di Scalea T, Hanusa BH, Wisner KL. (2009). Sexual function in postpartum women treated for depression: results from a randomized trial of nortriptyline versus sertraline. J Clin Psychiatry.
117 Latendresse G, Ruiz RJ. (2011). Maternal corticotropin-releasing hormone and the use of selective serotonin reuptake inhibitors independently predict the occurrence of preterm birth. J Midwifery Womens Health.
118 Lennestal R, Kallen B. (2007). Delivery outcome in relation to maternal use of some recently introduced antidepressants. J Clin Psychopharmacol.
119 Levinson-Castiel R, Merlob P, Linder N, et al. (2006). Neonatal abstinence syndrome after in utero exposure to selective serotonin reuptake inhibitors in term infants. Arch Pediatr Adolesc Med.
120 Lewis AJ, Galbally M, Opie G, et al. (2010). Neonatal growth outcomes at birth and one month postpartum following in utero exposure to antidepressant medication. Aust N Z J Psychiatry.
121 Logsdon MC, Wisner K, Hanusa BH. (2009). Does maternal role functioning improve with antidepressant treatment in women with postpartum depression?. J Womens Health (Larchmt).
122 Logsdon MC, Wisner K, Sit D, et al. (2011). Depression treatment and maternal functioning. Depress Anxiety.
123 Louik C, Lin AE, Werler MM, et al. (2007). First-trimester use of selective serotonin-reuptake inhibitors and the risk of birth defects. N Engl J Med.
124 Lund N, Pedersen LH, Henriksen TB. (2009). Selective serotonin reuptake inhibitor exposure in utero and pregnancy outcomes. Arch Pediatr Adolesc Med.
125 Malm H, Artama M, Gissler M, et al. (2011). Selective serotonin reuptake inhibitors and risk for major congenital anomalies. Obstet Gynecol.
126 Manakova E, Hubickova L. (2011). Antidepressant drug exposure during pregnancy. CZTIS small prospective study. Neuroendocrinol Lett.
127 Maschi S, Clavenna A, Campi R, et al. (2008). Neonatal outcome following pregnancy exposure to antidepressants: a prospective controlled cohort study. BJOG.
128 McElhatton PR, Garbis HM, Elefant E, et al. (1996). The outcome of pregnancy in 689 women exposed to therapeutic doses of antidepressants. A collaborative study of the European Network of Teratology Information Services (ENTIS). Reprod Toxicol.
129 McFarland J, Salisbury AL, Battle CL, et al. (2011). Major depressive disorder during pregnancy and emotional attachment to the fetus. Arch Womens Ment Health.
130 Merlob P, Birk E, Sirota L, et al. (2009). Are selective serotonin reuptake inhibitors cardiac teratogens? Echocardiographic screening of newborns with persistent heart murmur. Birth Defects Res Part A Clin Mol Teratol.
131 Misri S, Kendrick K, Oberlander TF, et al. (2010). Antenatal depression and anxiety affect postpartum parenting stress: a longitudinal, prospective study. Can J Psychiatry.
132 Misri S, Reebye P, Corral M, et al. (2004). The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. J Clin Psychiatry.
133 Misri S, Reebye P, Kendrick K, et al. (2006). Internalizing behaviors in 4-year-old children exposed in utero to psychotropic medications. Am J Psychiatry.
134 Misri S, Sivertz K. (1991). Tricyclic drugs in pregnancy and lactation: a preliminary report. Int J Psychiatry Med.
135 Mulder EJ, Ververs FF, de Heus R, et al. (2011). Selective serotonin reuptake inhibitors affect neurobehavioral development in the human fetus. Neuropsychopharmacology.
136 Nakhai-Pour HR, Broy P, Berard A. (2010). Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ.
137 Nijenhuis CM, ter Horst PGJ, van Rein N, et al. (2012). Disturbed development of the enteric nervous system after in utero exposure of selective serotonin re-uptake inhibitors and tricyclic antidepressants. Part 2: Testing the hypotheses. Br J Clin Pharmacol.
138 Nordeng H, van Gelder MMHJ, Spigset O, et al. (2012). Pregnancy outcome after exposure to antidepressants and the role of maternal depression: results from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol.
139 Nulman I, Koren G, Rovet J, et al. (2012). Neurodevelopment of children following prenatal exposure to venlafaxine, selective serotonin reuptake inhibitors, or untreated maternal depression. Am J Psychiatry.
140 Nulman I, Rovet J, Stewart DE, et al. (1997). Neurodevelopment of children exposed in utero to antidepressant drugs. N Engl J Med.
141 Nulman I, Rovet J, Stewart DE, et al. (2002). Child development following exposure to tricyclic antidepressants or fluoxetine throughout fetal life: a prospective, controlled study. Am J Psychiatry.
142 Oberlander TF, Bonaguro RJ, Misri S, et al. (2008). Infant serotonin transporter (SLC6A4) promoter genotype is associated with adverse neonatal outcomes after prenatal exposure to serotonin reuptake inhibitor medications. Mol Psychiatry.
143 Oberlander TF, Eckstein Grunau R, Fitzgerald C, et al. (2002). Prolonged prenatal psychotropic medication exposure alters neonatal acute pain response. Pediatr Res.
144 Oberlander TF, Misri S, Fitzgerald CE, et al. (2004). Pharmacologic factors associated with transient neonatal symptoms following prenatal psychotropic medication exposure. J Clin Psychiatry.
145 Oberlander TF, Papsdorf M, Brain UM, et al. (2010). Prenatal effects of selective serotonin reuptake inhibitor antidepressants, serotonin transporter promoter genotype (SLC6A4), and maternal mood on child behavior at 3 years of age. Arch Pediatr Adolesc Med.
146 Oberlander TF, Reebye P, Misri S, et al. (2007). Externalizing and attentional behaviors in children of depressed mothers treated with a selective serotonin reuptake inhibitor antidepressant during pregnancy. Arch Pediatr Adolesc Med.
147 Oberlander TF, Warburton W, Misri S, et al. (2006). Neonatal outcomes after prenatal exposure to selective serotonin reuptake inhibitor antidepressants and maternal depression using population-based linked health data. Arch Gen Psychiatry.
148 Oberlander TF, Warburton W, Misri S, et al. (2008). Effects of timing and duration of gestational exposure to serotonin reuptake inhibitor antidepressants: population-based study. Br J Psychiatry.
149 Oberlander TF, Warburton W, Misri S, et al. (2008). Major congenital malformations following prenatal exposure to serotonin reuptake inhibitors and benzodiazepines using population-based health data. Birth Defects Res Part B Dev Reprod Toxicol.
150 Okun ML, Kiewra K, Luther JF, et al. (2011). Sleep disturbances in depressed and nondepressed pregnant women. Depress Anxiety.
151 Okun ML, Luther JF, Wisniewski SR, et al. (2012). Disturbed sleep, a novel risk factor for preterm birth?. J Womens Health (Larchmt).
152 Palmsten K, Setoguchi S, Margulis AV, et al. (2012). Elevated risk of preeclampsia in pregnant women with depression: depression or antidepressants?. Am J Epidemiol.
153 Pastuszak A, Schick-Boschetto B, Zuber C, et al. (1993). Pregnancy outcome following first-trimester exposure to fluoxetine (Prozac). JAMA.
154 Pawluski JL, Galea LAM, Brain U, et al. (2009). Neonatal S100B protein levels after prenatal exposure to selective serotonin reuptake inhibitors. Pediatrics.
155 Pearlstein TB, Zlotnick C, Battle CL, et al. (2006). Patient choice of treatment for postpartum depression: a pilot study. Arch Women Ment Health.
156 Pearson KH, Nonacs RM, Viguera AC, et al. (2007). Birth outcomes following prenatal exposure to antidepressants. J Clin Psychiatry.
157 Pedersen L, Henriksen T, Bech B, et al. (2013). Prenatal antidepressant exposure and behavioral problems in early childhood - A cohort study. Acta Psychiatr Scand.
158 Pedersen LH, Henriksen TB, Olsen J. (2010). Fetal exposure to antidepressants and normal milestone development at 6 and 19 months of age. Pediatrics.
159 Pedersen LH, Henriksen TB, Vestergaard M, et al. (2009). Selective serotonin reuptake inhibitors in pregnancy and congenital malformations: population based cohort study. BMJ.
160 Polen KND, Rasmussen SA, Riehle-Colarusso T, et al. (2013). Association between reported venlafaxine use in early pregnancy and birth defects, national birth defects prevention study, 1997-2007. Birth Defects Res A Clin Mol Teratol.
161 Rai D, Lee BK, Dalman C, et al. (2013). Parental depression, maternal antidepressant use during pregnancy, and risk of autism spectrum disorders: population based case-control study. BMJ.
162 Ramos E, St-Andre M, Berard A. (2010). Association between antidepressant use during pregnancy and infants born small for gestational age. Can J Psychiatry.
163 Ramos E, St-Andre M, Rey E, et al. (2008). Duration of antidepressant use during pregnancy and risk of major congenital malformations. Br J Psychiatry.
164 Rampono J, Proud S, Hackett LP, et al. (2004). A pilot study of newer antidepressant concentrations in cord and maternal serum and possible effects in the neonate. Int J Neuropsychopharmcol.
165 Rampono J, Simmer K, Ilett KF, et al. (2009). Placental transfer of SSRI and SNRI antidepressants and effects on the neonate. Pharmacopsychiatry.
166 Reebye P, Morison SJ, Panikkar H, et al. (2002). Affect expression in prenatally psychotropic exposed and nonexposed mother-infant dyads. Infant Ment Health J.
167 Reis M, Kallen B. (2010). Delivery outcome after maternal use of antidepressant drugs in pregnancy: an update using Swedish data. Psychol Med.
168 Salisbury AL, Wisner KL, Pearlstein T, et al. (2011). Newborn neurobehavioral patterns are differentially related to prenatal maternal major depressive disorder and serotonin reuptake inhibitor treatment. Depress Anxiety.
169 Salkeld E, Ferris LE, Juurlink DN. (2008). The risk of postpartum hemorrhage with selective serotonin reuptake inhibitors and other antidepressants. J Clin Psychopharmacol.
170 Sharp DJ, Chew-Graham C, Tylee A, et al. (2010). A pragmatic randomised controlled trial to compare antidepressants with a community-based psychosocial intervention for the treatment of women with postnatal depression: the RESPOND trial. Health Technol Assess.
171 Simon GE, Cunningham ML, Davis RL. (2002). Outcomes of prenatal antidepressant exposure. Am J Psychiatry.
172 Sit D, Perel JM, Wisniewski SR, et al. (2011). Mother-infant antidepressant concentrations, maternal depression, and perinatal events. J Clin Psychiatry.
173 Sivojelezova A, Shuhaiber S, Sarkissian L, et al. (2005). Citalopram use in pregnancy: prospective comparative evaluation of pregnancy and fetal outcome. Am J Obstet Gynecol.
174 Smith MV, Sung A, Shah B, et al. (2013). Neurobehavioral assessment of infants born at term and in utero exposure to serotonin reuptake inhibitors. Early Hum Dev.
175 Stephansson O, Kieler H, Haglund B, et al. (2013). Selective serotonin reuptake inhibitors during pregnancy and risk of stillbirth and infant mortality. JAMA.
176 Suri R, Altshuler L, Hellemann G, et al. (2007). Effects of antenatal depression and antidepressant treatment on gestational age at birth and risk of preterm birth. Am J Psychiatry.
177 Suri R, Altshuler L, Hendrick V, et al. (2004). The impact of depression and fluoxetine treatment on obstetrical outcome. Arch Women Ment Health.
178 Suri R, Hellemann G, Stowe ZN, et al. (2011). A prospective, naturalistic, blinded study of early neurobehavioral outcomes for infants following prenatal antidepressant exposure. J Clin Psychiatry.
179 Ter Horst PGJ, Bos HJ, De Jong-Van De Berg LTW, et al. (2013). In utero exposure to antidepressants and the use of drugs for pulmonary diseases in children. Eur J Clin Pharmacol.
180 Toh S, Mitchell AA, Louik C, et al. (2009). Antidepressant use during pregnancy and the risk of preterm delivery and fetal growth restriction. J Clin Psychopharmacol.
181 Toh S, Mitchell AA, Louik C, et al. (2009). Selective serotonin reuptake inhibitor use and risk of gestational hypertension. Am J Psychiatry.
182 Ververs TF, van Wensen K, Freund MW, et al. (2009). Association between antidepressant drug use during pregnancy and child healthcare utilisation. BJOG.
183 Wan MW, Sharp DJ, Howard LM, et al. (2011). Attitudes and adjustment to the parental role in mothers following treatment for postnatal depression. J Affect Disord.
184 Wen SW, Yang Q, Garner P, et al. (2006). Selective serotonin reuptake inhibitors and adverse pregnancy outcomes. Am J Obstet Gynecol.
185 Wichman CL, Moore KM, Lang TR, et al. (2009). Congenital heart disease associated with selective serotonin reuptake inhibitor use during pregnancy. Mayo Clin Proc.
186 Wilson KL, Zelig CM, Harvey JP, et al. (2011). Persistent pulmonary hypertension of the newborn is associated with mode of delivery and not with maternal use of selective serotonin reuptake inhibitors. Am J Perinatol.
187 Wisner KL, Bogen DL, Sit D, et al. (2013). Does fetal exposure to SSRIs or maternal depression impact infant growth?. Am J Psychiatry.
188 Wisner KL, Hanusa BH, Perel JM, et al. (2006). Postpartum depression: a randomized trial of sertraline versus nortriptyline. J Clin Psychopharmacol.
189 Wisner KL, Sit DKY, Hanusa BH, et al. (2009). Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry.
190 Wogelius P, Norgaard M, Gislum M, et al. (2006). Maternal use of selective serotonin reuptake inhibitors and risk of congenital malformations. Epidemiology.
191 Yonkers KA, Lin H, Howell HB, et al. (2008). Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry.
192 Yonkers KA, Norwitz ER, Smith MV, et al. (2012). Depression and serotonin reuptake inhibitor treatment as risk factors for preterm birth. Epidemiology.
193 Zeskind PS, Stephens LE. (2004). Maternal selective serotonin reuptake inhibitor use during pregnancy and newborn neurobehavior. Pediatrics.
194 Liberati A, Altman DG, Tetzlaff J, et al. (2009). The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate healthcare interventions: explanation and elaboration. BMJ.
195 Institute of Medicine. (1990). Nutrition During Lactation: Subcommittee on Nutritional Status and Weight Gain during Pregnancy.
196 International Classification of Diseases (ICD).
197 EUROCAT: European Surveillance of Congenital Anomalies.
198 Holmes LB, Westgate MN. (2011). Inclusion and exclusion criteria for malformations in newborn infants exposed to potential teratogens. Birth Defects Res A Clin Mol Teratol.
199 Holmes LB, Westgate MN. (2012). Using ICD-9 codes to establish prevalence of malformations in newborn infants. Birth Defects Res A Clin Mol Teratol.
200 Lu M, Lange L, Slusser W, et al. (2001). Provider encouragement of breast-feeding: Evidence from a National Survey. Obstet Gynecol.
201 Philipp BL, Malone KL, Cimo S, et al. (2003). Sustained breastfeeding rates at a US baby-friendly hospital. Pediatrics.
202 Su LL, Chong YS, Chan YH, et al. (2007). Antenatal education and postnatal support strategies for improving rates of exclusive breast feeding: randomised controlled trial. BMJ.
203 Howland RH. (2010). Update on St. John's wort. J Psychosoc Nurs Ment Health Serv.
204 Moyer M. (2011). Why Pregnant Women Deserve Drug Trials. Body Politic [Blog].
205 The Second Wave Initiative. Toward the Responsible Inclusion of Pregnant Women in Research.
206 Research involving pregnant women or fetuses [45 CFR Part 46B Section 204]. In Code of Federal Regulations. Title 45: Public Welfare. Part 46: Protection of Human Subjects. Subpart B: Additional Protections for Pregnant Women, Human Fetuses and Neonates Involved in Research.
207 Aguilera A, Munoz RF. (2011). Text messaging as an adjunct to CBT in low-income populations: A usability and feasibility pilot study. Professional Psychology Research & Practice.
208 Boschen MJ, Casey LM. (2008). The use of mobile telephones as adjuncts to cognitive behavioral psychotherapy. Professional Psychology Research & Practice.
209 Moritz S, Schilling L, Hauschildt M, et al. (2012). A randomized controlled trial of internet-based therapy in depression. Behaviour Research and Therapy.