# Methods

The methods for this comparative effectiveness review follow the methods suggested in the ARHQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”42 The main sections in this chapter reflect the protocol elements established for the comparative effectiveness review; certain methods map to the PRISMA checklist.43 All methods and analyses were determined a priori. The research protocol was posted on the AHRQ Effective Health Care program Web site (http://www.effectivehealthcare.ahrq.gov), and we registered the protocol in the systematic review registry, PROSPERO (http://www.crd.york.ac.uk/NIHR_PROSPERO/).

## Search Strategy

To identify articles relevant to each Key Question, the librarian searched the Cochrane Database of Systematic Reviews (CDSR) from 2005 to July 2013, the Cochrane Central Register of Controlled Trials (CCRCT) July 2013, the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^) from 1941 to July 2013, Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ from 1946 to July 2013, PsychINFO^®^ from 1996 to July 2013, and Scopus® from 1974 to July 2013. Search dates and exact search strings are provided in Appendix A. Date restrictions are not placed on database searches. ClinicalTrials.gov was searched for gray literature. Scientific Information Packets were solicited from industry stakeholders through the Scientific Resource Center.

## Inclusion and Exclusion Criteria

### Populations

We defined the populations of interest as pregnant women and women during the first 12 months after delivery, who received treatment for a depressive episode, including:

- Women who met the diagnostic criteria for a major depressive disorder as described in the 4th edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-IV)18
- Women with subthreshold depressive symptoms that became the subject of clinical attention

We excluded populations of women who met the DSM-IV diagnosis for bipolar depression, psychotic depression, a mood disorder secondary to a general medical condition, or a mood disorder secondary to substance abuse.

This report focuses chiefly on women diagnosed with depression during pregnancy or the postpartum period, rather than on those with a continuing episode. The one exception is for Key Question 2e regarding teratogenicity of antidepressant drugs taken at the time of conception or in early pregnancy. Based on input from experts, we also included studies with populations of pregnant women receiving antidepressant drugs for unknown or mixed reasons. These studies were used to provide evidence when no evidence was available in women with known depression or depressive symptoms (gaps in the evidence). To differentiate these populations, in this report we refer to studies of women with known depression as “treated” or “untreated” populations, and studies of women with mixed or unknown diagnoses as “exposed” populations when receiving antidepressants (typically at unknown doses) or “nonexposed” populations when not receiving antidepressants.

### Interventions

Interventions included commonly used antidepressant drugs (see Table 1). Drugs no longer commonly used (e.g., monoamine oxidase inhibitors) were not included. We used the therapeutic classifications used in previous AHRQ Comparative Effectiveness Reviews,19,20 except that trazodone and nefazodone were classified as norepinephrine reuptake inhibitors for this report.

### Comparators

Comparators were:

- The drugs listed in Table 1 when compared with each other
- Placebo or no treatment
- Usual care: We defined usual care as receiving pregnancy and postpartum care similar to those with normal risk pregnancies. When “usual care” was the comparator, two reviewers with experience in delivering postpartum health care (JR and JMG) separately determined if it was “usual,” and if they believed it not to be usual, it was included as a separate “greater than usual care” comparator.
- Other active pharmacological treatments used to augment drugs with a U.S. Food and Drug Administration indication for unipolar or bipolar depression
- Any nonpharmacological treatment, including but not limited to over-the-counter treatments, osteopathic or naturopathic treatments, herbal remedies and vitamins, all forms of psychotherapy, case management, electroconvulsive therapy, nonrepetitive and repetitive transcranial magnetic stimulation, vagal nerve stimulation, exercise, meditation, and touch therapies. We recognized the important differences between these treatments and considered them separately when compared with pharmacological treatments, rather than as a group.

### Outcomes

Details on the maternal and child benefits and harms outcomes included in the review appear in Table 2.

Table 2 Maternal and child benefits and harms outcomes included in the review

Maternal Benefits | Fetus, Infant, Child Benefits
- Danger to self—suicidal and nonsuicidal behaviors; - Danger to infant—infanticidal behavior, abuse, or neglect); - Depression symptomatology as scored using validated scales measuring depression: response, remission, speed and duration of response or remission, relapse, recurrence; - Anxiety symptoms as scored as a subscale item using validated scales measuring depression, or validated scales used to measure anxiety symptoms; - Functional capacity; ○ Quality of life using validated scales, e.g., Medical Outcomes Survey 36-Item Short Form (SF-36); ○ Caring for self, infant, and family; ○ Mother-father dyad interaction success, including reduced violence among intimate partners; ○ Work productivity; - Delivery and postpartum parameters; ○ Breastfeeding; ○ Shared decision making around delivery choices (e.g., cesarean) and delivery mode; ○ Mother-infant dyad interaction patterns; ○ Pregnancy weight gain within or outside of 1990 Institute of Medicine Guidelines; - Social services utilization; prevention of child protective service involvement; - Maternal health system resource utilization including emergency department use, hospitalizations, and office visits; - Adherence or persistence with treatment regimen | - Parameters at birth and up to 12 months of age: preterm birth, e.g., < 32 weeks, < 37 weeks; appropriate growth (height, weight, and head circumference); gestational age, e.g., small for gestational age with race or ethnicity taken into consideration; birth hospitalization length of stay; infant attachment; developmental screening—Ages and Stages Questionnaire, Denver, Modified Checklist for Autism in Toddlers, Bayley Scales of Infant Development; - Growth and development after 1 year of age; ○ Developmental screening and diagnoses; growth parameters, such as height, weight, and body mass index percentile according to sex and age; ○ Learning, e.g., linguistic, cognitive, and social-emotional skills, and educational achievement; kindergarten readiness; age at kindergarten entry; third grade testing outcomes; other standard testing outcomes (eighth grade, etc.); ○ Intelligence tests (any), individualized education plans, use of school services; ○ School failure or dropout rate, high school graduation rate, missed school days; - Stress-related chronic disease, mental and Chronic illness; - Infant health system visits, e.g., well baby visits); health care utilization, including primary care, emergency department, hospitalization; - Social services utilization—Women, Infants, and Children Program (WIC), community health nurse, social worker, State Department of Health and Human Services, free or reduced-price lunch, and food stamps; - Community resource utilization; - Contact with juvenile justice system; - Social and emotional development, quality of life
Maternal Harms | Fetus, Infant, Child Harms
- Death, including suicide, all-cause mortality, and cause-specific death (e.g., cardiac death) | - All-cause mortality
- Specific adverse effects or withdrawals due to specific adverse events related to treatment, e.g., hyponatremia, activation of mania or hypomania, seizures, suicidal ideation, hepatoxicity, weight gain, metabolic syndrome, gastrointestinal symptoms, and loss of libido | - Congenital anomalies (any) Stratified into major and minor with further grouping by organ system or type of anomaly
- Overall adverse-event reports, adverse events associated with discontinuation of treatment, and serious adverse events; - Withdrawals from study and discontinuation of treatment due to adverse events | - Other specific adverse events, e.g., withdrawal symptoms (neonatal abstinence symptoms), pulmonary hypertension, respiratory distress, neonatal convulsions, and heart defects

### Timing

- All followup periods were eligible.

### Setting

- Studies conducted in economically advanced countries, as designated by the International Monetary Fund (http://www.imf.org/external), were included: Australia, Austria, Belgium, Canada, Cyprus, the Czech Republic, Denmark, Finland, France, Germany, Greece, Hong Kong, Iceland, Ireland, Israel, Italy, Japan, South Korea, Luxembourg, Malta, The Netherlands, New Zealand, Norway, Portugal, Singapore, the Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Taiwan, the United Kingdom, and the United States.

### Study Designs

- For efficacy or effectiveness, a “best evidence” approach was used. Randomized controlled clinical trials and systematic reviews comparing pharmacologic treatments for depression during pregnancy to control groups of pregnant women with depression who were treated with nonpharmacologic or no treatment were included as the top-tier evidence. If insufficient evidence was found with these study designs, we included observational study evidence (defined as cohort studies comparing at least two concurrent treatment groups, case-control studies, and time-series studies) and studies that had control groups of nonexposed pregnant women.
- For harms, in addition to randomized controlled clinical trials (RCTs) and systematic reviews, observational studies (defined as cohort studies comparing at least two concurrent treatment groups, case-control studies, and time-series studies) comparing pharmacologic treatments for depression during pregnancy to control groups of pregnant women with depression who were treated with nonpharmacologic or no treatment were included. If insufficient evidence was found with these designs, studies comparing to control groups of nonexposed pregnant women were included.
- The criteria for systematic reviews required that the review (1) searched at least two databases and (2) discussed methodology of quality assessment and data abstraction. In accordance with established methodologies, any included systematic reviews would be used in place of de novo analysis and synthesis of the included studies whenever possible, depending on the details of how closely the review matched our report scope and how recent the review was.44,45 We excluded case reports, case series, and single-group studies.

## Study Selection

Two reviewers independently assessed titles and abstracts of publications identified through literature searches using the criteria described above for inclusion and exclusion of studies. We retrieved full text articles of potentially relevant citations and two reviewers assessed these for inclusion and exclusion. Disagreements were resolved by consensus or a third-party arbitrator. Results published only in abstract form were not included because they do not provide enough information to assess the risk of bias of the study. At the full text level of review, we excluded studies if they met one or more of the following exclusion reasons: published in a language other than English; the intervention, outcome, population, and study design did not meet inclusion criteria; or they were letters, editorials, or nonsystematic reviews. Appendix B lists all studies included at full text review, and Appendix C lists all studies excluded at full text review, along with the exclusion reasons. All citations and screening decisions for each citation were entered in an electronic database (Endnote^®^ X3, Thomson Reuters).

## Data Extraction

The following data were abstracted from included studies: design; setting (community, private, or public clinic or hospital); population characteristics (race, age, socioeconomic status, family history of depressive/mood disorders, prior use of antidepressive drugs, severity of symptoms, situation at home, unplanned pregnancy, marital/partner status, comorbidities); study eligibility and exclusion criteria; characteristics of diagnosis (whether depression was detected during screening or not, time of diagnosis, method of diagnosis, and when treatment commenced relative to the onset of symptoms); intervention characteristics (dose, duration, and co-interventions); comparisons; medical provider characteristics (primary care physician, obstetrician, psychiatrist, nurse, midwife, community worker, and pediatrician visits); numbers of patients enrolled; and results for each outcome. One reviewer abstracted study data, and a second reviewer checked a random selection of data abstractions. Intention-to-treat results were recorded if available. Appendix E contains evidence tables for data abstraction of trials and observational studies. Studies that were considered high risk of bias were not abstracted as they were not included in the evidence synthesis.

## Risk of Bias Assessment of Individual Studies

We assessed the risk of bias (internal validity) of RCTs and cohort and case control studies based on predefined criteria established by the Drug Effectiveness Review Project.44 For trials, these criteria were based initially on the criteria used by the U.S. Preventive Services Task Force and the National Health Service Centre for Reviews and Dissemination (United Kingdom).46,47 In rating the risk of bias of trials, we evaluated methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; adequate reporting of dropouts, attrition, crossover, adherence, and contamination; loss to followup; and the use of intention-to-treat analysis.

We rated the risk of bias of observational studies based on the adequacy of the patient selection process, whether there was important differential loss to followup or overall high loss to followup, the adequacy of exposure and event ascertainment, whether acceptable statistical techniques were used to minimize potential confounding factors, and whether the duration of followup was reasonable to capture investigated events. Based on input from experts, we identified as key for all outcomes four potential confounding factors—age, race, parity, and other exposures (e.g., alcohol, smoking, and other potential teratogens)—factors to be adjusted for in analyses of observational studies. Low or moderate risk of bias studies that adjusted for these factors were considered best evidence if no RCTs were available.

All assessments resulted in a rating of high, medium or low risk of bias, primarily at the study level. In some cases, however, the reviewers determined that internal validity varied by outcome and rated risk of bias for different outcomes separately. Studies that have a fatal flaw were rated high risk of bias; studies that meet all criteria are rated low risk of bias; the remainder are rated medium risk of bias. As the medium risk of bias category is broad, studies with this rating vary in their strengths and weaknesses: The results of some medium risk of bias studies are likely to be valid, while others are only possibly valid. The results of a high risk of bias study are not valid; the results are at least as likely to reflect flaws in the study design as a true difference between the compared interventions. A fatal flaw is detected by failure of a study to meet combinations of items of the risk of bias checklist.

All studies were first rated by one reviewer and then checked by another reviewer, with disagreements resolved by consensus.

## Data Synthesis

Evidence tables were constructed to show the study characteristics, quality ratings, and results for all included studies. A hierarchy-of-evidence approach was used, where the best evidence is the focus of our synthesis for each question, population, intervention, and outcome addressed. Based on input from experts, we stratified our assessment of congenital anomalies into major and cardiovascular categories. Most cardiovascular malformations are considered to be major malformations in congenital anomaly classification systems and were included in our evaluation of major congenital anomalies as a whole. But due to our experts' particular concern for cardiovascular malformations with depression and/or pharmacologic therapy for depression, we also separately evaluated subsets of cardiovascular anomalies as reported in the studies. Data from high risk of bias studies were generally excluded from the synthesis, except to undertake sensitivity analyses or to note where high risk of bias studies constitute the only evidence for an important outcome.

We preferred direct comparisons over indirect comparisons, so they are the focus of our synthesis. We considered three types of directness: populations, intervention comparisons, and outcomes. Direct evidence consists of studies that (1) included the population of interest (depressed pregnant or postpartum women) in both intervention and control groups, (2) made the comparisons of interest (pharmacological treatments compared with each other, nonpharmacological interventions or no treatment), and (3) measured outcomes of interest directly (not using proxy measures, e.g. laboratory values). In this report, direct evidence included studies (trials or observational studies) that compared pregnant or postpartum women with depression who received antidepressant treatment with pregnant or postpartum women with depression who were not treated.

Indirect evidence included trials or observational studies of pregnant or postpartum women treated with antidepressants without specifying that the women had depression. Similarly, studies that compared pregnant or postpartum women who took an antidepressant drug with pregnant or postpartum women who did not take such medications but also were not known to have a diagnosis of depression (a general population) were considered indirect evidence. Indirect comparisons can be difficult to interpret for several reasons; in the latter case the issue is primarily heterogeneity of underlying risk of the populations. The underlying risk of untreated depression during pregnancy or the postpartum period is an important factor in assessing the relative benefits and harms of potential treatments. We used data from indirect comparisons when no other directly applicable evidence exists, but readers should interpret findings with caution because comparisons with a generally healthy population without depression rather than with a depressed population may underestimate the benefits and overestimate the harms of treatment.

We generally did not use data from high risk of bias studies in our main analysis, except to undertake sensitivity analyses for meta-analyses or when high risk of bias studies constituted the only evidence for an important outcome. (High risk of bias studies are not presented in the data evidence tables, but they are included in the risk of bias assessment evidence tables in Appendix E.) To determine the appropriateness of meta-analysis, we considered the internal validity of the studies and the heterogeneity among studies in design, patient population, interventions, and outcomes. Appropriate measures are chosen based on the type of data for meta-analysis, according to the guidance for the EPC program.48 Random-effects models were used to estimate pooled effects, except when only two studies were being pooled we used a fixed effect model.49,50 The Q statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess heterogeneity in effects between studies.51,52 When statistical heterogeneity was found, we explored the reasons by using subgroup analysis. For rare events, such as congenital malformations, relative risks would be similar to odds ratios. In meta-analysis, we combined relative risks and odds ratios for such outcomes. Where adjusted summary measures (e.g., odds ratios) were reported by individual studies, we combined summary measures using the 95% confidence intervals to estimate variance.

When meta-analysis could not be performed, the data were summarized qualitatively, grouping studies by similarity of population and/or intervention characteristics.

## Strength of the Body of Evidence

We used the methods outlined in the original chapter 10^53^ of the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (an edited version of the chapter has also been published in the Journal of Clinical Epidemiology54) to grade strength of evidence. Domains considered in grading the strength of evidence included consistency, directness, precision, and risk of bias. Based on this assessment, the body of evidence was assigned a strength-of-evidence grade of high, moderate, or low.

A rating of high means that we have high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect, while a rating of low means that we have low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of the effect and to change the estimate. In cases in which evidence did not exist, was sparse, or contained irreconcilable inconsistency, we assigned a grade of insufficient evidence. A rating of insufficient means that the evidence either is unavailable or does not permit estimation of an effect.

We consulted our technical experts to help us set priorities for the outcomes for grading. For any comparison with at least moderate risk-of-bias evidence, we selected specific outcomes for rating as follows. For maternal outcomes, we graded danger to self or infant, depression symptomatology (response and remission), breastfeeding intention and duration, number with adverse events, discontinuation due to adverse events, and weight gain. For infant outcomes, we graded preterm birth, small for gestational age, neonatal mortality, congenital malformations, persistent pulmonary hypertension, infant and child neurodevelopment, intellectual function, educational outcome and school performance, mental health, and health care or social service utilization.

## Applicability

We assessed applicability by examining study eligibility criteria, characteristics of the enrolled population in comparison to the target population, characteristics of the intervention and comparator used in comparison with care models currently in use, and clinical relevance and timing of the outcome measures. Technical experts identified items of particular interest that contribute to heterogeneity and impact applicability. In general, these included the subgroups specified in Key Question 3: population characteristics—race, age, socioeconomic status, family history of depressive or mood disorders, prior use of antidepressive drugs, severity of symptoms, situation at home, unplanned pregnancy, and marital/partner status; comorbid anxiety diagnoses and other comorbidities; characteristics of diagnosis—whether depression was detected during screening or not, time of diagnosis, method of diagnosis, and when treatment commenced relative to the onset of symptoms; intervention characteristics—dose, duration, and co-interventions; comparisons; and medical provider characteristics—primary care physician, obstetrician, pediatrician, psychiatrist, nurse, midwife, or community worker. We also considered how the evidence may be used by health care funders such as the Federal Children's Health Insurance Program (CHIP) to inform the development of quality measures.

## Peer Review and Public Commentary

Experts in treating and studying depression during pregnancy and postpartum, along with individuals representing stakeholder and user communities, provided external peer review of a draft of this comparative effectiveness review; AHRQ and an EPC associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comments. All comments were reviewed and addressed in a disposition of comments report that will be made available 3 months after the Agency posts the final report of the review on the AHRQ Web site (www.effectivehealthcare.ahrq.gov).