# Introduction

## Background

### Condition

Depression is a potentially life-threatening condition. With an incidence during pregnancy and the postpartum period estimated to be anywhere from 5.5 to 33.1 percent, the American Academy of Pediatrics estimates that more than 400,000 infants are born each year to mothers who are depressed.1-5 During the postpartum period, up to 85 percent of women experience some type of mood disturbance.3-6

Depression during pregnancy is known to be associated with harmful prenatal health consequences such as poor nutrition and poor prenatal medical care, risk of suicide, and harmful health behaviors, such as smoking and alcohol or other substance misuse. These circumstances compromise the health of both the woman and her fetus.7,8 Although causation has not been proven, several adverse obstetric complications have been reported with untreated prenatal depression, including pre-eclampsia, preterm delivery, low birth weight, miscarriage, small-for-gestational-age babies, low Apgar scores, and neonatal complications.9,10 These complications may be more common among women with lower socioeconomic status.9-11 In addition to being debilitating for the mother, postpartum depression affects maternal-infant interactions and some measures of infant development. In extreme cases postpartum depression may increase the risk of infant mortality through neglect, abuse, or homicide.12 It also negatively affects interactions within other members of the family unit and is associated with intimate partner violence.13

Depression during pregnancy and the postpartum period has a range of presentations, including continuation or relapse of a pre-existing mood disorder, development of changes in mood during pregnancy and the postpartum period, and postpartum “baby blues.” Differentiating the correct diagnosis can be complex. Problems with mood are often accompanied by co-existing anxiety and occasionally by potentially life-threatening psychosis.14

General risk factors for depression include female sex, previous depression, family history of depression, poor social support, and substance abuse. Additional factors associated with depression in pregnant women include younger age, being without a partner, traumatic events within the previous 12 months, and pregnancy complications.2,15 A 2013 Agency for Healthcare Research and Quality (AHRQ) report found that screening can significantly reduce postpartum depressive symptoms when there are systems in place to ensure adequate followup of women with positive results.16

### Treatment Strategies

Decisionmaking surrounding treatment of depression in pregnancy is complex because the potential harms of treatments must be balanced against the potential harms to mother and fetus of untreated depression. Management of mood disorders in pregnancy or the postpartum period varies case by case. In women with existing depression, the tactic may be to stabilize symptoms before attempting pregnancy. But providers and patients are often concerned about the safety of continued pharmacological treatment to the fetus during pregnancy and the postpartum period, particularly if the prospective mother is considering breastfeeding.17 This makes information about the comparative effectiveness of nonpharmacological treatments for depression during pregnancy of high interest. Treatment choice, or dosing, may vary by the severity of depression, for example, whether the symptoms meet criteria for a diagnosis of major depressive disorder according to the 4th edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM IV),18 are subclinical (symptoms are present but not meeting these criteria), or whether there are other co-existing psychiatric symptoms (most typically anxiety). Thus clear and accurate diagnosis, and reporting of diagnosis, is important to understanding the benefits and harms of treatment.

Interventions for depression both during pregnancy and in the postpartum period can include pharmacological treatments, nonpharmacological treatments, and watchful waiting or no intervention. Pharmacological treatments approved by the U.S. Food and Drug Administration (FDA) for treating depression are listed in Table 1. Antidepressant medications are also used to treat a variety of other indications, including anxiety disorders (e.g., generalized anxiety disorder, panic attacks, obsessive compulsive disorder, depressed phase of bipolar disorder, and neuropathic pain).

Table 1 Pharmacologic interventions: Antidepressant agents

Drug Category | Generic Name | Trade Name
Selective serotonin reuptake inhibitor (SSRI) | Citalopram | Celexa^®^, various generics
Selective serotonin reuptake inhibitor (SSRI) | Escitalopram | Lexapro^®^
Selective serotonin reuptake inhibitor (SSRI) | Fluoxetine | Prozac^®^, various generics Prozac Weekly^®^ Sarafem^®^
Selective serotonin reuptake inhibitor (SSRI) | Fluvoxamine | Luvox ^®^, various generics Luvox CR^®^
Selective serotonin reuptake inhibitor (SSRI) | Sertraline | Zoloft ^®^, various generics
Selective serotonin reuptake inhibitor (SSRI) | Paroxetine | Paxil^®^, various generics Paxil CR^®^
Selective serotonin reuptake inhibitor (SSRI) | Vilazodone | Viibryd^®^
Serotonin norepinephrine reuptake inhibitor (SNRI) | Desvenlafaxine | Pristiq^®^
Serotonin norepinephrine reuptake inhibitor (SNRI) | Venlafaxine | Effexor XR^®^
Serotonin norepinephrine reuptake inhibitor (SNRI) | Mirtazapine | Remeron ^®^, various generics Remeron Soltab^®^
Selective serotonin norepinephrine reuptake (SSNRI) | Duloxetine | Cymbalta^®^
Tricyclic antidepressants (TCAs) | Amitriptyline | Various generics
Tricyclic antidepressants (TCAs) | Desipramine | Norpramin^®^, various generics
Tricyclic antidepressants (TCAs) | Imipramine | Tofranil^®^, various generics
Tricyclic antidepressants (TCAs) | Nortriptyline | Aventyl hydrochloride^®^ Pamelor™ Various generics
Norepinephrine reuptake inhibitors (NRIs) | Nefazodone | Various generics (previously available as Serzone^®^)
Norepinephrine reuptake inhibitors (NRIs) | Trazodone | Desyrel^®^, various generics
Other | Bupropion | Wellbutrin^®^ Wellbutrin SR^®^ Wellbutrin XL^®^ Forfivo XL^®^ Aplenzin^®^

Antidepressant medications have been shown to be effective at reducing the symptoms of depression in nonpregnant adults.19,20 In general, medications that are effective in treating conditions outside of pregnancy are often presumed to remain effective in pregnancy, but the developing fetus and changes in maternal physiology raise questions about safety and dosing of various agents. The FDA Pregnancy Category for safety to the fetus of antidepressant medications taken during pregnancy is category C (“animal reproduction studies have shown an adverse effect on the fetus and there are no adequate and well-controlled studies in humans, but potential benefits may warrant use of the drug in pregnant women despite potential risks”), with the exception of paroxetine which is category D (“there is positive evidence of human fetal risk based on adverse reaction data from investigational or marketing experience or studies in humans, but potential benefits may warrant use of the drug in pregnant women despite potential risks”). However, evidence on how the risk of one antidepressant compares to another when taken during pregnancy is not well understood. In the postpartum period, depressed mothers often have concerns regarding the use of antidepressants while breastfeeding. Providers can offer encouragement by educating women as to the well-documented benefits of breastfeeding and guide their choice of an individual antidepressant by considering the degree to which each antidepressant is known to pass into breast milk.21-23

There are also a wide array of nonpharmacological interventions that can be used to treat depression, including various psychotherapies, electroconvulsive therapy, transmagnetic stimulation, and acupuncture.24-28 Some of these may be used during pregnancy, while others may be reserved for use in the postpartum period (e.g., electroconvulsive therapy).

## Scope and Key Questions

Previous reviews broadly evaluated infant and child outcomes following all-purpose maternal use of antidepressants during pregnancy,29-41 but they did not focus on specific populations of women with depression. The objective of this systematic review was to compare the benefits and harms of various pharmacological treatment options, to each other and to nonpharmacological treatments, for depression during pregnancy or the postpartum period. The focus was on women who develop depression during pregnancy or the postpartum period, rather than those with a continuing episode. We assessed factors that might impact maternal and child outcomes, including patient, provider, or environmental factors and a prior history of depression. Negative effects of untreated disease and exposure to antidepressive drugs were evaluated, highlighting the treatment dilemmas confronting women with depression during pregnancy or the postpartum period. Finally, we identified issues that future studies should address so that women, health care providers, and other stakeholders can make optimally informed decisions based on balancing benefits and harms.

### Key Questions

The Agency for Healthcare Research and Quality wrote preliminary Key Questions based on input from the topic nominator. The Pacific Northwest Evidence-based Practice Center (EPC) revised the Key Questions and developed eligibility criteria to identify the populations, interventions, comparators, outcomes, timing, and study designs of interest. The EPC solicited additional input from the Technical Expert Panel (TEP).

#### Key Question 1 What are the comparative benefits of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

a. How do pharmacological treatments affect maternal and child^a^ outcomes when compared with placebo or no active treatment or usual care?
b. How do pharmacological treatments affect maternal and child outcomes when compared with each other (drug A vs. drug B)?
c. How do pharmacological treatments affect maternal and child outcomes when compared with active nonpharmacological treatments?
d. How does combination therapy affect maternal and child outcomes? The combinations include:
  i. Using a second drug to augment the effects of the primary drug and comparing this treatment with monotherapy with a single drug
  ii. Combining pharmacological treatments with nonpharmacological treatments and comparing them with nonpharmacological treatments alone
  iii. Comparing pharmacological treatments alone with pharmacological treatments used in combination with nonpharmacological treatments

#### Key Question 2 What are the comparative harms of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period?

a. How do pharmacological treatments affect maternal and child^a^ outcomes when compared with placebo or no active treatment or usual care?
b. How do pharmacological treatments affect maternal and child outcomes when compared with each other (drug A vs. drug B)?
c. How do pharmacological treatments affect maternal and child outcomes when compared with active nonpharmacological treatments?
d. How does combination therapy affect maternal and child outcomes? The combinations include:
  i. Using a second drug to augment the effects of the primary drug and comparing this treatment with monotherapy with a single drug
  ii. Combining pharmacological treatments with nonpharmacological treatments and comparing them with nonpharmacological treatments alone
  iii. Comparing pharmacological treatments alone with pharmacological treatments used in combination with nonpharmacological treatments
e. In babies born to women who become pregnant while taking medications to treat depression, what is the comparative risk of teratogenicity?

#### Key Question 3 Is there evidence that the comparative effectiveness (benefits or harms) of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period varies based on characteristics^b^ such as:

a. Patient characteristics—race, age, socioeconomic status, family history of depressive/mood disorders, prior use of antidepressive drugs (for treatment or prevention), severity of symptoms, situation at home, unplanned pregnancy, and marital/partner status?
b. Patient comorbidities (e.g., anxiety diagnoses)?
c. Intervention characteristics—dosing regimens and duration of treatments?
d. Co-administration of other psychoactive drugs, specifically, antipsychotics, anti-anxiety agents (e.g., benzodiazepines), and drugs for insomnia?
e. Medical provider characteristics (primary care physician, obstetrician, pediatrician, psychiatrist, nurse, midwife, or community worker)?
f. Medical care environment (community/private/public clinic or hospital)?
g. Characteristics of diagnosis—whether depression was detected during screening or not, time of diagnosis, method of diagnosis, and when treatment commenced relative to the onset of symptoms?

### Analytic Frameworks

The analytic frameworks (Figure 1) illustrate the population, interventions, outcomes, and adverse effects studied and their relationship to the Key Questions. The first framework relates to pregnant women with depression (far left) who receive treatment. This population was intended to be women with an episode of depression beginning during pregnancy, rather than a continuing episode. The exception was Key Question 2e, for which the population was intended to be taking an antidepressant during the time of conception. Treatment leads to health outcomes in the box on the far right of the figure, connected by the overarching line. This evidence is the topic of Key Question 1, as marked on the line. Treatment may lead to intermediate outcomes, such as changes in level of depression symptoms, or adverse events, both noted as separate boxes on the diagram. The evidence showing that better intermediate outcomes (e.g., symptoms) improves health outcomes (e.g., reduced risk of suicide) is represented by a dotted line between boxes; we did not review that literature in this report. The second framework relates to postpartum women with depression (far left), and again the outcomes that may result from treatment are depicted in relationship to each other, the treatments, and the Key Questions. The outcomes considered for postpartum women with depression differed from those considered for pregnant women.

Figure 1 Analytic frameworks for treatment of depression in pregnant and postpartum women

^a^ The interventions and outcomes are too numerous to illustrate in their entirety in this diagram. See the Methods section, Inclusion and Exclusion Criteria, for complete details on interventions and outcomes.FDA = U.S. Food and Drug Administration; KQ = Key Question

Framework 1a is an analytic framework that depicts the population, interventions, outcomes, and adverse effects describing the impact of depression in pregnant women. The population includes women receiving treatment for depression symptoms during conception, and during pregnancy. Above the population description is a box that describes interventions: US Food and Drug Administration-approved antidepressants (e.g., selective serotonin reuptake inhibitors and serotonin norepinephrine reuptake inhibitors) and nonpharmacological treatments (as comparators). Below the population is an oval that describes harms outcomes: maternal (all-cause mortality and specific adverse events) and fetus, infant, and child (all-cause mortality, congenital anomalies, and specific adverse events). To the right of the population is a box describing intermediate outcomes. These include maternal (mood and anxiety symptoms and intent to breastfeed) and fetus, infant, and child (gestational age, birth growth parameters, delivery mode, and breastfeeding). To the right of intermediate outcomes is a box describing health outcomes. Maternal outcomes include reduced risk of suicide, reduced morbidity, and quality of life. Fetus, infant, and child outcomes include educational achievement, growth and development, and quality of life. Framework+B2 1b is an analytic framework that depicts the population, interventions, outcomes, and adverse effects describing the impact of depression in postpartum women. The population includes women receiving treatment for depression symptoms during the postpartum period. Above the population description is a box that describes interventions: US Food and Drug Administration-approved antidepressants (e.g., selective serotonin reuptake inhibitors and serotonin norepinephrine reuptake inhibitors) and nonpharmacological treatments (as comparators). Below the population is an oval that describes harms outcomes: maternal (all-cause mortality and specific adverse events) and fetus, infant, and child (all-cause mortality, and specific adverse events). To the right of the population is a box describing intermediate outcomes. These include maternal (mood and anxiety symptoms and breastfeeding outcomes) and fetus, infant, and child (mother-infant dyad interactions, breastfeeding). To the right of intermediate outcomes is a box describing health outcomes. Maternal outcomes include reduced risk of suicide, reduced morbidity, and quality of life. Fetus, infant, and child outcomes include educational achievement, growth and development, and quality of life.

## Organization of This Report

The evidence below is organized first by Key Question, then by the subquestions of the Key Questions, then by pregnancy status at the time of exposure—during pregnancy or postpartum. Within those categories the evidence is presented by pharmacological class with all outcomes for a given class presented together, then by comparisons of pharmacological and nonpharmacological or combination therapy. Under each intervention individual outcomes are assessed; outcomes listed in the inclusions criteria (above) for which no evidence was found are not itemized below.

a A child is defined as a fetus, infant, or a child up to age 18.

b Other factors will be considered as they are identified within the comparative studies.