# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Matthew A. Broom, M.D., FAAP
  Assistant Professor of Pediatrics
  Department of Pediatrics
  Saint Louis University School of Medicine
  Saint Louis, MO
- Jocelyn Huang Schiller, M.D.
  Associate Professor, Pediatrics
  C.S. Mott Children's Hospital
  University of Michigan
  Ann Arbor, MI
- Kimberly A. Yonkers, M.D.
  Professor of Psychiatry and of Obstetrics, Gynecology, and Reproductive Sciences
  Director, PMS and Perinatal Psychiatric Research Program
  New Haven, CT