# Technical Expert Panel

In designing the review questions and methodology at the outset of this report, the EPC consulted several technical and content experts, reflecting a variety of viewpoints relevant to this topic. Technical experts consulted are expected to have divergent and possibly conflicting opinions. This diversity is helpful in achieving a well-rounded report. The study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Wendy Davis, Ph.D.
  Executive Director
  Postpartum Support International
  Portland, OR
- Adrienne Einarson, R.N.
  Assistant Director of Clinical Services
  Motherisk
  Toronto, Canada
- Cathy Emeis, Ph.D., C.N.M.
  Assistant Professor & Assistant Program Director for Nurse Midwifery
  Oregon Health & Science University
  School of Nursing
  Portland, OR
- RJ Gillespie, M.D., M.H.P.E.
  Medical Director, Oregon Pediatric Improvement Partnership
  Portland, OR
- Kimberly D. Gregory, M.D., M.P.H.
  Vice Chair, Women's Healthcare Quality and Performance Improvement, Department of Obstetrics and Gynecology
  Cedars Sinai Medical Center
  Los Angeles, CA
- Susan G. Kornstein, M.D.
  Professor of Psychiatry and Obstetrics/Gynecology
  Executive Director, Institute for Women's Health
  Director of Clinical Research, Department of Psychiatry
  Virginia Commonwealth University
  Editor-in-Chief, Journal of Women's Health
  Richmond, VA
- Evan Myers, M.D., M.P.H.
  Division of Clinical and Epidemiological Research, Department of Obstetrics and Gynecology
  Duke Evidence Synthesis Group, Duke Clinical Research Institute
  Duke University School of Medicine
  Walter L. Thomas Professor
  Duke University Medical Center
  Durham, NC
- Gail Erlick Robinson, M.D., D.Psych., FRCPC, O.Ont.
  Director, Women's Mental Health Program
  University Health Network
  Professor of Psychiatry and Obstetrics-Gynecology, University of Toronto
  Toronto, Canada
- Barbara Yawn, M.D., M.Sc., FAAFP
  Director of Research, Olmsted Medical Center
  Adjunct Professor, Department of Family and Community Health, University of Minnesota
  Rochester, MN