# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tracy Dana, M.L.S., for assistance with literature search strategy development; Leah Williams, B.S., for editorial support; Elaine Graham, M.L.S., for assistance with project management; and Gabriel Valles for article retrieval. We would also like to thank our AHRQ Task Order Officer, Suchitra Iyer, Ph.D., and Denise Dougherty, Ph.D., Children's Health Point of Contact at AHRQ, for their support and guidance in developing this report, and our Associate Editor, Kathleen Lohr, Ph.D., for her review of the report and meaningful comments.