# Discussion

## Key Findings and Strength of Evidence

The results of our review highlight important concerns over the state of the evidence on benefits and harms of treating depression during and after pregnancy. The majority of the comparative evidence applies to selective serotonin reuptake inhibitors (SSRIs) taken during pregnancy, with little evidence for other types of antidepressant drugs or nonpharmacological interventions. Additionally, the majority of the evidence for this report was indirect, in that studies made comparisons of outcomes for women who took an antidepressant during pregnancy for any reason, with women who did not take an antidepressant during pregnancy; proportions of women with depression in either group were rarely reported and never analyzed. The applicability of indirect evidence of findings from studies of pregnant women with unknown depression status is unclear. We are left with a small body of direct evidence: studies that were designed to directly compare the benefits and harms of pharmacological treatments for depression in pregnant or postpartum women.

The overarching findings for Key Question 1 on comparative benefits are that there is little direct evidence on the maternal benefits of antidepressants used to treat depression in pregnancy, including important health outcomes such as functional status. Our questions were intended to compare a broad range of benefits with antidepressants compared with each other, with nonpharmacological treatments, and with ‘usual care’ or no treatment. The evidence was divided into treatment during pregnancy and treatment during the postpartum period. With exposure during pregnancy, the evidence we found was limited initially by the population comparisons made (the control groups) and also by the way outcomes were measured. In addition, the evidence was limited to observational studies, and these studies were generally not designed to measure health outcomes when women are treated during pregnancy. We were left with spotty evidence that did not allow comparisons among the specific classes or individual drugs. For example, while anxiety is a common feature of depression during pregnancy, direct evidence on the impact of treatment on this symptom was lacking. Where we did have evidence (Table 9), it was based on one or two small studies, with some methodological problems (none were low risk of bias), imprecise estimates of effect, and inconsistency when more than one study was found. These factors led to strength of evidence ratings of insufficient for the benefit of SSRI treatment on depressive symptoms during pregnancy and no evidence for other drug classes or other possible benefits. Similarly, the evidence on the effects of SSRI treatment during pregnancy on breastfeeding outcomes was insufficient to draw conclusions, as it was limited to a single study reporting the duration of breastfeeding. While the duration was two months longer in the group that received psychotherapy alone (8.5 months) compared with the group treated with an SSRI plus psychotherapy (6.4 months, p = 0.4), the difference was not statistically significant and the study was very small (n = 44). In contrast, women treated for depression with an SSRI throughout pregnancy were found to have better functional capacity than those with depression but not treated in a single small study. Again, this evidence was insufficient to draw conclusions for the reasons noted above. Evidence for benefits in mothers was insufficient for other antidepressant drugs or for nonpharmacologic therapy, and for all other maternal benefit outcomes we studied.

The potential benefits we evaluated in children included outcomes related to parameters at birth, child development, diagnosis of chronic diseases, and health care utilization. Here evidence was again very limited, with only the effect of SSRI treatment for depression compared with no treatment on preterm birth and some child development scales studied in direct comparisons of these populations. Although no differences were found between groups on rates of preterm birth (defined as less than 37 weeks gestation), and most child development scales (SSRI-exposed infants may have lower scores on the Bayley Psychomotor Development Index), this evidence was insufficient to draw conclusions.

While we identified randomized controlled trials (RCTs) on treatment of postpartum depression, they were small and included limited comparisons and outcomes. For benefits to mothers, this direct evidence was insufficient to draw conclusions on the benefits of drug therapy compared with placebo or to other drug therapies, and we found no evidence comparing drug therapy to nondrug therapy. Evidence for other outcomes or comparisons either for exposure during pregnancy or in the postpartum period was either not found or insufficient.

Indirect evidence was available for several other benefits outcomes, including the risk of autism spectrum disorder or attention deficit/hyperactivity disorder (ADHD). Diagnosis of ADHD in the children by the age of 5 was found to be associated with use of bupropion use (OR 3.63; p< 0.02), particularly in the second trimester. In contrast, a diagnosis of ADHD was not associated with use of SSRIs or other antidepressants during pregnancy. Filling a prescription for an SSRI after pregnancy (timing not reported) was statistically significantly associated with increased risk of ADHD diagnosis by age five in the child (OR 2.04, p<0.001). These analyses controlled for parental mental health diagnoses and found that a diagnosis of depression in the mother was statistically significantly associated with the diagnosis of ADHD in the child (OR 2.58; p<0.001).

Two studies suggested that maternal use of SSRIs is statistically significantly associated with diagnosis of autism spectrum disorder (ASD) in the child (OR 1.82; 95% CI 1.14 to 2.91). Both studies examined other antidepressant drugs but grouped them differently, one finding an increased risk with TCAs and the other finding no increased risk with TCAs combined with SNRIs or NRIs. Although these results were controlled for depression, the comparison groups were women who did not receive an antidepressant during pregnancy, rather than women with untreated depression. The role of depression was examined in one study through subgroup analyses. Analysis of women with depression who received an SSRI compared with a population of pregnant women who did not receive an SSRI (depression status unknown) found the risk for ASD was statistically significantly elevated with a greater odds ratio than the overall analysis (OR 3.34, 95% CI 1.50 to 7.47), while the risk in women taking an SSRI for another indication was lower and not statistically significant (OR 1.61; 95% CI 0.85 to 3.06).

Evidence on Key Question 2, comparative harms of pharmacological and nonpharmacological treatments for women with depression during pregnancy and in the postpartum period, was also limited by the comparison groups selected by most studies (pregnant women taking an antidepressant for any reason). The overarching findings for harms associated with exposure during pregnancy are that there is limited direct evidence about serious infant harms, with suggestion of increased risk of respiratory distress associated with exposure to SSRIs. The only outcomes for which we had direct evidence are major malformations, convulsions and respiratory distress in the neonate after exposure to SSRIs in utero (Table 10). This evidence is insufficient to draw conclusions for major malformations due to the limitations of the few small studies found. Low strength evidence suggests that there is no increased risk of neonatal convulsions, but a statistically significant increase in risk of neonatal respiratory distress with use of SSRIs. The increase in risk for respiratory distress is a pooled unadjusted odds ratio of 1.91 (95% CI 1.63 to 2.24). Because this is low strength evidence, the findings are likely to be altered by future studies.

Table 10 Key findings and strength of evidence of directly comparative evidence for depression during pregnancy

Intervention | Comparison | Outcome | Strength of Evidence Conclusions
Pregnancy
Potential benefits
SSRIs+psychotherapy | Psychotherapy alone | Depressive symptoms | Insufficient; no conclusions drawn
SSRIs: Fluoxetine | No treatment | Depressive symptoms | Insufficient; no conclusions drawn
SSRIs | No treatment | Functional capacity | Insufficient; no conclusions drawn
SSRIs+psychotherapy | Psychotherapy alone | Breastfeeding | Insufficient; no conclusions drawn
SSRIs | No treatment | Preterm birth | Low; Risk not increased
SSRIs+psychotherapy | Psychotherapy alone | Infant and child development: Bayley Scales | Insufficient; no conclusions drawn
SSRIs | No treatment | Infant and child development: Brazelton Neonatal Behavioral Assessment Scale | Insufficient; no conclusions drawn
Potential harms
SSRIs | No treatment | Major malformations | Insufficient; no conclusions drawn
SSRIs+psychotherapy | Psychotherapy alone | Major malformations | Insufficient; no conclusions drawn
SSRIs | No treatment | Neonatal convulsions | Low; Risk not increased
SSRIs | No treatment | Neonatal respiratory distress | Low; Risk higher with SSRIs
SSRIs | TCA (nortriptyline) | Neonatal respiratory distress | Insufficient; no conclusions drawn
Postpartum
Potential benefits
Sertraline+brief dynamic psychotherapy | brief dynamic psychotherapy | Depressive symptoms. | Low No difference in response or remission
Sertraline | Sertraline+interpersonal psychotherapy | Depressive symptoms | Insufficient; no conclusions drawn
Paroxetine | Paroxetine+cognitive behavioral therapy | Depressive symptoms. | Low No difference in response or remission
Potential harms
Sertraline+brief dynamic psychotherapy | brief psychodynamic | Adverse events | Insufficient; no conclusions drawn
Sertraline | Sertraline+interpersonal psychotherapy | Adverse events | Insufficient; no conclusions drawn
Fluoxetine+cognitive behavioral therapy | cognitive behavioral therapy | Adverse events | Insufficient; no conclusions drawn

SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant

Indirect evidence was available for several other harms outcomes. In cases where there is a signal of a serious harm, this evidence may be useful both clinically and to direct future research. An increased risk of infant death in the first year of life was found with exposure to SSRIs (as a group and individually) during pregnancy, compared with nonexposed children (SSRIs OR 1.81; 95% CI 1.26 to 2.60). While exposure to SSRIs as a group did not result in increased risk of major malformations in infants, evidence indicated a small but statistically significant risk with exposure to fluoxetine (OR 1.14, 95% CI 1.01 to 1.30) or paroxetine (OR 1.17, 95% CI 1.02 to 1.35), but not the other SSRIs individually. Timing of exposure was primarily in the first trimester, although sensitivity analyses removing studies that may have included exposures at other time points did not alter the results. Similar results were found for cardiac malformations, except that limiting our analysis to the highest quality studies of fluoxetine resulted in a nonsignificant increase in risk. The increased risk with paroxetine was 1.49 (95% CI 1.20 to 1.85). TCAs were also associated with increased risk for major (OR 1.31; 95% CI 1.04 to 1.65) and cardiac malformations (OR 1.58; 95% CI 1.10 to 2.29). Evidence for other antidepressants was insufficient.

Persistent pulmonary hypertension was statistically significantly associated with maternal SSRI use during late pregnancy (OR 2.72; 95% CI 1.63 to 4.54). Indirect evidence suggested that neonatal withdrawal symptoms were more common with fluoxetine use during the first trimester (RR 8.7; 95% CI 2.9 to 26.6), and with SSRIs or venlafaxine (grouped) in late pregnancy, but suggested no difference in risk between SSRIs and SNRIs. The risk of respiratory distress in the neonate was statistically significantly elevated for SSRIs and TCAs, but not with SNRIs. The pooled odds ratio was 2.11 (95% CI 1.57 to 2.83), comparing TCA exposure to nonexposed pregnant women. A single study indicated no difference in the risk of respiratory depression in the infant with maternal exposure to SSRIs compared with nortriptyline.

Only a few well-designed studies examined the risk for teratogenicity with exposure to antidepressants during the conception period, and even fewer studies specifically isolated exposure during this period; the evidence was insufficient.

In Key Question 3, we attempted to examine a wide range of subgroups defined by patient and intervention characteristics. Given the difficulty we had in identifying direct evidence for the first two Key Questions with appropriate control and intervention groups, it is not surprising that we found very little evidence to address these questions. Based on the best evidence, with comparisons between pregnant women with depression who did and did not take an antidepressant during pregnancy, and with data stratified to continuous use and use during only one trimester, the duration of treatment did not appear to influence the risk of preterm birth. In the postpartum period, we found that multiple sessions of cognitive behavioral therapy were not superior to a single session, when both were combined with fluoxetine. Depressive symptom response to dynamic psychotherapy, with or without sertraline, did not vary based on depression severity level. For all other subgroups (including co-administration of other drugs, medical provider characteristics, medical care environments, and characteristics of diagnosis) the evidence was limited. For example, co-administration of antidepressants and benzodiazepines in pregnant women may modify or confound adverse outcomes in neonates, but most studies did not report on this exposure. This may have been due to decreasing prevalence of benzodiazepine use, but we were not able to draw conclusions. Studies with definite diagnosis of depression in all comparison groups and that had medium or low risk of bias provided only insufficient evidence to draw conclusions about variation in treatment effects.

Table 10 highlights the findings from studies of depression in pregnant or postpartum women; these studies were designed to compare directly the benefits or the harms of pharmacological treatments with other pharmacological treatments, nonpharmacological treatment, and/or no treatment. As noted, we regarded these investigations as direct evidence (all comparison groups comprised participants with depression). We believe that this is the best evidence for the Key Questions posed for this review, as it is unclear how untreated or nonpharmacologically treated depression in control groups, or indications other than depression in the treatment groups, may have affected outcomes in the remainder of the evidence. (Table 10 does not show outcomes for which we only had indirect evidence.)

## Findings in Relationship to What Is Already Known

Putting these findings into the context of prior comparative effectiveness evidence reviews was difficult; we did not identify any other studies with as broad a scope as ours or other reviews that applied comparable methodologies. For example, a review by Bromley, et al.,31 assessed fetal and child outcomes and SSRIs only, but those authors did not limit their comparison group to women with depression, so our results are quite different from theirs. Additionally, we formally assessed the risk of bias in individual studies and graded the strength of evidence for the body of evidence for each key outcome, which other reviews did not.29-41

## Applicability

The comparative evidence on pharmacological treatment during pregnancy was limited to observational studies that generally met criteria for effectiveness studies. The evidence on treatment for postpartum depression came almost entirely from RCTs that met criteria for efficacy studies. These studies were limited by the exclusion of patients with common comorbidities, such as drug and alcohol misuse/abuse, other Axis I disorders, and suicidal ideation, the lack of health outcomes and comprehensive assessment of adverse events, short study durations, and small sample sizes.

The majority of studies were indirect in terms of population, comparing women using antidepressants during pregnancy for any reason to nonexposed pregnant women, with rates of depression not reported for either group. As maternal depression is widely recognized as a risk factor for poorer pregnancy outcomes, the findings from all the studies that do not account for maternal depression likely have very low applicability to our target population of pregnant women with depression. The mean maternal age ranged from 26 years to 34 years. Few studies reported race or socioeconomic status. In the studies that reported race, the populations were predominantly White. When reported, a medium socioeconomic status level was most common, and applicability to lower U.S. socioeconomic groups, including lesser availability of resources (e.g., insurance, family support) and access to mental health care was certainly not clear. The data sources for these studies typically did not include access to information about depressive symptom severity, co-existing anxiety diagnoses and other mental health or medical conditions, family history of depressive/mood disorders, prior use of antidepressive drugs, situation at home, unplanned pregnancy, marital/partner status, etc.; therefore, we know very little about these important patient characteristics.

There was very little evidence available to assess the benefits and harms of nonpharmacological treatment modalities, and what we found was limited to treatment during the postpartum period. The clinical relevance of the nonpharmacological treatment modalities was difficult to assess because of the general lack of detail about the characteristics of these interventions. Likewise, the clinical relevance of the pharmacological treatment regimens was also difficult to assess, due to a general lack of information about dose, duration, and co-interventions.

Only approximately 30 percent of included studies were conducted in the United States. Canada and Nordic countries each accounted for additional thirds of the studies, respectively. Findings from many of the studies conducted in the United States and Canada may not be reflective of the general population in North America, due to their reliance on highly selected samples with participants who voluntarily called teratogen information services, had specific health plan membership, or who attended specific community prenatal clinics. As they primarily relied on birth registry data, the studies from the Nordic countries are likely the most representative of the broad general populations. It is unclear how the differences in the health care systems and demographic characteristics between the United States and the various Nordic countries impact the applicability of the findings from the Nordic country studies to the U.S. context. Provider characteristics were generally not reported.

We were looking for evidence on women with a new episode (not necessarily the first) of depression during pregnancy or postpartum, rather than a continuing episode. The studies were unclear on this point and most simply identified women taking an antidepressant during pregnancy, with few identifying proportions of women with a history of depression, and even fewer reporting the number with a continuing episode. None analyzed results based on these characteristics. We believe that the evidence base applies to a mixed group, and does not reflect clearly one or the other.

Overall, the applicability of this evidence to programs such as the federal Children's Health Insurance Program (CHIP) is somewhat limited because of the issues noted above. The large number of studies conducted in health care settings outside the United States and in samples of women with medium socioeconomic status likely limits how well this evidence applies to children served by the CHIP program.

## Implications for Clinical and Policy Decisionmaking

Depression during pregnancy and postpartum can have adverse consequences for both mother and child. Knowing the best course of action when a woman is diagnosed with depression during these times is extremely important. For multiple reasons, the evidence base at present is extremely limited in the specific guidance it can provide. Our overall findings were based on insufficient or low strength of evidence. This means that future studies are very likely to alter the findings in a meaningful way. The implications for decisionmaking for women with depression during pregnancy are unclear. Without better evidence specific to this population, the balance of benefit and harm are uncertain. Shared decisionmaking based on the best evidence available and a woman's particular characteristics and circumstances is the best use for a comparative effectiveness review such as this.

Based on the best evidence available today, the benefits to mothers are unclear. For pregnant women, treatment with drugs may offer benefits, although the specific benefits, particularly in terms of tangible benefits (health outcomes), and how benefits compare across potential treatments are still very unclear. Although we believe that treating depressed women with SSRIs is likely to improve some symptoms based on indirect evidence from studies of nonpregnant patients, direct evidence comparing the interventions of interest in the population of interest is currently insufficient. Similarly, the evidence on functional outcomes for the mother is unfortunately insufficient, although it leans towards better outcomes in women treated with an SSRI compared with untreated pregnant women

Women taking antidepressants may be less likely to breastfeed or to breastfeed for shorter durations than women who are not taking an antidepressant in the postpartum period. We did not find evidence of harm to the infant of breastfeeding while the mother was taking an antidepressant, although evidence was insufficient to draw specific conclusions. Clinicians can know in advance that, for women treated with antidepressants, decisions about breastfeeding can be problematic; thus, early discussion and support for maternal intention to breastfeed is warranted. Women who receive antenatal education and professional encouragement, or who report that their health care provider encouraged them to breastfeed are more likely to initiate and sustain breastfeeding.200-202 Antidepressants are widely used in postpartum women. For most antidepressants, no or only negligible amounts are passed from mother to baby through breast milk (fluoxetine and citalopram may be exceptions, but the amount varies with dose and frequency of dosing).21-23

Evidence on the comparative benefits of treating depression during pregnancy (compared with not treating) is expected to include benefits in developmental achievement in the child. Our evidence indicates that SSRIs result in no differences on most measures, but may result in slightly worse motor development than no treatment at all, but again this evidence is insufficient to guide clinical decisions. When making direct comparisons, while the evidence does not indicate higher rates of preterm birth with use of SSRIs during pregnancy (unadjusted OR 1.73; 95% CI 0.63 to 4.42), it is insufficient to guide clinical decisions.

Numerous potentially serious harms have been suggested to be associated with use of antidepressants during pregnancy. However, in the comparison of treated and untreated depressed women, we found only the risk for respiratory distress to be associated with SSRIs (as a drug class). The fact that different conclusions may be drawn for some outcomes based on a large body of evidence that we consider indirect for our questions highlights the importance of making clinically relevant comparisons.

An example is the risk of ASD in children of women treated for depression during pregnancy. The increasing prevalence of ASD diagnosis, likely in part attributable to increased detection, temporally parallels an increasing tendency to prescribe antidepressants in pregnancy. Based on indirect evidence, whether ASD in the child is associated with maternal depression during pregnancy, treatment with antidepressants, or a combination of the two, remains unclear. Although we found that ASD was associated with maternal exposure to antidepressants, particularly SSRIs, compared with the maternal nonexposure (depression status unknown), we did not find clear evidence on the risk when untreated depressed women were the comparison group. Any suggestion of increased risk for ASD is very concerning. In studies comparing with maternal nonexposure, although researchers controlled for depression, the relationship between depression, antidepressant use, and risk of ASD remains unclear. The small, but statistically significant risk of ASD diagnosis with antidepressant use or depression or both is important to understand better, because treatment could mitigate this risk if severe depression underlies the association with ASD. One study examined the risk of having depression during pregnancy and a diagnosis of ASD in the child, finding statistically significant increased odds in depressed mothers (with and without known treatment), and a nonsignificant increase in mothers without depression. An interaction between depression and antidepressant treatment is possible, but has not been fully elucidated. Nevertheless, women should be informed about the risk of ASD in their offspring if antidepressants are found more conclusively to increase this risk. Because the fraction of cases of ASD that could potentially be attributed to antidepressants in these studies is exceedingly small (0.6 to 2.5 percent of the study populations), prenatal antidepressant use is not a major risk factor for ASD and does not explain the increasing prevalence of autism.

Evidence on the benefits or harms of treatment of depression in the postpartum is insufficient to draw conclusions. Women and clinicians are currently left with only evidence in nonpregnant populations and evidence on intermediate outcomes (e.g., which drugs are passed into breast milk) to guide treatment choices.

## Limitations of the Review Process

Methodological limitations of the review within the defined scope included the exclusion of studies published in languages other than English and lack of a specific search for unpublished studies. The review process and results could have benefited from further refinement of the scope to limit inclusion of studies of pregnant or postpartum women with depression, both in the intervention and control groups.

## Gaps in the Research

A major caveat to interpreting the findings of the majority of observational studies of exposure during pregnancy is the potential confounding role of depression itself and its severity.152 Most of the studies identified women taking an antidepressant for any reason, with few reporting the proportions with depression and even fewer using this information in their analyses. Studies of women who were taking an antidepressant during or after pregnancy but not known to be depressed are problematic; a major drawback is that we do not know what the differential baseline risk of various outcomes are for the various indications for which antidepressants can be used. We do know, however, that some baseline risks are associated with depression during pregnancy; this fact underscores the importance of limiting the treated group to women with depression.7,8 In this report we were interested in women who became depressed during pregnancy, with or without prior episodes, but the studies do not report on the timing of diagnosis in most cases. Equally problematic is the control groups used in most of the studies, which were general populations of nonexposed pregnant women. These groups could have included a proportion of women with depression, but in general this characteristic is not reported. When it was reported, the range of depression in the control groups was large (from 6% to 36%). For much of the evidence, then, the comparison is mostly depressed-treated women compared with nondepressed, untreated women. This comparison is problematic because of known effects of untreated depression on both mother and child. A small number of studies set out to examine these questions by comparing to untreated, depressed, pregnant women, but these did not measure both benefits and harms (in both mother and baby) simultaneously.

Some clinicians or investigators may still hesitate to conduct RCTs in pregnant women.203 Nevertheless, the assumption that the comparative effectiveness of interventions in nonpregnant populations is directly applicable to pregnant women may not be valid for various reasons (e.g., changes in pharmacokinetics of the drugs); moreover, trials in nonpregnant populations do not measure outcomes specific to pregnant or postpartum women. Various groups do advocate for RCTs in pregnant women;204,205 furthermore, the U.S. Department for Health and Human Services outlines detailed rules206 on protecting pregnant women research subjects, their fetuses, and fathers. Because clinicians already prescribe antidepressants on a regular basis to pregnant women, RCTs comparing treatments and adequately measuring appropriate outcomes, with measurement of depression severity at baseline and during followup among such populations do not necessarily increase risk to either the women or their fetuses. Comparisons of specific treatments in pregnancy are badly needed to better uncover variation in risk across drugs, even within a class. Ascertainment of exposure, including both timing and dose, must be done in a way that insures accuracy and reliability. Outcomes should be determined by blinded evaluators, which is possible for nearly all outcomes considered here. Randomization would be the best approach to minimize potential confounding, but observational studies could also be done in a way that addresses the gaps in the research. For example, studies could identify women being treated for depression as the study population and make comparisons across treatments (including no treatment). These studies should adjust for important prognostic factors such as pre-existing illness, depression history, depression severity, age, race, parity, socioeconomic status, and other exposures (e.g., alcohol, smoking, and other potential teratogens).

Nonpharmacological treatments are generally thought to have fewer risks than antidepressants. Nonetheless, evidence is almost entirely lacking on this point or on the question of the effectiveness of combinations of drug and nondrug treatments. Newer approaches to nonpharmacological interventions using technology such as Internet-based therapies, web-camera counseling, and mobile phone applications are emerging. These may offer pregnant and postpartum women alternatives to more established treatments, particularly in lower-income or rural populations. 207-209

Studies of women in the postpartum period are both small and methodologically weak. These limitations leave a large gap in knowledge about treatments for a group of patients in whom RCTs could be undertaken. In addition to comparative efficacy (e.g., effects on symptoms) little is known about the benefits of treatments on important outcomes such as improving the mother-infant dyad, enhancing breastfeeding outcomes or reducing domestic violence. The need for specifically-designed research that addresses these problems is substantial.

## Conclusion

The current evidence base is insufficient to fully support clinical decisionmaking, which requires knowing both benefits and harms and being able to determine the tradeoffs that individual patients might make. For example, if a medication has a lower adverse event profile but is also less effective for a given condition, it would not make sense to prescribe that for a patient who needs treatment for that particular condition, just because of a lower adverse event profile. We know that depression during pregnancy and the postpartum period can lead to serious adverse outcomes for both mother and child, such that treatment is important. There is a real need for research in this area to simultaneously measure both benefits and harms so that better evidence can inform the tradeoffs that women and clinicians need to weigh in making their health care decisions.