# Appendix D Strength of Evidence

## Key Question 1a Maternal and Child Benefits: Pharmacotherapy Compared With Placebo or No Treatment

Table 1 Fluoxetine compared with no treatment during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression Symptomotology: Mean CES-D Score1
1; N=46 | High (1Observational/High) | Unknown | Direct | Unknown | Third trimester: 14.33 vs 25.93; P=0.0010 | Insufficient

Table 2 SSRIs compared with no treatment during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Functional capacity: SF-12 mental component score2
1; N=62 | Medium (1Observational/Medium) | Unknown | Direct | Unknown | 45.2 vs 35.3, post-hoc Scheffé tests described as showing a significant difference, but results not reported | Insufficient
Preterm birth3
2; N=266 | Medium (1Observational/Medium) | Consistent | Direct | Imprecise | Unadjusted OR 1.87 (95% CI; 0.89-3.89) | Low
Infant/Child Development: Brazelton Neonatal Behavioral Assessment Scale4
1; N=49 | Medium (1Observational/Medium) | Unknown | Direct | Unknown | No significant differences on any summary scores for 7 major clusters | Insufficient

Table 3 Paroxetine compared with placebo during the postpartum period5

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Danger to self
1; N=70 | High (RCT/High) | Unknown | Direct | Imprecise | No episodes | Insufficient
Danger to infant
1; N= 70 | High (RCT/High) | Unknown | Direct | Imprecise | No episodes | Insufficient
Depression response^1^
1; N= 70 | High (RCT/High) | Unknown | Direct | Imprecise | OR 1.31 (0.50-3.41) | Insufficient
Depression remission^2^
1; N=70 | High (RCT/High) | Unknown | Direct | Precise | OR 3.54 (1.10-11.41) | Insufficient
Breastfeeding
NA | NA | NA | NA | NA | No evidence | Insufficient
Weight gain
NA | NA | NA | NA | NA | No evidence | Insufficient

1 Response at week 8 as measured by Clinical Global Impression-Improvement (CGI-I ) of 1 or 2.

2 Remission by week 8 as measured by the 17 Item Hamilton rating Scale for Depression (HAM-D-17) ≤ 8.

## Key Question 1b Maternal and Child Benefits: Pharmacological Treatments Compared With Each Other

Table 4 Sertraline compared with nortriptyline during the postpartum period

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression response^1^ 6
1; N=109 | High (RCT/High) | Unknown | Direct | Imprecise | Week 4: OR 0.79 (0.28-2.19) | Insufficient
1; N=109 | High (RCT/High) | Unknown | Direct | Imprecise | Week 8: OR 0.99 (0.29-3.42) | Insufficient
Depression remission^2,6^
1; N=109 | High (RCT/High) | Unknown | Direct | Imprecise | Week 4: OR 1.04 (0.41-2.65) | Insufficient
1; N=109 | High (RCT/High) | Unknown | Direct | Imprecise | Week 8: OR 1.75 (0.69-4.38) | Insufficient
Intention to Breastfeed
| NA | NA | NA | NA | No evidence | Insufficient
Duration of Breastfeeding^3^ 7
1; N=70 | High (RCT/High) | Unknown | Direct | Imprecise | Week 8: OR 2.78 (0.86-8.94) | Insufficient
Weight gain
NA | NA | NA | NA | NA | No evidence | Insufficient

1 Response is considered >= 50% reduction in Hamilton Rating Scale for Depression (HSRD) .

2 Remission is considered a Hamilton Rating Scale for Depression (HRDS) <7.

3 Reported as breast feeding yes or no at 8^th^ week of study.

## Key Question 1d2 Maternal and Child Benefits: Pharmacological Treatments Plus Nonpharmacological Treatment Compared With Nonpharmacological Treatments Alone

Table 5 SSRIs plus psychotherapy compared with psychotherapy alone during pregnancy8

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression Symptomotology: BDI maximum score8
1; N=44 | Medium (1Observational/Medium) | Unknown | Direct | Imprecise | 21.3 vs 24.0; P=0.58 | insufficient
Breastfeeding: Mean duration in months
1; N=44 | Medium (Observational/Medium) | Unknown | Direct | Imprecise | 8.5 vs 6.4; P = 0.4 | Insufficient

Table 6 Sertraline and brief dynamic psychotherapy compared with brief psychodynamic psychotherapy during the postpartum period9

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression response^1^
1; N=40 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | Week 8: OR 1.91 (0.52-7.00) | Low
Depression remission^2^
1; N=40 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | Week 8: OR 3.09 (0.78-12.14) | Low
1; N=40 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | Week 12: OR 3.64 (0.34-39.02) | Low

1 Response was defined as >50% reduction in MADRS or EPDS scores.

2 Remission was considered as final score on the MADRS of <10 or the EPDS <7.

Table 7 Paroxetine plus cognitive behavioral therapy compared with cognitive behavioral therapy alone during the postpartum period10

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression response1, 2:
1; N=87 | Medium (RCT/Medium) | NA | NA | NA | No evidence | Insufficient

## Key Question 1d3 Maternal and Child Benefits: Comparing Pharmacological Treatments Alone With Pharmacological Treatments Used in Combination With Nonpharmacological Treatments

Table 8 Paroxetine compared with paroxetine plus cognitive behavioral therapy during the postpartum period11

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression response1, 2:
1; N=35 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | HAM-D^1^: OR 1.87 (0.29-11.84) | Low
1; N=35 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | EPDS^2^: OR 2.71 (0.73-10.04) | Low

1 Response on Hamilton Rating Scale for Depression (HAM-D) (>= 50% score reduction).

2 Response on Edinburgh Post Natal Depression Scale is (EDPS) (>= 50% score reduction).

Table 9 Sertraline compared with sertraline plus interpersonal psychotherapy during the postpartum period12

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Depression response
1; N=23 | High (RCT/High) | Unknown | Direct | Imprecise | No significant differences * | Insufficient
Depression remission
1; N=23 | High (RCT/High) | Unknown | Direct | Imprecise | No significant differences * | Insufficient

* ANCOVA adjusted for pretreatment depression

## Key Question 2a Maternal and Child Harms: Pharmacotherapy Compared With Placebo or No Treatment

Table 10 SSRIs compared with no treatment during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Major malformations2
1; N=72 | Medium (1 Observational/Medium) | Unknown | Direct | Imprecise | No events | Insufficient
Convulsions13
1; N=15,685 | Medium (1 observational/Medium) | Unknown | Direct | Precise | 0.14% vs 0.11%; RD 0.0005; 95% CI, -0.0015 to 0.0025) | Low
Respiratory Distress2, 8, 13
3; N=15,793 | Medium (3 observational/Medium) | Consistent | Direct | Precise | Pooled unadjusted OR 1.91 (95% CI, 1.63 to 2.24) | Low

Table 11 Bupropion compared with no treatment during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Major malformations14
1; N=126 | High (1 Observational/ High) | Unknown | Direct | Imprecise | No events | Insufficient

## Key Question 2b Maternal and Child Harms: Pharmacological Treatments Compared With Each Other

Table 12 SSRIs compared with TCAs (nortriptyline) during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Respiratory Distress15
1; N=21 | Medium (1Observational/Medium) | Unknown | Direct | Imprecise | 10% vs 0%; P not reported | Insufficient

Table 13 SSRIs compared with SSRIs during pregnancy

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Respiratory Distress15
1; N=20 | Medium (1Observational/Medium) | Unknown | Direct | Imprecise | 22% vs 0%, P=NR | Insufficient

Table 14 Sertraline compared with nortriptyline during the postpartum period6

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Overall adverse events and withdrawals due to adverse events
1; N=109 | High (1Observational/High) | Unknown | Direct | Imprecise | No events | Insufficient

## Key Question 2d2 Maternal and Child Harms: Pharmacological Treatments Plus Nonpharmacological Treatment Compared With Nonpharmacological Treatments Alone

Table 15 SSRIs plus psychotherapy compared with psychotherapy alone during pregnancy8

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Major malformations
1; N=44 | Medium (Observational/Medium) | Unknown | Direct | Imprecise | Unadjusted OR 0.40; 95% CI, 0.02 to 6.93 | Insufficient

Table 16 Sertraline and brief dynamic psychotherapy compared with brief psychodynamic psychotherapy during the postpartum period9

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
% Discontinuing due to adverse events
1; N=40 | Medium (RCT/Medium) | Unknown | Direct | Precise | OR 5.54 (0.25-123.09) | Insufficient

Table 17 Fluoxetine plus cognitive behavioral therapy compared with cognitive behavioral therapy alone during the postpartum period10

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
% Discontinuing due to adverse events
1; N=87 | Medium (RCT/Medium) | Unknown | Direct | Imprecise | 1 session: 0% vs 9%; P not reported 6 sessions: 5% vs 5%; P not reported | Insufficient

Table 18 Sertraline plus interpersonal therapy compared with interpersonal therapy alone during the postpartum period12

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
% Discontinuing due to adverse events
1; N=23 | High (RCT/High) | Unknown | Direct | Imprecise | No events | Insufficient

## Key Question 2d3 Maternal and Child Harms: Pharmacological Treatments Alone Compared With Pharmacological Treatments Plus Nonpharmacological Treatments

Table 19 Sertraline alone compared with sertraline plus interpersonal therapy during the postpartum period12

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of evidence
Number of studies; Number of subjects | Methodological Limitations | Consistency | Directness | Precision | Summary effect size (95% CI) | High, moderate, low, insufficient
Overall adverse events
1; N=23 | High (RCT/High) | Unknown | Direct | Imprecise | No events | Insufficient

## Appendix D. References

1 Suri R, Altshuler L, Hendrick V, et al. (2004). The impact of depression and fluoxetine treatment on obstetrical outcome. Archives of Women's Mental Health.
2 Wisner KL, Sit DKY, Hanusa BH, et al. (2009). Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. American Journal of Psychiatry.
3 Yonkers KA, Norwitz ER, Smith MV, et al. (2012). Depression and serotonin reuptake inhibitor treatment as risk factors for preterm birth. Epidemiology.
4 Suri R, Hellemann G, Stowe ZN, et al. (2011). A prospective, naturalistic, blinded study of early neurobehavioral outcomes for infants following prenatal antidepressant exposure. Journal of Clinical Psychiatry.
5 Yonkers KA, Lin H, Howell HB, et al. (2008). Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. Journal of Clinical Psychiatry.
6 Wisner KL, Hanusa BH, Perel JM, et al. (2006). Postpartum depression: a randomized trial of sertraline versus nortriptyline. Journal of Clinical Psychopharmacology.
7 Lanza di Scalea T, Hanusa BH, Wisner KL. (2009). Sexual function in postpartum women treated for depression: results from a randomized trial of nortriptyline versus sertraline. Journal of Clinical Psychiatry.
8 Casper RC, Fleisher BE, Lee-Ancajas JC, et al. (2003). Follow-up of children of depressed mothers exposed or not exposed to antidepressant drugs during pregnancy. Journal of Pediatrics.
9 Bloch M, Meiboom H, Lorberblatt M, et al. (2012). The effect of sertraline add-on to brief dynamic psychotherapy for the treatment of postpartum depression: a randomized, double-blind, placebo-controlled study. Journal of Clinical Psychiatry.
10 Appleby L, Warner R, Whitton A, et al. (1997). A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ.
11 Misri S, Reebye P, Corral M, et al. (2004). The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. Journal of Clinical Psychiatry.
12 Pearlstein TB, Zlotnick C, Battle CL, et al. (2006). Patient choice of treatment for postpartum depression: a pilot study. Archives of Women's Mental Health.
13 Oberlander TF, Warburton W, Misri S, et al. (2006). Neonatal outcomes after prenatal exposure to selective serotonin reuptake inhibitor antidepressants and maternal depression using population-based linked health data. Archives of General Psychiatry.
14 Bakker MK, Jentink J, Vroom F, et al. (2006). Drug prescription patterns before, during and after pregnancy for chronic, occasional and pregnancy-related drugs in the Netherlands. BJOG: An International Journal of Obstetrics and Gynaecology.
15 Sit D, Perel JM, Wisniewski SR, et al. (2011). Mother-infant antidepressant concentrations, maternal depression, and perinatal events. Journal of Clinical Psychiatry.