# Appendix C Excluded Studies

The following full text articles were reviewed for inclusion but failed to meet inclusion criteria for reasons specified below.

1: Foreign language, 2: ineligible outcome, 3: ineligible intervention, 4: ineligible population, 5: ineligible publication type, 6: ineligible study design, 8: outdated or ineligible systematic review.

Study | Exclusion Code
1. (2004). St John's wort and depression: slight efficacy at best, many drug interactions. Prescrire Int. | 5
2. (2004). Neonatal complications after intrauterine exposure to SSRI antidepressants. Prescrire Int. | 5
3. (2005). Bupropion (amfebutamone): caution during pregnancy. Prescrire Int. | 5
4. (2006). Prenatal exposure to mirtazapine and birth outcomes. | 5
5. (2007). Teratogenicity of SSRI antidepressants: study 2. | 5
6. (2008). Selective serotonin reuptake inhibitors and birth defects. | 5
7. (2009). Safety of SSRIs in pregnancy. Obstet Gynecol. | 5
8. (2012). Study: Both SSRI use and depression in pregnancy linked to risky birth outcomes. | 5
9. Altamura AC, De Gaspari IF, Rovera C, et al. (2013). Safety of SSRIs during pregnancy: A controlled study. Hum Psychopharmacol. | 2
10. Ananth J. (1975). Congenital malformations with psychopharmacologic agents. Compr Psychiatry. | 5
11. Andrade C. (2012). Selective serotonin reuptake inhibitors and persistent pulmonary hypertension of the newborn. J Clin Psychiatry. | 5
12. Andrade SE, Raebel MA, Brown J, et al. (2008). Use of antidepressant medications during pregnancy: a multisite study. Am J Obstet Gynecol. | 2
13. Appleby L, Koren G, Sharp D. (1999). Depression in pregnant and postnatal women: an evidence-based approach to treatment in primary care. Br J Gen Pract. | 5
14. Babu GN, Thippeswamy H, Chandra PS. (2013). Use of electroconvulsive therapy (ECT) in postpartum psychosis-a naturalistic prospective study. Arch Womens Ment Health. | 3
15. Bar-Oz B, Einarson T, Einarson A, et al. (2007). Paroxetine and congenital malformations: meta-Analysis and consideration of potential confounding factors. Clin Ther. | 8
16. Bellantuono C, Migliarese G, Gentile S. (2007). Serotonin reuptake inhibitors in pregnancy and the risk of major malformations: a systematic review. Hum Psychopharmacol. | 6
17. Berard A. (2010). Paroxetine exposure during pregnancy and the risk of cardiac malformations: what is the evidence?. Birth Defects Res Part A Clin Mol Teratol. | 5
18. Birnbaum CS, Cohen LS, Bailey JW, et al. (1999). Serum concentrations of antidepressants and benzodiazepines in nursing infants: A case series. Pediatrics. | 5
19. Blier P. (2006). Pregnancy, depression, antidepressants and breast-feeding. J Psychiatry Neurosci. | 5
20. Bodnar LM, Sunder KR, Wisner KL. (2006). Treatment with selective serotonin reuptake inhibitors during pregnancy: deceleration of weight gain because of depression or drug?. Am J Psychiatry. | 5
21. Boucher N, Koren G, Beaulac-Baillargeon L. (2009). Maternal use of venlafaxine near term: correlation between neonatal effects and plasma concentrations. Ther Drug Monit. | 6
22. Bowen A, Bowen R, Butt P, et al. (2012). Patterns of depression and treatment in pregnant and postpartum women. Can J Psychiatry. | 6
23. Brandon AR. (2011). Ethical Barriers to Perinatal Mental Health Research and Evidence-Based Treatment: An Empirical Study. AJOB Prim Res. | 6
24. Bromley RL, Wieck A, Makarova D, et al. (2012). Fetal effects of selective serotonin reuptake inhibitor treatment during pregnancy: Immediate and longer term child outcomes. Fetal Matern Med Rev. | 8
25. Brosh K, Matok I, Sheine E, et al. (2011). Teratogenic determinants of first- trimester exposure to antiepileptic medications. J Popul Ther Clin Pharmacol. | 3
26. Burns A, O'Mahen H, Baxter H, et al. (2013). A pilot randomised controlled trial of cognitive behavioural therapy for antenatal depression. BMC Psychiatry. | 3
27. Byatt N, Deligiannidis K, Freeman M. (2013). Antidepressant use in pregnancy: A critical review focused on risks and controversies. Acta Psychiatr Scand. | 6
28. Casper RC, Gilles AA, Fleisher BE, et al. (2011). Length of prenatal exposure to selective serotonin reuptake inhibitor (SSRI) antidepressants: effects on neonatal adaptation and psychomotor development. Psychopharmacology (Berl). | 6
29. Chaudron LH. (2013). Complex challenges in treating depression during pregnancy. Am J Psychiatry. | 5
30. Cipriani A, Koesters M, Furukawa TA, et al. (2012). Duloxetine versus other anti-depressive agents for depression. Cochrane Database Syst Rev. | 8
31. Cipriani A, Purgato M, Furukawa TA, et al. (2012). Citalopram versus other anti-depressive agents for depression. Cochrane Database Syst Rev. | 8
32. Clementi M, Di Gianantonio E, Ornoy A. (2002). Teratology Information Services in Europe and Their Contribution to the Prevention of Congenital Anomalies. Public Health Genomics. | 5
33. Cohen LS, Altshuler LL, Harlow BL, et al. (2006). Relapse of major depression during pregnancy in women who maintain or discontinue antidepressant treatment. JAMA. | 4
34. Cohen LS, Altshuler LL, Stowe ZN, et al. (2004). Reintroduction of antidepressant therapy across pregnancy in women who previously discontinued treatment. A preliminary retrospective study. Psychother Psychosom. | 4
35. Cohen LS, Heller VL, Bailey JW, et al. (2000). Birth outcomes following prenatal exposure to fluoxetine. Biol Psychiatry. | 6
36. Cohen LS, Nonacs RM, Bailey JW, et al. (2004). Relapse of depression during pregnancy following antidepressant discontinuation: a preliminary prospective study. Arch Women Ment Health. | 4
37. Cohen LS, Rosenbaum JF. (1997). Birth outcomes in pregnant women taking fluoxetine. N Engl J Med. | 5
38. Cohen LS, Viguera AC, Bouffard SM, et al. (2001). Venlafaxine in the treatment of postpartum depression. J Clin Psychiatry. | 6
39. Condon J. (2003). Serotonergic symptoms in neonates exposed to SSRIs during pregnancy. Aust N Z J Psychiatry. | 5
40. Conlon O, Price J. (2006). A comparative study of pregnant women attending a tertiary obstetric unit and a district general hospital with a previous history of postnatal depression. J Obstet Gynaecol. | 2
41. Courtney K. (2009). Use of SSRIs in pregnancy: neonatal implications. Nurs Womens Health. | 5
42. Coverdale JH, McCullough LB, Chervenak FA. (2008). The ethics of randomized placebo-controlled trials of antidepressants with pregnant women: a systematic review. Obstet Gynecol. | 6
43. D C. (2010). OPEN-LABEL TRIAL OF ESCITALOPRAM IN WOMEN WITH POSTPARTUM MOOD AND ANXIETY DISORDERS. Prim psychiatry. | 5
44. Davis RL, Andrade S, Platt R. (2008). Risk of congenital malformations among infants exposed to antidepressants during pregnancy. Pharmacoepidemiol Drug Saf. | 5
45. Dennis CLE, Stewart DE. (2004). Treatment of postpartum depression, part 1: a critical review of biological interventions. J Clin Psychiatry. | 8
46. Desai G, Babu GN, Chandra PS. (2012). Unplanned pregnancies leading to psychotropic exposure in women with mental illness - Findings from a perinatal psychiatry clinic. Indian J Psychiatry. | 6
47. di Scalea TL, Wisner KL. (2009). Pharmacotherapy of postpartum depression. Expert Opin Pharmacother. | 6
48. Dolk H, Jentink J, Loane M, et al. (2008). Does lamotrigine use in pregnancy increase orofacial cleft risk relative to other malformations?. Neurology. | 3
49. Einarson A, Fatoye B, Sarkar M, et al. (2001). Pregnancy outcome following gestational exposure to venlafaxine: a multicenter prospective controlled study. Am J Psychiatry. | 6
50. Einarson A, Koren G. (2004). New antidepressants in pregnancy. Can Fam Physician. | 5
51. Einarson A, Pistelli A, DeSantis M, et al. (2008). Evaluation of the risk of congenital cardiovascular defects associated with use of paroxetine during pregnancy. Am J Psychiatry. | 6
52. Einarson TR, Einarson A. (2005). Newer antidepressants in pregnancy and rates of major malformations: a meta-analysis of prospective comparative studies. Pharmacoepidemiol Drug Saf. | 8
53. Farr SL, Dietz PM, Rizzo JH, et al. (2013). Health care utilisation in the first year of life among infants of mothers with perinatal depression or anxiety. Paediatr Perinat Epidemiol. | 3
54. Flynn HA, Blow FC, Marcus SM. (2006). Rates and predictors of depression treatment among pregnant women in hospital-affiliated obstetrics practices. Gen Hosp Psychiatry. | 2
55. Freeman MP. (2007). New data inform the risk/benefit analysis in antenatal depression. J Clin Psychiatry. | 5
56. Freeman MP. (2009). Complementary and alternative medicine for perinatal depression. J Affect Disord. | 5
57. Galanti M, Jeffrey Newport D, Pennell PB, et al. (2009). Postpartum depression in women with epilepsy: Influence of antiepileptic drugs in a prospective study. Epilepsy Behav. | 3
58. Galbally M, Gentile S, Lewis AJ. (2012). Further findings linking SSRIs during pregnancy and persistent pulmonary hypertension of the newborn: Clinical implications. CNS Drugs. | 5
59. Gentile S. (2005). SSRIs in pregnancy and lactation: emphasis on neurodevelopmental outcome. CNS Drugs. | 5
60. Gentile S. (2005). The safety of newer antidepressants in pregnancy and breastfeeding. Drug Saf. | 5
61. Gentile S. (2007). Serotonin reuptake inhibitor-induced perinatal complications. Paediatr Drugs. | 5
62. Gentile S. (2010). On categorizing gestational, birth, and neonatal complications following late pregnancy exposure to antidepressants: the prenatal antidepressant exposure syndrome. CNS Spectr. | 6
63. Gentile S. (2011). Neonatal Withdrawal Reactions Following Late in Utero Exposure to Antidepressant Medications. Curr Womens Health Rev. | 6
64. Gentile S. (2011). Selective serotonin reuptake inhibitor exposure during early pregnancy and the risk of birth defects. Acta Psychiatr Scand. | 5
65. Gentile S, Bellantuono C. (2009). Selective serotonin reuptake inhibitor exposure during early pregnancy and the risk of fetal major malformations: focus on paroxetine. J Clin Psychiatry. | 5
66. Gentile S, Galbally M. (2011). Prenatal exposure to antidepressant medications and neurodevelopmental outcomes: a systematic review. J Affect Disord. | 5
67. Gjerdingen D. (2003). The effectiveness of various postpartum depression treatments and the impact of antidepressant drugs on nursing infants. J Am Board Fam Pract. | 5
68. Gold KJ, Marcus SM. (2008). Effect of maternal mental illness on pregnancy outcomes. Expert Rev Obstet Gynecol. | 5
69. Goldfarb C, Keating G. (1981). Use of antidepressants from conception to delivery. J Med Soc N J. | 5
70. Goldstein DJ, Corbin LA, Sundell KL. (1997). Effects of first-trimester fluoxetine exposure on the newborn. Obstet Gynecol. | 6
71. Grigoriadis S, VonderPorten EH, Mamisashvili L. (2013). Antidepressant Exposure During Pregnancy and Congenital Malformations: Is There an Association? A Systematic Review and Meta-Analysis of the Best Evidence. J Clin Psychiatry. | 8
72. Grigoriadis S, VonderPorten EH, Mamisashvili L. (2013). The Effect of Prenatal Antidepressant Exposure on Neonatal Adaptation: A Systematic Review and Meta-Analysis. J Clin Psychiatry. | 8
73. Grigoriadis S, VonderPorten EH, Mamisashvili L. (2013). The Impact of Maternal Depression During Pregnancy on Perinatal Outcomes: A Systematic Review and Meta-Analysis. J Clin Psychiatry. | 5
74. Grush LR, Cohen LS. (1998). Treatment of depression during pregnancy: balancing the risks. Harv Rev Psychiatry. | 5
75. Gunlicks ML, Weissman MM. (2008). Change in child psychopathology with improvement in parental depression: a systematic review. J Am Acad Child Adolesc Psychiatry. | 2
76. (2005). Depression during and after pregnancy: what does the primary care physician need to know?. | 5
77. Harrington RA, Lee LC, Crum RM, et al. (2013). Serotonin Hypothesis of Autism: Implications for Selective Serotonin Reuptake Inhibitor Use during Pregnancy. Autism Res. | 5
78. Hayes LJ, Goodman SH, Carlson E. (2013). Maternal antenatal depression and infant disorganized attachment at 12 months. Attach Hum Dev. | 3
79. Hemels MEH, Einarson A, Koren G, et al. (2005). Antidepressant use during pregnancy and the rates of spontaneous abortions: a meta-analysis. Ann Pharmacother. | 8
80. Hendrick V, Altshuler L. (2002). Management of major depression during pregnancy. Am J Psychiatry. | 5
81. Hendrick V, Altshuler L, Strouse T, et al. (2000). Postpartum and nonpostpartum depression: differences in presentation and response to pharmacologic treatment. Depress Anxiety. | 4
82. Hendrick V, Smith LM, Hwang S, et al. (2003). Weight gain in breastfed infants of mothers taking antidepressant medications. J Clin Psychiatry. | 6
83. Hendrick V, Smith LM, Suri R, et al. (2003). Birth outcomes after prenatal exposure to antidepressant medication. Am J Obstet Gynecol. | 6
84. Highet N, Drummond P. (2004). A comparative evaluation of community treatments for post-partum depression: Implications for treatment and management practices. Aust N Z J Psychiatry. | 2
85. Hilli J, Heikkinen T, Rontu R, et al. (2009). MAO-A and COMT genotypes as possible regulators of perinatal serotonergic symptoms after in utero exposure to SSRIs. Eur Neuropsychopharmacol. | 6
86. Hoffbrand S, Howard L, Crawley H. (2001). Antidepressant treatment for post-natal depression. Nurs Times. | 5
87. Hoffbrand S, Howard L, Crawley H. (2001). Antidepressant drug treatment for postnatal depression. Cochrane Database Syst Rev. | 8
88. Howard L. (2004). Postnatal depression. Clin Evid. | 4
89. Howard L. (2005). Postnatal depression. Clin Evid. | 8
90. Howard L. (2006). Postnatal depression. Clin Evid. | 6
91. Howard LM, Hoffbrand S, Henshaw C, et al. (2005). Antidepressant prevention of postnatal depression. Cochrane Database Syst Rev. | 8
92. Huang H, Chan Y, Katon W, et al. (2012). Variations in depression care and outcomes among high-risk mothers from different racial/ethnic groups. Fam Pract. | 6
93. Hunter SK, Mendoza JH, D'Anna K, et al. (2012). Antidepressants may mitigate the effects of prenatal maternal anxiety on infant auditory sensory gating. Am J Psychiatry. | 2
94. Jermain DM. (1995). Treatment of postpartum depression. Am Pharm. | 5
95. Kellner CH, Pasculli RM, Briggs MC. (2012). Treatment of depression during pregnancy. J ECT. | 5
96. Kendall-Tackett K, Hale TW. (2010). The use of antidepressants in pregnant and breastfeeding women: a review of recent studies. | 8
97. Koke SC, Brown EB, Miner CM. (2002). Safety and efficacy of fluoxetine in patients who receive oral contraceptive therapy. Am J Obstet Gynecol. | 4
98. Koren G. (2009). ACP Journal Club. SSRIs in early pregnancy were associated with increased risk for septal heart defects but not major congenital malformations overall. Ann Intern Med. | 5
99. Koren G. (2011). The effect of ascertainment bias in evaluating gestational antidepressant exposure. J Popul Ther Clin Pharmacol. | 5
100. Koren G. (2012). SSRIs and persistent pulmonary hypertension in newborns. | 5
101. Koren G, Boucher N. (2009). Adverse effects in neonates exposed to SSRIs and SNRI in late gestation--Motherisk Update 2008. Can J Clin Pharmacol. | 5
102. Koren G, Nordeng H. (2012). Antidepressant use during pregnancy: The benefit-risk ratio. Am J Obstet Gynecol. | 5
103. Koren G, Nordeng H. (2012). SSRIs and persistent pulmonary hypertension of the newborn: Observational evidence suggests a link, but causation is yet to be established. BMJ (Online). | 6
104. Koren G, Nulman I, Addis A. (1998). Outcome of children exposed in utero to fluoxetine: a critical review. Depress Anxiety. | 5
105. Krebs C. (2010). Depression in pregnancy. | 5
106. Kwon P, Lefkowitz W. (2008). Neonatal extrapyramidal movements. Neonatal withdrawal due to maternal citalopram and ondansetron use. Pediatr Ann. | 5
107. Lewis JD, Schinnar R, Bilker WB, et al. (2007). Validation studies of the health improvement network (THIN) database for pharmacoepidemiology research. Pharmacoepidemiol Drug Saf. | 5
108. Logsdon MC, Wisner K, Hanusa BH, et al. (2003). Role functioning and symptom remission in women with postpartum depression after antidepressant treatment. Arch Psychiatr Nurs. | 3
109. Lopez-Yarto M, Ruiz-Mirazo E, Holloway AC, et al. (2012). Do psychiatric medications, especially antidepressants, adversely impact maternal metabolic outcomes?. J Affect Disord. | 8
110. Lorenzo L, Byers B, Einarson A. (2011). Antidepressant use in pregnancy. Expert Opin Drug Saf. | 5
111. Loughhead AM, Stowe ZN, Newport DJ, et al. (2006). Placental passage of tricyclic antidepressants. Biol Psychiatry. | 6
112. MacQueen GM, Ramakrishnan K, Ratnasingan R, et al. (2003). Desipramine treatment reduces the long-term behavioural and neurochemical sequelae of early-life maternal separation. Int J Neuropsychopharmacol. | 6
113. Malm H. (2012). Prenatal exposure to selective serotonin reuptake inhibitors and infant outcome. Ther Drug Monit. | 5
114. Malm H, Klaukka T, Neuvonen PJ. (2005). Risks associated with selective serotonin reuptake inhibitors in pregnancy. Obstet Gynecol. | 4
115. Marcus SM, Flynn HA. (2008). Depression, antidepressant medication, and functioning outcomes among pregnant women. Int J Gynaecol Obstet. | 6
116. Misri S, Kendrick K. (2007). Treatment of perinatal mood and anxiety disorders: a review. Can J Psychiatry. | 6
117. Morrison JL, Riggs KW, Rurak DW. (2005). Fluoxetine during pregnancy: Impact on fetal development. Reprod Fertil Dev. | 5
118. Morrow AW. (1972). Imipramine and congenital abnormalities. N Z Med J. | 5
119. Moses-Kolko EL, Bogen D, Perel J, et al. (2005). Neonatal signs after late in utero exposure to serotonin reuptake inhibitors: literature review and implications for clinical applications. JAMA. | 6
120. Murthy L, Shepperd S, Clarke MJ, et al. (2012). Interventions to improve the use of systematic reviews in decision-making by health system managers, policy makers and clinicians. Cochrane Database Syst Rev. | 3
121. Myles N, Newall H, Ward H, et al. (2013). Systematic meta-analysis of individual selective serotonin reuptake inhibitor medications and congenital malformations. Aust N Z J Psychiatry. | 8
122. Ng RC, Hirata CK, Yeung W, et al. (2010). Pharmacologic treatment for postpartum depression: a systematic review. Pharmacotherapy. | 6
123. (2004). Maternal SSRI Use Associated with Neurobehavioral Disruptions in Neonates. Prim psychiatry. | 4
124. (2009). Depression, SSRIs, and premature birth. Am J Psychiatry. | 5
125. Oberlander TF, Grunau RE, Fitzgerald C, et al. (2005). Pain reactivity in 2-month-old infants after prenatal and postnatal serotonin reuptake inhibitor medication exposure. Pediatrics. | 2
126. O'Brien LAM. (2010). Critical determinants of the risk-benefit assessment of antidepressants in pregnancy: Pharmacokinetic, safety and economic considerations. | 2
127. O'Mahen H, Himle JA, Fedock G, et al. (2013). A Pilot Randomized Controlled Trial of Cognitive Behavioral Therapy for Perinatal Depression Adapted for Women with Low Incomes. Depress Anxiety. | 3
128. Oyebode F, Rastogi A, Berrisford G, et al. (2012). Psychotropics in pregnancy: safety and other considerations. Pharmacol Ther. | 6
129. Painuly N, Heun R, Painuly R, et al. (2013). Risk of cardiovascular malformations after exposure to paroxetine in pregnancy: meta-analysis. Psychiatrist. | 8
130. Payne JL. (2013). Use of antidepressants in the second trimester is associated with reduced pregnancy duration, and third trimester antidepressant use with infant convulsions. Evid Based Nurs. | 6
131. Pupco A, Bozzo P, Koren G. (2011). Selective serotonin reuptake inhibitors and risk for major congenital anomalies. Obstet Gynecol. | 5
132. Rahimi R, Nikfar S, Abdollahi M. (2006). Pregnancy outcomes following exposure to serotonin reuptake inhibitors: a meta-analysis of clinical trials. Reprod Toxicol. | 6
133. Raudzus J, Misri S. (2009). Managing unipolar depression in pregnancy. Curr Opin Psychiatry. | 6
134. Reefhuis J, Rasmussen SA, Friedman JM. (2006). Selective serotonin-reuptake inhibitors and persistent pulmonary hypertension of the newborn. N Engl J Med. | 5
135. Richards EM, Payne JL. (2013). The management of mood disorders in pregnancy: alternatives to antidepressants. CNS Spectr. | 5
136. Ricke AK, Farrell CE, Chambers JE. (2009). The pharmacotherapy of perinatal mood disorders. Psychopharm Review. | 5
137. Roca A, Garcia-Esteve L, Imaz ML, et al. (2011). Obstetrical and neonatal outcomes after prenatal exposure to selective serotonin reuptake inhibitors: the relevance of dose. J Affect Disord. | 6
138. Ross EL, Grigoriadis S, Mamisashvili L. (2013). Selected pregnancy and delivery outcomes after exposure to antidepressant medication: A systematic review and meta-analysis. JAMA Psychiatry. | 8
139. Ross LE, Grigoriadis S, Mamisashvili L, et al. (2013). Selected pregnancy and delivery outcomes after exposure to antidepressant medication: A systematic review and meta-analysis. JAMA Psychiatry. | 8
140. Ruchkin V, Martin A. (2005). SSRIs and the developing brain. Lancet. | 5
141. Russell EJ, Fawcett JM, Mazmanian D. (2013). Risk of Obsessive-Compulsive Disorder in Pregnant and Postpartum Women: A Meta-Analysis. J Clin Psychiatry. | 3
142. Santone G, Ricchi G, Rocchetti D, et al. (2009). Is the exposure to antidepressant drugs in early pregnancy a risk factor for spontaneous abortion? A review of available evidences. Epidemiol Psichiatr Soc. | 6
143. Santos F, Sola I, Rigau D, et al. (2012). Quality assessment of clinical practice guidelines for the prescription of antidepressant drugs during pregnancy. Curr Clin Pharmacol. | 5
144. Sanz EJ, De-las-Cuevas C, Kiuru A, et al. (2005). Selective serotonin reuptake inhibitors in pregnant women and neonatal withdrawal syndrome: a database analysis. Lancet. | 6
145. Schroeder JW, Smith AK, Brennan PA, et al. (2012). DNA methylation in neonates born to women receiving psychiatric care. Epigenetics. | 2
146. Seifritz E, Holsboer-Trachsler E, Haberthur F, et al. (1993). Unrecognized pregnancy during citalopram treatment. Am J Psychiatry. | 5
147. Shea AK, Kamath MV, Fleming A, et al. (2008). The effect of depression on heart rate variability during pregnancy. A naturalistic study. Clin Auton Res. | 3
148. Silvani P, Camporesi A. (2007). Drug-induced pulmonary hypertension in newborns: A review. Curr Vasc Pharmacol. | 5
149. Simoncelli M, Martin BZ, Berard A. (2010). Antidepressant use during pregnancy: a critical systematic review of the literature. Curr Drug Saf. | 6
150. Sockol LE, Epperson CN, Barber JP. (2011). A meta-analysis of treatments for perinatal depression. Clin Psychol Rev. | 6
151. Sontheimer DL, Ables AZ. (2000). Safety of antidepressant medications during pregnancy. JAMA. | 5
152. Speisman BB, Storch EA, Abramowitz JS. (2011). Postpartum obsessive-compulsive disorder. J Obstet Gynecol Neonatal Nurs. | 4
153. Steinberg SI, Bellavance F. (1999). Characteristics and treatment of women with antenatal and postpartum depression. Int J Psychiatry Med. | 2
154. Stewart DE. (1998). Are there special considerations in the prescription of serotonin reuptake inhibitors for women?. Can J Psychiatry. | 5
155. Stowe ZN. (2007). The use of mood stabilizers during breastfeeding. J Clin Psychiatry. | 5
156. Strom M, Mortensen EL, Halldorson TI, et al. (2009). Leisure-time physical activity in pregnancy and risk of postpartum depression: a prospective study in a large national birth cohort. J Clin Psychiatry. | 2
157. Sunder KR, Wisner KL, Hanusa BH, et al. (2004). Postpartum depression recurrence versus discontinuation syndrome: observations from a randomized controlled trial. J Clin Psychiatry. | 4
158. t Jong GW, Einarson T, Koren G, et al. (2012). Antidepressant use in pregnancy and persistent pulmonary hypertension of the newborn (PPHN): A systematic review. Reprod Toxicol. | 8
159. Ter Horst P, Smit J. (2009). Antidepressants during pregnancy and lactation. Tijdschr Psychiatr. | 1
160. Thompson BL, Levitt P, Stanwood GD. (2009). Prenatal exposure to drugs: effects on brain development and implications for policy and education. Nat Rev Neurosci. | 5
161. Thormahlen GM. (2006). Paroxetine use during pregnancy: is it safe?. Ann Pharmacother. | 5
162. Tuccori M, Montagnani S, Testi A, et al. (2010). Use of selective serotonin reuptake inhibitors during pregnancy and risk of major and cardiovascular malformations: an update. Postgrad Med. | 5
163. Tuccori M, Testi A, Antonioli L, et al. (2009). Safety concerns associated with the use of serotonin reuptake inhibitors and other serotonergic/noradrenergic antidepressants during pregnancy: a review. Clin Ther. | 5
164. Udechuku A, Nguyen T, Hill R, et al. (2010). Antidepressants in pregnancy: a systematic review. Aust N Z J Psychiatry. | 5
165. Ververs T, Kaasenbrood H, Visser G, et al. (2006). Prevalence and patterns of antidepressant drug use during pregnancy. Eur J Clin Pharmacol. | 2
166. Warburton W, Hertzman C, Oberlander TF. (2010). A register study of the impact of stopping third trimester selective serotonin reuptake inhibitor exposure on neonatal health. Acta Psychiatr Scand. | 6
167. Watanabe N, Omori IM, Nakagawa A, et al. (2011). Mirtazapine versus other antidepressive agents for depression. Cochrane Database Syst Rev. | 8
168. Weikum WM, Oberlander TF, Hensch TK, et al. (2012). Prenatal exposure to antidepressants and depressed maternal mood alter trajectory of infant speech perception. Proc Natl Acad Sci U S A. | 5
169. Wenstrom KD. (2006). [Commentary on] Selective serotonin-reuptake inhibitors and risk of persistent pulmonary hypertension of the newborn. Obstet Gynecol Surv. | 5
170. Werler MM, Bower C, Payne J, et al. (2003). Findings on potential teratogens from a case-control study in Western Australia. Aust N Z J Obstet Gynaecol. | 3
171. Wisner KL, Gelenberg AJ, Leonard H, et al. (1999). Pharmacologic treatment of depression during pregnancy. JAMA. | 6
172. Wisner KL, Perel JM, Peindl KS, et al. (2004). Prevention of postpartum depression: a pilot randomized clinical trial. Am J Psychiatry. | 4
173. Wu J, Viguera A, Riley L, et al. (2002). Mood disturbance in pregnancy and the mode of delivery. Am J Obstet Gynecol. | 6
174. Wurst KE, Poole C, Ephross SA, et al. (2010). First trimester paroxetine use and the prevalence of congenital, specifically cardiac, defects: a meta-analysis of epidemiological studies. Birth Defects Res Part A Clin Mol Teratol. | 8
175. Yaris F, Ulku C, Kesim M, et al. (2005). Psychotropic drugs in pregnancy: A case-control study. Prog Neuropsychopharmacol Biol Psychiatry. | 1
176. Yonkers KA, Gotman N, Smith MV, et al. (2011). Does antidepressant use attenuate the risk of a major depressive episode in pregnancy. Epidemiology. | 4
177. Zeskind PS. (2004). [Commentary on] Maternal selective serotonin reuptake inhibitor use during pregnancy and newborn neurobehavior. Obstet Gynecol Surv. | 5
178. Zhou S, Chan E, Pan SQ, et al. (2004). Pharmacokinetic interactions of drugs with St John's wort. J Psychopharmacol. | 5
179. Zuccotti GV, Fabiano V, Manfredini V. (2012). Neonates born to mothers using antidepressant drugs. Early Hum Dev. | 5