# Appendix B Included Studies

## Observational Studies

1 Alwan S, Reefhuis J, Botto LD, et al. (2010). Maternal use of bupropion and risk for congenital heart defects. Am J Obstet Gynecol.
2 Alwan S, Reefhuis J, Rasmussen SA, et al. (2007). Use of selective serotonin-reuptake inhibitors in pregnancy and the risk of birth defects. N Engl J Med.
3 Andrade SE, McPhillips H, Loren D, et al. (2009). Antidepressant medication use and risk of persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf.
4 Bakker MK, De Walle HEK, Wilffert B, et al. (2010). Fluoxetine and infantile hypertrophic pylorus stenosis: a signal from a birth defects-drug exposure surveillance study. Pharmacoepidemiol Drug Saf.
5 Bakker MK, Kerstjens-Frederikse WS, Buys CHCM, et al. (2010). First-trimester use of paroxetine and congenital heart defects: a population-based case-control study. Birth Defects Res Part A Clin Mol Teratol.
6 Ban L, Tata LJ, West J, et al. (2012). Live and non-live pregnancy outcomes among women with depression and anxiety: A population-based study. PLoS ONE.
7 Batton B, Batton E, Weigler K, et al. (2013). In utero antidepressant exposure and neurodevelopment in preterm infants. Am J Perinatol.
8 Bérard A, Ramos É, Rey É, et al. (2007). First trimester exposure to paroxetine and risk of cardiac malformations in infants: The importance of dosage. Birth Defects Res B Dev Reprod Toxicol.
9 Berle JO, Steen VM, Aamo TO, et al. (2004). Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry.
10 Bogen DL, Hanusa BH, Moses-Kolko E, et al. (2010). Are maternal depression or symptom severity associated with breastfeeding intention or outcomes?. J Clin Psychiatry.
11 Boucher N, Bairam A, Beaulac-Baillargeon L. (2008). A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol.
12 Bracken MB, Holford TR. (1981). Exposure to prescribed drugs in pregnancy and association with congenital malformations. Obstet Gynecol.
13 Casper RC, Fleisher BE, Lee-Ancajas JC, et al. (2003). Follow-up of children of depressed mothers exposed or not exposed to antidepressant drugs during pregnancy. J Pediatr.
14 Chambers CD, Hernandez-Diaz S, Van Marter LJ, et al. (2006). Selective serotonin-reuptake inhibitors and risk of persistent pulmonary hypertension of the newborn. N Engl J Med.
15 Chambers CD, Johnson KA, Dick LM, et al. (1996). Birth outcomes in pregnant women taking fluoxetine. N Engl J Med.
16 Chun-Fai-Chan B, Koren G, Fayez I, et al. (2005). Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol.
17 Cole JA, Ephross SA, Cosmatos IS, et al. (2007). Paroxetine in the first trimester and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf.
18 Cole JA, Modell JG, Haight BR, et al. (2007). Bupropion in pregnancy and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf.
19 Colvin L, Slack-Smith L, Stanley FJ, et al. (2010). Linking a pharmaceutical claims database with a birth defects registry to investigate birth defect rates of suspected teratogens. Pharmacoepidemiol Drug Saf.
20 Colvin L, Slack-Smith L, Stanley FJ, et al. (2011). Dispensing patterns and pregnancy outcomes for women dispensed selective serotonin reuptake inhibitors in pregnancy. Birth Defects Res Part A Clin Mol Teratol.
21 Colvin L, Slack-Smith L, Stanley FJ, et al. (2012). Early morbidity and mortality following in utero exposure to selective serotonin reuptake inhibitors: a population-based study in Western australia. CNS Drugs.
22 Costei AM, Kozer E, Ho T, et al. (2002). Perinatal outcome following third trimester exposure to paroxetine. Arch Pediatr Adolesc Med.
23 Croen LA, Grether JK, Yoshida CK, et al. (2011). Antidepressant use during pregnancy and childhood autism spectrum disorders. Arch Gen Psychiatry.
24 Davidson S, Prokonov D, Taler M, et al. (2009). Effect of exposure to selective serotonin reuptake inhibitors in utero on fetal growth: potential role for the IGF-I and HPA axes. Pediatr Res.
25 Davis RL, Rubanowice D, McPhillips H, et al. (2007). Risks of congenital malformations and perinatal events among infants exposed to antidepressant medications during pregnancy. Pharmacoepidemiol Drug Saf.
26 De Vera MA, Bérard A. (2012). Antidepressant use during pregnancy and the risk of pregnancy-induced hypertension. Br J Clin Pharmacol.
27 de Vries NKS, van der Veere CN, Reijneveld SA, et al. (2013). Early Neurological Outcome of Young Infants Exposed to Selective Serotonin Reuptake Inhibitors during Pregnancy: Results from the Observational SMOK Study. PLoS ONE.
28 Diav-Citrin O, Shechtman S, Weinbaum D, et al. (2008). Paroxetine and fluoxetine in pregnancy: a prospective, multicentre, controlled, observational study. Br J Clin Pharmacol.
29 Djulus J, Koren G, Einarson TR, et al. (2006). Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry.
30 Dubnov-Raz G, Hemila H, Vurembrand Y, et al. (2012). Maternal use of selective serotonin reuptake inhibitors during pregnancy and neonatal bone density. Early Hum Dev.
31 Dubnov-Raz G, Juurlink DN, Fogelman R, et al. (2008). Antenatal use of selective serotonin-reuptake inhibitors and QT interval prolongation in newborns. Pediatrics.
32 Einarson A, Bonari L, Voyer-Lavigne S, et al. (2003). A multicentre prospective controlled study to determine the safety of trazodone and nefazodone use during pregnancy. Can J Psychiatry.
33 Einarson A, Choi J, Einarson TR, et al. (2009). Rates of spontaneous and therapeutic abortions following use of antidepressants in pregnancy: results from a large prospective database. J Obstet Gynaecol Can.
34 Einarson A, Choi J, Einarson TR, et al. (2009). Incidence of major malformations in infants following antidepressant exposure in pregnancy: results of a large prospective cohort study. Can J Psychiatry.
35 Einarson A, Choi J, Einarson TR, et al. (2010). Adverse effects of antidepressant use in pregnancy: an evaluation of fetal growth and preterm birth. Depress Anxiety.
36 Einarson A, Choi J, Koren G, et al. (2011). Outcomes of infants exposed to multiple antidepressants during pregnancy: results of a cohort study. J Popul Ther Clin Pharmacol.
37 El Marroun H, Jaddoe VWV, Hudziak JJ, et al. (2012). Maternal use of selective serotonin reuptake inhibitors, fetal growth, and risk of adverse birth outcomes. Arch Gen Psychiatry.
38 Ericson A, Kallen B, Wiholm B. (1999). Delivery outcome after the use of antidepressants in early pregnancy. Eur J Clin Pharmacol.
39 Ferreira E, Carceller AM, Agogue C, et al. (2007). Effects of selective serotonin reuptake inhibitors and venlafaxine during pregnancy in term and preterm neonates. Pediatrics.
40 Figueroa R. (2010). Use of antidepressants during pregnancy and risk of attention-deficit/hyperactivity disorder in the offspring. J Dev Behav Pediatr.
41 Galbally M, Lewis AJ, Buist A. (2011). Developmental outcomes of children exposed to antidepressants in pregnancy. Aust N Z J Psychiatry.
42 Galbally M, Lewis AJ, Lum J, et al. (2009). Serotonin discontinuation syndrome following in utero exposure to antidepressant medication: prospective controlled study. Aust N Z J Psychiatry.
43 Gorman JR, Kao K, Chambers CD. (2012). Breastfeeding among Women Exposed to Antidepressants during Pregnancy. J Hum Lact.
44 Grzeskowiak LE, Gilbert AL, Morrison JL. (2012). Neonatal outcomes after late-gestation exposure to selective serotonin reuptake inhibitors. J Clin Psychopharmacol.
45 Hale TW, Kendall-Tackett K, Cong Z, et al. (2010). Discontinuation syndrome in newborns whose mothers took antidepressants while pregnant or breastfeeding. Breastfeed Med.
46 Hanley GE, Brain U, Oberlander TF. (2013). Infant developmental outcomes following prenatal exposure to antidepressants, and maternal depressed mood and positive affect. Early Hum Dev.
47 Heikkinen T, Ekblad U, Kero P, et al. (2002). Citalopram in pregnancy and lactation. Clin Pharmacol Ther.
48 Jimenez-Solem E, Andersen JT, Petersen M, et al. (2012). Exposure to selective serotonin reuptake inhibitors and the risk of congenital malformations: A nationwide cohort study. BMJ Open.
49 Jimenez-Solem E, Andersen JT, Petersen M, et al. (2013). SSRI Use During Pregnancy and Risk of Stillbirth and Neonatal Mortality. Am J Psychiatry.
50 Jordan AE, Jackson GL, Deardorff D, et al. (2008). Serotonin reuptake inhibitor use in pregnancy and the neonatal behavioral syndrome. J Matern Fetal Neonatal Med.
51 Kallen B. (2004). Neonate characteristics after maternal use of antidepressants in late pregnancy. Arch Pediatr Adolesc Med.
52 Kallen B, Olausson PO. (2008). Maternal use of selective serotonin re-uptake inhibitors and persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf.
53 Kallen BAJ, Otterblad Olausson P. (2007). Maternal use of selective serotonin re-uptake inhibitors in early pregnancy and infant congenital malformations. Birth Defects Res Part A Clin Mol Teratol.
54 Kieler H, Artama M, Engeland A, et al. (2012). Selective serotonin reuptake inhibitors during pregnancy and risk of persistent pulmonary hypertension in the newborn: population based cohort study from the five Nordic countries. BMJ.
55 Klieger-Grossmann C, Weitzner B, Panchaud A, et al. (2012). Pregnancy outcomes following use of escitalopram: a prospective comparative cohort study. J Clin Pharmacol.
56 Klinger G, Frankenthal D, Merlob P, et al. (2011). Long-term outcome following selective serotonin reuptake inhibitor induced neonatal abstinence syndrome. J Perinatol.
57 Kornum JB. (2010). Use of selective serotonin-reuptake inhibitors during early pregnancy and risk of congenital malformations: updated analysis. Clin Epidemiol.
58 Kulin NA, Pastuszak A, Sage SR, et al. (1998). Pregnancy outcome following maternal use of the new selective serotonin reuptake inhibitors: a prospective controlled multicenter study. JAMA.
59 Laine K, Heikkinen T, Ekblad U, et al. (2003). Effects of exposure to selective serotonin reuptake inhibitors during pregnancy on serotonergic symptoms in newborns and cord blood monoamine and prolactin concentrations. Arch Gen Psychiatry.
60 Latendresse G, Ruiz RJ. (2011). Maternal corticotropin-releasing hormone and the use of selective serotonin reuptake inhibitors independently predict the occurrence of preterm birth. J Midwifery Womens Health.
61 Lennestal R, Kallen B. (2007). Delivery outcome in relation to maternal use of some recently introduced antidepressants. J Clin Psychopharmacol.
62 Levinson-Castiel R, Merlob P, Linder N, et al. (2006). Neonatal abstinence syndrome after in utero exposure to selective serotonin reuptake inhibitors in term infants. Arch Pediatr Adolesc Med.
63 Lewis AJ, Galbally M, Opie G, et al. (2010). Neonatal growth outcomes at birth and one month postpartum following in utero exposure to antidepressant medication. Aust N Z J Psychiatry.
64 Logsdon MC, Wisner K, Sit D, et al. (2011). Depression treatment and maternal functioning. Depress Anxiety.
65 Louik C, Lin AE, Werler MM, et al. (2007). First-trimester use of selective serotonin-reuptake inhibitors and the risk of birth defects. N Engl J Med.
66 Lund N, Pedersen LH, Henriksen TB. (2009). Selective serotonin reuptake inhibitor exposure in utero and pregnancy outcomes. Arch Pediatr Adolesc Med.
67 Malm H, Artama M, Gissler M, et al. (2011). Selective serotonin reuptake inhibitors and risk for major congenital anomalies. Obstet Gynecol.
68 Manakova E, Hubickova L. (2011). Antidepressant drug exposure during pregnancy. CZTIS small prospective study. Neuroendocrinol Lett.
69 Maschi S, Clavenna A, Campi R, et al. (2008). Neonatal outcome following pregnancy exposure to antidepressants: a prospective controlled cohort study. BJOG.
70 McElhatton PR, Garbis HM, Elefant E, et al. (1996). The outcome of pregnancy in 689 women exposed to therapeutic doses of antidepressants. A collaborative study of the European Network of Teratology Information Services (ENTIS). Reprod Toxicol.
71 McFarland J, Salisbury AL, Battle CL, et al. (2011). Major depressive disorder during pregnancy and emotional attachment to the fetus. Arch Womens Ment Health.
72 Merlob P, Birk E, Sirota L, et al. (2009). Are selective serotonin reuptake inhibitors cardiac teratogens? Echocardiographic screening of newborns with persistent heart murmur. Birth Defects Res Part A Clin Mol Teratol.
73 Misri S, Kendrick K, Oberlander TF, et al. (2010). Antenatal depression and anxiety affect postpartum parenting stress: a longitudinal, prospective study. Can J Psychiatry.
74 Misri S, Reebye P, Kendrick K, et al. (2006). Internalizing behaviors in 4-year-old children exposed in utero to psychotropic medications. Am J Psychiatry.
75 Misri S, Sivertz K. (1991). Tricyclic drugs in pregnancy and lactation: a preliminary report. Int J Psychiatry Med.
76 Mulder EJ, Ververs FF, de Heus R, et al. (2011). Selective serotonin reuptake inhibitors affect neurobehavioral development in the human fetus. Neuropsychopharmacology.
77 Nakhai-Pour HR, Broy P, Berard A. (2010). Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ.
78 Nijenhuis CM, ter Horst PGJ, van Rein N, et al. (2012). Disturbed development of the enteric nervous system after in utero exposure of selective serotonin re-uptake inhibitors and tricyclic antidepressants. Part 2: Testing the hypotheses. Br J Clin Pharmacol.
79 Nordeng H, van Gelder MMHJ, Spigset O, et al. (2012). Pregnancy outcome after exposure to antidepressants and the role of maternal depression: results from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol.
80 Nulman I, Koren G, Rovet J, et al. (2012). Neurodevelopment of children following prenatal exposure to venlafaxine, selective serotonin reuptake inhibitors, or untreated maternal depression. Am J Psychiatry.
81 Nulman I, Rovet J, Stewart DE, et al. (1997). Neurodevelopment of children exposed in utero to antidepressant drugs. N Engl J Med.
82 Nulman I, Rovet J, Stewart DE, et al. (2002). Child development following exposure to tricyclic antidepressants or fluoxetine throughout fetal life: a prospective, controlled study. Am J Psychiatry.
83 O S, H K, B H, et al. (2013). Selective serotonin reuptake inhibitors during pregnancy and risk of stillbirth and infant mortality. JAMA.
84 Oberlander TF, Bonaguro RJ, Misri S, et al. (2008). Infant serotonin transporter (SLC6A4) promoter genotype is associated with adverse neonatal outcomes after prenatal exposure to serotonin reuptake inhibitor medications. Mol Psychiatry.
85 Oberlander TF, Eckstein Grunau R, Fitzgerald C, et al. (2002). Prolonged prenatal psychotropic medication exposure alters neonatal acute pain response. Pediatr Res.
86 Oberlander TF, Misri S, Fitzgerald CE, et al. (2004). Pharmacologic factors associated with transient neonatal symptoms following prenatal psychotropic medication exposure. J Clin Psychiatry.
87 Oberlander TF, Papsdorf M, Brain UM, et al. (2010). Prenatal effects of selective serotonin reuptake inhibitor antidepressants, serotonin transporter promoter genotype (SLC6A4), and maternal mood on child behavior at 3 years of age. Arch Pediatr Adolesc Med.
88 Oberlander TF, Reebye P, Misri S, et al. (2007). Externalizing and attentional behaviors in children of depressed mothers treated with a selective serotonin reuptake inhibitor antidepressant during pregnancy. Arch Pediatr Adolesc Med.
89 Oberlander TF, Warburton W, Misri S, et al. (2006). Neonatal outcomes after prenatal exposure to selective serotonin reuptake inhibitor antidepressants and maternal depression using population-based linked health data. Arch Gen Psychiatry.
90 Oberlander TF, Warburton W, Misri S, et al. (2008). Effects of timing and duration of gestational exposure to serotonin reuptake inhibitor antidepressants: population-based study. Br J Psychiatry.
91 Oberlander TF, Warburton W, Misri S, et al. (2008). Major congenital malformations following prenatal exposure to serotonin reuptake inhibitors and benzodiazepines using population-based health data. Birth Defects Res Part B Dev Reprod Toxicol.
92 Okun ML, Kiewra K, Luther JF, et al. (2011). Sleep disturbances in depressed and nondepressed pregnant women. Depress Anxiety.
93 Okun ML, Luther JF, Wisniewski SR, et al. (2012). Disturbed sleep, a novel risk factor for preterm birth? J Womens Health (Larchmt).
94 Palmsten K, Setoguchi S, Margulis AV, et al. (2012). Elevated risk of preeclampsia in pregnant women with depression: depression or antidepressants?. Am J Epidemiol.
95 Pastuszak A, Schick-Boschetto B, Zuber C, et al. (1993). Pregnancy outcome following first-trimester exposure to fluoxetine (Prozac). JAMA.
96 Pawluski JL, Galea LAM, Brain U, et al. (2009). Neonatal S100B protein levels after prenatal exposure to selective serotonin reuptake inhibitors. Pediatrics.
97 Pearlstein TB, Zlotnick C, Battle CL, et al. (2006). Patient choice of treatment for postpartum depression: a pilot study. Arch Women Ment Health.
98 Pearson KH, Nonacs RM, Viguera AC, et al. (2007). Birth outcomes following prenatal exposure to antidepressants. J Clin Psychiatry.
99 Pedersen L, Henriksen T, Bech B, et al. (2013). Prenatal antidepressant exposure and behavioral problems in early childhood - A cohort study. Acta Psychiatr Scand.
100 Pedersen LH, Henriksen TB, Olsen J. (2010). Fetal exposure to antidepressants and normal milestone development at 6 and 19 months of age. Pediatrics.
101 Pedersen LH, Henriksen TB, Vestergaard M, et al. (2009). Selective serotonin reuptake inhibitors in pregnancy and congenital malformations: population based cohort study. BMJ.
102 Polen KND, Rasmussen SA, Riehle-Colarusso T, et al. (2013). Association between reported venlafaxine use in early pregnancy and birth defects, national birth defects prevention study, 1997-2007. Birth Defects Res A Clin Mol Teratol.
103 Rai D, Lee BK, Dalman C, et al. (2013). Parental depression, maternal antidepressant use during pregnancy, and risk of autism spectrum disorders: population based case-control study. BMJ.
104 Ramos E, St-Andre M, Berard A. (2010). Association between antidepressant use during pregnancy and infants born small for gestational age. Can J Psychiatry.
105 Ramos E, St-Andre M, Rey E, et al. (2008). Duration of antidepressant use during pregnancy and risk of major congenital malformations. Br J Psychiatry.
106 Rampono J, Proud S, Hackett LP, et al. (2004). A pilot study of newer antidepressant concentrations in cord and maternal serum and possible effects in the neonate. Int J Neuropsychopharmcol.
107 Rampono J, Simmer K, Ilett KF, et al. (2009). Placental transfer of SSRI and SNRI antidepressants and effects on the neonate. Pharmacopsychiatry.
108 Reebye P, Morison SJ, Panikkar H, et al. (2002). Affect expression in prenatally psychotropic exposed and nonexposed mother-infant dyads. Infant Ment Health J.
109 Reis M, Kallen B. (2010). Delivery outcome after maternal use of antidepressant drugs in pregnancy: an update using Swedish data. Psychol Med.
110 Salisbury AL, Wisner KL, Pearlstein T, et al. (2011). Newborn neurobehavioral patterns are differentially related to prenatal maternal major depressive disorder and serotonin reuptake inhibitor treatment. Depress Anxiety.
111 Salkeld E, Ferris LE, Juurlink DN. (2008). The risk of postpartum hemorrhage with selective serotonin reuptake inhibitors and other antidepressants. J Clin Psychopharmacol.
112 Simon GE, Cunningham ML, Davis RL. (2002). Outcomes of prenatal antidepressant exposure. Am J Psychiatry.
113 Sit D, Perel JM, Wisniewski SR, et al. (2011). Mother-infant antidepressant concentrations, maternal depression, and perinatal events. J Clin Psychiatry.
114 Sivojelezova A, Shuhaiber S, Sarkissian L, et al. (2005). Citalopram use in pregnancy: prospective comparative evaluation of pregnancy and fetal outcome. Am J Obstet Gynecol.
115 Smith MV, Sung A, Shah B, et al. (2013). Neurobehavioral assessment of infants born at term and in utero exposure to serotonin reuptake inhibitors. Early Hum Dev.
116 Suri R, Altshuler L, Hellemann G, et al. (2007). Effects of antenatal depression and antidepressant treatment on gestational age at birth and risk of preterm birth. Am J Psychiatry.
117 Suri R, Altshuler L, Hendrick V, et al. (2004). The impact of depression and fluoxetine treatment on obstetrical outcome. Arch Women Ment Health.
118 Suri R, Hellemann G, Stowe ZN, et al. (2011). A prospective, naturalistic, blinded study of early neurobehavioral outcomes for infants following prenatal antidepressant exposure. J Clin Psychiatry.
119 Ter Horst PGJ, Bos HJ, De Jong-Van De Berg LTW, et al. (2013). In utero exposure to antidepressants and the use of drugs for pulmonary diseases in children. Eur J Clin Pharmacol.
120 Toh S, Mitchell AA, Louik C, et al. (2009). Antidepressant use during pregnancy and the risk of preterm delivery and fetal growth restriction. J Clin Psychopharmacol.
121 Toh S, Mitchell AA, Louik C, et al. (2009). Selective serotonin reuptake inhibitor use and risk of gestational hypertension. Am J Psychiatry.
122 Ververs TF, van Wensen K, Freund MW, et al. (2009). Association between antidepressant drug use during pregnancy and child healthcare utilisation. BJOG.
123 Wen SW, Yang Q, Garner P, et al. (2006). Selective serotonin reuptake inhibitors and adverse pregnancy outcomes. Am J Obstet Gynecol.
124 Wichman CL, Moore KM, Lang TR, et al. (2009). Congenital heart disease associated with selective serotonin reuptake inhibitor use during pregnancy. Mayo Clin Proc.
125 Wilson KL, Zelig CM, Harvey JP, et al. (2011). Persistent pulmonary hypertension of the newborn is associated with mode of delivery and not with maternal use of selective serotonin reuptake inhibitors. Am J Perinatol.
126 Wisner KL, Bogen DL, Sit D, et al. (2013). Does Fetal Exposure to SSRIs or Maternal Depression Impact Infant Growth?. Am J Psychiatry.
127 Wisner KL, Sit DKY, Hanusa BH, et al. (2009). Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry.
128 Wogelius P, Norgaard M, Gislum M, et al. (2006). Maternal use of selective serotonin reuptake inhibitors and risk of congenital malformations. Epidemiology.
129 Yonkers KA, Norwitz ER, Smith MV, et al. (2012). Depression and serotonin reuptake inhibitor treatment as risk factors for preterm birth. Epidemiology.
130 Zeskind PS, Stephens LE. (2004). Maternal selective serotonin reuptake inhibitor use during pregnancy and newborn neurobehavior. Pediatrics.

## Randomized Controlled Trials

1 Appleby L, Warner R, Whitton A, et al. (1997). A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ.
2 Bloch M, Meiboom H, Lorberblatt M, et al. (2012). The effect of sertraline add-on to brief dynamic psychotherapy for the treatment of postpartum depression: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry.
3 Lanza di Scalea T, Hanusa BH, Wisner KL. (2009). Sexual function in postpartum women treated for depression: results from a randomized trial of nortriptyline versus sertraline. J Clin Psychiatry.
4 Logsdon MC, Wisner K, Hanusa BH. (2009). Does maternal role functioning improve with antidepressant treatment in women with postpartum depression?. J Womens Health (Larchmt).
5 Misri S, Reebye P, Corral M, et al. (2004). The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. J Clin Psychiatry.
6 Morrell CJ, Warner R, Slade P, et al. (2009). Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PoNDER trial. Health Technol Assess.
7 Sharp DJ, Chew-Graham C, Tylee A, et al. (2010). A pragmatic randomised controlled trial to compare antidepressants with a community-based psychosocial intervention for the treatment of women with postnatal depression: the RESPOND trial. Health Technol Assess.
8 Wan MW, Sharp DJ, Howard LM, et al. (2011). Attitudes and adjustment to the parental role in mothers following treatment for postnatal depression. J Affect Disord.
9 Wisner KL, Hanusa BH, Perel JM, et al. (2006). Postpartum depression: a randomized trial of sertraline versus nortriptyline. J Clin Psychopharmacol.
10 Yonkers KA, Lin H, Howell HB, et al. (2008). Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry.