# Appendix A Search Strategies

## CINAHL Plus With Full Text 1941–July 2013

S1 MH Pregnancy+
S2 “pregnan*”
S3 MH Postnatal Period+
S4 (MH “Affective Disorders+”)
S5 MH Seasonal Affective Disorder
S6 MH Depression+ OR MH Depression, Postpartum
S7 MH Serotonin Uptake Inhibitors+
S8 “selective serotonin reuptake inhibitor”
S9 “ssri”
S10 MH Citalopram OR citalopram
S11 “escitalopram”
S12 MH Fluoxetine OR fluoxetine OR MH Olanzapine-Fluoxetine
S13 MH Fluvoxamine Maleate OR fluvoxamine
S14 MH Sertraline Hydrochloride OR sertraline
S15 MH Paroxetine OR paroxetine
S16 “celexa”
S17 “lexapro”
S18 “prozac”
S19 “luvox”
S20 “zoloft”
S21 “paxil”
S22 MH Desvenlafaxine Succinate OR desvenlafaxine
S23 MH Mirtazapine OR mirtazapine
S24 “pristiq”
S25 MH Venlafaxine OR effexor
S26 “noradrenergic and specific serotonergic reuptake inhibitor”
S27 (MH “Duloxetine Hydrochloride”) OR “duloxetine”
S28 “cymbalta”
S29 (MH “Norepinephrine”) OR “norepinephrine”
S30 MH Dopamine Uptake Inhibitors OR dopamine reuptake inhibitor
S31 MH Bupropion OR bupropion
S32 “wellbutrin”
S33 MH Nefazodone OR nefazodone
S34 “serzone”
S35 (MH “Antidepressive Agents+”) OR (MH “Antidepressive Agents, Tricyclic+”)
S36 (MH “Amitriptyline”) OR “amitriptyline”
S37 (MH “Imipramine”) OR “imipramine”
S38 (MH “Desipramine”) OR “desipramine”
S39 (MH “Nortriptyline”) OR “nortriptyline”
S40 MH Teratogens OR teratogenicity
S41 S1 OR S2 OR S3
S42 S4 OR S5 OR S6
S43 S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39
S44 S41 AND S42 AND S43
S45 S40 AND S43
S46 S44 OR S45
S47 S44 OR S45

## EBM Reviews - Cochrane Central Register of Controlled Trials July 2013

1. exp Pregnancy/
2. pregnan$.mp.
3. Perinatal Care/
4. Postnatal Care/
5. Peripartum Period/
6. exp Postpartum Period/
7. mood disorders/ or depressive disorder/ or depression, postpartum/ or depressive disorder, major/ or depressive disorder, treatment-resistant/ or dysthymic disorder/ or seasonal affective disorder/
8. Depression/
9. (depressi$ or dysthymi$ or “mood disorder$” or “seasonal affective disorder” or sad).mp.
10. or/7–9
11. 10 and (de or dh or dt or pc or th).fs.
12. Serotonin Uptake Inhibitors/
13. (selective serotonin reuptake inhibitor$ or ssri).mp.
14. (citalopram or escitalopram or fluoxetine or fluvoxamine or sertraline or paroxetine).mp.
15. (celexa or lexapro or prozac or luvox or zoloft or paxil).mp.
16. serotonin norepinephrine reuptake inhibitor.mp.
17. (desvenlafaxine or mirtazapine).mp.
18. (pristiq or effexor).mp.
19. (noradrenergic and specific serotonergic reuptake inhibitor).mp.
20. remeron.mp.
21. (selective serotonin and norepinephrine reuptake inhibitor).mp.
22. ssnri.mp.
23. (duloxetine or cymbalta).mp.
24. (norepinephrine and dopamine reuptake inhibitor).mp.
25. ndri.mp.
26. (bupropion or wellbutrin).mp.
27. (nefazodone or serzone).mp.
28. (olanzapine adj1 fluoxetine).mp.
29. exp Antidepressive Agents/
30. Antidepressive Agents, Tricyclic/
31. (amitriptyline or imipramine).mp.
32. desipramine.mp. or Desipramine/
33. nortriptyline.mp. or Nortriptyline/
34. or/12–33
35. exp Prenatal Injuries/
36. exp Maternal Exposure/
37. exp Pregnancy Complications/
38. exp Pregnancy Outcome/
39. exp Fetal Development/
40. or/35–39
41. exp Infant/
42. exp Infant Mortality/
43. exp child/ or exp child, preschool/
44. (infant$ or child$ or pediatri$).mp.
45. or/41–44
46. exp Prenatal Care/
47. exp Preconception Care/
48. Abnormalities, Drug-Induced/ or Prenatal Exposure Delayed Effects/
49. teratogen$.mp.
50. or/1–6
51. (pregnan$ or perinatal or postpartum).mp.
52. 50 or 51
53. 46 or 47 or 52
54. 48 or 49
55. 11 and 34 and 53
56. 34 and 40
57. 34 and 54
58. 34 and 45 and 52
59. or/55–58

## EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 2013

1. (depressi$ or bipolar$ or dysthymi$ or cyclotymi$ or “mood disorder$” or “seasonal affective disorder” or sad).mp.
2. (selective serotonin reuptake inhibitor$ or ssri).mp.
3. (citalopram or escitalopram or fluoxetine or fluvoxamine or sertraline or paroxetine).mp.
4. (celexa or lexapro or prozac or luvox or zoloft or paxil).mp.
5. serotonin norepinephrine reuptake inhibitor.mp.
6. (desvenlafaxine or mirtazapine).mp.
7. (pristiq or effexor).mp.
8. (noradrenergic and specific serotonergic reuptake inhibitor).mp.
9. mirtazapine.mp.
10. remeron.mp.
11. (selective serotonin and norepinephrine reuptake inhibitor).mp.
12. ssnri.mp.
13. (duloxetine or cymbalta).mp.
14. (norepinephrine and dopamine reuptake inhibitor).mp.
15. ndri.mp.
16. (bupropion or wellbutrin).mp.
17. (nefazodone or serzone).mp.
18. (olanzapine adj1 fluoxetine).mp.
19. antidepressant$.mp.
20. (amitriptyline or imipramine or desipramine or nortriptyline).mp.
21. (pregnan$ or prenatal$ or postnatal$ or peripartum or postpartum).mp.
22. or/2–20
23. 1 and 21 and 22
24. limit 23 to full systematic reviews

## Ovid MEDLINE and Ovid OLDMEDLINE 1946 to July 2013

1. exp Pregnancy/
2. pregnan$.mp.
3. Perinatal Care/
4. Postnatal Care/
5. Peripartum Period/
6. exp Postpartum Period/
7. mood disorders/ or depressive disorder/ or depression, postpartum/ or depressive disorder, major/ or depressive disorder, treatment-resistant/ or dysthymic disorder/ or seasonal affective disorder/
8. Depression/
9. (depressi$ or dysthymi$ or “mood disorder$” or “seasonal affective disorder” or sad).mp.
10. or/7–9
11. 10 and (de or dh or dt or pc or th).fs.
12. Serotonin Uptake Inhibitors/
13. (selective serotonin reuptake inhibitor$ or ssri).mp.
14. (citalopram or escitalopram or fluoxetine or fluvoxamine or sertraline or paroxetine).mp.
15. (celexa or lexapro or prozac or luvox or zoloft or paxil).mp.
16. serotonin norepinephrine reuptake inhibitor.mp.
17. (desvenlafaxine or mirtazapine).mp.
18. (pristiq or effexor).mp.
19. (noradrenergic and specific serotonergic reuptake inhibitor).mp.
20. remeron.mp.
21. (selective serotonin and norepinephrine reuptake inhibitor).mp.
22. ssnri.mp.
23. (duloxetine or cymbalta).mp.
24. (norepinephrine and dopamine reuptake inhibitor).mp.
25. ndri.mp.
26. (bupropion or wellbutrin).mp.
27. (nefazodone or serzone).mp.
28. (olanzapine adj1 fluoxetine).mp.
29. exp Antidepressive Agents/
30. Antidepressive Agents, Tricyclic/
31. (amitriptyline or imipramine).mp.
32. desipramine.mp. or Desipramine/
33. nortriptyline.mp. or Nortriptyline/
34. or/12–33
35. exp Prenatal Injuries/
36. exp Maternal Exposure/
37. exp Pregnancy Complications/
38. exp Pregnancy Outcome/
39. exp Fetal Development/
40. or/35–39
41. exp Infant/
42. exp Infant Mortality/
43. exp child/ or exp child, preschool/
44. (infant$ or child$ or pediatri$).mp.
45. or/41–44
46. exp Prenatal Care/
47. exp Preconception Care/
48. Abnormalities, Drug-Induced/ or Prenatal Exposure Delayed Effects/
49. teratogen$.mp.
50. or/1–6
51. (pregnan$ or perinatal or postpartum).mp.
52. 50 or 51
53. 46 or 47 or 52
54. 48 or 49
55. 11 and 34 and 53
56. 34 and 40
57. 34 and 54
58. 34 and 45 and 52
59. or/55–58
60. limit 59 to humans
61. limit 60 to english language
62. limit 60 to abstracts
63. 61 or 62

## PsychInfo 1806 to July 2013

1. exp Pregnancy/
2. pregnan$.mp.
3. mood disorders/ or depressive disorder/ or depression, postpartum/ or depressive disorder, major/ or depressive disorder, treatment-resistant/ or dysthymic disorder/ or seasonal affective disorder/
4. Depression/
5. (depressi$ or dysthymi$ or “mood disorder$” or “seasonal affective disorder” or sad).mp.
6. (selective serotonin reuptake inhibitor$ or ssri).mp.
7. (citalopram or escitalopram or fluoxetine or fluvoxamine or sertraline or paroxetine).mp.
8. (celexa or lexapro or prozac or luvox or zoloft or paxil).mp.
9. serotonin norepinephrine reuptake inhibitor.mp.
10. (desvenlafaxine or mirtazapine).mp.
11. (pristiq or effexor).mp.
12. (noradrenergic and specific serotonergic reuptake inhibitor).mp.
13. mirtazapine.mp.
14. remeron.mp.
15. (selective serotonin and norepinephrine reuptake inhibitor).mp.
16. ssnri.mp.
17. (duloxetine or cymbalta).mp.
18. (norepinephrine and dopamine reuptake inhibitor).mp.
19. ndri.mp.
20. (bupropion or wellbutrin).mp.
21. (nefazodone or serzone).mp.
22. (olanzapine adj1 fluoxetine).mp.
23. (amitriptyline or imipramine or desipramine or nortriptyline).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
24. exp Tricyclic Antidepressant Drugs/ or exp Antidepressant Drugs/
25. exp Pregnancy Outcome/
26. (infant$ or child$ or pediatri$).mp.
27. 1 or 2
28. or/3–5
29. or/6–24
30. 25 and 26
31. 27 and 28 and 29
32. 29 and 30
33. 31 or 32

## Sciverse Scopus 1974 to July 2013

(TITLE-ABS-KEY((pregnan*) AND (“mood disorder*” OR “affective disorder*” OR “depressive disorder” OR depression OR “seasonal affective disorder” OR “dysthymic disorder”)) OR (TITLE-ABS-KEY(teratogen*)) AND ((TITLE-ABS-KEY(antidepressant* OR antidepressive agent* OR “selective serotonin reuptake inhibitor*” OR “ssri” OR citalopram OR escitalopram OR fluoxetine OR fluvoxamine OR sertraline OR paroxetine OR celexa OR lexapro OR prozac OR luvox OR zoloft OR paxil OR desvenlafaxine OR mirtazapine OR pristiq OR effexor OR “noradrenergic and specific serotonergic reuptake inhibitor” OR “selective serotonin and norepinephrine reuptake inhibitor” OR “ssnri” OR “norepinephrine and dopamine reuptake inhibitor” OR bupropion OR wellbutrin OR nefazodone OR serzone OR amitriptyline OR imipramine OR desipramine OR nortriptyline OR remeron OR olanzapine))