# Abbreviations and Acronyms

ADHD: Attention deficit hyperactivity disorder
AHRQ: Agency for Healthcare Research and Quality
ASD: Autism spectrum disorder
BNBAS: Brazelton Neonatal Behavioral Assessment Scale
CCRCT: Cochrane Central Register of Controlled Trials
CES-D: Center for Epidemiologic Studies Depression Scale
CDSR: Cochrane Database of Systematic Reviews
CGI –I: Clinical Global Impressions Improvement Scale
CHIP: Children's Health Insurance Program
CI: Confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CIS-R: Clinical Interview Schedule–Revised
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
EPC: Evidence-based Practice Center
EPDS: Edinburgh Postnatal Depression Scale
FDA: U.S. Food and Drug Administration
GP: General practitioner
HAM-A: Hamilton Rating Scale for Anxiety
HAM-D: Hamilton Rating Scale for Depression
HMO: Health maintenance organization
ICD: International Classification of Diseases
ICD-9: International Classification of Diseases, Ninth Revision
KQ: Key Question
MADRS: Montgomery Asberg Depression Rating Scale
MDI: Mental Development Index
NR: Not reported
NRI: Norepinephrine reuptake inhibitor
NS: Not significant
NSD: No significant difference
OR: Odds ratio
RCT: Randomized controlled trial
RR: Relative risk
RRR: Relative risk reduction
SD: Standard deviation
SF-12: Medical Outcomes Survey 12-Item Short Form
SF-36: Medical Outcomes Survey 36-Item Short Form
SNRI: Serotonin norepinephrine reuptake inhibitor
SSNRI: Selective serotonin norepinephrine reuptake inhibitor
SSRI: Selective serotonin reuptake inhibitor
TCA: Tricyclic antidepressant
Zung SDS: Zung Self-Rating Depression Scale