# Summary and Discussion

At the request of AHRQ and the Office of the Assistant Secretary for Health (OASH) we conducted an assessment of the evidence for the safety of vaccines recommended for routine use in the United States among adults, children, and pregnant women, according to ACIP guidelines. We conducted an extensive literature search for clinical trials and observational studies meeting our inclusion criteria: cohort studies comparing vaccinated and unvaccinated groups, case-control studies, self-controlled case series, and multivariate risk factor analyses. In this chapter, we describe the limitations of our review and present our conclusions. We also include a section on Research Gaps.

## Limitations

Our literature search procedures were extensive; however, some unpublished trial results may not have been identified. An independent Scientific Resource Center (SRC) under contract with AHRQ requested Scientific Information Packets (SIPs) from the manufacturers of all vaccines routinely recommended in the United States. (The research team was prohibited from contacting manufacturers directly.) Only two companies responded; both manufacture vaccines against seasonal influenza.

We excluded non-English language studies. Although we were considering only vaccines approved for use in the United States, it is possible relevant epidemiological studies have been published in non-English journals.

An important limitation common to systematic reviews is the quality of the original studies included. We used a quality-rating instrument32 developed by another Evidence-based Practice Center specifically to evaluate studies reporting harms. The scores are presented in the results tables and taken into consideration when rating the strength of the evidence. Studies that reported timing and severity, and defined AEs using standard, precise definitions were rated higher than those that did not. Epidemiological studies that used medical records to ascertain vaccination and health outcomes were also rated higher than those that relied on patient or parent report. Strengths and weaknesses of studies vary according to their design. Cohort studies of vaccines may use multivariate analyses to control for confounding factors, but they cannot capture potential differences between those who get vaccinated and those who do no. Self-controlled case series control for patient characteristics that do not change over time (gender, race-ethnicity, genetics) but cannot capture factors that are time-related. This is especially important when studying vaccinations of infants and toddlers.

Studies using passive surveillance such as the U.S. Vaccine Adverse Event Reporting System (VAERS),16 are crucial in identifying signals regarding adverse events post-licensure. However, because by definition they do not consider the rate of such events in non-vaccinated populations, they are not designed to assess a statistical association between a vaccine and an adverse event, so they were excluded from this project. Thus, there may be important adverse event signals not identified in this report that warrant future research.

We included controlled trials that used formulations currently approved in the United States. We tried to exclude Phase II studies that used dosages that were never licensed and/ or formulations available only in other countries. Some studies reported the potency of the vaccines under study in a different manner or unit than that reported in other studies or the product materials. We assessed these findings to the best of our capabilities. We point out discrepancies in our results text.

Except where explicitly stated in the text, controlled trials of vaccines are conducted in healthy patients. Thus, persons who may be more susceptible to AEs may be excluded from trials, yet eligible to receive a vaccine after it is licensed. In addition, trials are generally underpowered to detect very rare events. For example, a trial of 1,000 patients may not detect an AE with an expected incidence of one in 5,000. Trials may also be underpowered to assess risk factors for the AEs they do detect.

Post-licensure epidemiological studies are conducted to investigate possible associations between vaccines and AEs reported in passive surveillance or multiple case reports. Such studies often do not limit their investigation to a particular brand or formulation. They may lump vaccines against a specific disease together. For example, a study might investigate the effect of “seasonal influenza vaccines” in general. Formulations of seasonal influenza vaccines change each season, the vaccine comes in inactivated or live form, and a particular batch may or may not contain a strain of H1N1. It is difficult to assess the applicability of studies that do not report specific details about vaccines.

In many studies, the severity of AEs was not reported. Our researchers coded the severity according to CATAE classification when possible. Severity is listed in our tables where available.

Most studies did not investigate potential risk factors for AEs that were found to be associated with vaccination.

Some post-licensure surveys use patient or parent recall for ascertainment of vaccination or health outcomes, rather than medical records. Subjects may not have copies of their vaccination or medical records, introducing recall bias. Advanced health information technology (HIT) systems that contain vaccination and medical records can make surveys unnecessary, leading to higher quality studies. In the United States, the CDC's Vaccine Safety Datalink (VSD) uses data obtained through such systems at nine large health care organizations, enabling very high quality studies. Nations with single payer healthcare often have electronic registries, which allow epidemiological studies of entire populations.

## Conclusions

Table 33 summarizes our conclusions, given the caveats described in the Limitations section. The second column displays the strength of evidence (SOE) regarding statistical association of each vaccine type with key AEs.

Table 33 Summary: safety of vaccines used for routine immunization of adults (including pregnant women) and children

Vaccine | EPC Conclusions and Strength of Evidence | IOM Findings | Additional Findings From EPC
Adults
Diphtheria Toxoid, Tetanus Toxoid, and Acellular Pertussis Vaccines (Td, Tdap) | High - anaphylaxis | Evidence “convincingly supports” a causal relationship between the tetanus toxoid vaccine and anaphylaxis. | We identified two additional trial in adults. No AEs were associated with vaccine.
Hepatitis A Vaccine | Insufficient- acute disseminated encephalomyelitis, transverse myelitis, MS, Guillain-Barré Syndrome, chronic inflammatory disseminated polyneuropathy, Bells' Palsy, anaphylaxis, and autoimmune hepatitis | Evidence is “inadequate to accept or reject” any causal relationships with AEs the committee was tasked with investigating: acute disseminated encephalomyelitis, transverse myelitis, MS, Guillain-Barré Syndrome, chronic inflammatory demyelinating polyneuropathy, Bells' Palsy, anaphylaxis, and autoimmune hepatitis. | We identified one additional post-licensure study; there was no association of the vaccine with any adverse events or onset of medical conditions.
Hepatitis B Vaccine | Insufficient - optic neuritis, first demyelinating event, Guillain-Barré Syndrome, SLE, onset or exacerbation of vasculitis, polyarteritis nodosa, and onset or exacerbation of rheumatoid arthritis Moderate – No association with MS onset or exacerbation Moderate – anaphylaxis in patients allergic to yeast | Although no epidemiological studies were identified on anaphylaxis, mechanistic evidence “favors acceptance” of a causal relationship between the vaccine and anaphylaxis in yeast-sensitive individuals. Epidemiological studies of the following AEs in adults had evidence “inadequate to accept or reject” a causal relationship: optic neuritis, first demyelinating event, Guillain-Barré Syndrome, SLE, onset or exacerbation of vasculitis, polyarteritis nodosa, and onset or exacerbation of rheumatoid arthritis. A 2002 IOM review on Hep B vaccine and demyelinating neurological disorders concluded that the evidence “favors rejection” of a causal relationship with incident MS or MS relapse. No epidemiological studies of the following AEs in adults were found, evidence is also “inadequate to accept or reject” a causal relationship: encephalitis, encephalopathy, acute disseminated encephalomyelitis ADEM, transverse myelitis, neuromyelitis optica, chronic inflammatory demyelinating polyneuropathy, brachial neuritis, erythema nodosum, onset or exacerbation of psoriatic arthritis, onset or exacerbation of reactive arthritis, and fibromyalgia. | No additional studies met our inclusion criteria.
Influenza Vaccines | High – arthralgia, myalgia, malaise, fever, pain at injection site, anaphylaxis High – 2009 Monovalent H1N1 vaccine with Guillain-Barré Syndrome (GBS) High – No association with cardiovascular events in the elderly Insufficient - Multiple Sclerosis (MS) onset & exacerbation | Studied two forms of influenza vaccine: live attenuated form, administered intranasally (LAIV), and inactivated form (TIV), administered intramuscularly. Evidence “convincingly supports” a causal relationship between influenza vaccines and anaphylaxis in persons allergic to egg or gelatin. However, in recent years, manufacturers have reduced the egg protein content. | Many clinical trials reported that influenza vaccines are associated with arthralgia, myalgia, malaise, fever, and pain in the short-term in adults. These adverse events (AEs) were not considered serious; severity was graded mild to moderate. Odds of experiencing these events were 1.5 to 2 times higher in vaccinated patients than in unvaccinated. Risk factors were not discussed in the trials. A high quality meta-analysis found an association between 2009 monovalent H1N1 vaccine and Guillain-Barré Syndrome (GBS) in the 42 days post vaccination; results translate to about 1.6 excess cases per million vaccinated. Post-licensure studies have found inconsistent evidence associating influenza vaccines with onset or exacerbation of MS in adults. Post-licensure studies have found influenza vaccines are NOT associated with increased risk of cardiovascular or cerebrovascular events in the elderly. Post-licensure studies have shown that influenza vaccines are NOT associated with increased risk of serious AEs (SAEs) in renal patients.
MMR Vaccine | Moderate – No association with Type 1 diabetes Moderate - transient arthralgia in women Insufficient - MS onset, Guillain-Barré Syndrome, chronic arthralgia in women, and chronic arthritis and arthropathy in men. | Evidence “favors acceptance” of a causal relationship with transient arthralgia in women. Evidence is “inadequate to accept or reject” a causal relationship with MS onset, Guillain-Barré Syndrome, chronic arthralgia in women, and chronic arthritis and arthropathy in men. | MMR was NOT associated with onset of type 1 diabetes in adults in one large high quality epidemiological study. RR=0.71 (95% CI 0.61, 0.83)
Pneumococcal Polysaccharide Vaccine | High – No association cardiovascular or cerebrovascular events in the elderly | Not covered | We found no placebo-controlled trials of the current formulation that reported adverse events data. (We did find trials of the current formulation that reported pneumonia or mortality; these were considered efficacy outcomes). Post-licensure studies of pneumococcal polysaccharide vaccine found vaccination was not associated with increased risk of cardiovascular events in older adults.
Zoster Vaccine | Moderate – injection site reactions, allergic reactions cellulitis possibly related to allergy | Recommended for U.S. adults over age 60; AEs specific to this age group were not covered. | In some reports of clinical trials, adverse events were reported only in categories such as “injection–related adverse events,” “systematic adverse events,” or “serious adverse events”. Vaccination was associated with injection site reactions. In post-licensure studies, vaccination was associated with cellulitis possibly related to allergy and allergic reactions, such as redness and swelling 1 to 7 days post vaccination. These mild AEs occurred in less than 1% of patients, and were more likely in the younger (aged 50-59) vaccinees.85,86
Children and Adolescents
Diphtheria Toxoid, Tetanus Toxoid, and Acellular Pertussis-Containing Vaccines (DTap, Td, Tdap) | Moderate - No association with type 1 diabetes Insufficient - infantile spasms, seizures, cerebellar ataxia, autism, ADEM, transverse myelitis, MS relapse, serum sickness, immune thrombocytopenic purpura, and SIDS. | Evidence “favors rejection” of a causal relationship between vaccines containing diphtheria toxoid, tetanus toxoid, and acellular pertussis antigens and type 1 diabetes. Evidence is “inadequate to accept or reject” causal relationships between vaccination and the following: infantile spasms, seizures, cerebellar ataxia, autism, ADEM, transverse myelitis, MS relapse in children, serum sickness, immune thrombocytopenic purpura, and SIDS. | We found no additional studies that met our inclusion criteria.
Hepatitis B Vaccine | Insufficient – food allergy Moderate – No association with MS | Although no epidemiological studies were identified by the IOM, mechanistic evidence “favored acceptance” of a causal relationship between the vaccine and anaphylaxis in yeast-sensitive individuals. The IOM found evidence “inadequate to accept or reject” a causal relationship with any other AEs. A 2002 IOM report “favors rejection” of a causal relationship with MS onset or exacerbation. | Hepatitis B vaccine in the first 6 months of life was associated with elevated total IgE in a post-licensure study of children with a family history of food allergy, but not with clinical allergy215,215,216,216
Hib | Moderate – No association with Serious Adverse Events in short term | Not covered | No serious adverse events were associated in three high quality clinical trials.
HPV Vaccine | Moderate – No association with juvenile rheumatoid arthritis, Type 1 diabetes, appendicitis, Guillain Barré Syndrome, seizures, stroke, syncope, venous thromboembolism Moderate – anaphylaxis in persons with allergies, fever, headache, mild GI AEs, skin infection High – Pain at injection site Insufficient - ADEM, transverse myelitis, neuromyelitis optica, MS, onset of Hashimoto's disease, chronic inflammatory demyelinating polyneuropathy, brachial neuritis, amyotrophic lateral sclerosis, transient arthralgia, pancreatitis, thromboembolic events, spontaneous abortion, and hypercoagulable states | Evidence “favors acceptance” of a causal relationship between the HPV vaccine and anaphylaxis. Evidence is “inadequate to accept or reject” causal relationships between HPV vaccines and the following: ADEM, transverse myelitis, neuromyelitis optica, MS, Guillain-Barré syndrome, chronic inflammatory demyelinating polyneuropathy, brachial neuritis, amyotrophic lateral sclerosis, transient arthralgia, pancreatitis, thromboembolic events, and hypercoagulable states. | A large post-licensure study found HPV vaccine was not associated with onset of juvenile rheumatoid arthritis or Type 1 diabetes. This study reported an IRR of 1.29 (95% CI 1.08, 1.56) of onset of Hashimoto's disease. However, investigation of a temporal relationship and biological plausibility revealed no consistent evidence of a safety signal. A large post-licensure study found HPV vaccine was NOT associated with Guillain Barré Syndrome, seizures, stroke, syncope, or venous thromboembolism. Several clinical trials found HPV vaccination associated with short-term severe pain at injection site. Trials also found vaccine associated with fever, headache, nausea and stomach ache. A secondary analysis including only black women who became pregnant within 3 to 4 years of receiving HPV vaccine in two trials reported a higher rate of spontaneous abortion in vaccinated subjects.
Inactivated polio vaccine | Insufficient – food allergy | Not covered | One post-licensure study reported association between polio vaccine in newborns and sensitivity to food allergens.
Influenza Vaccines | Moderate - mild gastrointestinal disorders, febrile seizures Low – No association with other Serious Adverse Events in the short term in children with cancer or who have received organ transplants Low - influenza-like symptoms Insufficient – asthma exacerbation (with live vaccine), ADEM, transverse myelitis | The IOM committee studied seasonal influenza vaccines. The influenza vaccine is administered in two forms: a live attenuated form, administered intranasally, and an inactivated form, administered intramuscularly. Evidence was “inadequate to accept or reject” a causal relationship in the pediatric population between seasonal influenza vaccines and the following: seizures, (ADEM), and transverse myelitis. Evidence was “inadequate to accept or reject” a causal relationship between live attenuated influenza vaccine (LAIV) and asthma exacerbation or reactive airway disease (RAD) episodes. | Seasonal influenza vaccines were NOT associated with any serious adverse events in the short term in children with malignancy, IBD, urea cycle disorders or children who had received organ transplant in post-licensure studies. Both seasonal influenza vaccines and monovalent H1N1 vaccine were associated with mild gastrointestinal disorders, such as vomiting and diarrhea in children in the short-term in several large post-licensure studies. One large study114,114,114,115 found that younger vaccinated children (aged 5 to 8 years) were more likely to experience these symptoms than older vaccinated children (aged 9 to 17 years). (Children under 5 years of age were not included in that study). Both live and inactivated seasonal influenza vaccines were associated with influenza-like symptoms in children in the short term in multiple studies, while not associated in others. A large U.S. post-licensure study of children under age 5 years found TIV associated with febrile seizures. Risk was increased if PCV13 was administered concomitantly
Measles-Mumps-Rubella | High – No association with Autism Spectrum Disorders High - anaphylaxis in children with allergies, febrile seizures Moderate – Transient arthralgia Moderate - thrombocytopenic purpura Insufficient - encephalitis, encephalopathy, afebrile seizures, meningitis, cerebellar ataxia, acute disseminated encephalomyelitis, transverse myelitis, optic neuritis, neuromyelitis optica, MS onset, and chronic arthropathy | Evidence “convincingly supports” causal relationships with febrile seizures and, anaphylaxis. Evidence “convincingly supports” a causal relationship with measles inclusion body encephalitis in immunocompromised patients. Evidence “favors acceptance” of a causal relationship between MMR and transient arthralgia Evidence “favors rejection” of a causal relationship between MMR and autism. Evidence is “inadequate to accept or reject” a causal relationship with encephalitis, encephalopathy, afebrile seizures, cerebellar ataxia, acute disseminated encephalomyelitis, transverse myelitis, optic neuritis, neuromyelitis optica, MS onset, and chronic arthropathy. | Four additional postmarketing studies were identified. Vaccination was associated with thrombocytopenic purpura in the short term. MMR vaccination was associated with increased emergency department visits within two weeks; this is indirect support of the IOM's findings that MMR vaccine is associated with febrile seizures.
Meningococcal Vaccines (MCV4. MPSV) | Moderate – anaphylaxis in children with allergies Insufficient - encephalitis, encephalopathy, ADEM, transverse myelitis, MS, Guillain-Barré syndrome, CIDP, chronic headache. | Evidence “convincingly supports” a causal relationship with anaphylaxis in children who may be allergic to ingredients. Evidence is “inadequate to accept or reject” causal relationships between meningococcal vaccine (unspecified) and the following: encephalitis, encephalopathy, ADEM, transverse myelitis, MS, Guillain-Barré syndrome, CIDP, and chronic headache. | Two new trials of quadrivalent meningococcal conjugate vaccines found no association with any AEs assessed.
Miscellaneous & Combination Vaccines | Moderate - DTaP-IPV-Hib vaccination with febrile seizures High – no association of childhood leukemia with MMR, DTaP, Td, Hib, Hep B, and polio vaccines Moderate – Hepatitis A, MMR, and varicella vaccine with purpura | Not covered | Association of DTaP-IPV-Hib vaccination with febrile seizures in children was found in a very large, high quality post-licensure study. Rate for first dose was estimated as 5.5 cases per 100,000 person/days. Rate for second dose was estimated as 5.7 cases per 100,000 person/days. Multiple large epidemiological studies have assessed MMR, DTaP, Td, Hib, Hep B, and polio vaccine and have found no association with childhood leukemia. In a large post-licensure study of over 1.8 million vaccines recipients, purpura was associated with vaccination against Hepatitis A in children aged 7 to 17 years, vaccination against varicella in children aged 11 to 17, and MMR in children from 12 to 19 months of age. These results were based on one or two cases per vaccine type/age group. According to the authors most cases were mild and acute.
Pneumococcal Conjugate (PCV13) | Moderate – Febrile seizures | Not covered. | A recent study using the U.S. Vaccine Safety Datalink (VSD) found an association with febrile seizures. Estimated rate for 16-month old patients is 13.7 cases per 100,000 doses for PCV13 without concomitant TIV, and 44.9 per 100,000 doses for concomitant TIV and PCV13.
Rotavirus Vaccines: RotaTeq and Rotarix | Moderate – intussusception | Not covered. | In clinical trials, there was no association between either of the two currently available vaccines (RotaTeq and Rotarix) and any serious adverse events, including intussusception, in the long or short-term. A high quality epidemiological study in Australia found RotaTeq was associated with intussusception 1 to 21 days following the first of three required doses in infants 1 to 3 months of age. Two case-control studies conducted in Latin America found an association of Rotarix with intussusception in children following the first of two required doses. Although one U.S. epidemiological study found no association, a recent analysis of the U.S. Post-Licensure Rapid Immunization Safety Monitoring (PRISM) program found both RotaTeq and Rotarix associated with intussusception in the short term. Estimated rate was 1.1 to 1.5 cases per 100,000 doses of RotaTeq and 5.1 cases per 100,000 doses of Rotarix.
Varicella Vaccine | High – anaphylaxis, disseminated Oka VZV without other organ involvement, disseminated Oka VZV with subsequent infection resulting in pneumonia, meningitis, or hepatitis in individuals with demonstrated immunodeficiencies, vaccine strain viral reactivation without other organ involvement, vaccine strain viral reactivation with subsequent infection resulting in meningitis or encephalitis Insufficient – seizures, ADEM, transverse myelitis, Guillain-Barré syndrome, small fiber neuropathy, onset or exacerbation of arthropathy, thrombocytopenia. | Evidence “convincingly supports” causal relationships between varicella virus vaccine and the following: disseminated Oka VZV without other organ involvement disseminated Oka VZV with subsequent infection resulting in pneumonia, meningitis, or hepatitis in individuals with demonstrated immunodeficiencies, vaccine strain viral reactivation without other organ involvement, vaccine strain viral reactivation with subsequent infection resulting in meningitis or encephalitis, and anaphylaxis. The evidence is “inadequate to accept or reject” a causal relationship between the vaccine and seizures, ADEM, transverse myelitis, Guillain-Barré syndrome, small fiber neuropathy, onset or exacerbation of arthropathy, and thrombocytopenia. | We identifying one small trial in children with lupus (SLE); the trial reported no association with AEs.
Pregnant Women
Influenza Vaccines | Moderate – No association with serious adverse events | Results not specific to pregnant women | Both monovalent H1N1 vaccine and seasonal influenza vaccine (inactivated) containing H1N1 strains were not associated with serious adverse events in pregnant women or their offspring in multiple trials and post-licensure studies. Studies report an association with lower risk of adverse pregnancy outcomes.

ADEM = acute disseminated encephalomyelitis; AEs = adverse events; CIDP = chronic inflammatory demyelinating polyneuropathy; DTaP = diphtheria, tetanus, and pertussis vaccine; EPC = Evidence-based Practice Center; GBS = Guillain-Barré Syndrome; Hep B = hepatitis B; Hib = Haemophilus influenzae type B; HPV = human papillomavirus; IOM = Institute of Medicine; LAIV = live attenuated influenza vaccine; MMR = measles, mumps, rubella vaccine; MS = multiple sclerosis; RAD = reactive airway disease; SIDS = sudden infant death syndrome; SLE = systemic lupus erythematosus; Td = tetanus-diphtheria; TIV = trivalent influenza vaccine; VZV = varicella-zoster virus

## Research Gaps

### Adults

There was insufficient evidence to determine whether influenza vaccines are associated with onset or exacerbation of MS.

A recent meta-analysis on 2009 monovalent H1N1 vaccine provided high strength evidence of association with Guillain Barré Syndrome in adults. As the vaccine is associated with only 1.6 excess cases per million vaccinated, it will be very difficult to assess risk factors.

The unknown association regarding MS and GBS and vaccines against hepatitis A, hepatitis B, and MMR presents a research gap; the IOM found evidence inadequate to accept or reject a causal relationship.

Some published vaccine trials were not specific in reporting AEs. Broad categories such as “injection–related adverse events,” “systemic adverse events,” “one or more adverse events” or “serious adverse events” were reported rather than specific AE. In addition, many studies reported on a list of pre-defined adverse events but did not rate the severity or provide enough information for our investigators to determine severity. Future trials of vaccines should report results with more granularity.

### Children and Adolescents

There is insufficient evidence to determine any potential association between trivalent inactivated vaccine and asthma exacerbation, acute disseminated encephalomyelitis (ADEM), and transverse myelitis.

Febrile seizures were associated with MMR, influenza, and pneumococcal conjugate vaccines. Younger age was associated with increased risk in several studies. Large scale epidemiological studies could determine other patient risk factors.

A large post-licensure study found associations between both Rotarix and RotaTeq and intussusception in the short term following vaccination in U.S. children; patient risk factors were not reported.

Strong evidence for a lack of association of HPV vaccines with several serious medical conditions (juvenile rheumatoid arthritis, type 1 diabetes, GBS) has been found in large post-licensure studies. However, there is insufficient evidence regarding other serious conditions such as MS, chronic inflammatory demyelinating polyneuropathy, amyotrophic lateral sclerosis, and pancreatitis. Importantly, a recent analysis of long term follow-up data from two trials of Gardasil showed a possible increased risk of miscarriage of pregnancies within four years of vaccination among Black women. Large datasets from U.S. Managed Care Organizations (MCOs) include both immunizations and pregnancy records needed to investigate the potential relationship.

There is insufficient evidence to determine the possible association, if any, between vaccines such as DTaP, meningococcal vaccine, and varicella vaccine and the onset of nervous system conditions such as ADEM, transverse myelitis, MS, and GBS. Large scale epidemiological studies could provide additional data; however, as these medical conditions are extremely rare, it may be difficult to reach a level of evidence beyond “insufficient”.

### Pregnant Women

There is moderate strength of evidence that inactivated influenza vaccine is not associated with serious adverse events in pregnant women or their offspring. Given the 2013 recommendation to administer the Tdap vaccine during every pregnancy, passive surveillance systems should be monitored regularly for AEs in this population. This is a particular concern for women with multiple pregnancies over a period of a few years.

A reliable system of tracking when in pregnancy the vaccine was given is extremely important. In addition, in any study of vaccines and pregnancy, follow-up of newborns should be sufficiently long, as not all adverse effects may be apparent immediately after birth. The need for large numbers of pregnant exposures is particularly important given the relative low frequency of some birth defects and defining which are causal to vaccine. In addition, little is known about the patient factors which may influence the effect of the vaccine. Another unknown is how vaccination in pregnancy may affect the newborn's immune system/reaction to newborn vaccinations. The Vaccines and Medications in Pregnancy Surveillance System (VAMPSS) has components to monitor safety of maternally-administered vaccines and their effect on recipients and their offspring. VAMPSS is a collaboration of the American Academy of Asthma Allergy and Immunology, the Organization of Teratology Information Specialists (OTIS) Research Center at the University of California San Diego and the Slone Epidemiology Center (SEC) at Boston University. The U.S. Department of Health and Human Services Biomedical Advanced Research and Development Authority contracted VAMPSS to perform safety monitoring of pandemic H1N1 influenza vaccine administered during the 2009 pandemic. As this report was being finalized, a VAMPSS study on the safety of H1N1 was released;238,239 the authors found no meaningful evidence of increase risk of major birth defects, miscarriage, or low birth weight for gestational age. Further, existing federal systems such as the VSD and/or PRISM could be potentially be used, as well.

### General Methodological Observations

Advanced health information technology (HIT) systems that contain both vaccination and health outcome records can be used to conduct high quality epidemiological studies. In the United States, the VSD contains data obtained through such systems at nine very large MCOs. The FDA's Mini-Sentinel program also conducts active surveillance using electronic healthcare databases from MCOs. Nations with single payer healthcare systems often have electronic registries which allow very large epidemiological studies of entire populations. Studies using these databases have greater validity than studies that rely on surveys that use patient / parent recall for ascertainment of vaccination or health outcome. Not only are such surveys subject to recall bias, but there may be no way of determining the formulation or brand of vaccination.

Observational studies should be powered adequately to determine risk factors such as demographic and health characteristics of patients. Analysis should be stratified by formulation and brand of vaccine, if possible. This is especially true for influenza vaccine, which differs from season to season.

Independent abstraction and systematic reassessment of the studies included in the Institute of Medicine consensus report “Adverse Effects of Vaccines: Evidence and Causality” may be a useful future endeavor. Odds ratios could be calculated for each event reported in each trial and post-licensure study, and, where appropriate, meta-analysis conducted to calculate overall odds ratios for each AE and each vaccine type. If these studies were abstracted, the totality of data could be statistically analyzed to explore additional hypotheses and issues beyond the scope of the current report.