# References

1 (1999). Ten great public health achievements--United States, 1900-1999. MMWR Morb Mortal Wkly Rep.
2 (2012). National state, and local area vaccination coverage among children aged 19-35 months - United States, 2011. MMWR Morb Mortal Wkly Rep.
3 (2012). National and state vaccination coverage among adolescents aged 13-17 years - United States, 2011. MMWR Morb Mortal Wkly Rep.
4 (2012). Adult vaccination coverage--United States, 2010. MMWR Morb Mortal Wkly Rep.
5 (2011). Influenza vaccination coverage among pregnant women --- United States, 2010-11 influenza season. MMWR Morb Mortal Wkly Rep.
6 Molinari NA, Ortega-Sanchez IR, Messonnier ML, et al. (2007). The annual impact of seasonal influenza in the US: measuring disease burden and costs. Vaccine.
7 U.S. Cancer Statistics Working Group. (2012). United States Cancer Statistics: 1999–2008 Incidence and Mortality Web-based Report.
8 Centers for Disease Control and Prevention (CDC). (2013). Updated Recommendations for Use of Tetanus Toxoid, Reduced Diphtheria Toxoid, and Acellular Pertussis Vaccine (Tdap) in Pregnant Women — Advisory Committee on Immunization Practices (ACIP), 2012. MMWR Morb Mortal Wkly Rep.
9 Marshall V, Baylor NW. (2011). Food and Drug Administration regulation and evaluation of vaccines. Pediatrics.
10 Salmon DA, Pavia A, Gellin B. (2011). Editors' introduction: Vaccine safety throughout the product life cycle. Pediatrics.
11 U.S. Food and Drug Administration (FDA). (2013). Postmarket Requirements and Commitments.
12 Nguyen M, Ball R, Midthun K, et al. (2012). The Food and Drug Administration's Post-Licensure Rapid Immunization Safety Monitoring program: strengthening the federal vaccine safety enterprise. Pharmacoepidemiology & Drug Safety.
13 (2011). Mini-Sentinel.
14 U.S. Food and Drug Administration (FDA). (2013). Vaccines, Blood & Biologics.
15 Ball R, Horne D, Izurieta H, et al. (2011). Statistical, epidemiological, and risk-assessment approaches to evaluating safety of vaccines throughout the life cycle at the Food and Drug Administration. Pediatrics.
16 Haber P, Iskander J, Walton K, et al. (2011). Internet-based reporting to the vaccine adverse event reporting system: A more timely and complete way for providers to support vaccine safety. Pediatrics.
17 Baggs J, Gee J, Lewis E, et al. (2011). The Vaccine Safety Datalink: a model for monitoring immunization safety. Pediatrics.
18 LaRussa PS, Edwards KM, Dekker CL, et al. (2011). Understanding the role of human variation in vaccine adverse events: the Clinical Immunization Safety Assessment Network. Pediatrics.
19 Wakefield AJ, Murch SH, Anthony A, et al. (1998). Ileal-lymphoid-nodular hyperplasia, non-specific colitis, and pervasive developmental disorder in children. Lancet.
20 Jansen VA, Stollenwerk N, Jensen HJ, et al. (2003). Measles outbreaks in a population with declining vaccine uptake. Science.
21 (2010). Retraction--Ileal-lymphoid-nodular hyperplasia, non-specific colitis, and pervasive developmental disorder in children. Lancet.
22 Freed GL, Clark SJ, Hibbs BF, et al. (2004). Parental vaccine safety concerns. The experiences of pediatricians and family physicians. Am J Prev Med.
23 Advisory Committee on Immunization Practices. (2011). Recommended adult immunization schedule: United States, 2011. Ann Intern Med.
24 CDC (Centers for Disease Control and Prevention). (2012). ACIP Recommendations Advisory Committee for Immunization Practices (ACIP).
25 CDC (Centers for Disease Control and Prevention). (2012). Guidelines for Vaccinating Pregnant Women.
26 Evidence Partners. (2011). DistillerSR.
27 (2011). Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0.
28 Mann CJ. (2003). Observational research methods. Research design II: cohort, cross sectional, and case-control studies. Emerg Med J.
29 Whitaker HJ, Farrington CP, Spiessens B, et al. (2006). Tutorial in biostatistics: the self-controlled case series method. Statistics in Medicine.
30 DHHS (U.S. Department of Health and Human Services). (2009). Common Terminology Criteria for Adverse Events (CTCAE). Version 4.0.
31 SAS/STAT software. Version 9.3 of the SAS System for [Unix].
32 Santaguida PL, Raina P. (2008). The Development of the McHarm Quality Assessment Scale for adverse events: Delphi Consensus on important criteria for evaluating harms.
33 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol.
34 Balshem H, Helfand M, Schunemann HJ, et al. (2011). GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol.
35 Greene SK, Kulldorff M, Lewis EM, et al. (2010). Near real-time surveillance for influenza vaccine safety: proof-of-concept in the Vaccine Safety Datalink Project. Am J Epidemiol.
36 De Serres G, Skowronski DM, Guay M, et al. (2004). Recurrence risk of oculorespiratory syndrome after influenza vaccination: randomized controlled trial of previously affected persons. Arch Intern Med.
37 Hambidge SJ, Glanz JM, France EK, et al. (2006). Safety of trivalent inactivated influenza vaccine in children 6 to 23 months old. JAMA.
38 Scheifele DW, Duval B, Russell ML, et al. (2003). Ocular and respiratory symptoms attributable to inactivated split influenza vaccine: evidence from a controlled trial involving adults. Clin Infect Dis.
39 Skowronski DM, De Serres G, Scheifele D, et al. (2003). Randomized, double-blind, placebo-controlled trial to assess the rate of recurrence of oculorespiratory syndrome following influenza vaccination among persons previously affected. Clin Infect Dis.
40 Castro M, Dozor A, Fish J, et al. (2001). The safety of inactivated influenza vaccine in adults and children with asthma. New England Journal of Medicine.
41 Kmiecik T, Arnoux S, Kobryn A, et al. (2007). Influenza vaccination in adults with asthma: safety of an inactivated trivalent influenza vaccine. J Asthma.
42 Nicholson KG, Nguyen-Van-Tam JS, Ahmed AH, et al. (1998). Randomised placebo-controlled crossover trial on effect of inactivated influenza vaccine on pulmonary function in asthma. Lancet.
43 Pedroza A, Huerta JG, Garcia Mde L, et al. (2009). The safety and immunogenicity of influenza vaccine in children with asthma in Mexico. Int J Infect Dis.
44 Stenius-Aarniala B, Huttunen JK, Pyhala R, et al. (1986). Lack of clinical exacerbations in adults with chronic asthma after immunization with killed influenza virus. Chest.
45 Tata LJ, West J, Harrison T, et al. (2003). Does influenza vaccination increase consultations, corticosteroid prescriptions, or exacerbations in subjects with asthma or chronic obstructive pulmonary disease?. Thorax.
46 Langley JM, Aoki F, Ward BJ, et al. (2011). A nasally administered trivalent inactivated influenza vaccine is well tolerated, stimulates both mucosal and systemic immunity, and potentially protects against influenza illness. Vaccine.
47 Barrett PN, Berezuk G, Fritsch S, et al. (2011). Efficacy, safety, and immunogenicity of a Vero-cell-culture-derived trivalent influenza vaccine: a multicentre, double-blind, randomised, placebo-controlled trial. Lancet.
48 Frey S, Vesikari T, Szymczakiewicz-Multanowska A, et al. (2010). Clinical efficacy of cell culture-derived and egg-derived inactivated subunit influenza vaccines in healthy adults. Clinical Infectious Diseases.
49 Iorio A, Basileo M, Marcucci M, et al. (2010). Influenza vaccination and vitamin K antagonist treatment: a placebo-controlled, randomized, double-blind crossover study. Archives of Internal Medicine.
50 Jackson LA, Gaglani MJ, Keyserling HL, et al. (2010). Safety, efficacy, and immunogenicity of an inactivated influenza vaccine in healthy adults: a randomized, placebo-controlled trial over two influenza seasons. BMC Infectious Diseases.
51 Treanor JJ, El Sahly H, King J, et al. (2011). Protective efficacy of a trivalent recombinant hemagglutinin protein vaccine (FluBlok[REGISTERED]) against influenza in healthy adults: a randomized, placebo-controlled trial. Vaccine.
52 Talaat KR, Greenberg ME, Lai MH, et al. (2010). A single dose of unadjuvanted novel 2009 H1N1 vaccine is immunogenic and well tolerated in young and elderly adults. Journal of Infectious Diseases.
53 Madhi SA, Maskew M, Koen A, et al. (2011). Trivalent inactivated influenza vaccine in African adults infected with human immunodeficient virus: double blind, randomized clinical trial of efficacy, immunogenicity, and safety. Clinical Infectious Diseases.
54 Wang IK, Lin CL, Lin PC, et al. (2013). Effectiveness of influenza vaccination in patients with end-stage renal disease receiving hemodialysis: a population-based study. PLoS ONE.
55 Baxter R, Bakshi N, Fireman B, et al. (2013). Lack of association of guillain-barre syndrome with vaccinations. Clin Infect Dis.
56 Greene SK, Rett M, Weintraub ES, et al. (2012). Risk of Confirmed Guillain-Barre Syndrome Following Receipt of Monovalent Inactivated Influenza A (H1N1) and Seasonal Influenza Vaccines in the Vaccine Safety Datalink Project, 2009-2010. American Journal of Epidemiology.
57 Salmon DA, Proschan M, Forshee R, et al. (2013). Association between Guillain-Barre syndrome and influenza A (H1N1) 2009 monovalent inactivated vaccines in the USA: a meta-analysis. Lancet.
58 Grimaldi-Bensouda L, Alperovitch A, Besson G, et al. (2011). Guillain-Barre syndrome, influenzalike illnesses, and influenza vaccination during seasons with and without circulating A/H1N1 viruses. American Journal of Epidemiology.
59 Crawford NW, Cheng A, Andrews N, et al. (2012). Guillain-Barre syndrome following pandemic (H1N1) 2009 influenza A immunisation in Victoria: a self-controlled case series. Medical Journal of Australia.
60 Lee GM, Greene SK, Weintraub ES, et al. (2011). H1N1 and seasonal influenza vaccine safety in the vaccine safety datalink project. American Journal of Preventive Medicine.
61 Isai A, Durand J, Le Meur S, et al. (2012). Autoimmune disorders after immunisation with Influenza A/H1N1 vaccines with and without adjuvant: EudraVigilance data and literature review. Vaccine.
62 Farez MF, Ysrraelit MC, Fiol M, et al. (2012). H1N1 vaccination does not increase risk of relapse in multiple sclerosis: a self-controlled case-series study. Multiple Sclerosis.
63 Tanner K, Roy N, Merrill RM, et al. (2012). Case-control study of risk factors for spasmodic dysphonia: A comparison with other voice disorders. Laryngoscope.
64 Siriwardena AN, Gwini SM, Coupland CAC. (2010). Influenza vaccination, pneumococcal vaccination and risk of acute myocardial infarction: matched case-control study. CMAJ Canadian Medical Association Journal.
65 Johnstone J, Loeb M, Teo KK, et al. (2012). Influenza vaccination and major adverse vascular events in high risk patients. Circulation.
66 Hedlund J, Christenson B, Lundbergh P, et al. (2003). Effects of a large-scale intervention with influenza and 23-valent pneumococcal vaccines in elderly people: A 1-year follow-up. Vaccine.
67 Gwini SM, Coupland CAC, Siriwardena AN. (2011). The effect of influenza vaccination on risk of acute myocardial infarction: self-controlled case-series study. Vaccine.
68 Garbe E, Andersohn F, Bronder E, et al. (2012). Drug-induced immune thrombocytopaenia: results from the Berlin Case-Control Surveillance Study. European Journal of Clinical Pharmacology.
69 Hambidge SJ, Ross C, McClure D, et al. (2011). Trivalent inactivated influenza vaccine is not associated with sickle cell hospitalizations in adults from a large cohort. Vaccine.
70 Gilbertson DT, Guo H, Arneson TJ, et al. (2011). The association of pneumococcal vaccination with hospitalization and mortality in hemodialysis patients. Nephrology Dialysis Transplantation.
71 Hurst FP, Lee JJ, Jindal RM, et al. (2011). Outcomes associated with influenza vaccination in the first year after kidney transplantation. Clinical Journal of The American Society of Nephrology: CJASN.
72 Ting SCH, Crooks SW, South G. (2011). The effect of influenza vaccination on the incidence of chronic obstructive pulmonary disease exacerbations in the immediate postvaccination period. Journal of Epidemiology & Community Health.
73 Baxter R, Toback SL, Sifakis F, et al. (2012). A postmarketing evaluation of the safety of Ann Arbor strain live attenuated influenza vaccine in adults 18-49 years of age. Vaccine.
74 Tseng HF, Slezak JM, Quinn VP, et al. (2010). Pneumococcal vaccination and risk of acute myocardial infarction and stroke in men. JAMA.
75 Eurich DT, Johnstone JJ, Minhas-Sandhu JK, et al. (2012). Pneumococcal vaccination and risk of acute coronary syndromes in patients with pneumonia: population-based cohort study. Heart.
76 Vila-Corcoles A, Ochoa-Gondar O, Rodriguez-Blanco T, et al. (2012). Clinical effectiveness of pneumococcal vaccination against acute myocardial infarction and stroke in people over 60 years: the CAPAMIS study, one-year follow-up. BMC Public Health.
77 Smeeth L, Thomas SL, Hall AJ, et al. (2004). Risk of myocardial infarction and stroke after acute infection or vaccination. New England Journal of Medicine.
78 Macaladad N, Marcano T, Guzman M, et al. (2007). Safety and immunogenicity of a zoster vaccine in varicella-zoster virus seronegative and low-seropositive healthy adults. Vaccine.
79 Schmader KE, Levin MJ, Gnann JW, et al. (2012). Efficacy, safety, and tolerability of herpes zoster vaccine in persons aged 50-59 years. Clinical Infectious Diseases.
80 Vermeulen JN, Lange JMA, Tyring SK, et al. (2012). Safety, tolerability, and immunogenicity after 1 and 2 doses of zoster vaccine in healthy adults >=60 years of age. Vaccine.
81 Mills R, Tyring SK, Levin MJ, et al. (2010). Safety, tolerability, and immunogenicity of zoster vaccine in subjects with a history of herpes zoster. Vaccine.
82 Simberkoff MS, Arbeit RD, Johnson GR, et al. (2010). Safety of herpes zoster vaccine in the shingles prevention study: a randomized trial. Annals of Internal Medicine.
83 Murray AV, Reisinger KS, Kerzner B, et al. (2011). Safety and tolerability of zoster vaccine in adults >=60 years old. Human Vaccines.
84 Zhang J, Xie F, Delzell E, et al. (2012). Association between vaccination for herpes zoster and risk of herpes zoster infection among older patients with selected immune-mediated diseases. JAMA.
85 Tseng HF, Liu A, Sy L, et al. (2012). Safety of zoster vaccine in adults from a large managed-care cohort: a Vaccine Safety Datalink study. Journal of Internal Medicine.
86 Baxter R, Tran TN, Hansen J, et al. (2012). Safety of ZostavaxTM--a cohort study in a managed care organization. Vaccine.
87 Weinberg A, Levin MJ, Macgregor RR. (2010). Safety and immunogenicity of a live attenuated varicella vaccine in VZV-seropositive HIV-infected adults. Human Vaccines.
88 Ngan HYS, Cheung ANY, Tam KF, et al. (2010). Human papillomavirus-16/18 AS04-adjuvanted cervical cancer vaccine: Immunogenicity and safety in healthy Chinese women from Hong Kong. Hong Kong Medical Journal.
89 Bhatla N, Suri V, Basu P, et al. (2010). Immunogenicity and safety of human papillomavirus-16/18 AS04-adjuvanted cervical cancer vaccine in healthy Indian women. Journal of Obstetrics & Gynaecology Research.
90 Lee S, Park WB, Shin KH, et al. (2011). Immunogenicity and safety of a single intramuscular dose of a diphtheria-tetanus toxoid (Td) vaccine (GC1107) in Korean adults. Vaccine.
91 Eder L, Law T, Chandran V, et al. (2011). Association between environmental factors and onset of psoriatic arthritis in patients with psoriasis. Arthritis Care and Research.
92 Duderstadt SK, Rose CE, Real TM, et al. (2012). Vaccination and risk of type 1 diabetes mellitus in active component U.S. Military, 2002-2008. Vaccine.
93 Yu O, Bohlke K, Hanson CA, et al. (2007). Hepatitis B vaccine and risk of autoimmune thyroid disease: A Vaccine Safety Datalink study. Pharmacoepidemiology and Drug Safety.
94 Mitchell LA, Tingle AJ, MacWilliam L, et al. (1998). HLA-DR class II associations with rubella vaccine-induced joint manifestations. J Infect Dis.
95 Ray P, Black S, Shinefield H, et al. (1997). Risk of chronic arthropathy among women after rubella vaccination. Vaccine Safety Datalink Team. JAMA.
96 Slater PE, Ben-Zvi T, Fogel A, et al. (1995). Absence of an association between rubella vaccination and arthritis in underimmune postpartum women. Vaccine.
97 Tingle AJ, Mitchell LA, Grace M, et al. (1997). Randomised double-blind placebo-controlled study on adverse effects of rubella immunisation in seronegative women. Lancet.
98 IOM (Instituite of Medicine). (2002). Immunization Safety Review: Multiple Immunizations and Immune Dysfunction.
99 Belshe RB, Nichol KL, Black SB, et al. (2004). Safety, efficacy, and effectiveness of live, attenuated, cold-adapted influenza vaccine in an indicated population aged 5-49 years. Clin Infect Dis.
100 Bergen R, Black S, Shinefield H, et al. (2004). Safety of cold-adapted live attenuated influenza vaccine in a large cohort of children and adolescents. Pediatr Infect Dis J.
101 Gaglani MJ, Piedra PA, Riggs M, et al. (2008). Safety of the intranasal, trivalent, live attenuated influenza vaccine (LAIV) in children with intermittent wheezing in an open-label field trial. Pediatr Infect Dis J.
102 Piedra PA, Gaglani MJ, Riggs M, et al. (2005). Live attenuated influenza vaccine, trivalent, is safe in healthy children 18 months to 4 years, 5 to 9 years, and 10 to 18 years of age in a community-based, nonrandomized, open-label trial. Pediatrics.
103 Ashkenazi S, Vertruyen A, Aristegui J, et al. (2006). Superior relative efficacy of live attenuated influenza vaccine compared with inactivated influenza vaccine in young children with recurrent respiratory tract infections. Pediatr Infect Dis J.
104 Belshe RB, Edwards KM, Vesikari T, et al. (2007). Live attenuated versus inactivated influenza vaccine in infants and young children. N Engl J Med.
105 Englund JA, Walter E, Black S, et al. (2010). Safety and immunogenicity of trivalent inactivated influenza vaccine in infants: a randomized double-blind placebo-controlled study. Pediatric Infectious Disease Journal.
106 Halasa N, Englund JA, Nachman S, et al. (2011). Safety of live attenuated influenza vaccine in mild to moderately immunocompromised children with cancer. Vaccine.
107 Mallory RM, Malkin E, Ambrose CS, et al. (2010). Safety and Immunogenicity Following Administration of a Live, Attenuated Monovalent 2009 H1N1 Influenza Vaccine to Children and Adults in Two Randomized Controlled Trials. PLoS ONE.
108 Madhi SA, Dittmer S, Kuwanda L, et al. (2013). Efficacy and immunogenicity of influenza vaccine in HIV-infected children: a randomized, double-blind, placebo controlled trial. AIDS.
109 Greenhawt MJ, Spergel JM, Rank MA, et al. (2012). Safe administration of the seasonal trivalent influenza vaccine to children with severe egg allergy. Annals of Allergy, Asthma, & Immunology.
110 Gotoh K, Ito Y, Suzuki E, et al. (2011). Effectiveness and safety of inactivated influenza vaccination in pediatric liver transplant recipients over three influenza seasons. Pediatric Transplantation.
111 Stowe J, Andrews N, Bryan P, et al. (2011). Risk of convulsions in children after monovalent H1N1 (2009) and trivalent influenza vaccines: A database study. Vaccine.
112 Tse A, Tseng HF, Greene SK, et al. (2012). Signal identification and evaluation for risk of febrile seizures in children following trivalent inactivated influenza vaccine in the Vaccine Safety Datalink Project, 2010-2011. Vaccine.
113 Italian Multicenter Study Group for D, Vaccine Safety in C. (2011). Effectiveness and safety of the A-H1N1 vaccine in children: a hospital-based case-control study. BMJ Open.
114 Baxter R, Toback SL, Sifakis F, et al. (2012). A postmarketing evaluation of the safety of Ann Arbor strain live attenuated influenza vaccine in children 5 through 17 years of age. Vaccine.
115 Glanz JM, Newcomer SR, Hambidge SJ, et al. (2011). Safety of trivalent inactivated influenza vaccine in children aged 24 to 59 months in the vaccine safety datalink. Archives of Pediatrics & Adolescent Medicine.
116 Benchimol EI, Hawken S, Kwong JC, et al. (2013). Safety and utilization of influenza immunization in children with inflammatory bowel disease. Pediatrics.
117 Morgan TM, Schlegel C, Edwards KM, et al. (2011). Vaccines are not associated with metabolic events in children with urea cycle disorders. Pediatrics.
118 Huu TN, Toan NT, Tuan HM, et al. (2013). Safety and reactogenicity of primary vaccination with the 10-valent pneumococcal non-typeable Haemophilus influenzae protein D conjugate vaccine in Vietnamese infants: a randomised, controlled trial. BMC Infectious Diseases.
119 Santosham M, Wolff M, Reid R, et al. (1991). The efficacy in Navajo infants of a conjugate vaccine consisting of Haemophilus influenzae type b polysaccharide and Neisseria meningitidis outer-membrane protein complex. New England Journal of Medicine.
120 Capeding MRZ, Nohynek H, Pascual LG, et al. (1996). The immunogenicity of three Haemophilus influenzae type B conjugate vaccines after a primary vaccination series in Philippine infants. American Journal of Tropical Medicine and Hygiene.
121 Andrews N, Stowe J, Miller E, et al. (2007). Post-licensure safety of the meningococcal group C conjugate vaccine. Hum Vaccin.
122 Barlow WE, Davis RL, Glasser JW, et al. (2001). The risk of seizures after receipt of whole-cell pertussis or measles, mumps, and rubella vaccine. N Engl J Med.
123 Chen RT, Glasser JW, Rhodes PH, et al. (1997). Vaccine Safety Datalink project: a new tool for improving vaccine safety monitoring in the United States. The Vaccine Safety Datalink Team. Pediatrics.
124 Farrington P, Pugh S, Colville A, et al. (1995). A new method for active surveillance of adverse events from diphtheria/tetanus/pertussis and measles/mumps/rubella vaccines. Lancet.
125 Griffin MR, Ray WA, Mortimer EA, et al. (1991). Risk of seizures after measles-mumps-rubella immunization. Pediatrics.
126 Miller E, Andrews N, Stowe J, et al. (2007). Risks of convulsion and aseptic meningitis following measles-mumps-rubella vaccination in the United Kingdom. Am J Epidemiol.
127 Vestergaard M, Hviid A, Madsen KM, et al. (2004). MMR vaccination and febrile seizures: evaluation of susceptible subgroups and long-term prognosis. JAMA.
128 Ward KN, Bryant NJ, Andrews NJ, et al. (2007). Risk of serious neurologic disease after immunization of young children in Britain and Ireland. Pediatrics.
129 Benjamin CM, Chew GC, Silman AJ. (1992). Joint and limb symptoms in children after immunisation with measles, mumps, and rubella vaccine. BMJ.
130 Davis RL, Marcuse E, Black S, et al. (1997). MMR2 immunization at 4 to 5 years and 10 to 12 years of age: a comparison of adverse clinical events after immunization in the Vaccine Safety Datalink project. The Vaccine Safety Datalink Team. Pediatrics.
131 Dos Santos BA, Ranieri TS, Bercini M, et al. (2002). An evaluation of the adverse reaction potential of three measles-mumps-rubella combination vaccines. Rev Panam Salud Publica.
132 Heijstek MW, Pileggi GC, Zonneveld-Huijssoon E, et al. (2007). Safety of measles, mumps and rubella vaccination in juvenile idiopathic arthritis. Ann Rheum Dis.
133 LeBaron CW, Bi D, Sullivan BJ, et al. (2006). Evaluation of potentially common adverse events associated with the first and second doses of measles-mumps-rubella vaccine. Pediatrics.
134 Peltola H, Heinonen OP. (1986). Frequency of true adverse reactions to measles-mumps-rubella vaccine. A double-blind placebo-controlled trial in twins. Lancet.
135 Virtanen M, Peltola H, Paunio M, et al. (2000). Day-to-day reactogenicity and the healthy vaccinee effect of measles-mumps-rubella vaccination. Pediatrics.
136 Farrington CP, Miller E, Taylor B. (2001). MMR and autism: further evidence against a causal association. Vaccine.
137 Madsen KM, Hviid A, Vestergaard M, et al. (2002). A population-based study of measles, mumps, and rubella vaccination and autism. N Engl J Med.
138 Mrozek-Budzyn D, Kieltyka A, Majewska R. (2010). Lack of association between measles-mumps-rubella vaccination and autism in children: a case-control study. Pediatr Infect Dis J.
139 Smeeth L, Cook C, Fombonne E, et al. (2004). MMR vaccination and pervasive developmental disorders: a case-control study. Lancet.
140 Taylor B, Miller E, Farrington CP, et al. (1999). Autism and measles, mumps, and rubella vaccine: no epidemiological evidence for a causal association. Lancet.
141 Andrews N, Stowe J, Miller E, et al. (2012). A collaborative approach to investigating the risk of thrombocytopenic purpura after measles-mumps-rubella vaccination in England and Denmark. Vaccine.
142 Bertuola F, Morando C, Menniti-Ippolito F, et al. (2010). Association between drug and vaccine use and acute immune thrombocytopenia in childhood: a case-control study in Italy. Drug Safety.
143 O'Leary ST, Glanz JM, McClure DL, et al. (2012). The risk of immune thrombocytopenic purpura after vaccination in children and adolescents. Pediatrics.
144 Wilson K, Hawken S, Kwong JC, et al. (2011). Adverse events following 12 and 18 month vaccinations: a population-based, self-controlled case series analysis. PLoS ONE.
145 Uno Y, Uchiyama T, Kurosawa M, et al. (2012). The combined measles, mumps, and rubella vaccines and the total number of vaccines are not associated with development of autism spectrum disorder: The first case-control study in Asia. Vaccine.
146 Armah GE, Sow SO, Breiman RF, et al. (2010). Efficacy of pentavalent rotavirus vaccine against severe rotavirus gastroenteritis in infants in developing countries in sub-Saharan Africa: a randomised, double-blind, placebo-controlled trial. Lancet.
147 Block SL, Vesikari T, Goveia MG, et al. (2007). Efficacy, immunogenicity, and safety of a pentavalent human-bovine (WC3) reassortant rotavirus vaccine at the end of shelf life. Pediatrics.
148 Chang CC, Chang MH, Lin TY, et al. (2009). Experience of pentavalent human-bovine reassortant rotavirus vaccine among healthy infants in Taiwan. Journal of the Formosan Medical Association.
149 Christie CDC, Duncan ND, Thame KA, et al. (2010). Pentavalent rotavirus vaccine in developing countries: safety and health care resource utilization. Pediatrics.
150 Dennehy PH, Brady RC, Halperin SA, et al. (2005). Comparative evaluation of safety and immunogenicity of two dosages of an oral live attenuated human rotavirus vaccine. Pediatric Infectious Disease Journal.
151 Goveia MG, Rodriguez ZM, Dallas MJ, et al. (2007). Safety and efficacy of the pentavalent human-bovine (WC3) reassortant rotavirus vaccine in healthy premature infants. Pediatric Infectious Disease Journal.
152 Grant LR, Watt JP, Weatherholtz RC, et al. (2012). Efficacy of a pentavalent human-bovine reassortant rotavirus vaccine against rotavirus gastroenteritis among American Indian children. Pediatric Infectious Disease Journal.
153 Kawamura N, Tokoeda Y, Oshima M, et al. (2011). Efficacy, safety and immunogenicity of RIX4414 in Japanese infants during the first two years of life. Vaccine.
154 Kerdpanich A, Chokephaibulkit K, Watanaveeradej V, et al. (2010). Immunogenicity of a live-attenuated human rotavirus RIX4414 vaccine with or without buffering agent. Human Vaccines.
155 Kim DS, Lee TJ, Kang JH, et al. (2008). Immunogenicity and safety of a pentavalent human-bovine (WC3) reassortant rotavirus vaccine in healthy infants in Korea. Pediatric Infectious Disease Journal.
156 Kim JS, Bae CW, Lee KY, et al. (2012). Immunogenicity, reactogenicity and safety of a human rotavirus vaccine (RIX4414) in Korean infants: A randomized, double-blind, placebo-controlled, phase IV study. Human Vaccines and Immunotherapeutics.
157 Laserson KF, Nyakundi D, Feikin DR, et al. (2012). Safety of the pentavalent rotavirus vaccine (PRV), RotaTeq([REGISTERED]), in Kenya, including among HIV-infected and HIV-exposed infants. Vaccine.
158 Madhi SA, Cunliffe NA, Steele D, et al. (2010). Effect of human rotavirus vaccine on severe diarrhea in African infants. New England Journal of Medicine.
159 Narang A, Bose A, Pandit AN, et al. (2009). Immunogenicity, reactogenicity and safety of human rotavirus vaccine (RIX4414) in Indian infants. Human Vaccines.
160 Omenaca F, Sarlangue J, Szenborn L, et al. (2012). Safety, reactogenicity and immunogenicity of the human rotavirus vaccine in preterm European Infants: a randomized phase IIIb study. Pediatric Infectious Disease Journal.
161 Phua KB, Quak SH, Lee BW, et al. (2005). Evaluation of RIX4414, A live, attenuated rotavirus vaccine, in a randomized, double-blind, placebo-controlled phase 2 trial involving 2464 Singaporean infants. Journal of Infectious Diseases.
162 Phua KB, Lim FS, Lau YL, et al. (2009). Safety and efficacy of human rotavirus vaccine during the first 2 years of life in Asian infants: randomised, double-blind, controlled study. Vaccine.
163 Phua KB, Lim FS, Lau YL, et al. (2012). Rotavirus vaccine RIX4414 efficacy sustained during the third year of life: A randomized clinical trial in an Asian population. Vaccine.
164 Rodriguez ZM, Goveia MG, Stek JE, et al. (2007). Concomitant use of an oral live pentavalent human-bovine reassortant rotavirus vaccine with licensed parenteral pediatric vaccines in the United States. Pediatric Infectious Disease Journal.
165 Ruiz-Palacios GM, Perez-Schael I, Velazquez FR, et al. (2006). Safety and efficacy of an attenuated vaccine against severe rotavirus gastroenteritis. New England Journal of Medicine.
166 Sow SO, Tapia M, Haidara FC, et al. (2012). Efficacy of the oral pentavalent rotavirus vaccine in Mali. Vaccine.
167 Steele AD, Reynders J, Scholtz F, et al. (2010). Comparison of 2 different regimens for reactogenicity, safety, and immunogenicity of the live attenuated oral rotavirus vaccine RIX4414 coadministered with oral polio vaccine in South African infants. Journal of Infectious Diseases.
168 Steele AD, Madhi SA, Louw CE, et al. (2011). Safety, Reactogenicity, and Immunogenicity of Human Rotavirus Vaccine RIX4414 in Human Immunodeficiency Virus-positive Infants in South Africa. Pediatric Infectious Disease Journal.
169 Tregnaghi MW, Abate HJ, Valencia A, et al. (2011). Human rotavirus vaccine is highly efficacious when coadministered with routine expanded program of immunization vaccines including oral poliovirus vaccine in Latin America. Pediatric Infectious Disease Journal.
170 Vesikari T, Karvonen A, Puustinen L, et al. (2004). Efficacy of RIX4414 live attenuated human rotavirus vaccine in Finnish infants. Pediatric Infectious Disease Journal.
171 Vesikari T, Clark HF, Offit PA, et al. (2006). Effects of the potency and composition of the multivalent human-bovine (WC3) reassortant rotavirus vaccine on efficacy, safety and immunogenicity in healthy infants. Vaccine.
172 Vesikari T, Matson DO, Dennehy P, et al. (2006). Safety and efficacy of a pentavalent human-bovine (WC3) reassortant rotavirus vaccine. New England Journal of Medicine.
173 Vesikari T, Karvonen A, Bouckenooghe A, et al. (2011). Immunogenicity, reactogenicity and safety of the human rotavirus vaccine RIX4414 oral suspension (liquid formulation) in Finnish infants. Vaccine.
174 Vesikari T, Karvonen A, Korhonen T, et al. (2004). Safety and immunogenicity of RIX4414 live attenuated human rotavirus vaccine in adults, toddlers and previously uninfected infants. Vaccine.
175 Zaman K, Sack DA, Yunus M, et al. (2009). Successful co-administration of a human rotavirus and oral poliovirus vaccines in Bangladeshi infants in a 2-dose schedule at 12 and 16 weeks of age. Vaccine.
176 Zaman K, Dang DA, Victor JC, et al. (2010). Efficacy of pentavalent rotavirus vaccine against severe rotavirus gastroenteritis in infants in developing countries in Asia: a randomised, double-blind, placebo-controlled trial. Lancet.
177 Zaman K, Yunus M, El Arifeen S, et al. (2012). Methodology and lessons-learned from the efficacy clinical trial of the pentavalent rotavirus vaccine in Bangladesh. Vaccine.
178 Sow SO, Tapia M, Haidara FC, et al. (2012). Efficacy of the oral pentavalent rotavirus vaccine in Mali. Vaccine.
179 Lau YL, Nelson EA, Poon KH, et al. (2013). Efficacy, safety and immunogenicity of a human rotavirus vaccine (RIX4414) in Hong Kong children up to three years of age: a randomized, controlled trial. Vaccine.
180 Zaman K, Yunus M, El Arifeen S, et al. (2012). Methodology and lessons-learned from the efficacy clinical trial of the pentavalent rotavirus vaccine in Bangladesh. Vaccine.
181 Buttery JP, Danchin MH, Lee KJ, et al. (2011). Intussusception following rotavirus vaccine administration: post-marketing surveillance in the National Immunization Program in Australia. Vaccine.
182 Velazquez FR, Colindres RE, Grajales C, et al. (2012). Postmarketing surveillance of intussusception following mass introduction of the attenuated human rotavirus vaccine in Mexico. Pediatric Infectious Disease Journal.
183 Patel MM, Lopez-Collada VR, Bulhoes MM, et al. (2011). Intussusception risk and health benefits of rotavirus vaccination in Mexico and Brazil. New England Journal of Medicine.
184 Shui IM, Baggs J, Patel M, et al. (2012). Risk of intussusception following administration of a pentavalent rotavirus vaccine in US infants. JAMA.
185 Yih K, Lieu T, Kulldorff M, et al. (2013). Intussusception Risk After Rotavirus Vaccination in U.S. Infants.
186 Gallagher CM, Goodman MS. (2010). Hepatitis B Vaccination of Male Neonates and Autism Diagnosis, NHIS 1997-2002. Journal of Toxicology and Environmental Health-Part a-Current Issues.
187 Moreira ED, Palefsky JM, Giuliano AR, et al. (2011). Safety and reactogenicity of a quadrivalent human papillomavirus (types 6, 11, 16, 18) L1 viral-like-particle vaccine in older adolescents and young adults. Human Vaccines.
188 Block SL, Brown DR, Chatterjee A, et al. (2010). Clinical trial and post-licensure safety profile of a prophylactic human papillomavirus (Types 6, 11, 16, and 18) L1 virus-like particle vaccine. Pediatric Infectious Disease Journal.
189 Li R, Li Y, Radley D, et al. (2012). Safety and immunogenicity of a vaccine targeting human papillomavirus types 6, 11, 16 and 18: a randomized, double-blind, placebo-controlled trial in Chinese males and females. Vaccine.
190 Levin MJ, Moscicki AB, Song LY, et al. (2010). Safety and immunogenicity of a quadrivalent human papillomavirus (types 6, 11, 16, and 18) vaccine in HIV-infected children 7 to 12 years old. Journal of Acquired Immune Deficiency Syndromes: JAIDS.
191 Kim SC, Song YS, Kim YT, et al. (2011). Human papillomavirus 16/18 AS04-adjuvanted cervical cancer vaccine: immunogenicity and safety in 15-25 years old healthy Korean women. Journal of Gynecologic Oncology.
192 Khatun S, Akram Hussain SM, Chowdhury S, et al. (2012). Safety and immunogenicity profile of human papillomavirus-16/18 AS04 adjuvant cervical cancer vaccine: a randomized controlled trial in healthy adolescent girls of Bangladesh. Japanese Journal of Clinical Oncology.
193 Giuliano AR, Palefsky JM, Goldstone S, et al. (2011). Efficacy of quadrivalent HPV vaccine against HPV Infection and disease in males. New England Journal of Medicine.
194 De Carvalho N, Teixeira J, Roteli-Martins CM, et al. (2010). Sustained efficacy and immunogenicity of the HPV-16/18 AS04-adjuvanted vaccine up to 7.3 years in young adult women. Vaccine.
195 Roteli-Martins CM, Naud P, De Borba P, et al. (2012). Sustained immunogenicity and efficacy of the HPV-16/18 AS04-adjuvanted vaccine: Up to 8.4 years of follow-up. Human Vaccines and Immunotherapeutics.
196 Schwarz TF, Huang LM, Medina DM, et al. (2012). Four-year follow-up of the immunogenicity and safety of the HPV-16/18 AS04-adjuvanted vaccine when administered to adolescent girls aged 10-14 years. Journal of Adolescent Health.
197 Sow PS, Watson-Jones D, Kiviat N, et al. (2013). Safety and immunogenicity of human papillomavirus-16/18 AS04-adjuvanted vaccine: a randomized trial in 10-25-year-old HIV-Seronegative African girls and young women. Journal of Infectious Diseases.
198 Khatun S, Akram Hussain SM, Chowdhury S, et al. (2012). Safety and immunogenicity profile of human papillomavirus-16/18 AS04 adjuvant cervical cancer vaccine: a randomized controlled trial in healthy adolescent girls of Bangladesh. Japanese Journal of Clinical Oncology.
199 Kang S, Kim KH, Kim YT, et al. (2008). Safety and immunogenicity of a vaccine targeting human papillomavirus types 6, 11, 16 and 18: a randomized, placebo-controlled trial in 176 Korean subjects. Int J Gynecol Cancer.
200 Clark LR, Myers ER, Huh W, et al. (2013). Clinical trial experience with prophylactic human papillomavirus 6/11/16/18 vaccine in young black women. Journal of Adolescent Health.
201 Chao C, Klein NP, Velicer CM, et al. (2012). Surveillance of autoimmune conditions following routine use of quadrivalent human papillomavirus vaccine. Journal of Internal Medicine.
202 Gee J, Naleway A, Shui I, et al. (2011). Monitoring the safety of quadrivalent human papillomavirus vaccine: findings from the Vaccine Safety Datalink. Vaccine.
203 Klein NP, Hansen J, Chao C, et al. (2012). Safety of quadrivalent human papillomavirus vaccine administered routinely to females. Archives of Pediatrics & Adolescent Medicine.
204 Black S, Shinefield H, Ray P, et al. (1999). Postmarketing evaluation of the safety and effectiveness of varicella vaccine. Pediatr Infect Dis J.
205 Donahue JG, Kieke BA, Yih WK, et al. (2009). Varicella vaccination and ischemic stroke in children: is there an association?. Pediatrics.
206 Barbosa CM, Terreri MT, Rosario PO, et al. (2012). Immune response and tolerability of varicella vaccine in children and adolescents with systemic lupus erythematosus previously exposed to varicella-zoster virus. Clinical & Experimental Rheumatology.
207 Blom L, Nystrom L, Dahlquist G. (1991). The Swedish childhood diabetes study. Vaccinations and infections as risk determinants for diabetes in childhood. Diabetologia.
208 DeStefano F, Mullooly JP, Okoro CA, et al. (2001). Childhood vaccinations, vaccination timing, and risk of type 1 diabetes mellitus. Pediatrics.
209 Hviid A, Stellfeld M, Wohlfahrt J, et al. (2004). Childhood vaccination and type 1 diabetes. N Engl J Med.
210 Klein NP, Hansen J, Lewis E, et al. (2010). Post-marketing safety evaluation of a tetanus toxoid, reduced diphtheria toxoid and 3-component acellular pertussis vaccine administered to a cohort of adolescents in a United States health maintenance organization. Pediatr Infect Dis J.
211 (2000). Infections and vaccinations as risk factors for childhood type I (insulin-dependent) diabetes mellitus: a multicentre case-control investigation. EURODIAB Substudy 2 Study Group. Diabetologia.
212 Khalil M, Al-Mazrou Y, Findlow H, et al. (2012). Safety and immunogenicity of a meningococcal quadrivalent conjugate vaccine in five- to eight-year-old Saudi Arabian children previously vaccinated with two doses of a meningococcal quadrivalent polysaccharide vaccine. Clinical & Vaccine Immunology: CVI.
213 Klein NP, Reisinger KS, Johnston W, et al. (2012). Safety and immunogenicity of a novel quadrivalent meningococcal CRM-conjugate vaccine given concomitantly with routine vaccinations in infants. Pediatric Infectious Disease Journal.
214 Bernsen RMD, de Jongste JC, Koes BW, et al. (2006). Diphtheria tetanus pertussis poliomyelitis vaccination and reported atopic disorders in 8-12-year-old children. Vaccine.
215 Gruber C, Warner J, Hill D, et al. (2008). Early atopic disease and early childhood immunization--is there a link?. Allergy.
216 Mommers M, Weishoff-Houben M, Swaen GM, et al. (2004). Infant immunization and the occurrence of atopic disease in Dutch and German children: a nested case-control study. Pediatr Pulmonol.
217 Mullooly JP, Schuler R, Barrett M, et al. (2007). Vaccines, antibiotics, and atopy. Pharmacoepidemiology and Drug Safety.
218 Thomson JA, Widjaja C, Darmaputra AAP, et al. (2010). Early childhood infections and immunisation and the development of allergic disease in particular asthma in a high-risk cohort: A prospective study of allergy-prone children from birth to six years. Pediatric Allergy & Immunology.
219 Sun YL, Christensen J, Hviid A, et al. (2012). Risk of Febrile Seizures and Epilepsy After Vaccination With Diphtheria, Tetanus, Acellular Pertussis, Inactivated Poliovirus, and Haemophilus Influenzae Type b. Jama-Journal of the American Medical Association.
220 Chen RT, Glasser JW, Rhodes PH, et al. (1997). Vaccine safety datalink project: A new tool for improving vaccine safety monitoring in the United States. Pediatrics.
221 Gold M, Dugdale S, Woodman RJ, et al. (2010). Use of the Australian Childhood Immunisation Register for vaccine safety data linkage. Vaccine.
222 Rowhani-Rahbar A, Klein NP, Lewis N, et al. (2012). Immunization and bell's palsy in children: A case-centered analysis. American Journal of Epidemiology.
223 Velentgas P, Amato AA, Bohn RL, et al. (2012). Risk of Guillain-Barre syndrome after meningococcal conjugate vaccination. Pharmacoepidemiology & Drug Safety.
224 Groves FD, Gridley G, Wacholder S, et al. (1999). Infant vaccinations and risk of childhood acute lymphoblastic leukaemia in the USA. Br J Cancer.
225 Ma X, Does MB, Metayer C, et al. (2005). Vaccination history and risk of childhood leukaemia. Int J Epidemiol.
226 MacArthur AC, McBride ML, Spinelli JJ, et al. (2008). Risk of childhood leukemia associated with vaccination, infection, and medication use in childhood: the Cross-Canada Childhood Leukemia Study. Am J Epidemiol.
227 Pagaoa MA, Okcu MF, Bondy ML, et al. (2011). Associations between vaccination and childhood cancers in Texas regions. Journal of Pediatrics.
228 Hummel M, Fuchtenbusch M, Schenker M, et al. (2000). No major association of breast-feeding, vaccinations, and childhood viral diseases with early islet autoimmunity in the German BABYDIAB study. Diabetes Care.
229 Pahud BA, Rowhani-Rahbar A, Glaser C, et al. (2012). Lack of association between childhood immunizations and encephalitis in California, 1998-2008. Vaccine.
230 Lin TH, Lin SY, Lin CH, et al. (2012). AdimFlu-S((registered trademark)) influenza A (H1N1) vaccine during pregnancy: The Taiwanese Pharmacovigilance Survey. Vaccine.
231 Fell DB, Sprague AE, Liu N, et al. (2012). H1N1 influenza vaccination during pregnancy and fetal and neonatal outcomes. American Journal of Public Health.
232 Richards JL, Hansen C, Bredfeldt C, et al. (2013). Neonatal outcomes after antenatal influenza immunization during the 2009 H1N1 influenza pandemic: impact on preterm birth, birth weight, and small for gestational age birth. Clinical Infectious Diseases.
233 Nordin JD, Kharbanda EO, Benitez GV, et al. (2013). Maternal safety of trivalent inactivated influenza vaccine in pregnant women. Obstetrics & Gynecology.
234 Dodds L, Macdonald N, Scott J, et al. (2012). The association between influenza vaccine in pregnancy and adverse neonatal outcomes. Journal of Obstetrics & Gynaecology Canada: JOGC.
235 Omer SB, Goodman D, Steinhoff MC, et al. (2011). Maternal influenza immunization and reduced likelihood of prematurity and small for gestational age births: a retrospective cohort study. PLoS Med.
236 Irving SA, Kieke BA, Donahue JG, et al. (2013). Trivalent inactivated influenza vaccine and spontaneous abortion. Obstetrics & Gynecology.
237 Xu R, Luo Y, Chambers C. (2012). Assessing the effect of vaccine on spontaneous abortion using time-dependent covariates Cox models. Pharmacoepidemiology and Drug Safety.
238 Louik C, Ahrens K, Kerr S, et al. (2013). Risks and safety of pandemic H1N1 influenza vaccine in pregnancy: exposure prevalence, preterm delivery, and specific birth defects. Vaccine.
239 Chambers CD, Johnson D, Xu R, et al. (2013). Risks and safety of pandemic h1n1 influenza vaccine in pregnancy: birth defects, spontaneous abortion, preterm delivery, and small for gestational age infants. Vaccine.
240 Johnstone J, Loeb M, Teo KK, et al. (2012). Influenza vaccination and major adverse vascular events in high-risk patients. Circulation.
241 Hambidge SJ, Ross C, Glanz J, et al. (2012). Trivalent inactivated influenza vaccine is not associated with sickle cell crises in children. Pediatrics.
242 Kelly H, Carcione D, Dowse GK, et al. (2012). The vaccine-attributable risk for febrile convulsions following influenza vaccine. Pediatric Infectious Disease Journal.
243 Klein NP, Massolo ML, Greene J, et al. (2008). Risk factors for developing apnea after immunization in the neonatal intensive care unit. Pediatrics.
244 Klein NP, Aukes L, Lee J, et al. (2011). Evaluation of immunization rates and safety among children with inborn errors of metabolism. Pediatrics.
245 Mullooly JP, Schuler R, Mesa J, et al. (2011). Wheezing lower respiratory disease and vaccination of premature infants. Vaccine.
246 Andrews N, Stowe J, Wise L, et al. (2010). Post-licensure comparison of the safety profile of diphtheria/tetanus/whole cell pertussis/haemophilus influenza type b vaccine and a 5-in-1 diphtheria/tetanus/acellular pertussis/haemophilus influenza type b/polio vaccine in the United Kingdom. Vaccine.
247 Matheson MC, Haydn Walters E, Burgess JA, et al. (2010). Childhood immunization and atopic disease into middle-age--a prospective cohort study. Pediatric Allergy & Immunology.
248 Nakajima K, Dharmage SC, Carlin JB, et al. (2007). Is childhood immunisation associated with atopic disease from age 7 to 32 years?. Thorax.
249 Ray P, Black S, Shinefield H, et al. (2011). Risk of rheumatoid arthritis following vaccination with tetanus, influenza and hepatitis B vaccines among persons 15-59 years of age. Vaccine.
250 Siberry GK, Williams PL, Lujan-Zilbermann J, et al. (2010). Phase I/II, open-label trial of safety and immunogenicity of meningococcal (groups A, C, Y, and W-135) polysaccharide diphtheria toxoid conjugate vaccine in human immunodeficiency virus-infected adolescents. Pediatric Infectious Disease Journal.
251 Tokars JI, Lewis P, DeStefano F, et al. (2012). The risk of Guillain-Barre syndrome associated with influenza A (H1N1) 2009 monovalent vaccine and 2009-2010 seasonal influenza vaccines: results from self-controlled analyses. Pharmacoepidemiology & Drug Safety.
252 Wise ME, Viray M, Sejvar JJ, et al. (2012). Guillain-Barre Syndrome During the 2009-2010 H1N1 Influenza Vaccination Campaign: Population-based Surveillance Among 45 Million Americans. American Journal of Epidemiology.
253 Yih WK, Lee GM, Lieu TA, et al. (2012). Surveillance for Adverse Events Following Receipt of Pandemic 2009 H1N1 Vaccine in the Post-Licensure Rapid Immunization Safety Monitoring (PRISM) System, 2009-2010. American Journal of Epidemiology.
254 Phonrat B, Pitisuttithum P, Chamnanchanunt S, et al. (2013). Safety and immune responses following administration of H1N1 live attenuated influenza vaccine in Thais. Vaccine.
255 Whitehouse AJO, Maybery M, Wray JA, et al. (2011). No association between early gastrointestinal problems and autistic-like traits in the general population. Developmental Medicine & Child Neurology.