# Methods

## Original Proposed Key Questions

AHRQ provided following original Key Questions (KQs). Not all questions were answerable through a systematic review of the published research; we discuss important research gaps later in this report.

- KQ 1. What is the evidence that vaccines included in the 2011 immunization schedule recommended for U.S. adults23 are safe in the short term (within 30–42 days following immunization) or long term (>42 days after immunization)?
  a. What adverse events (AEs) are collected in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  b. What AEs are reported in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  c. What AEs are associated with these vaccines?
    1. For each AE associated with a particular vaccine, what is the average severity (grade 1/mild; grade 2/moderate; grades 3 and 4/severe)?
    2. For AEs without statistically significant associations with a particular vaccine, what is the level of certainty?^a^
    3. For each AE associated with a particular vaccine, what are the risk factors for the AE (including age, sex, race/ethnicity, genotype, underlying medical condition, whether a vaccine is administered individually or in a combination vaccine product, schedule of vaccine administration, adjuvants, and medications administered concomitantly)?
- KQ 2. What is the evidence that vaccines included in the immunization schedules recommended for U.S. children and adolescents in 2011^24^ are safe in the short term (within 30–42 days following immunization) or long term (>42 days after immunization)?
  a. What AEs are collected in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  b. What AEs are reported in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  c. What AEs are associated with these vaccines?
    1. For each AE associated with a particular vaccine, what is the average severity (grade 1/mild; grade 2/moderate; grades 3 and 4/severe)?
    2. For AEs without statistically significant associations with a particular vaccine, what is the level of certainty?^a^
    3. For each AE associated with a particular vaccine, what are the risk factors for the AE (including age, sex, race/ethnicity, genotype, underlying medical condition, whether a vaccine is administered individually or in a combination vaccine product, schedule of vaccine administration, adjuvants, and medications administered concomitantly)?
- KQ 3. What is the evidence that vaccines recommended for pregnant women25 are safe both for the woman and for her fetus/infant?
  a. What AEs are collected in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  b. What AEs are reported in clinical studies (phases I–IV) and in observational studies containing a control/comparison group?
  c. What AEs are associated with these vaccines in women?
    1. For each AE associated with a particular vaccine, what is the average severity (grade 1/mild; grade 2/moderate; grades 3 and 4/severe)?
    2. For AEs without statistically significant associations with a particular vaccine, what is the level of certainty?^a^
    3. For each AE associated with a particular vaccine, what are the risk factors for the AE (including age, sex, race/ethnicity, genotype, underlying medical condition, whether the vaccine is administered individually or in a combination vaccine product, the schedule of vaccine administration, adjuvants, and medications administered concomitantly)?
  d. What AEs are associated with these vaccines in the fetus/infant?
    1. For each AE associated with a particular vaccine, what is the average severity (grade 1/mild; grade 2/moderate; grades 3 and 4/severe)?
    2. For AEs without statistically significant associations with a particular vaccine, what is the level of certainty?^a^
    3. For each AE associated with a particular vaccine, what are risk factors for the AE (including age, gender, race/ethnicity, genotype, underlying medical condition, whether vaccine administered individually or in a combination vaccine product, vaccine schedule of administration, adjuvants, medications administered concomitantly)?

## Technical Expert Panel

For each Agency for Healthcare Research and Quality (AHRQ) systematic review, a Technical Expert Panel (TEP) is assembled to provide clinical expertise and context. A distinguished group of scientists and clinicians were invited to participate in the TEP for this report. Potential members submitted conflict of interest disclosure forms; any current or prior relationship with a vaccine manufacturer was grounds for disqualification per AHRQ. A list of members is included in the front matter.

TEP conference calls were held on June 18, June 19, and July 19, 2012; they were attended by project staff and Task Order Officers (TOO) from AHRQ and the Office of the Assistant Secretary for Health (OASH). The TEP informed staff of recent developments in the field, gave input on which AEs and issues were most important, and emphasized we should only include studies which use the same dosage and formulation as currently used in the U.S . Vaccines with adjuvants not currently used in the U.S. (for example, ASO3) or strengths that were never licensed in the U.S. (for example, those used in Phase II studies that did not advance to Phase III) should be excluded. They also advised that, given resource limitations, minor AEs such as crying and injection site redness need not be discussed in the report.

Panel members were invited to review the draft version of this report and provide feedback.

## Analytic Framework

The analytic framework for the project is displayed in Figure 1. Vaccinations recommended by the Centers for Disease Control and Prevention (CDC) are listed in the large oval. Various subsets are administered annually to children, adolescents, and adults, including pregnant women (next circle), according to a schedule developed by the Advisory Committee on Immunization Practices (ACIP). Both patient factors (i.e., age, pre-existing conditions) and vaccine factors (i.e., formulation, dosage, and timing) may be risk factors for potential AEs.

Figure 1 Analytic framework

Hep A = hepatitis A; Hep B = hepatitis B; HPV = human papillomavirus; MMR = measles, mumps, rubella

Figure 1 displays the analytic framework for this systematic review. A large circle on the left contains a list of the vaccines routinely recommended by the Advisory Committee on Immunization Practices (ACIP). Depending on age and pregnancy status, these may include vaccines against influenza, Haemophilus Influenza B (Hib), tetanus, diphtheria, and pertussis, varicella, zoster, human papilloma virus (HPV), measles, mumps, and rubella, pneumonia, polio, meningitis, hepatitis A, and hepatitis B. The next circle includes the target populations: children, adolescents, adults, and pregnant women. Patient characteristics (age, gender, race/ethnicity, location, medical condition) are listed one circle, vaccine factors (dosage, timing, formulation) in another. Both patient and vaccine characteristics may be risk factors for adverse events (AEs). This report will assess the statistical association of vaccines with any reported AEs. Where associations exist, the type of event, severity, timing, and risk factors will be described.

## Literature Search

The following databases were searched to identify relevant studies: DARE, the Cochrane Database of Systematic Reviews, CENTRAL, PubMed^®^, EMBASE^®^, CINAHL^®^, TOXLINE^®^, and TOXFILE^®^. The Institute of Medicine (IOM) report, ACIP statements, and vaccine package inserts were reviewed. Review articles were mined for references.

Our search strategy built upon the recent IOM report for the eight vaccines contained therein. Using the IOM keyword search strategy, we updated their searches on varicella, influenza, Hepatitis A, Hepatitis B, HPV, MMR, meningococcal, diphtheria, pertussis, and tetanus vaccines to identify more recently published studies. The following structure was used in the IOM keyword search strategy: “vaccine term” AND “health term,” where vaccine terms include the technical vaccine name, general descriptions of the vaccine of interest (e.g., rotavirus AND vaccine), or manufacturer names; health terms include a list of AEs potentially associated with the vaccine. We also added more general AE keywords to the list of health terms such as “safe” or “safety,” “side effect” or “harm.” We searched from a year before the publication of the IOM report through August, 2013.

Using this approach, we developed new search strategies for the vaccines not originally included in the IOM report: pneumococcal, rotavirus, H. influenzae type b, inactivated poliovirus, and zoster. We searched each of the databases mentioned above from their inception to August, 2013.

Searches were based on AEs reported in systems such as the Vaccine Injury Compensation Program (VICP), Vaccine Adverse Event Reporting System (VAERS) and the FDA's Mini-Sentinel Program. The Technical Expert Panel (TEP) reviewed the draft list of AEs and suggested additional AEs of interest. Appendix A contains the detailed search strategy and a list of AEs included in the searches.

## Article Review

Two researchers independently reviewed the titles and abstracts identified. The union of their selections was retrieved. Two researchers also independently reviewed the full text of study reports, entered data into an electronic form, and met to reach consensus on any conflicts regarding exclusion/inclusion. Disputes were settled by the lead investigators and team physician experts.

Data were entered directly by researchers into DistillerSR software (Evidence Partners Inc., Ottawa, Ontario, Canada),26 which is designed specifically for systematic reviews and meta-analyses, and exported to SAS (SAS Institute Inc., Cary, NC) for analysis.

## Study Inclusion

We included the following study designs:

- Controlled clinical trial—A study where human subjects are assigned prospectively, usually through randomization, to receive an intervention (in this case a vaccine) or an alternate intervention (another vaccine) or placebo. Clinical trials are used to determine safety and efficacy.27
- Cohort study—Follows two or more groups who differ with respect to whether they received a vaccine (the “exposure”), over time to determine how/whether the vaccination affects rates of one or more adverse events (the “outcome”).27,28
- Case-control study—A study that compares persons who have a disease or adverse event (AE) (cases) with persons who do not have the disease or AE (the “outcome”), and looks back retrospectively to compare exposure to vaccine in each group to determine the relationship between the vaccine and the disease / AE.27,28
- Self-controlled case series (SCCS)—Only cases (individuals who experienced the AEs) are included in the analysis. With SCCS, each individual serves as their own control. The analysis inherently controls for covariates that remain stable within a person during the study period; for example, race and gender. SCCS compares outcome event rates during times when a person is exposed (post-vaccination) with those during times when the same person is unexposed (pre-vaccination) to calculate the relative incidence of AEs.27,29
- Other designs—We included all active surveillance studies that used regression to control for confounders and test multiple relationships simultaneously. We refer to these as multivariate risk factor analyses. Data sources may include medical records, health insurance claims, and government registries.27

Studies using passive surveillance such as the U.S. Vaccine Adverse Event Reporting System (VAERS)16 are crucial in identifying signals regarding adverse events post-licensure. However, because by definition they do not consider the rate of such events in non-vaccinated populations, they are not designed to assess a statistical association between a vaccine and an adverse event, so they were excluded from this project. We also excluded studies of vaccines not on the current U.S. recommended schedules. These include brands and formulations never available in the United States and or no longer used. Examples include whole cell pertussis vaccine, oral polio vaccine, and PCV7 pneumococcal vaccine.

The following publication types/studies were excluded:

- Letters
- Editorials
- Individual case reports
- Animal studies
- Mechanistic/in vitro studies
- Conference abstracts
- Vaccine efficacy studies that did not report the presence or absence of AEs
- Observational studies which use passive surveillance for AEs
- Non–English-language studies. (Given the focus of this review and the corresponding literature base, we concluded the risk of language bias to be low and that it was thereby acceptable to limit the inclusion criteria to English studies only.)
- Studies of vaccines not on the U.S.-recommended schedules, including brands/formulations never available in the United States, or no longer used.

## Data Abstraction and Synthesis of Results

Based on our experience conducting systematic reviews of the evidence on other health care interventions, we developed a structured approach to assessing AEs instead of relying on a random post hoc grouping. We used a tested and standardized form to extract AEs. If a study reported severity, or if adequate information was provided for our investigators to categorize severity, we used the Common Terminology Criteria for Adverse Events (CTCAE) classification system30 to characterize AEs. Serious adverse events (SAE) were defined and coded. The definition of “serious” differs by AE type; each category of AE (i.e. fever, headache) is rated on a scale of 1 to 5, with 1 being very mild and 5 being death due to the event.

Clinical trials and cohort comparisons were abstracted using an electronic form which contained items for sample size, population description (age, gender, race/ethnicity, country, any co-morbidities), items on study quality (described below), vaccine description (name, manufacturer, dosage, formulation, adjuvants, preservatives, timing, mode of administration), and AEs (exact description, severity, timing, number) for each group. Odds ratios of AEs for vaccination and comparison arms were computed for each study, along with the 95% confidence interval. Studies were included for analysis if the total number of people in each group and the number of people with events in each group were reported. Occasionally, this information was missing, or the number of AEs and number of doses (rather than number of persons) was provided. Since AEs are generally rare, conditional pooling using exact methods provided a fixed effects estimate of the odds ratio. Analyses were conducted with StatXact^®^ Procs for SAS.31 Subgroup analyses are narrative in order to be able to make comparisons between study designs and other variables in the heterogeneous dataset.

The case-control, self-controlled case series, and multivariate risk factor analyses were abstracted onto a different electronic form containing similar items; however, the statistical findings were abstracted directly. These types of studies generally do not include enough information for researchers to re-calculate the statistics independently, as they are not simple comparisons of a vaccinated group with an unvaccinated group. To assess the reliability and validity of the findings, we abstracted how vaccination status and health outcomes were ascertained (self-report, national registry, parent interview, medical record, etc.); potential sources of bias due to selection, participation, attrition, and non-response of subjects; amount of missing data; funding source; and how potential confounders were handled. The abstraction forms are presented in Appendix B.

We created detailed evidence tables displaying critical data for each included study. Multiple publications of the same study are noted and counted (extracted, assessed for quality, and analyzed) as one study to ensure that the same participants do not enter the analyses multiple times. Multiple publications were defined by the investigated patients.

## Assessment of Methodological Quality

For controlled trials and cohort comparisons, we used a quality-rating instrument Santaguida and colleagues (2008)32 developed for evaluating studies reporting adverse events. Called McHarm, the tool was developed from quality rating items generated by a review of the literature on harms and from previous quality assessment instruments. Scores range from 0 to 15; a copy of the instrument and scoring instructions are included in Appendix B. McHarm was tested for reliability and face, construct, and criterion validity and includes important factors such as:

- Were AEs predefined using standard, precise definitions?
- Was the mode of harms collection active (participants are asked about the occurrence of specific AEs) or passive (participants are not specifically asked about or tested for the occurrence of AEs; patient reports of AEs are made on their own initiative)?
- Did the study specify who collected the AE data?
- Did the study specify the timing of AEs?
- Was the number of participants who withdrew or were lost to follow up reported?

## Grading the Evidence for Each Key Question

We assess the overall strength of evidence by using guidance suggested by AHRQ for its Effective Health Care Program.33 This method is based on one developed by the GRADE Working Group34 and classifies the grade of evidence according to the following criteria:

- High. High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate. Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low. Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient. Evidence either is unavailable or does not permit a conclusion.

The evidence grade is based on four primary (required) domains and four optional domains. The required domains are risk of bias, consistency, directness, and precision, as described in Table 4 below. The additional domains are dose-response, plausible confounders that would decrease the observed effect, strength of association, and publication bias.

Table 4 Grading the strength of a body of evidence: required domains and their definitions

Domain | Definition and Elements | Score and Application
Risk of Bias | Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration; Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies. | Use one of three levels of aggregate risk of bias:; - Low risk of bias; - Medium risk of bias; - High risk of bias
Consistency | The principal definition of consistency is the degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”).; - The range of effect sizes is narrow. | Use one of three levels of consistency:; - Consistent (i.e., no inconsistency); - Inconsistent; - Unknown or not applicable (e.g., single study); As noted in the text, single-study evidence bases (even mega-trials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study).”
Directness | The rating of directness relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Two types of directness, which can coexist, may be of concern: Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes.; - It uses two or more bodies of evidence to compare interventions A and B—e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not A vs. B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes. Directness may be contingent on the outcomes of interest. EPC authors are expected to make clear the outcomes involved when assessing this domain. | Score dichotomously as one of two levels directness; - Direct; - Indirect; If indirect, specify which of the two types of indirectness account for the rating (or both, if that is the case) —namely, use of intermediate/surrogate outcomes rather than health outcomes, and use of indirect comparisons. Comment on the potential weaknesses caused by, or inherent in, the indirect analysis. The EPC should note if both direct and indirect evidence was available, particularly when indirect evidence supports a small body of direct evidence.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the confidence interval around the summary effect size. | Score dichotomously as one of two levels of precision:; - Precise; - Imprecise; A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions. For example, results may be statistically compatible with both clinically important superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that will preclude a valid conclusion.

It is important to note that the 2011 IOM report used different terminology; evidence was classified as either “convincingly supports,” “favors acceptance,” “inadequate to accept or reject” or “favors rejection” of a causal association. They included mechanistic studies and individual case reports to assess the biological plausibility of AE and considered this in addition to any statistical association. For each vaccine discussed in the IOM report, we started with the IOM findings and modified them, if needed, based on any additional evidence identified. For example, if the IOM found that evidence “convincingly supports” an association, we rated the strength of evidence as “high” unless additional evidence was identified. Similarly, if the IOM found evidence “favors acceptance” we started with by rating as “moderate” strength of evidence and evidence rated as “inadequate to accept or reject” was considered “insufficient” in our grading system. If new evidence was identified for vaccines evaluated by the IOM, ratings could be adjusted up or down according to our assessment of the new studies. If the IOM found that evidence “favors rejection” of a causal relationship we choose between moderate and high based on our review of the IOM evidence plus any studies published after their search.

## Peer Review and Public Commentary

A draft of this report was submitted in May, 2013. The AHRQ Effective Healthcare Program Scientific Resource Center (SRC) located at Portland VA Research Foundation coordinated peer review by experts and stakeholders. The report was posted on AHRQ's web site for a month for public comment. Resulting comments were considered by the authors in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers, and service as a peer reviewer or member of the Technical Expert Panel cannot be construed as endorsement of the report's findings.

a Level of certainty was operationalized as the 95-percent confidence interval surrounding the risk or odds estimate—i.e., the statistical significance.