# Introduction

## Background

Vaccines are considered one of the greatest public health achievements of the last century for their role in eradicating smallpox and controlling polio, measles, rubella, and other infectious diseases in the United States.1 Despite their effectiveness in preventing and eradicating disease, substantial gaps in vaccine uptake exist. Vaccination rates for young children are high;2 however, vaccination rates remain well below established Healthy People 2020 targets for many vaccines recommended for adolescents,3 adults,4 and pregnant women.5

Increasing vaccination rates remains critically important, as vaccine-preventable diseases such as influenza, pertussis, and human papillomavirus (HPV)-associated cervical cancer continue to take a heavy toll despite the widespread availability of effective vaccines. The health and productivity costs of influenza infection alone in adults are have been estimated to be as high as $87 billion per year.6 The recent pertussis outbreaks in California, Washington, Minnesota, and Wisconsin highlight the importance of protecting vulnerable infants by vaccinating their pregnant mothers, caregivers, and other contacts. HPV is the most common sexually transmitted infection. HPV-16 and HPV-18— two strains included in the HPV vaccine —are thought to be responsible for approximately 70 percent of incident cervical cancer. Nationally, in 2005, there were nearly 12,000 new cases of cervical cancer reported, with 4,000 cervical cancer-related deaths.7 Despite the availability of an HPV vaccine that could prevent a substantial proportion of these cases of cervical cancer, completion of the three-dose series was only 34.8 percent among adolescent females in 2011.^3^

The shortfall in vaccination coverage rates occurs in the context of a rapidly changing immunization schedule. Routine immunizations recommended as of October, 2011 for children (Table 1), adolescents (Table 1), adults (Table 2), and pregnant women (Table 3) are presented below. Since 2005, the routine adolescent vaccination schedule has grown to include these vaccines at ages 11 or 12 years: meningococcal conjugate vaccine; tetanus, diphtheria, and acellular pertussis (Tdap); HPV; and influenza (one dose annually). In 2013, pregnant women were advised to receive Tdap during every pregnancy to protect their newborns from pertussis regardless of prior history of receiving Tdap.8

Table 1 Vaccines routinely recommended for children and adolescents, 2011

Vaccine | Age
DTaP (diphtheria, tetanus, and acellular pertussis) | 2 months–6 years
Hepatitis A | 12 months and older
Hepatitis B | Birth and older
Hib (Haemophilus influenzae type b) | 6 weeks–59 months
HPV (human papillomavirus) | 9 years–21 years (male) 9 years–26 years (female)
Influenza (inactivated) | 6 months and older
Influenza (live attenuated) | 2 years and older
IPV (inactivated polio vaccine) | 6 weeks and older
MCV (meningococcal conjugate vaccine) | 2 years and older
MMR (measles, mumps, and rubella) | 12 months and older
MPSV (meningococcal polysaccharide vaccine) | 2 years and older, in specific circumstances
PCV13 (pneumococcal conjugate vaccine) | 6 weeks–18 years
Pneumococcal polysaccharide vaccine | 2 years and older, in specific circumstances
Rotavirus | 6 weeks–8 months
Tdap (tetanus, diphtheria, and acellular pertussis) | 7 years and older
Varicella | 12 months and older

Table 2 Vaccines routinely recommended for nonpregnant adults, 2011

Vaccine | Recommendation
Hepatitis A | All adults at increased risk for hepatitis A infection
Hepatitis B | All unvaccinated adults at risk for or requesting protection from Hepatitis B infection
HPV (human papillomavirus) | Adults 26 years and younger
Influenza (inactivated) | All adults
Influenza (live attenuated) | All adults 49 years and younger
Meningococcal conjugate vaccine (MCV4) and meningococcal polysaccharide vaccine (MPSV) | Adults at risk of meningococcal disease (MCV4 or MPSV if younger than 55 years; MPSV if older than 55 years)
MMR (measles, mumps, and rubella) | All adults who are not immune through prior infection
Pneumococcal polysaccharide vaccine | Adults 64 years and younger with certain conditions, and all adults 65 years and older
Td (tetanus, diphtheria) | All adults
Tdap (tetanus, diphtheria, and acellular pertussis) | All adults 19–64 years old; some adults 65 years and older
Varicella | All adults without evidence of varicella immunity
Zoster | All adults 60 years and older

Table 3 Vaccines routinely recommended for pregnant women, 2011

Vaccine | Recommendation
Hepatitis B | Recommended in some circumstances
Influenza (inactivated) | All pregnant women
Td (tetanus, diphtheria) | Should be used if indicated
Tdap (tetanus, diphtheria, and acellular pertussis) | All pregnant women after first trimester if indicated^*^

* In 2013, pregnant women were advised to receive Tdap during pregnancy to protect their newborns from pertussis.

As the number of recommended immunizations has expanded across the population, so too have concerns about the safety of vaccines, despite the rigorous processes new vaccines must undergo before receiving approval from the U.S. Food and Drug Administration (FDA). Vaccine development and commercialization are complex processes, and the regulatory review process is overseen by the Center for Biologics Evaluation and Research of the FDA.9 Vaccines are unique when compared with many other medications because they are administered to a large population of mostly young healthy people to prevent rather than treat disease. Vaccines must meet stringent criteria for safety, efficacy, and potency. Preclinical studies are conducted in the early stages of vaccine development and are meant to be sufficient to rule out overt toxicity and identify potential toxic effects that might occur during the clinical trial. Once a vaccine is ready for clinical evaluation, an Investigational New Drug application must be submitted so the FDA can monitor the safety of clinical trial subjects and ensure that the study design is appropriate to assess the vaccine's effectiveness and safety.

The clinical evaluation of a vaccine typically consists of three phases.9 Phase I studies—which typically enroll 20 to 80 subjects—are designed to evaluate vaccine safety and tolerability and to generate preliminary immunogenicity data. Phase II studies evaluate the immunogenicity of the vaccine and provide preliminary estimates on the rates of common adverse events, typically enrolling several hundred subjects. Phase III trials provide the information on a vaccine's safety and efficacy that is required to support licensure. After a vaccine is licensed and in use, multiple systems are in place to ensure ongoing assessments of safety,10 including post licensure safety surveillance conducted by sponsors as postmarketing commitments or requirements to the FDA,11 the FDA's Post-Licensure Rapid Immunization Monitoring (PRISM) system,12-14 FDA surveillance using databases of Federal Partners such as the Centers for Medicare and Medicaid Services (CMS),15 the Vaccine Adverse Event Reporting System (VAERS) co-administered by the FDA and the Centers for Disease Control and Prevention (CDC),16 CDC's Vaccine Safety Datalink,17 and CDC's Clinical Immunization Safety Assessment project.18

Despite the stringent regulation and evaluation of vaccines, public concerns about vaccine safety continue to persist. Perhaps the most highly publicized safety concern of the last two decades has been the alleged link between autism and the MMR vaccine, first reported in The Lancet by Dr. Andrew Wakefield.19 Vaccination rates for measles, mumps, and rubella plummeted in the United Kingdom leading to measles outbreaks20 and concern about vaccines and autism spread globally. In 2010, The Lancet fully retracted the 1998 publication,21 noting that elements of the manuscript had been deliberately falsified. Subsequently, Dr. Wakefield was barred from practicing medicine in the United Kingdom. Although multiple large studies have confirmed the lack of association between MMR and autism, parental worries about the safety of the vaccine persist. In addition to autism, other parental concerns about childhood vaccines include possible links to multiple sclerosis, sudden infant death syndrome, asthma, and diabetes.22 Though no systematic data exist on the safety concerns of pregnant women, this is likely to be an active focus given the relatively recent introduction of the recommendation to administer the Tdap vaccine during pregnancy.

The Agency for Healthcare Research and Quality (AHRQ) requested an evidence report on the safety of vaccines used for routine immunization of adults (including pregnant women), children, and adolescents that will, based on a comprehensive and systematic review of the scientific literature, describe associations between vaccines and adverse events (AEs) and help to outline the gaps in evidence. This report focuses on the adverse events (AEs) potentially associated with vaccines as opposed to the benefits, as all of these vaccines are already recommended.

Our work expands upon the consensus report “Adverse Effects of Vaccines: Evidence and Causality,” published by the Institute of Medicine (IOM) in late 2011. That report evaluated the scientific evidence for event-vaccine relationships and covered many vaccines included in the 2011 U.S. recommended immunization schedules (varicella, influenza, Hepatitis A, Hepatitis B, HPV, MMR, meningococcal, tetanus, diphtheria, and pertussis). Our work builds upon the IOM report in a number of important ways. In addition to vaccines covered by the IOM report, our systematic review covers pneumococcal, rotavirus, Haemophilus influenzae type b, inactivated poliovirus, and zoster vaccines. We report the 2011 IOM conclusions, update the literature with more recent studies, and conduct original searches for the recommended vaccines that were not included; we provide an assessment of AEs reported.