# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Janet D. Cragan, M.D., M.P.H.
  National Center on Birth Defects and Developmental Disabilities
  Centers for Disease Control and Prevention
  Atlanta, GA
- Francesca Cunningham, Pharm.D.
  Director
  Center for Medication Safety (VAMedSAFE)
  Department of Veterans Affairs
  Hines, IL
- Frank Destefano, M.D., M.P.H
  Director
  Immunization Safety Office
  Division of Healthcare Quality Promotion
  National Center for Emerging and Zoonotic Infectious Diseases
  Centers for Disease Control and Prevention
  Atlanta, GA
- Laura Elizabeth Riley, M.D.
  Massachusetts General Hospital
  Boston, MA