# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Meghan Baker, M.D., Sc.D.
  Harvard Pilgrim Health Care Institute/Harvard Medical School
  Boston, MA
- Richard Beigi, M.D., M.Sc.
  Magee-Women's Hospital
  University of Pittsburgh Medical Center
  Pittsburgh, PA
- Kathryn Edwards, M.D.
  Vanderbilt University Vaccine Research Program
  Nashville, TN
- Kristen Feemster, M.D., M.P.H., M.S.P.H.
  Children's Hospital of Philadelphia
  University of Pennsylvania Perelman School of Medicine
  Philadelphia, PA
- Bruce Fireman, M.A.
  Kaiser Permanente Northern California
  Oakland, CA
- David Martin, M.D.
  Deputy Director
  U.S. Food and Drug Administration
  Rockville, MD
- Claudia Vellozzi, M.D., M.P.H.
  Deputy Director
  Immunization Safety Office
  Centers for Disease Control and Prevention
  Atlanta, GA