# Addendum

This evidence report summarizes scientific data on the safety of vaccines currently recommended in the United States. High strength of evidence was found for an association of measles-mumps-rubella (MMR) vaccine with febrile seizures in children under age 5 (Key Question 2c). On May 19, 2014 (while this evidence report was in press), an important study investigating the timing of MMR and MMRV (measles-mumps-rubella-varicella) vaccine and risk of febrile seizures1 was published. We felt this information warranted inclusion in this review of the evidence.

Researchers conducted a self-controlled case series analysis using records from over 300,000 U.S. children from the Vaccine Safety Datalink (VSD). They found timing was unrelated to risk of post-vaccination seizure in infants, but found that delaying measles containing vaccines past 15 months results in a higher risk of seizures.

According to the study's authors, these adverse events are very rare, and occurred at the rate of about 1 per 100,000 person-days at seven months of age, compared to a high of five per 100,000 person-days at 17 months of age.

## Reference

1 Hambidge S J, Newcomer SR, Narwaney KJ, et al. (2014). Timely versus delayed early childhood vaccination and seizures. Pediatrics.