# Acknowledgments

The authors would like to thank Aneesa Motala, B.A., for her excellent assistance on the project after the peer review period. We would like to thank Paul Shekelle, M.D., Ph.D., for his advice and review of the draft and final versions of the report.