# Appendix D Excluded Studies and Background Papers

## Articles Could Not Be Obtained – 5

1 Blatter M. (1996). Open trial to evaluate the safety and immunogenicity of a fifth (booster) dose of diphtheria, tetanus, acellullar pertussis vaccine in healthy children.
2 Fox S. (2001). Study confirms rotavirus vaccine-intussusception link. Infections in Medicine.
3 Gustafsson L, Hallander HO, Gothefors L. (2011). An immunogenicity and safety study of combined adsorbed tetanus, low dose diptheria and acellullar pertussis vaccine (TdaP5v and TdaP1v) given as a school-leaving booster to 14–15-year old adolescents primed with a five-component acellullar pertussis vaccine at 3, 5 and 12 months of age and a booster dose at 5 1/2 years of age.
4 Santosham M, Hill J, Wolff M, et al. (1991). Safety and immunogenicity of a Haemophilus influenzae type b conjugate vaccine in a high risk Native American population. Pediatric Infectious Disease Journal.
5 Taranger J, Trollfors B. (1996). Safety and immunogenicity of combined vaccines against diphtheria, tetanus, pertussis and polio at six years of age.

## Rejected for Participants (Animal or In-Vitro Study) – 20

1 Abraham E. (1992). Intranasal Immunization with Bacterial Polysaccharide Containing Liposomes Enhances Antigen-Specific Pulmonary Secretory Antibody-Response. Vaccine.
2 Bellinzoni RC, Blackhall J, Baro N, et al. (1989). Efficacy of an inactivated oil-adjuvanted rotavirus vaccine in the control of calf diarrhoea in beef herds in Argentina. Vaccine.
3 Bucardo F, Rippinger CM, Svensson L, et al. (2012). Vaccine-derived NSP2 segment in rotaviruses from vaccinated children with gastroenteritis in Nicaragua. Infection, Genetics and Evolution.
4 Choi NW, Estes MK, Langridge WHR. (2006). Mucosal immunization with a ricin toxin B subunit-rotavirus NSP4 fusion protein stimulates a Th1 lymphocyte response. Journal of Biotechnology.
5 Cui YL, Zhang XM, Gong Y, et al. (2011). Immunization with DnaJ (hsp40) could elicit protection against nasopharyngeal colonization and invasive infection caused by different strains of Streptococcus pneumoniae. Vaccine.
6 Dorea JG. (2011). Integrating experimental (in vitro and in vivo) neurotoxicity studies of low-dose thimerosal relevant to vaccines. Neurochemical Research.
7 Gotschlich EC, Goldschneider I, Artenstein MS. (1969). Human immunity to the meningococcus. IV. Immunogenicity of group A and group C meningococcal polysaccharides in human volunteers. Journal of Experimental Medicine.
8 Hainisch EK, Brandt S, Shafti-Keramat S, et al. (2012). Safety and immunogenicity of BPV-1 L1 virus-like particles in a dose-escalation vaccination trial in horses. Equine Veterinary Journal.
9 Iosef C, Van Nguyen T, Jeong KI, et al. (2002). Systemic and intestinal antibody secreting cell responses and protection in gnotobiotic pigs immunized orally with attenuated Wa human rotavirus and Wa 2/6-rotavirus-like-particles associated with immunostimulating complexes. Vaccine.
10 Koyama S, Aoshi T, Tanimoto T, et al. (2010). Plasmacytoid dendritic cells delineate immunogenicity of influenza vaccine subtypes. Science Translational Medicine.
11 Neeper CA, Seastone CV. (1964). Mechanisms of Immunologic Paralysis by Pneumococcal Polysaccharide. Iv. Comparison of Polysaccharide and Whole Organisms. Journal of Immunology.
12 Ranheim T, Mathis PK, Joelsson DB, et al. (2006). Development and application of a quantitative RT-PCR potency assay for a pentavalent rotavirus vaccine (RotaTeq (R)). Journal of Virological Methods.
13 Roldao A, Vieira HLA, Charpilienne A, et al. (2007). Modeling rotavirus-like particles production in a baculovirus expression vector system: Infection kinetics, baculovirus DNA replication, mRNA synthesis and protein production. Journal of Biotechnology.
14 Rubin SA, Afzal MA. (2011). Neurovirulence safety testing of mumps vaccines--historical perspective and current status. Vaccine.
15 Shen Z, Lei H. (2012). Expression of hBD-2 induced by 23-valent pneumococcal polysaccharide vaccine, Haemophilus influenzae type b vaccine and split influenza virus vaccine. Molecular Medicine Reports.
16 Soto PC, Stein LL, Hurtado-Ziola N, et al. (2010). Relative Over-Reactivity of Human versus Chimpanzee Lymphocytes: Implications for the Human Diseases Associated with Immune Activation. Journal of Immunology.
17 Spadaccini A, Virnik K, Ni YS, et al. (2010). Stable expression of a foreign protein by a replication-competent rubella viral vector. Vaccine.
18 Thiele S, Borschewski A, Kuchler J, et al. (2011). Molecular analysis of varicella vaccines and varicella-zoster virus from vaccine-related skin lesions. Clinical & Vaccine Immunology: CVI.
19 Wise RP, Iskander J, Pratt RD, et al. (2004). Postlicensure safety surveillance for 7-valent pneumococcal conjugate vaccine. JAMA.
20 Xu PL, Iwata M, Leong S, et al. (1990). Highly virulent strains of Pseudomonas solanacearum that are defective in extracellular-polysaccharide production. Journal of Bacteriology.

## Rejected for Language (Not English) – 9

1 (2011). Beneficios y riesgos de la vacunacion contra el virus del papiloma humano. Ginecologia y Obstetricia de Mexico.
2 Akazawa M. (2010). Economic analysis of vaccine programs. Japanese Journal of Clinical Pharmacology and Therapeutics.
3 Autret E, Jonville-Bera AP, Galy-Eyraud C, et al. (1996). Therapie.
4 Forster J. (2005). Current rotavirus vaccines. Efficacy and cost-effectiveness. Monatsschrift Kinderheilkunde.
5 Li YP, Zhang SM, Ye Q. (2010). Safety and immunogenicity of the diphtheria, tetanus, accellular pertussis plus hemophilus influenza type b combined vaccine (DTaP-Hib) to Chinese infants. Zhongguo ji hua mian yi.
6 Minodier P, Noel G, Blanc P, et al. (2007). Rotavirus vaccines and the risk of intussusception. Archives de Pediatrie.
7 Mrozek-Budzyn D, Majewska R, Kieltyka A, et al. (2011). Brak zwiazku miedzy ekspozycja na szczepionki zawierajace tiomersal i rozwojem autyzmu u dzieci. Przeglad Epidemiologiczny.
8 Yang SP, Li JY, Yan XX, et al. (2011). A review on adverse events following immunization of meningococcal vaccines. Chinese Journal of Evidence-Based Medicine.
9 Zahedpasha Y, Ahmadpour Kacho M, Pour Nasrollah M, et al. (2011). Immune response in preterm infants to hepatitis B vaccine. Journal of Babol University of Medical Sciences.

## Rejected for Conference Abstract – 191

1 (2006). Global Advisory Committee on Vaccine Safety, 6-7 June 2006. Weekly Epidemiological Record.
2 (2007). Global Advisory Committee on Vaccine Safety, 12-13 June 2007. Weekly Epidemiological Record.
3 (2008). Global Advisory Committee on Vaccine Safety, 12-13 December 2007. Weekly Epidemiological Record.
4 (2009). Global Advisory Committee on Vaccine Safety, 17-18 December 2008. Weekly Epidemiological Record.
5 (2009). Global Advisory Committee on Vaccine Safety, report of meeting held 17-18 June 2009. Weekly Epidemiological Record.
6 (2010). Canadian Society of Allergy and Clinical Immunology Annual Scientific Meeting 2010. Allergy, Asthma and Clinical Immunology.
7 (2010). Pneumococcal immunization in older adults. Clinical Geriatrics.
8 Ackerman K, Cohen DC, Erickson RA. (2011). Hepatitis B Vaccination Induced Idiopathic Thrombocytopenic Purpura. Gastroenterology.
9 Ahmed S, Perveen I. (2011). Safety, Immunogenicity and reactogenicity of recombinant hepatitis B vaccine Engerix(trademark)-B. Immunology.
10 Al Qudah Z, Abukwaik W, Souayah N. (2012). Stroke after vaccination in United States. A report from the CDC/FDA vaccine adverse event reporting system. [1990-2010. Neurology.
11 Ali AK. (2011). Vaccine-associated guillain-barre syndrome: A pharmacovigilance analysis of data in the United States' vaccine adverse event reporting system (1990-2009). Value in Health.
12 Allwin R, Gauer S, Roessel, et al. (2011). Eficacy and side effects of H1N1 vaccination in renal transplant and dialysis patients. Transplant International.
13 Alvarez MM, Fernandez CG, Exposito AG. (2011). Antibody response to the standard hepatitis B vaccination in patients with rheumatoid arthritis and ankylosign spondylitis treated with infliximab. Arthritis and Rheumatism.
14 Alvarez-Soria MJ, Hernandez-Gonzalez A, Carrasco-Garcia de Leon S, et al. (2010). Demyelinating disease and papillomavirus vaccine: Report of three cases. Journal of Neurology.
15 Andreas J, Jenke A, Weckelmann A, et al. (2009). Incidence, management and protective factors of intussusception in children: Results from a nationwide german surveillance. Journal of Pediatric Gastroenterology and Nutrition.
16 Anh DD, Thiem VD, Hutagalung Y, et al. (2008). Immunogenicity, Reactogenicity and Safety of the Oral Live Attenuated Human Rotavirus Vaccine RIX4414(Rotarix (TM)) Oral Suspension (Liquid Formulation) in Vietnamese Infants. International Journal of Infectious Diseases.
17 Aqua KA, Basu P, Petit RG. (2011). ADXS11-001 immunotherapy targeting HPV-E7: Preliminary safety data from two phase 2 studies in women with CIN 2/3 and with recurrent/refractory cervical cancer. Journal of Immunotherapy.
18 Autret-Leca E, Daubin C, Poggi P, et al. (2009). Pneumococcal conjugate vaccine: national monitoring of serious adverse effects. Fundamental & Clinical Pharmacology.
19 Baluch A, Humar A, Egli A, et al. (2012). A randomized controlled trial of high-dose intradermal vs. standard intramuscular influenza vaccine in solid organ transplant recipients. American Journal of Transplantation.
20 Benoit B, Claire PN, Vincent M, et al. (2011). Safety and Efficacy of an Inactivated, Unadjuvanted Vaccine Against the Novel Influenza A Variant (H1N1v) in Renal Transplant Recipients (INSERM C09-32, Transfluvac Study). American Journal of Transplantation.
21 Bermal N, Alberto E, Hernandez M, et al. (2008). Safety and Reactogenicity of a 10-Valent Pneumococcal Non-Typeable Haemophilus influenzae Protein D-Conjugate Vaccine (PHiD-CV) in Filipino Infants. International Journal of Infectious Diseases.
22 Bharadwaj AS, Rathod A, Badheka A, et al. (2011). Vaccination Serology Status (Non-Pneumococcal and Non-Influenza) and Cardiovascular Mortality: Insights from Nhanes Iii. Journal of the American College of Cardiology.
23 Black S, Shinefield H, Ray P, et al. (1996). Safety and immunogenicity of heptavalent pneumococcal conjugate vaccine (Wyeth-Lederle) in infancy. Pediatric Research.
24 Black SB, Shinefield HR, Hiatt RH, et al. (1991). Safety and Efficacy of Hboc Conjugate Haemophilus Influenzae Type-B Vaccine in 61,000 Infants. Pediatric Research.
25 Boen M, DeLeon D, Bennett CL, et al. (2010). Gardasil: A false sense of immunity?. Journal of Clinical Oncology.
26 Borba EF, Saad CGS, Calich ALG, et al. (2010). The novel pandemic influenza A (H1N1) 2009 vaccine: Low rate of Seroconversion after vaccination in systemic lupus erythematosus. Arthritis and Rheumatism.
27 Brauner S, Kvarnstom M, Gorgen S, et al. (2011). Vaccination of patients with primary Sjogren's syndrome reveals hyperreactive B cell compartment with a skewed maturation pattern. Annals of the Rheumatic Diseases.
28 Broder K, Haber P, Miller E, et al. (2011). Detecting signals in the vaccine adverse event reporting system. Pharmacoepidemiology and Drug Safety.
29 Brookhart SMA, Li J, Paeglow C, et al. (2011). Characterizing vaccine-associated risk using natural smoothing. Pharmacoepidemiology and Drug Safety.
30 Callejo D, Lopez-Polin A, Blasco JA. (2010). Cost utility of human papiloma virus vaccine in Spain. Value in Health.
31 Camacho LH, Betts RF, Wertheim MS, et al. (2010). Safety and immunogenicity of heat-treated zoster vaccine (ZV(HT)) in adults with hematologic malignancy (HM). Blood.
32 Ceschi A, Ingram K, Curkovic I, et al. (2009). Adverse drug reactions: The most commonly involved drugs and organ systems in pharmacovigilance reports at the University Hospital Zurich. British Journal of Clinical Pharmacology.
33 Chambers CD, Johnson DL, Xu R, et al. (2011). Challenges and design of a prospective, observational cohort study to assess the risk of spontaneous abortion following administration of human papillomavirus (HPV) bivalent (Types 16 and 18) recombinant vaccine. Pharmacoepidemiology and Drug Safety.
34 Chambers CD, Schatz M, Mitchell AA, et al. (2010). The vaccines and medications in pregnancy surveillance system (VAMPSS): Launch of a new system for post-marketing surveillance. Birth Defects Research Part A - Clinical and Molecular Teratology.
35 Chenaf C, Zenut M, Eschalier A. (2010). Thrombocytopenic Purpura and vaccination: Where do we stand?. Fundamental and Clinical Pharmacology.
36 Chioato A, Noseda E, Stevens M, et al. (2011). Efficacy of influenza and meningococcal vaccinations in healthy subjects exposed to secukinumab 150 mg: Preliminary study results. Arthritis and Rheumatism.
37 Chlebna-Sokol D, Szynczewska E. (2009). Immunogenicity and Safety of Heptavalent Pneumococcal Conjugate Vaccine in Very Preterm Infants - Draft Report. Acta Paediatrica.
38 Cordero E, Perez-Ordonez A, Aydillo T, et al. (2011). Immunogenicity, efficacy, and safety of the pandemic influenza A/H1N1 vaccine in solid organ transplant recipients. Clinical Microbiology and Infection.
39 Cowan ML, Chon WJ, Josephson M, et al. (2012). Impaired response to influenza vaccination in kidney transplant recipients. American Journal of Transplantation.
40 Crespo M, Collado S, Mir M, et al. (2011). Renal patients showed a poor response to the 2009 pandemic new influenza a H1N1 virus vaccine. Transplant International.
41 Dagan R, Kassis I, Sarov B, et al. (1991). Safety and Immunogenicity of Oral Rhesus Rotavirus Tetravalent Vaccine (Orrtv) in Neonates. Pediatric Research.
42 Daniel BS, Venugopal SS, Murrell DF. (2011). Complete resolution of chronic multiple verruca vulgaris treated with quadrivalent human papilloma virus (HPV) vaccine. Australasian Journal of Dermatology.
43 Davies EG, Ashton L, McDermott E, et al. (2008). Immunogenicity of conjugate pneumococcal vaccine (Prevenar) in ataxia telangiectasia: evidence of a genotype/phenotype correlation. Clinical and Experimental Immunology.
44 de Boer AW, McNeil S, Halperin SA, et al. (2010). Safety and Immunogenicity of a Novel Hepatitis B Vaccine Adjuvanted with Immunostimulatory Sequence (Iss) in Renal Predialysis and Dialyis Patients. American Journal of Kidney Diseases.
45 De La Hoz F, Alvis N, Gamboa O, et al. (2011). Cost-effectiveness analysis of the introduction of the varicellavaccine in Colombia. Value in Health.
46 De Lavallade H, Garland PL, Sekine T, et al. (2010). 2009 pandemic influenza A H1N1 vaccination in the patients with hematologic malignancies: Requirement for repeated dosing to optimize seroprotection. Blood.
47 Del Pozo Garcia G, Gallego C, Gomez JJ, et al. (2011). Possible indicators of intussusception post-rotavirus vaccine. Pediatric Radiology.
48 Dieleman J, Lecomte C, Schuemie M, et al. (2011). Safety of adjuvanted pandemic influenza vaccines: Background rate of narcolepsy in Europe. Pharmacoepidemiology and Drug Safety.
49 Dieleman JP, Romio SS, de Vries CS, et al. (2011). Guillain-Barre Syndrome and Adjuvanted Pandemic Influenza A (H1N1) 2009 Vaccines - A Multinational Case Control Study in Europe. Pharmacoepidemiology and Drug Safety.
50 Dodds L, McNeil S, Scott J, et al. (2011). Influenza vaccination in pregnancy. American Journal of Epidemiology.
51 Doran I, Shaharabani H, Kariv R, et al. (2011). Influenza A H1N1 Vaccine is Safe and Effective in Patients With Inflammatory Bowel Disease (IBD) Treated With Thiopurines and TNF-alpha Blockers. Gastroenterology.
52 Doug BR, Xu Y, Zhang YL, et al. (2005). Efficacy and safety of 23-valent pneumococcal polysaccharide vaccine in prevention of lower respiratory tract infections in the Chinese elderly: A prospective concurrent controlled trial. Chest.
53 Duan ZP, Zou HB, Chen Y, et al. (2011). Efficacy and Safety of Double Vs. Standard Dose Recombinant Hepatitis B Vaccine in Infants Born to Hbsag-Positive Mothers:An Interim Report of a Multi-Center, Randomized and Controlled Trial. Hepatology.
54 Farez MF, Ysrraelit MC, Fiol M, et al. (2011). H1N1 vaccination does not increase risk of exacerbation in MS: A self-controlled case-series study. Multiple Sclerosis.
55 Farinas-Alvarez C, Nunez-Viejo MA, Ansorena-Pool L, et al. (2011). Impact of pneumococcal vaccination in preventing invasive pneumococcal disease in Cantabria (SPAIN). Clinical Microbiology and Infection.
56 Faure C, Koller A, Hartmann K, et al. (2011). Development of a large safety database using studies conducted during the clinical development and post-marketing of a virosomal aluminium-free hepatitis a vaccine. Value in Health.
57 Ferreira GLC, Almeida JM, Alena K. (2011). Implementation of panenza A(H1N1) 2009 pandemic vaccine pharmacovigilance plan. Pharmacoepidemiology and Drug Safety.
58 Fontaine H, Chazallon C, Mancini-Bourgine M, et al. (2011). Relapse after analogues treatment discontinuation is not prevented by DNA vaccination in chronic hepatitis B (ANRS HB 02 VAC-ADN). Hepatology.
59 Franca ILA, Ribeiro ACM, Aikawa NE, et al. (2011). Influenza a H1N1/2009 vaccine in rheumatic disease patients under anti-TNF therapy: Safety and response. Arthritis and Rheumatism.
60 Fremond ML, Duchamp M, Guerin V, et al. (2010). CD4 T-cell response to pandemic H1N1 specific vaccine after HSCT in pediatric recipients. Blood.
61 Galindo CM, Rosillon D, Holick CN, et al. (2011). Post-marketing study of autoimmune diseases following vaccination with human papillomavirus bivalent (types 16 and 18) recombinant vaccine in females in the US: Rationale and design. Pharmacoepidemiology and Drug Safety.
62 Garbe E, Andersohn F, Bronder E, et al. (2011). Association between drug use and acute immune thrombocytopenia in adults: Results from the berlin case-control surveillance study. Pharmacoepidemiology and Drug Safety.
63 Geier DA, Young HA, Geier MR. (2010). Thimerosal exposure & increasing trends of premature puberty in the vaccine safety datalink. Indian Journal of Medical Research.
64 George C, Taylor DN, Cathaud O. (2011). Electronic data capture (EDC) with digital pen and paper in a phase I clinical trial of a new influenza vaccine. Journal of Clinical Pharmacology.
65 Gilbert CL, Klopfer SO, Schodel FP, et al. (2011). Immunogenicity and Safety of a Hepatitis B Vaccine Manufactured by a Modified Process in Healthy Adults 50-64 years of age and >= 65 years of age. Journal of the American Geriatrics Society.
66 Goldstone S. (2011). Efficacy of the quadrivalent hpv vaccine to prevent anal intraepithelial neoplasia among young men who have sex with men. Sexually Transmitted Infections.
67 Goss MA, Lievano F, Seminack M, et al. (2012). No adverse signals observed after exposure to human papillomavirus type 6/11/16/18 vaccine during pregnancy: Five year pregnancy registry data. Birth Defects Research Part A - Clinical and Molecular Teratology.
68 Gregg M, Blackhouse G, Loeb M, et al. (2012). Economic evaluation of a cluster randomized controlled trial of an influenza immunization program directed at healthy children. Value in Health.
69 Grimaldi-Bensouda L, Alperovitch A, Besson G, et al. (2011). Guillain-barre syndrome, influenza-like illnesses and influenza vaccination during seasons with and without circulating a/H1N1 viruses. Pharmacoepidemiology and Drug Safety.
70 Grimaldi-Bensouda L, Michel M, Viallard JF, et al. (2011). A multicenter case-control prospective study to assess the risk of immune thrombocytopenia (ITP) associated with vaccines in adults using the PGRx-ITP registry. Blood.
71 Guissa VR, Aikawa NE, Sallum AM, et al. (2011). Influenza a H1N1/2009 vaccine in juvenile dermatomyositis: Rreduced response in patients under immunosuppressive agents. Arthritis and Rheumatism.
72 Haber P, Izurieta H, Patel M, et al. (2007). Intussusception reports following RotaTeq (TM) vaccination: Vaccine adverse event reporting system (VAERS), 3/2006-02/2007. Pharmacoepidemiology and Drug Safety.
73 Halperin SA, Gupta A, Jeanfreau R, et al. (2010). Clinical immunogenicity and reactogenicity of menveo(registered trademark) (MenACWY-CRM) versus menactra(registered trademark) (MCV4) in healthy 2-to-10-year-old children. Canadian Journal of Infectious Diseases and Medical Microbiology.
74 Han GR, Pan C, Jiang HX, et al. (2010). A PROSPECTIVE STUDY FOR THE EFFICACY AND SAFETY OF THE COMBINATION WITH 200 IU HBIG AND 20 UG RECOMBINANT HBV VACCINE FOR THE PREVENTION OF PERINATAL TRANSMISSION OF HEPATITIS B VIRUS (HBV) IN THE INFANTS BORN TO HBEAG plus AND HIGHLY VIREMIC MOTHERS. Hepatology.
75 Hansen J, Black S, Shinefield H, et al. (2001). Lack of association of seizures with receipt of seven valent pneumococcal conjugate vaccine (Prevnar (c), Wyeth). Clinical Infectious Diseases.
76 Harandi AA, Pakdaman H, Sahraian MA, et al. (2012). Infectious diseases, related vaccinations, and risk of multiple sclerosis later in life: A case-control study. Neurology.
77 Harandi AM, Medaglini D, Shattock RJ. (2010). Vaccine adjuvants: A priority for vaccine research. Vaccine.
78 Harris K. (2000). A retrospective study of adverse drug reactions following the administration of influenza, pneumococcal and/or tetanus vaccines to geriatric nursing facility patients. Journal of the American Geriatrics Society.
79 Harris MA, Shen H, Marion S, et al. (2011). Associations between viral infections and Parkinson's disease in a case-control study. Movement Disorders.
80 Heijstek MW, Heijstek M, Ott De Bruin L, et al. (2011). Vaccinations in pediatric autoimmune and autoinflammatory diseases: A systematic literature review. Clinical and Experimental Rheumatology.
81 Hitchon CA, Peschken CA, Mailley T, et al. (2011). Environmental and genetic contributions to disease severity in north american natives with early inflammatory arthritis. Arthritis and Rheumatism.
82 Hua W, Tiernan R, Steffey A, et al. (2010). Postmarketing safety review for rotarix1: Data from the vaccine adverse event reporting system (VAERS), April 2008-October 2009. Pharmacoepidemiology and Drug Safety.
83 Huang WT, Chang S, Miller ER, et al. (2008). Safety assessment after recall of haemophilus influenzae type B (Hib) vaccine - United States, 2007-2008. Pharmacoepidemiology and Drug Safety.
84 Huu TN, Phuong NTM, Toan NT, et al. (2012). Assessment of the immunogenicity and safety of Quinvaxem(registered trademark) (DTwP-HepB- Hib) against diphtheria, pertussis, tetanus, hepatitis B and diseases caused by H. influenzae among healthy Vietnamese children. International Journal of Infectious Diseases.
85 Huu TN, Toan NT, Tuan HM, et al. (2012). Safety and reactogenicity of the 10-valent pneumococcal non-typeable Haemophilus influenzae protein D conjugate vaccine (PHiD-CV) co-administered with DTPa-HBV-IPV/Hib in Vietnamese infants. International Journal of Infectious Diseases.
86 Huu TN, Toan NT, Tuan HM, et al. (2012). Safety and reactogenicity of the 10-valent pneumococcal nontypeable Haemophilus influenzae protein D conjugate vaccine (PHiD-CV) co-administered with DTPa-HBV-IPV/Hib in Vietnamese infants. International Journal of Infectious Diseases.
87 Jessen H. (2012). HPV-Impfung bei Mannern. JDDG - Journal of the German Society of Dermatology.
88 Kang HY, Kim KH, Kim HM, et al. (2010). Public heath and economic impact of rotavirus vaccination in Korea. Value in Health.
89 Kemmeren JM, Timmer SS, Van Der Maas NAT, et al. (2011). Comparing the tolerability of a fifth dose of an acellular pertussis-containing booster vaccination in differently primed children. Pharmacoepidemiology and Drug Safety.
90 King J, Vink P, Farley J, et al. (1996). Safety and immunogenicity of 3 doses of a 5-valent pneumococcal conjugate vaccine (PCV) in HIV and non-HIV-infected children <2 yrs of age. Pediatric Research.
91 Kivitz A, Schechtman J, Texter M, et al. (2011). Assessment of immune responses to pneumococcal and influenza vaccines in patients with rheumatoid arthritis receiving certolizumab pegol. Arthritis and Rheumatism.
92 Koksal B, Ozbek O. (2011). Evaluation of the effects of influenza vaccination on asthma control in schoolage children. Allergy: European Journal of Allergy and Clinical Immunology.
93 Kombo LA, Gerber MA, Pickering LK, et al. (2001). Intussusception, infection, and immunization: summary of a workshop on rotavirus. Pediatrics.
94 Kumar D, Lien D, Campbell P, et al. (2010). Safety and immunogenicity of quadrivalent human papillomavirus vaccine in solid organ transplant recipients. American Journal of Transplantation.
95 Lapeyre-Mestre M, Saussier C, Dumolard C, et al. (2011). Guillain Barre Syndrome and A(H1N1) 2009 vaccination: A French case-control study. Fundamental and Clinical Pharmacology.
96 Lawrence J, He S, Hille D, et al. (2012). A study of RotaTeqTM (pentavalent rotavirus vaccine) in Chinese healthy adults, children and infants. International Journal of Infectious Diseases.
97 Le NM, Ontaneda D, Moodley M, et al. (2009). Neuromyelitis optica: Disease onset in relationship with infections and vaccinations. Journal of Neurology.
98 Lepage AK, McIntyre RC, Kennedy SE, et al. (2011). Safety and reactogenicity of the human papilloma virus vaccine in kidney transplant patients. Immunology and Cell Biology.
99 Li J, Daniel GW, Paeglow C, et al. (2011). Use of self-controlled risk-interval design in childhood vaccine safety. Pharmacoepidemiology and Drug Safety.
100 Liu IF, Huang CC, Chan WL, et al. (2011). Effect of annual influenza vaccination on mortality and hospitalization in patients with chronic heart disease. Journal of the American College of Cardiology.
101 Loughlin J, Christopher Mast T, Wang FT, et al. (2011). A general safety evaluation of the pentavalent rotavirus vaccine. Pharmacoepidemiology and Drug Safety.
102 Loughlin J, Florence W, Eng PM, et al. (2009). A post-marketing surveillance program for pentavalent rotavirus vaccine. Pharmacoepidemiology and Drug Safety.
103 Loulergue P, Rousseau B, Mir O, et al. (2011). Immunogenicity and safety of two doses of AS03Aadjuvanted influenza A/H1N1 2009 vaccine in cancer patients on chemotherapy - VACANCE study. Clinical Microbiology and Infection.
104 Lu Y, Ashworth LA, Bousvaros A, et al. (2011). Immune response to human papillomavirus vaccine (Gardasil) in girls and young women with inflammatory bowel disease. Gastroenterology.
105 Makris M, Polyzos K, Mavros M, et al. (2011). Safety of hepatitis B, pneumococcal, and meningococcal vaccines in pregnancy: Evaluation of the published evidence. Clinical Microbiology and Infection.
106 Manoff S, McFetridge R, Liss C, et al. (2010). Antibody Persistence 10 Years after 1st and 2nd Doses of 23-Valent Pneumococcal Polysaccharide Vaccine (PN23), and Immunogenicity and Safety of 2nd and 3rd Doses in Older Adults. Journal of the American Geriatrics Society.
107 Marman SE, Yousef E. (2007). Adverse reactions to Pneumovax pneumococcal vaccine-cases of hyperimmunization?. Journal of Allergy and Clinical Immunology.
108 Mehling M, Hilbert P, Fritz S, et al. (2010). Viral antigen-specific adaptive immune responses in fingolimod-treated MS patients. Multiple Sclerosis.
109 Menschik VD, Martin D. (2011). Empirical bayesian data mining as an FDA tool for prospective early detection of novel safety signals in the vaccine adverse events reporting system (VAERS): A case study of febrile seizures after an influenza virus. Pharmacoepidemiology and Drug Safety.
110 Miossi R, Fuller R, Moraes JCB, et al. (2011). Influenza H1N1 vaccination in mixed connective tissue disease: Effectiveness and safety independent of disease or therapy. Arthritis and Rheumatism.
111 Mohty B, Bel M, Vukicevic M, et al. (2011). Immunogenicity and safety of the ASO3-adjuvanted A/09/H1N1 influenza vaccine in adult allogeneic haematopoietic stem cell transplantation recipients. Bone Marrow Transplantation.
112 Moro PL, Arana J, Cano M, et al. (2011). Clinical patterns of adverse events after high-dose influenza vaccine reported to the vaccine adverse event reporting system. Pharmacoepidemiology and Drug Safety.
113 Mullane KM, Mullane MR, Wong BMY, et al. (2011). Safety and immunogenicity of heat-treated zoster vaccine (ZVHT) in adults with solid tumor malignancy (STM). Journal of Clinical Oncology.
114 Mundt AJ. (2012). Overall efficacy of HPV-16/18 AS04-adjuvanted vaccine against grade 3 or greater cervical intraepithelial neoplasia: 4-Year End-of-study analysis of the randomised, double-blind PATRICIA trial. International Journal of Radiation Oncology Biology Physics.
115 Naleway A, Weintraub E, Riedlinger K, et al. (2012). CC5-02: A Descriptive Study of Vaccinations Occurring During Pregnancy, 2002-2006. Clinical Medicine & Research.
116 Namkoong JM, Park GC, Hwang S, et al. (2011). Retransplantation for recurrent hepatitis A virus infection following liver transplantation for fulminant hepatitis A infection. Liver Transplantation.
117 Nath K, Burel J, Pritchard AL, et al. (2011). Impaired immune response to influenza vaccination in chronic obstructive pulmonary disease. Internal Medicine Journal.
118 Nkanza J, Lafleche J, Anyoti H, et al. (2010). Adverse events following immunization (AEFI) with human papillomavirus vaccine and hepatitis B vaccines in females aged 9 to 26 Years in Canada, 2006-2010. Canadian Journal of Infectious Diseases and Medical Microbiology.
119 Omenaca F, Merino JM, Tejedor JC, et al. (2010). Immunogenicity and Safety of the 10-Valent Pneumococcal Non-Typeable Haemophilus Influenzae Protein D Conjugate Vaccine (Phid-Cv) Following Primary and Booster Vaccination in Preterm-Born Children. Child Care Health and Development.
120 Oude Bruin LM, Heijstek M, Bijl M, et al. (2011). Vaccinations in pediatric patients receiving DMARDs, glucocorti-costeroids or biological therapy: A systematic literature review. Clinical and Experimental Rheumatology.
121 Ouwens M, Littlewood K, Sauboin C, et al. (2010). Impact of mmrv mass vaccination with or without a catch up program on the incidence of varicella complications in France. Value in Health.
122 Parisi CAS, Maspero JF, Gervasoni ME, et al. (2011). Anaphylaxis to oral poliovirus vaccine in children with cow milk protein allergy. Journal of Allergy and Clinical Immunology.
123 Parrino J, Marquez F, Fisher CL, et al. (2011). Safety, tolerability, and immunogenicity of zoster vaccine in patients on chronic/maintenance corticosteroids. Arthritis and Rheumatism.
124 Pasoto SG, Calich ALG, Aikawa NE, et al. (2011). Antimalarials: A window of opportunity to improve the influenza A/H1N1 vaccine response in lupus patients under immunosuppressive agents. Arthritis and Rheumatism.
125 Perez-Lloret S, Rey MV, Bondon-Guitton E, et al. (2012). Drugs related to Tourette-like syndrome: A case/non-case study in the French Pharmacovigilance database. Movement Disorders.
126 Prelog M, Schonlaub J, Zlamy M, et al. (2010). Reduced IgG antibody avidity in organ transplant recipients after varicella-zoster-virus vaccination. Clinical Microbiology and Infection.
127 Rahbar H, Abreu-Lanfrranco O, Singh A, et al. (2012). Risk factors for readmissions in patients 65 or older admitted for pneumonia. Journal of the American Geriatrics Society.
128 Rajeshwari K. (2006). Prevention of rotavirus gastroenteritis. Indian Pediatrics.
129 Rennels MB, Edwards KM, Keyserling HL, et al. (1996). Immunogenicity and safety of 7-valent pneumococcal-CRM(197) conjugate vaccine. Pediatric Research.
130 Riaz H, Denyer M. (2012). The efficacy of bivalent and tetravalent HPV vaccination against cervical intraepithelial neoplasia and persistent HPV 16 and 18 infection. BJOG: An International Journal of Obstetrics and Gynaecology.
131 Rohde KA, Moran JJM, Hayney MS. (2011). Effectiveness and safety of influenza vaccine in first six months post-lung transplant. Pharmacotherapy.
132 Rossi JF, Caumes B, Cymbalista F, et al. (2010). Immunogenicity and safety of one dose of influenza A H1N1v 2009 adjuvanted vaccine for unpreviously treated patients with binet-stage a chronic lymphoid leukaemia of B-cell type (B-CLL): Result of a prospective study conducted in 9 French centers by the intergroupe Francnullais GOELAMS/GFLLC-MW. Blood.
133 Rothberg M. (2010). Herpes zoster: is there a role for vaccination?. Clinical Microbiology and Infection.
134 Rothova A, De Groot JDF, Mudrikova T. (2011). Reactivation of acute retinal necrosis after flu H1N1 vaccination. British Journal of Ophthalmology.
135 Rousseau BJ, Loulergue P, Mir O, et al. (2010). Immunogenicity and Safety of Two Doses of As03a-Adjuvanted Influenza a H1n1v 2009 Vaccine in Cancer Patients on Chemotherapy - Vacance Study. Annals of Oncology.
136 Rowhani-Rahbar A, Fireman B, Lewis N, et al. (2011). Use of the case-centered analytic method in epidemiologic studies of immunization safety. American Journal of Epidemiology.
137 Rowhani-Rahbar A, Klein NP, Dekker CL, et al. (2011). Biologically plausible risk intervals to assess febrile seizure following immunization with influenza and pneumococcal conjugate vaccines. Pharmacoepidemiology and Drug Safety.
138 Saah A. (2011). An evaluation of the long-term effectiveness, immunogenicity, and safety of gardasil in previously vaccinated women. Sexually Transmitted Infections.
139 Saddier P, Tran T, Ackerson B, et al. (2010). Importance of medical record review for database studies: Example of Febrile Convulsion (FC). Pharmacoepidemiology and Drug Safety.
140 Samad L, Bashir HE, Marven S, et al. (2010). Intussusception in the first year of life: A UK national surveillance study. Archives of Disease in Childhood.
141 Sambatakou H. (2011). Adverse effect of influenza A/H1N1 vaccination on endothelial function of HIV infected patients. Clinical Microbiology and Infection.
142 Sammon CJ, McGrogan A, Snowball J, et al. (2011). Swine flu vaccination in pregnancy and associated miscarriage risk. Pharmacoepidemiology and Drug Safety.
143 Santanello NC, Mast C, Loughlin J, et al. (2009). Cautionary example of potential exposure-based differential misclassification in a post-marketing vaccine safety study. Pharmacoepidemiology and Drug Safety.
144 Sargsyan N, Balyan AY. (2010). Retrospective study of pentavalent vaccine administration in children. New Armenian Medical Journal.
145 Saussier CS, Hill CH, Castot AC. (2010). Number of Spontaneous Reports of Guillain-Barre Syndrome after Flu A(H1N1) Vaccination versus Expected Number in France. Drug Safety.
146 Schilling A, Morgan T. (2011). High grade cervical dysplasia in young women after HPV vaccination. Reproductive Sciences.
147 Schwarz TF, Pauksens K, Juergens C, et al. (2011). An Open-label Trial to Assess the Safety of 13-Valent Pneumococcal Conjugate Vaccine in Older Adults, Previously Vaccinated With 23-Valent Pneumococcal Polysaccharide Vaccine. Journal of the American Geriatrics Society.
148 Scott P, Moss WJ, Gilani Z, et al. (2010). Safety and immunogenicity of measles vaccine in HIV-infected children: Systematic review and meta-analysis. International Journal of Infectious Diseases.
149 Shaikh AG, Termsarasab P, Nwankwo C, et al. (2011). Guillain-Barre Syndrome Following Swine Influenza Vaccination. Muscle & Nerve.
150 Sheikh Z, Abukwaik W, Souayah N. (2012). Ataxia after vaccination in united states, a report from the CDC/FDA vaccine adverse event reporting system [1990-2010]. Neurology.
151 Sheikh Z, Abukwaik W, Souayah N. (2012). Meningitis after vaccination in United States, a report from the CDC/FDA vaccine adverse event reporting system [1990-2010]. Neurology.
152 Shinjo SK, Neto ML, Silva CA, et al. (2011). Pandemic unadjuvanted influenza a 2009 vaccine in adult dermatomyositis and polymyositis: Immunogenicity independent of therapy and no harmful effect in disease. Arthritis and Rheumatism.
153 Sibunruang S. (2011). Two-site intradermal influenza vaccination in elderly. Clinical Microbiology and Infection.
154 Small TN, Iovino CS, Abboud M, et al. (2010). Vaccine response in recipients of HLA mismatched unrelated double unit cord blood transplantation (CBT). Blood.
155 Small TN, Jakubowski AA, Barker JN, et al. (2011). Safety and immunogenicity of the 13-valent protein-conjugated pneumococcal vaccine(PCV13) following related and unrelated hematopoietic stem cell transplantation (HCT). Blood.
156 Smith K, Muther J, Duke A, et al. (2011). Antibody secreting cells arising after vaccination from anti-cardiolipin positive individuals can produce antibodies which are bi-specific and bind to both cardiolipin and the vaccinating antigen. Arthritis and Rheumatism.
157 Smith LM, Srighanthan J, Poon KKY, et al. (2010). Quality of reporting of harms in randomized controlled trials: An example using human papillomavirus (HPV) vaccines. Pharmacoepidemiology and Drug Safety.
158 Sonmezer M, Tuncer Ertem G, Ucal Bakkal S, et al. (2011). The side effects of H1N1 pandemic vaccine in pregnant women and comparison to other healthcare workers. Clinical Microbiology and Infection.
159 Steffey A, Lizewski R, Sutherland A, et al. (2010). Acute pancreatitis after quadrivalent human papillomavirus vaccination: Reports to a post-marketing passive surveillance system 2006-2009. Pharmacoepidemiology and Drug Safety.
160 Suryakiran PV, Vinals C, Vanfraechem K, et al. (2011). The human rotavirus vaccine rix4414 in infants: An integrated safety summary (ISS). Acta Paediatrica, International Journal of Paediatrics.
161 Swamy GK. (2011). Phase II Study To Assess the Safety and Immunogenicity of Two Dose Levels of 2009 H1N1 Influenza Vaccine in Pregnant Women. Reproductive Sciences.
162 Tan SJ, Chean R, Hurt A, et al. (2011). Follow-up response of renal transplant recipients to booster influenza a H1N1 vaccine. Nephrology.
163 Trabert B, Graubard BI, Erickson RL, et al. (2011). Mumps, orchitis and testicular germ cell tumors: A cause for concern?. American Journal of Epidemiology.
164 Tran GMK, Gerbaud L, Caprani A. (2010). Auto-immune thrombocytopenia after Measles Mumps Rubella MMR vaccination: molecular mimicry of measles virus phosphoprotein with platelet gpIIb. Retrovirology.
165 Tricotel A, Fagot J, Tubert-Bitter P, et al. (2011). Human papillomavirus vaccine and autoimmune disorders: A cohort study of 5.8 millions of adolescents and young women. Two years follow-up results. Fundamental and Clinical Pharmacology.
166 Tseng YR, Chen HL, Hu FC, et al. (2011). Symptomatic and fulminant hepatitis B in infancy after universal hepatitis B vaccination: Clinical outcome and risk factors. Hepatology.
167 Ulanova M, Hawdon N, Nix E, et al. (2011). Risk of invasive haemophilus influenzae type B (Hib) disease and response to Hib vaccine in patients with chronic renal failure. Canadian Journal of Infectious Diseases and Medical Microbiology.
168 Umapathi T. (2011). International collaborative safety monitoring for pandemic 2009 H1N1 vaccines: Estimation of the risk of Guillain-Barre syndrome-Singapore experience. Journal of the Peripheral Nervous System.
169 Van Besouw NM, Zuijderwijk JM, Noorlander I, et al. (2012). Varicella zoster virus vaccination induces virus-specific class II restricted memory responses in seronegative kidney transplant recipients. American Journal of Transplantation.
170 Van Der Maas N, Wesselo C, Phaff T, et al. (2010). Adverse events following bivalent human papillomavirus vaccination reported to the enhanced passive surveillance system of the Netherlands. Pharmacoepidemiology and Drug Safety.
171 Van Der Maas N, Zonnenberg-Hoff I, Kemmeren J, et al. (2010). Immediate occurring adverse events following bivalent human papillomavirus vaccination in the Netherlands. Pharmacoepidemiology and Drug Safety.
172 Van Praet S, Puertolas PA, Alvarez SZ. (2011). Study on Pandemrix pharmacovigilance at CHU St. Pierre. International Journal of Clinical Pharmacy.
173 Vardeny O, Hermanson MP, Moran JM, et al. (2011). A randomized study of double-dose versus single-dose influenza vaccination in patients with heart failure. Circulation.
174 Velazquez FR, Colindres R, Grajales C, et al. (2010). Postmarketing surveillance of intussusception following mass introduction of the human rotavirus vaccine in Mexico: An interim analysis. Acta Paediatrica, International Journal of Paediatrics.
175 Verity C, Stellitano L, Winstone A, et al. (2011). Is guillain barre syndrome/fisher syndrome associated with swine 'flu vaccination in children? Results: from a UK-wide epidemiological study. Archives of Disease in Childhood.
176 Vesikari T, Esposito S, Kimura A, et al. (2010). Immunogenicity of an investigational multicomponent meningococcal serogroup B vaccine in healthy infants at 2, 4 and 6 months of age. Canadian Journal of Infectious Diseases and Medical Microbiology.
177 Wade A, Crawford G, Pumford N, et al. (2011). Sensitivity of pro's in evaluating adverse events in people receiving influenza vaccination. Value in Health.
178 Walker AM, Puenpatom T, Li J, et al. (2011). Search for new safety signals in the patterns of care following MMR vaccine. Pharmacoepidemiology and Drug Safety.
179 Wang FT, Mast TC, Glass RJ, et al. (2009). Effectiveness of the pentavalent rotavirus vaccine in preventing gastroenteritis in the United States: A claims-based analysis. Pharmacoepidemiology and Drug Safety.
180 Wang M, Khromava A, Mahmood A, et al. (2011). Pregnant women receiving tetanus-diphtheria-acellular pertussis (Tdap) vaccine: 6 Years of adacel vaccine pregnancy registry data. Pharmacoepidemiology and Drug Safety.
181 Wijnans E, Dieleman J, Voordouw A, et al. (2011). Estimating the effectiveness of pandemic influenza vaccination in a dutch population. Pharmacoepidemiology and Drug Safety.
182 Winnick A, Mitsiev I, Diflo T, et al. (2011). The effects of H1N1 vaccination in liver transplantation. Liver Transplantation.
183 Winston D, Mullane K, Boeckh M, et al. (2011). Safety and immunogenicity of heat-treated zoster vaccine (ZV(HT)) in adults with allogeneic or autologous hematopoietic stem-cell transplants (HCT). Biology of Blood and Marrow Transplantation.
184 Wood D, Group WHOIC. (2005). WHO informal consultation on quality, safety and efficacy specifications for live attenuated rotavirus vaccines Mexico City, Mexico, 8-9 February 2005. Vaccine.
185 Wood N, Cannings K, Quinn H, et al. (2011). Rotavirus vaccines and intussusception: An increased risk. Journal of Paediatrics and Child Health.
186 Yuki N, Ihara T, Ito S, et al. (2010). Do influenza vaccines induce anti-ganglioside antibodies?. Journal of the Peripheral Nervous System.
187 Zaiem A, El Adii S, Kastalli S, et al. (2009). Adverse effect following immunization associated with diphtheria-tetanus-pertussis and oral poliomyelitis vaccine. Drug Safety.
188 Zangwill KM, Greenberg DP, Wong VK, et al. (1996). Safety and immunogenicity of two lots of pneumococcal conjugate vaccine in infants. Pediatric Research.
189 Zhang J, Delzell ES, Xie F, et al. (2011). The use, safety and effectiveness of herpes zoster vaccination in individuals with inflammatory and autoimmune diseases. Pharmacoepidemiology and Drug Safety.
190 Zhang J, Xie F, Delzell ES, et al. (2011). Safety of zoster vaccine in individuals with rheumatoid arthritis, psoriatic arthritis, ankylosing spondylitis, and inflammatory bowel disease. Arthritis and Rheumatism.
191 Zhang J, Xie FL, Delzell ES, et al. (2011). Safety of Zoster Vaccine in Individuals with Rheumatoid Arthritis, Psoriatic Arthritis, Ankylosing Spondylitis, and Inflammatory Bowel Disease. Arthritis and Rheumatism.

## Rejected for Adverse Events Not Assessed – 458

1 From the Centers for Disease Control and Prevention. (1997). Status report on the Childhood Immunization Initiative: national, state, and urban area vaccination coverage levels among children aged 19-35 months--United States, 1996. JAMA.
2 (2007). Safety and immunogenicity of a fully liquid vaccine containing five-component pertussis-diphtheria-tetanus-inactivated poliomyelitis- Haemophilus influenzae type b conjugate vaccines administered at two, four, six and 18 months of age. Canadian Journal of Infectious Diseases and Medical Microbiology.
3 (2010). FDA panel recommends continued use of rotarix and rotateq vaccines viral DNA contamination. Formulary.
4 (2011). Rotavirus vaccination and risk of intussusception: Investigation of a possible safety signal. Australian Prescriber.
5 Aaby P, Benn CS. (2011). Non-specific and sex-differential effects of routine vaccines: what evidence is needed to take these effects into consideration in low-income countries?. Human Vaccines.
6 Aaby P, Martins CL, Garly ML, et al. (2010). Non-specific effects of standard measles vaccine at 4.5 and 9 months of age on childhood mortality: randomised controlled trial. British Medical Journal.
7 Abbott KC, Yuan CM, Lee JL. (2011). Nothing to sneeze at: Efficacy and cost-effectiveness of the influenza vaccine in patients receiving long-term dialysis. American Journal of Kidney Diseases.
8 Abramson JS, Almquist JR, Jenkins RR, et al. (2008). Prioritisation of routine vaccines: a mistake for the USA. The Lancet.
9 Adamkiewicz TV, Silk BJ, Howgate J, et al. (2008). Effectiveness of the 7-valent pneumococcal conjugate vaccine in children with sickle cell disease in the first decade of life. Pediatrics.
10 Adegbola RA, Leach A, Mulholland K, et al. (1998). Antigenuria in Gambian infants following immunization with a Haemophilus influenzae type b polyribosylribitol phosphate-tetanus toxoid protein conjugate (PRP-T) vaccine. Diagnostic Microbiology & Infectious Disease.
11 Ahlgren C, Oden A, Haghighi S, et al. (2010). The effect of live attenuated measles vaccine and measles infection on measles antibody levels in serum and CSF of multiple sclerosis patients. Multiple Sclerosis.
12 Alfageme I, Vazquez R, Reyes N, et al. (2006). Clinical efficacy of anti-pneumococcal vaccination in patients with COPD. Thorax.
13 Ali NK, Bhutta ZA. (2003). A review of rotavirus diarrhea in Pakistan: How much do we know?. Journal of the College of Physicians and Surgeons Pakistan.
14 AlonsoDeVelasco E, Verheul AF, Verhoef J, et al. (1995). Streptococcus pneumoniae: virulence factors, pathogenesis, and vaccines. Microbiological Reviews.
15 Amador JJ, Vasquez J, Orozco M, et al. (2010). Rotavirus disease burden, Nicaragua 2001-2005: defining the potential impact of a rotavirus vaccination program. International Journal of Infectious Diseases.
16 Ameratunga SN, Lennon DR, Entwistle B, et al. (1997). The immunogenicity of Haemophilus influenzae: Meningococcal protein conjugate vaccine in Polynesian and non-Polynesian New Zealand infants. Journal of Paediatrics and Child Health.
17 Anar C, Bicmen C, Yapicioglu S, et al. (2010). Evaluation of clinical data and antibody response following influenza vaccination in patients with chronic obstructive pulmonary disease. New Microbiologica.
18 Anderson EL, Kennedy DJ, Geldmacher KM, et al. (1996). Immunogenicity of heptavalent pneumococcal conjugate vaccine in infants. Journal of Pediatrics.
19 Andrews N, Waight P, Yung CF, et al. (2011). Age-specific effectiveness of an oil-in-water adjuvanted pandemic (H1N1) 2009 vaccine against confirmed infection in high risk groups in England. Journal of Infectious Diseases.
20 Andrews N, Waight PA, Borrow R, et al. (2011). Using the indirect cohort design to estimate the effectiveness of the seven valent pneumococcal conjugate vaccine in England and Wales. PLoS ONE.
21 Ansaldi F, Sticchi L, Durando P, et al. (2008). Decline in pneumonia and acute otitis media after the introduction of childhood pneumococcal vaccination in Liguria, Italy. Journal of International Medical Research.
22 Anttila M, Eskola J, Ahman H, et al. (1999). Differences in the avidity of antibodies evoked by four different pneumococcal conjugate vaccines in early childhood. Vaccine.
23 Ardern-Holmes SL, Lennon D, Pinnock R, et al. (1999). Trends in hospitalization and mortality from rotavirus disease in New Zealand infants. Pediatric Infectious Disease Journal.
24 Arkwright PD, Patel L, Moran A, et al. (2000). Atopic eczema is associated with delayed maturation of the antibody response to pneumococcal vaccine. Clinical and Experimental Immunology.
25 Auriel E, Gadoth A, Regev K, et al. (2012). Seasonal and H1N1v influenza vaccines in MS: safety and compliance. Journal of the Neurological Sciences.
26 Auvinen A, Hakulinen T, Groves F. (2000). Haemophilus influenzae type B vaccination and risk of childhood leukaemia in a vaccine trial in Finland. British Journal of Cancer.
27 Babu GR, Bhatnagar T. (2010). Influenza vaccination to elderly: Quantifying the potential role of unmeasured confounders through an example. Internet Journal of Epidemiology.
28 Bakir M, Yagci A, Ulger N, et al. (2002). Pharyngeal colonization with Haemophilus influenzae type b among healthy Turkish infants and children. Pediatrics International.
29 Baldo V, Baldovin T, Pellegrini M, et al. (2010). Immunogenicity of Three Different Influenza Vaccines against Homologous and Heterologous Strains in Nursing Home Elderly Residents. Clinical & Developmental Immunology.
30 Balmer P, Orrow RB, Arkwright PD. (2007). The 23-valent pneumococcal polysaccharide vaccine does not provide additional serotype antibody protection in children who have been primed with two doses of heptavalent pneumococcal conjugate vaccine. Vaccine.
31 Barry DW, Mayner RE, Hochstein HD, et al. (1976). Comparative trial of influenza vaccines. II. Adverse reactions in children and adults. Am J Epidemiol.
32 Baxendale HE, Keating SM, Johnson M, et al. (2010). The early kinetics of circulating pneumococcal-specific memory B cells following pneumococcal conjugate and plain polysaccharide vaccines in the elderly. Vaccine.
33 Bayard V, DeAntonio R, Contreras R, et al. (2012). Impact of rotavirus vaccination on childhood gastroenteritis-related mortality and hospital discharges in Panama. International Journal of Infectious Diseases.
34 Bedford HE, Elliman DAC. (2002). The adverse effects of vaccines - Fact and fiction. Current Paediatrics.
35 Bennett EM, Domachowske JB. (2007). Progress in adolescent immunization. Clinical Microbiology Newsletter.
36 Beran J, Vesikari T, Wertzova V, et al. (2009). Efficacy of inactivated split-virus influenza vaccine against culture-confirmed influenza in healthy adults: a prospective, randomized, placebo-controlled trial. J Infect Dis.
37 Berger F, Njamkepo E, Minaberry S, et al. (2010). Investigation on a pertussis outbreak in a military school: risk factors and approach to vaccine efficacy. Vaccine.
38 Bhatla N, Suri V, Basu P, et al. (2010). Immunogenicity and safety of human papillomavirus-16/18 AS04-adjuvanted cervical cancer vaccine in healthy Indian women. Journal of Obstetrics and Gynaecology Research.
39 Block SL, Busman TA, Paris MM, et al. (2004). Comparison of five-day cefdinir treatment with ten-day low dose amoxicillin/clavulanate treatment for acute otitis media. Pediatric Infectious Disease Journal.
40 Bloom DE, Canning D, Shenoy ES. (2012). The effect of vaccination on children's physical and cognitive development in the Philippines. Applied Economics.
41 Bluestone CD. (2001). Pneumococcal conjugate vaccine - Impact on otitis media and otolaryngology. Archives of Otolaryngology-Head & Neck Surgery.
42 Blum MD, Dagan R, Mendelman PM, et al. (2000). A comparison of multiple regimens of pneumococcal polysaccharide-meningococcal outer membrane protein complex conjugate vaccine and pneumococcal polysaccharide vaccine in toddlers. Vaccine.
43 Bogaards JA, Coupe VMH, Xiridou M, et al. (2011). Long-term impact of human papillomavirus vaccination on infection rates, cervical abnormalities, and cancer incidence. Epidemiology.
44 Bolgiano B, Mawas F, Burkin K, et al. (2007). A retrospective study on the quality of Haemophilus influenzae type b vaccines used in the UK between 1996 and 2004. Human Vaccines.
45 Bomprezzi R, Wildemann B. (2010). Acute disseminated encephalomyelitis following vaccination against human papilloma virus. Neurology.
46 Booy R, Hodgson SA, Slack MPE, et al. (1993). Invasive Haemophilus-Influenzae Type-B Disease in the Oxford Region (1985-91). Archives of Disease in Childhood.
47 Braeckman T, Van Herck K, Raes M, et al. (2011). Rotavirus Vaccines in Belgium Policy and Impact. Pediatric Infectious Disease Journal.
48 Breiman RF, Zaman K, Armah G, et al. (2012). Analyses of health outcomes from the 5 sites participating in the Africa and Asia clinical efficacy trials of the oral pentavalent rotavirus vaccine. Vaccine.
49 Bricks LF, Berezin E. (2006). Impact of pneumococcal conjugate vaccine on the prevention of invasive pneumococcal diseases. Jornal de Pediatria.
50 Brown B, Blas M, Cabral A, et al. (2012). Randomized trial of HPV4 vaccine assessing the response to HPV4 vaccine in two schedules among Peruvian female sex workers. Vaccine.
51 Buettcher M, Baer G, Bonhoeffer J, et al. (2007). Three-year surveillance of intussusception in children in Switzerland. Pediatrics.
52 Burwen DR, La Voie L, Braun MM, et al. (2007). Evaluating adverse events after vaccination in the Medicare population. Pharmacoepidemiology & Drug Safety.
53 Butler JC, Breiman RF, Campbell JF, et al. (1993). Pneumococcal Polysaccharide Vaccine Efficacy - an Evaluation of Current Recommendations. Jama-Journal of the American Medical Association.
54 Cai Y, Rodriguez S, Rameswaran R, et al. (2010). Production of pharmaceutical-grade plasmids at high concentration and high supercoiled percentage. Vaccine.
55 Campitelli MA, Rosella LC, Stukel TA, et al. (2010). Influenza vaccination and all-cause mortality in community-dwelling elderly in Ontario, Canada, a cohort study. Vaccine.
56 Carmo GMID, Yen C, Cortes J, et al. (2011). Decline in diarrhea mortality and admissions after routine childhood rotavirus immunization in Brazil: A time-series analysis. PLoS Medicine.
57 Carty CL, Heagerty P, Nakayama K, et al. (2006). Inflammatory response after influenza vaccination in men with and without carotid artery disease. Arterioscler Thromb Vasc Biol.
58 Castilla J, Beristain X, Martinez-Artola V, et al. (2012). Effectiveness of rotavirus vaccines in preventing cases and hospitalizations due to rotavirus gastroenteritis in Navarre, Spain. Vaccine.
59 Castilla J, Moran J, Martinez-Artola V, et al. (2011). Effectiveness of the monovalent influenza A(H1N1)2009 vaccine in Navarre, Spain, 2009-2010: Cohort and case-control study. Vaccine.
60 Cavenaugh JS, Awi D, Mendy M, et al. (2011). Partially Randomized, Non-Blinded Trial of DNA and MVA Therapeutic Vaccines Based on Hepatitis B Virus Surface Protein for Chronic HBV Infection. PLoS ONE.
61 Chan TC, Hung IFN, Luk JKH, et al. (2011). Efficacy of dual vaccination of pandemic H1N1 2009 influenza and seasonal influenza on institutionalized elderly: A one-year prospective cohort study. Vaccine.
62 Chan TC, Hung IFN, Luk JKH, et al. (2012). Prevention of Mortality and Pneumonia Among Nursing Home Older Adults by Dual Pneumococcal and Seasonal Influenza Vaccination During a Pandemic Caused by Novel Pandemic Influenza A (H1N1). Journal of the American Medical Directors Association.
63 Chang YC, Chou YJ, Liu JY, et al. (2012). Additive benefits of pneumococcal and influenza vaccines among elderly persons aged 75 years or older in Taiwan - A representative population-based comparative study. Journal of Infection.
64 Chen RT, Rastogi SC, Mullen JR, et al. (1994). The vaccine adverse event reporting system (VAERS). Vaccine.
65 Chen WH, El-Kamary SS. (2012). Vaccines for enteric infections. Current Opinion in Gastroenterology.
66 Chen YE, Beasley S, Grimwood K. (2005). Intussusception and rotavirus associated hospitalisation in New Zealand. Archives of Disease in Childhood.
67 Cherian MP, Al-Kanani KA, Al Qahtani SS, et al. (2010). The rising incidence of type 1 diabetes mellitus and the role of environmental factors - Three decade experience in a primary care health center in Saudi Arabia. Journal of Pediatric Endocrinology and Metabolism.
68 Chernin LR, Swender D, Hostoffer RW. (2011). Cracking the shell on egg-hypersensitive patients and egg-containing vaccines. Journal of the American Osteopathic Association.
69 Chi RC, Reiber GE, Neuzil KM. (2006). Influenza and pneumococcal vaccination in older veterans: results from the behavioral risk factor surveillance system. Journal of the American Geriatrics Society.
70 Choo S, Zhang QB, Seymour L, et al. (2000). Primary and booster salivary antibody responses to a 7-valent pneumococcal conjugate vaccine in infants. Journal of Infectious Diseases.
71 Christenson B, Hedlund J, Lundbergh P, et al. (2004). Additive preventive effect of influenza and pneumococcal vaccines in elderly persons. European Respiratory Journal.
72 Christenson B, Pauksen K, Sylvan SPE. (2008). Effect of influenza and pneumococcal vaccines in elderly persons in years of low influenza activity. Virology Journal.
73 Clark. (2004). Safety, efficacy, and immunogenicity of a live, quadrivalent human-bovine reassortant rotavirus vaccine in healthy infants. Journal of Pediatrics.
74 Clark HF, Lawley D, Mallette LA, et al. (2009). Decline in Cases of Rotavirus Gastroenteritis Presenting to The Children's Hospital of Philadelphia after Introduction of a Pentavalent Rotavirus Vaccine. Clinical and Vaccine Immunology.
75 Clark HF, Lawley D, Shrager D, et al. (2004). Infant immune response to human rotavirus serotype G1 vaccine candidate reassortant WI79-9: Different dose response patterns to virus surface proteins VP7 and VP4. Pediatric Infectious Disease Journal.
76 Conterno LO, da Silva Filho CR, Ruggeberg JU, et al. (2011). WITHDRAWN: Conjugate vaccines for preventing meningococcal C meningitis and septicaemia. Cochrane Database of Systematic Reviews.
77 Correia JB, Patel MM, Nakagomi O, et al. (2010). Effectiveness of Monovalent Rotavirus Vaccine (Rotarix) against Severe Diarrhea Caused by Serotypically Unrelated G2P[4] Strains in Brazil. Journal of Infectious Diseases.
78 Cortes JE, Curns AT, Tate JE, et al. (2011). Rotavirus vaccine and health care utilization for diarrhea in U.S. children. New England Journal of Medicine.
79 Cortese MM, Staat MA, Weinberg GA, et al. (2009). Underestimates of intussusception rates among US infants based on inpatient discharge data: implications for monitoring the safety of rotavirus vaccines. Journal of Infectious Diseases.
80 Couch RB. (2011). Lessons learned from clinical trials in 1976 and 1977 of vaccines for the Newly Emerged swine and Russian Influenza A/H1N1 viruses. Birkhauser Advances in Infectious Diseases.
81 Cowling BJ, Fang VJ, Nishiura H, et al. (2012). Increased risk of noninfluenza respiratory virus infections associated with receipt of inactivated influenza vaccine. Clinical Infectious Diseases.
82 Crocetti E, Arniani S, Bordoni F, et al. (2001). Effectiveness of influenza vaccination in the elderly in a community in Italy. European Journal of Epidemiology.
83 Crooks CJ, Prieto-Merino D, Evans SJW. (2012). Identifying adverse events of vaccines using a bayesian method of medically guided information sharing. Drug Safety.
84 Cunliffe NA, Witte D, Ngwira BM, et al. (2012). Efficacy of human rotavirus vaccine against severe gastroenteritis in Malawian children in the first two years of life: A randomized, double-blind, placebo controlled trial. Vaccine.
85 Czajka H, Schuster V, Zepp F, et al. (2010). Corrigendum to “A combined measles, mumps, rubella and varicella vaccine (Priorix-Tetra <trade>): Immunogenicity and safety profile” Vaccine 27 (2009) 6504-6511. Vaccine.
86 Dagan R, Sikuler-Cohen M, Zamir O, et al. (2001). Effect of a conjugate pneumococcal vaccine on the occurrence of respiratory infections and antibiotic use in day-care center attendees. Pediatric Infectious Disease Journal.
87 Dalton CB, Cretikos MA, Durrheim DN, et al. (2010). Comparison of adult patients hospitalised with pandemic (H1N1) 2009 influenza and seasonal influenza during the “PROTECT” phase of the pandemic response. Medical Journal of Australia.
88 Das MK, Bhattacharyya N. (2002). Paediatric immunisation: Special emphasis on measles and MMR vaccinations. Journal of the Indian Medical Association.
89 Dashefsky B, Wald E, Guerra N, et al. (1990). Safety, Tolerability, and Immunogenicity of Concurrent Administration of Haemophilus-Influenzae Type-B Conjugate Vaccine (Meningococcal Protein Conjugate) with Either Measles-Mumps-Rubella Vaccine or Diphtheria-Tetanus-Pertussis and Oral Poliovirus Vaccines in 14-Month-Old to 23-Month-Old Infants. Pediatrics.
90 Davies K, Woo P. (2002). Immunization in rheumatic diseases of childhood: An audit of the clinical practice of british paediatric rheumatology group members and a review of the evidence. Rheumatology.
91 Dennehy PH. (2012). Effects of vaccine on rotavirus disease in the pediatric population. Current Opinion in Pediatrics.
92 Dennehy PH, Vesikari T, Matson DO, et al. (2011). Efficacy of the pentavalent rotavirus vaccine, RotaTeq[REGISTERED] (RV5), between doses of a 3-dose series and with less than 3 doses (incomplete regimen). Human Vaccines.
93 Desselberger U. (1998). Prospects for vaccines against rotaviruses. Reviews in Medical Virology.
94 Desselberger U, Huppertz HI. (2011). Immune responses to rotavirus infection and vaccination and associated correlates of protection. Journal of Infectious Diseases.
95 Dewan P, Gupta P. (2012). Burden of Congenital Rubella Syndrome (CRS) in India: A Systematic Review. Indian Pediatrics.
96 Dey AK, Srivastava IK. (2011). Novel adjuvants and delivery systems for enhancing immune responses induced by immunogens. Expert Review of Vaccines.
97 D'Heilly S, Bauman WL, Nichol KL. (2002). Safety and acceptability of pneumococcal vaccinations administered in nontraditional settings. American Journal of Infection Control.
98 Di Pasquale A, De Ridder M, Van Der Meeren O. (2012). Hepatitis B virus vaccine in chronic kidney diseases: Improved immunogenicity by adjuvants? Limits of a meta-analysis. Vaccine.
99 Dodds L, McNeil SA, Fell DB, et al. (2007). Impact of influenza exposure on rates of hospital admissions and physician visits because of respiratory illness among pregnant women. Canadian Medical Association Journal.
100 Driver C. (2012). Pneumonia part 2: signs, symptoms and vaccinations. British Journal of Nursing.
101 Duclos P, Hofmann CA. (2001). Immunisation safety: A priority of the World Health Organization's Department of Vaccines and Biologicals. Drug Safety.
102 Eberly MD, Gorman GH, Eide MB, et al. (2011). The effect of rotavirus immunization on rotavirus gastroenteritis hospitalization rates in military dependents. Vaccine.
103 Eglee Perez M, Glass R, Alvarez G, et al. (2000). Rhesus rotavirus-based quadrivalent vaccine is efficacious despite age, socioeconomic conditions and seasonality in Venezuela. Vaccine.
104 Einollahi B. (2011). Immune response to hepatitis B vaccine in patients with chronic kidney disease. Hepatitis Monthly.
105 El Khoury AC, Mast TC, Ciarlet M, et al. (2011). Projecting the effectiveness of RotaTeq(registered trademark) against rotavirus-related hospitalizations and deaths in six Asian countries. Human Vaccines.
106 Ellenberg SS, Braun MM. (2002). Monitoring the safety of vaccines: Assessing the risks. Drug Safety.
107 Englund JA, Mbawuike IN, Hammill H, et al. (1993). Maternal immunization with influenza or tetanus toxoid vaccine for passive antibody protection in young infants. J Infect Dis.
108 Farr BM, Johnston BL, Cobb DK, et al. (1995). Preventing pneumococcal bacteremia in patients at risk. Results of a matched case-control study. Arch Intern Med.
109 Fasunla AJ. (2010). Challenges of tracheostomy in patients managed for severe tetanus in a developing country. International Journal of Preventive Medicine.
110 Fedson DS. (1999). The clinical effectiveness of pneumococcal vaccination: A brief review. Vaccine.
111 Fedson DS, Liss C. (2004). Precise answers to the wrong question: Prospective clinical trials and the meta-analyses of pneumococcal vaccine in elderly and high-risk adults. Vaccine.
112 Ferreyra L, Bustos D, Biganzoli P, et al. (2010). HHV-6 IgG4 isotype response following measles infection. Journal of Medical Virology.
113 Ferris DG, Shulman L. (2010). Prevention of human papillomavirus in women of childbearing age. Sexuality, Reproduction and Menopause.
114 Findlow H, Southern J, Mabey L, et al. (2006). Immunoglobulin G subclass response to a meningococcal quadrivalent polysaccharide-diphtheria toxoid conjugate vaccine. Clinical and Vaccine Immunology.
115 Finn A, Booy R, Moxon R, et al. (2002). Should the new pneumococcal vaccine be used in high-risk children?. Archives of Disease in Childhood.
116 Fireman B, Black SB, Shinefield HR, et al. (2003). Impact of the pneumococcal conjugate vaccine on otitis media. Pediatric Infectious Disease Journal.
117 Firmansyah A, Dwipoerwantoro PG, Kadim M, et al. (2011). Improved growth of toddlers fed a milk containing synbiotics. Asia Pacific Journal of Clinical Nutrition.
118 Fischer TK, Anh DD, Antil L, et al. (2005). Health care costs of diarrheal disease and estimates of the cost-effectiveness of rotavirus vaccination in Vietnam. Journal of Infectious Diseases.
119 Fischer TK, Gentsch JR. (2004). Rotavirus typing methods and algorithms. Reviews in Medical Virology.
120 Fischer TK, Viboud C, Parashar U, et al. (2007). Hospitalizations and deaths from diarrhea and rotavirus among children <5 years of age in the United States, 1993-2003. Journal of Infectious Diseases.
121 Fleming DM, Verlander NQ, Elliot AJ, et al. (2010). An assessment of the effect of statin use on the incidence of acute respiratory infections in England during winters 1998-1999 to 2005-2006. Epidemiology and Infection.
122 Flores AR, Szilagyi PG, Auinger P, et al. (2010). Estimated burden of rotavirus-associated diarrhea in ambulatory settings in the United States. Pediatrics.
123 Forstner C, Plefka S, Tobudic S, et al. (2012). Effectiveness and immunogenicity of pneumococcal vaccination in splenectomized and functionally asplenic patients. Vaccine.
124 Foster DA, Talsma A, Furumotodawson A, et al. (1992). Influenza Vaccine Effectiveness in Preventing Hospitalization for Pneumonia in the Elderly. American Journal of Epidemiology.
125 Fox PG, Kumchum S. (1996). Caring for Myanmar refugees in Thailand. International Nursing Review.
126 France EK, Smith-Ray R, McClure D, et al. (2006). Impact of maternal influenza vaccination during pregnancy on the incidence of acute respiratory illness visits among infants. Arch Pediatr Adolesc Med.
127 Frasch CE, Hiner EE, Gross TP. (1991). Haemophilus b disease after vaccination with Haemophilus b polysaccharide or conjugate vaccine. American Journal of Diseases of Children.
128 French N, Gilks CF, Mujugira A, et al. (1998). Pneumococcal vaccination in HIV-1-infected adults in Uganda: Humoral response and two vaccine failures. Aids.
129 French N, Nakiyingi J, Carpenter LM, et al. (2000). 23-valent pneumococcal polysaccharide vaccine in HIV-1-infected Ugandan adults: double-blind, randomised and placebo controlled trial. Lancet.
130 Frenck RW, Yeh S. (2012). The development of 13-valent pneumococcal conjugate vaccine and its possible use in adults. Expert Opinion on Biological Therapy.
131 Fritzell B, Fletcher MA. (2011). Pneumococcal polysaccharide-protein (CRM(197)) conjugate vaccines, 7- or 9-valent, in the 2 + 1 schedule. Expert Review of Vaccines.
132 Furumoto A, Ohkusa Y, Chen M, et al. (2008). Additive effect of pneumococcal vaccine and influenza vaccine on acute exacerbation in patients with chronic lung disease. Vaccine.
133 Gall RM, Witterick IJ, Shargill NS, et al. (2002). Control of bleeding in endoscopic sinus surgery: use of a novel gelatin-based hemostatic agent. Journal of Otolaryngology.
134 Gatibelza ME, Laroye B, Lombard J, et al. (2009). Management of a ruptured infected abdominal aortic aneurysm and a spondylodiscitis due to Gemella haemolysans. Annals of Vascular Surgery.
135 Gattringer R, Winkler H, Roedler S, et al. (2011). Immunogenicity of a combined schedule of 7-valent pneumococcal conjugate vaccine followed by a 23-valent polysaccharide vaccine in adult recipients of heart or lung transplants. Transplant Infectious Disease.
136 Giles ML, Visvanathan K, Lewin SR, et al. (2012). Chronic Hepatitis B Infection and Pregnancy. Obstetrical & Gynecological Survey.
137 Gilsdorf JR. (1988). Haemophilus influenzae type b vaccine. Indian Journal of Pediatrics.
138 Glanz JM, McClure DL, Magid DJ, et al. (2010). Parental refusal of varicella vaccination and the associated risk of varicella infection in children. Archives of Pediatrics and Adolescent Medicine.
139 Gomez E, Zoth SC, Berinstein A. (2009). Plant-based vaccines for potential human application: A review. Human Vaccines.
140 Govaert TM, Sprenger MJ, Dinant GJ, et al. (1994). Immune response to influenza vaccination of elderly people. A randomized double-blind placebo-controlled trial. Vaccine.
141 Govaert TME, Thijs C, Masurel N, et al. (1994). The Efficacy of Influenza Vaccination in Elderly Individuals - a Randomized Double-Blind Placebo-Controlled Trial. Jama-Journal of the American Medical Association.
142 Greenberg DP, Vadheim CM, Partridge S, et al. (1994). Immunogenicity of Haemophilus-Influenzae Type-B Tetanus Toroid Conjugate Vaccine in Young Infants. Journal of Infectious Diseases.
143 Gross PA, Hermogenes AW, Sacks HS, et al. (1995). The Efficacy of Influenza Vaccine in Elderly Persons - a Metaanalysis and Review of the Literature. Annals of Internal Medicine.
144 Guerra FA. (2007). Delays in immunization have potentially serious health consequences. Pediatric Drugs.
145 Gulland A. (2010). Rotavirus vaccine cuts deaths of Mexican babies from diarrhoea by 40%. British Medical Journal.
146 Gurgel RQ, Ilozue C, Correia JB, et al. (2011). Impact of rotavirus vaccination on diarrhoea mortality and hospital admissions in Brazil. Tropical Medicine and International Health.
147 Guthridge S, McIntyre P, Isaacs D, et al. (2000). Differing serologic responses to an Haemophilus influenzae type b polysaccharide-Neisseria meningitidis outer membrane protein conjugate (PRP-OMPC) vaccine in Australian Aboriginal and Caucasian infants - implications for disease epidemiology. Vaccine.
148 Gutzeit C, Raftery MJ, Peiser M, et al. (2010). Identification of an important immunological difference between virulent varicella-zoster virus and its avirulent vaccine: viral disruption of dendritic cell instruction. Journal of Immunology.
149 Hahne S, van den Hoek A, Baayen D, et al. (2012). Prevention of perinatal hepatitis B virus transmission in the Netherlands, 2003-2007: Children of Chinese mothers are at increased risk of breakthrough infection. Vaccine.
150 Hak E, Grobbee DE, Sanders EAM, et al. (2008). Rationale and design of CAPITA: A RCT of 13-valent conjugated pneumococcal vaccine efficacy among older adults. Netherlands Journal of Medicine.
151 Hak E, Hoes AW, Grobbee DE, et al. (2003). Conventional influenza vaccination is not associated with complications in working-age patients with asthma or chronic obstructive pulmonary disease. American Journal of Epidemiology.
152 Halsey NA. (2001). Safety of combination vaccines: Perception versus reality. Pediatric Infectious Disease Journal.
153 Halsey NA, Abramson JS, Chesney PJ, et al. (1998). Prevention of rotavirus disease: Guidelines for use of rotavirus vaccine. Pediatrics.
154 Hanna JN, Gratten M, Tiley SM, et al. (1997). Pneumococcal vaccination: an important strategy to prevent pneumonia in Aboriginal and Torres Strait Island adults. Australian and New Zealand Journal of Public Health.
155 Hattotuwa KL, Hind CR. (1997). Pneumococcal vaccine. Postgraduate Medical Journal.
156 Healy P, Zochling J, March L. (2008). Immunisation of adult patients with rheumatic diseases. Medicine Today.
157 Heath PT, Booy R, Griffiths H, et al. (2000). Clinical and immunological risk factors associated with haemophilus influenzae type b conjugate vaccine failure in childhood. Clinical Infectious Diseases.
158 Heffelfinger JD, Heckbert SR, Psaty BM, et al. (2006). Influenza vaccination and risk of incident myocardial infarction. Hum Vaccin.
159 Heinonen S, Silvennoinen H, Lehtinen P, et al. (2011). Effectiveness of inactivated influenza vaccine in children aged 9 months to 3 years: an observational cohort study. The Lancet Infectious Diseases.
160 Hendrickson DJ, Blumberg DA, Joad JP, et al. (2008). Five-fold increase in pediatric parapneumonic empyema since introduction of pneumococcal conjugate vaccine. Pediatric Infectious Disease Journal.
161 Hensley E, Briars L. (2010). Closer look at autism and the measles-mumps-rubella vaccine. Journal of the American Pharmacists Association: JAPhA.
162 Heyse JF, Kaplan KM. (2000). The reactogenicity and immunogenicity of commercial Haemophilus influenzae type b conjugate vaccines. European Journal of Pediatrics.
163 Hillman RJ, Giuliano AR, Palefsky JM, et al. (2012). Immunogenicity of the quadrivalent human papillomavirus (type 6/11/16/18) vaccine in males 16 to 26 years old. Clinical & Vaccine Immunology: CVI.
164 Hillman RJ, Giuliano AR, Palefsky JM, et al. (2012). Immunogenicity of the quadrivalent human papillomavirus (type 6/11/16/18) vaccine in males 16 to 26 years old. Clinical & Vaccine Immunology: CVI.
165 Hiner EE, Frasch CE. (1988). Spectrum of disease due to Haemophilus influenzae type b occurring in vaccinated children. Journal of Infectious Diseases.
166 Hiner EE, Frasch CE. (1988). Spectrum of disease due to Haemophilus influenza type b occurring in vaccinated children. Journal of Infectious Diseases.
167 Hoare S. (2003). HIV infection in children--impact upon ENT doctors. International Journal of Pediatric Otorhinolaryngology.
168 Hoft DF, Babusis E, Worku S, et al. (2011). Live and inactivated influenza vaccines induce similar humoral responses, but only live vaccines induce diverse T-cell responses in young children. Journal of Infectious Diseases.
169 Holmes SJ, Lucas AH, Osterholm MT, et al. (1991). Immunoglobulin deficiency and idiotype expression in children developing Haemophilus influenzae type b disease after vaccination with conjugate vaccine. The Collaborative Study Group. JAMA.
170 Hom J, Medwid K. (2011). The low rate of bacterial meningitis in children, ages 6 to 18 months, with simple febrile seizures. Academic Emergency Medicine.
171 Horst D, Ressing ME, Wiertz E. (2011). Exploiting human herpesvirus immune evasion for therapeutic gain: potential and pitfalls. Immunology and Cell Biology.
172 Hoshino Y, Wagner M, Yan XY, et al. (2003). Horizontal transmission of rhesus monkey rotavirus-based quadrivalent vaccine during a phase 3 clinical trial in Caracas, Venezuela. Journal of Infectious Diseases.
173 Hotopf M, David A, Hull L, et al. (2000). Role of vaccinations as risk factors for ill health in veterans of the Gulf war: Cross sectional study. British Medical Journal.
174 Howard PF, McCaw JM, Richmond PC, et al. (2012). Virus detection and its association with symptoms during influenza-like illness in a sample of healthy adults enrolled in a randomised controlled vaccine trial. Influenza and other Respiratory Viruses.
175 Huebner RE, Mbelle N, Forrest B, et al. (2002). Immunogenicity after one, two or three doses and impact on the antibody response to coadministered antigens of a nonavalent pneumococcal conjugate vaccine in infants of Soweto, South Africa. Pediatric Infectious Disease Journal.
176 Hung IFN, Yuen KY. (2011). Dual pneumococcal and influenza vaccination in elderly patients with chronic illnesses: Protective benefits overestimated?. Clinical Infectious Diseases.
177 Huo Z, Miles J, Harris T, et al. (2002). Effect of Pneumovax(registered trademark) II vaccination in high-risk individuals on specific antibody and opsonic capacity against specific and non-specific antigen. Vaccine.
178 Huss A, Scott P, Stuck AE, et al. (2009). Efficacy of pneumococcal vaccination in adults: a meta-analysis. CMAJ Canadian Medical Association Journal.
179 Hviid A, Svanstrom H. (2009). Antibiotic use and intussusception in early childhood. Journal of Antimicrobial Chemotherapy.
180 Hyser JM, Estes MK. (2009). Rotavirus vaccines and pathogenesis: 2008. Current Opinion in Gastroenterology.
181 Inaba H, Hartford CM, Pei D, et al. (2012). Longitudinal analysis of antibody response to immunization in paediatric survivors after allogeneic haematopoietic stem cell transplantation. British Journal of Haematology.
182 Inoue S, Watanuki Y, Kaneko T, et al. (2011). Heterogeneity of the efficacy of the 23-valent pneumococcal polysaccharide vaccine caused by various underlying conditions of chronic pulmonary disease in older patients: prospective cohort study. BMJ Open.
183 Iskander JK, Miller ER, Chen RT. (2004). The role of the vaccine adverse event reporting system (VAERS) in monitoring vaccine safety. Pediatric Annals.
184 Itzler R, Koch G, Matson DO, et al. (2010). Robustness of the healthcare utilization results from the Rotavirus Efficacy and Safety Trial (REST) evaluating the human-bovine (WC3) reassortant pentavalent rotavirus vaccine (RV5). Bmc Pediatrics.
185 Jackowska T, Pluta J. (2012). Routine infant immunization with the 7- and 13-valent pneumococcal conjugate vaccines: current perspective on reduced-dosage regimens. Archives of Medical Science.
186 Jackson LA, Neuzil KM, Yu O, et al. (2003). Effectiveness of pneumococcal polysaccharide vaccine in older adults. N Engl J Med.
187 Jackson LA, Peterson D, Dunn J, et al. (2011). A randomized placebo-controlled trial of acetaminophen for prevention of post-vaccination fever in infants. PLoS ONE.
188 Jackson LA, Yu O, Nelson JC, et al. (2011). Injection site and risk of medically attended local reactions to acellular pertussis vaccine. Pediatrics.
189 Jacobs AL. (2012). Liability and maternal immunization: In utero injury claims in the VICP. American Journal of Obstetrics and Gynecology.
190 Jacobson RM, Swan A, Adegbenro A, et al. (2001). Making vaccines more acceptable - Methods to prevent and minimize pain and other common adverse events associated with vaccines. Vaccine.
191 Jacobson RM, Zabel KS, Poland GA. (2002). The challenge of vaccine safety. Seminars in Pediatric Infectious Diseases.
192 Jaffe S. (2005). New rotavirus vaccines on the horizon. Scientist.
193 Jatana SK, Nair MNG. (2007). Combination vaccines. Medical Journal Armed Forces India.
194 Jefferson T, Rivetti D, Rivetti A, et al. (2005). Efficacy and effectiveness of influenza vaccines in elderly people: a systematic review. Lancet.
195 Jiang T, Li X, Liu W, et al. (2010). Serum antibody response to the novel influenza A (H1N1) virus in the elderly. Clinical Infectious Diseases.
196 Johns MC, Eick AA, Blazes DL, et al. (2010). Seasonal influenza vaccine and protection against pandemic (H1N1) 2009-associated illness among US military personnel. PLoS One.
197 Johnson B, Gargiullo P, Murphy TV, et al. (2012). Factors associated with bowel resection among infants with intussusception in the United States. Pediatric Emergency Care.
198 Johnstone J, Eurich DT, Minhas JK, et al. (2010). Impact of the pneumococcal vaccine on long-term morbidity and mortality of adults at high risk for pneumonia. Clinical Infectious Diseases.
199 Jones RG, Bass JW, Weisse ME, et al. (1991). Antigenuria after immunization with Haemophilus influenzae oligosaccharide CRM(197) conjugate (HbOC) vaccine. Pediatric Infectious Disease Journal.
200 Jones T. (2002). Varivax Merck & Co. Current Opinion in Investigational Drugs.
201 Jones TF, McMillian M, Boothe E, et al. (2010). Hospital discharge data for Guillain-Barre syndrome and influenza A (H1N1) vaccine adverse events. Emerging Infectious Diseases.
202 Justice FA, Nguyen LT, Tran SN, et al. (2011). Recurrent intussusception in infants. Journal of Paediatrics and Child Health.
203 Kamboj KK, Kirchner HL, Kimmel R, et al. (2003). Significant variation in serotype-specific immunogenicity of the seven-valent Streptococcus pneumoniae capsular polysaccharide-CRM197 conjugate vaccine occurs despite vigorous T cell help induced by the carrier protein. Journal of Infectious Diseases.
204 Kansu E. (2005). Late effects of hematopoietic stem cell transplantation. Hematology.
205 Kapikian AZ, Hoshino Y, Chanock RM, et al. (1996). Efficacy of a quadrivalent rhesus rotavirus-based human rotavirus vaccine aimed at preventing severe rotavirus diarrhea in infants and young children. Journal of Infectious Diseases.
206 Kapikian AZ, Vesikari T, Ruuska T, et al. (1992). An update on the ‘Jennerian’ and modified ‘Jennerian’ approach to vaccination of infants and young children against rotavirus diarrhea. Advances in Experimental Medicine and Biology.
207 Kapikian AZ, Wyatt RG, Levine MM. (1983). Oral administration of human rotavirus to volunteers: Indication of illness and correlates of resistance. Journal of Infectious Diseases.
208 Kaplan J. (1998). 1997 USPHS/IDSA report on the prevention of opportunistic infections in patients infected with human immunodeficiency virus. Pediatrics.
209 Karande S, Gogtay NJ, Kshirsagar NA. (2003). Improving Drug Safety Monitoring. Indian Pediatrics.
210 Kawakami K, Ohkusa Y, Kuroki R, et al. (2010). Effectiveness of pneumococcal polysaccharide vaccine against pneumonia and cost analysis for the elderly who receive seasonal influenza vaccine in Japan. Vaccine.
211 Kelly HA, Grant KA, Fielding JE, et al. (2011). Pandemic influenza H1N1 2009 infection in Victoria, Australia: no evidence for harm or benefit following receipt of seasonal influenza vaccine in 2009. Vaccine.
212 Kelso JM. (2009). Update on vaccination guidelines for allergic children. Expert Review of Vaccines.
213 Keyser JS, Derkay CS. (1994). Haemophilus influenzae type B epiglottitis after immunization with HbOC conjugate vaccine. American Journal of Otolaryngology.
214 Kharbanda EO, Vazquez-Benitez G, Shi WX, et al. (2012). Assessing the safety of influenza immunization during pregnancy: the Vaccine Safety Datalink. American Journal of Obstetrics & Gynecology.
215 Kidd S, Goodson JL, Aramburu J, et al. (2011). Poliomyelitis outbreaks in Angola genetically linked to India: risk factors and implications for prevention of outbreaks due to wild poliovirus importations. Vaccine.
216 King JC, Vink PE, Farley JJ, et al. (1996). Comparison of the safety and immunogenicity of a pneumococcal conjugate with a licensed polysaccharide vaccine in human immunodeficiency virus and non-human immunodeficiency virus-infected children. Pediatric Infectious Disease Journal.
217 Kling S. (2009). Vaccination and ethical issues. Current Allergy and Clinical Immunology.
218 Kobayashi M, Thompson J, Tollefson SJ, et al. (1994). Tetravalent rhesus rotavirus vaccine in young infants. Journal of Infectious Diseases.
219 Koivula I, Sten M, Leinonen M, et al. (1997). Clinical efficacy of pneumococcal vaccine in the elderly: A randomized, single-blind population-based trial. American Journal of Medicine.
220 Kreimer AR, Gonzalez P, Katki HA, et al. (2011). Efficacy of a bivalent HPV 16/18 vaccine against anal HPV 16/18 infection among young women: a nested analysis within the Costa Rica Vaccine Trial. Lancet Oncology.
221 Krueger JG, Ochs HD, Patel P, et al. (2008). Effect of therapeutic integrin (CD11a) blockade with efalizumab on immune responses to model antigens in humans: Results of a randomized, single blind study. Journal of Investigative Dermatology.
222 Kuehn BM. (2008). CDC panel recommends vaccine for smokers; reviews HPV safety data. JAMA.
223 Kuehn BM. (2010). FDA: Benefits of rotavirus vaccination outweigh potential contamination risk. JAMA - Journal of the American Medical Association.
224 Kuehn BM. (2012). Immunization recommendations expanded for hepatitis B, HPV, pertussis vaccines. JAMA - Journal of the American Medical Association.
225 Kulkarni PS, Sapru A, Bavdekar A, et al. (2011). Immunogenicity of two diphtheria-tetanus-whole cell pertussis-hepatitis B vaccines in infants: A comparative trial. Human Vaccines.
226 Kwon S, Kim S, Cho Mh, et al. (2012). Neurologic complications and outcomes of pandemic (H1N1) 2009 in Korean children. Journal of Korean Medical Science.
227 Kyaw MH, Bramley JC, Chalmers J, et al. (2001). Pneumococcal vaccination: opinion of general practitioners and hospital doctors in Scotland, 1999-2000. Communicable Disease & Public Health.
228 Ladhani S, Heath PT, Ramsay ME, et al. (2009). Long-term immunological follow-up of children with haemophilus influenzae serotype b vaccine failure in the United Kingdom. Clinical Infectious Diseases.
229 Lambert SB, Faux CE, Hall L, et al. (2009). Early evidence for direct and indirect effects of the infant rotavirus vaccine program in Queensland. Medical Journal of Australia.
230 Lamontagne F, Garant MP, Carvalho JC, et al. (2008). Pneumococcal vaccination and risk of myocardial infarction. CMAJ Canadian Medical Association Journal.
231 Lanata CF, Black RE, Del Aguila R, et al. (1989). Protection of Peruvian children against rotavirus diarrhea of specific serotypes by one, two, or three doses of the RIT 4237 attenuated bovine rotavirus vaccine. Journal of Infectious Diseases.
232 Landrum ML, Hullsiek KH, Ganesan A, et al. (2010). Hepatitis B vaccination and risk of hepatitis B infection in HIV-infected individuals. Aids.
233 Lanzieri TM, Linhares AC, Costa I, et al. (2011). Impact of rotavirus vaccination on childhood deaths from diarrhea in Brazil. International Journal of Infectious Diseases.
234 Lashkari HP, El Bashir H. (2010). Immunisations among school leavers: is there a place for measles-mumps-rubella vaccine?. Bulletin Europeen sur les Maladies Transmissibles.
235 Laupland KB, Fisman DN. (2009). Zoster vaccination: A new opportunity for adult immunization. Canadian Journal of Infectious Diseases and Medical Microbiology.
236 Lazarsfeld R, Cavallario S. (2010). Two adult vaccination survey papers. Vaccine.
237 Lei T, Siu KL, Kok KH, et al. (2012). Anti-ganglioside antibodies were not detected in human subjects infected with or vaccinated against 2009 pandemic influenza A (H1N1) virus. Vaccine.
238 Leonardi S, La Rosa M. (2010). Are Hepatitis B Virus and Celiac Disease Linked?. Hepatitis Monthly.
239 Levin MJ, Oxman MN, Zhang JH, et al. (2008). Varicella-zoster virus-specific immune responses in elderly recipients of a herpes zoster vaccine. J Infect Dis.
240 Lewindon PJ, Harkness L, Lewindon N. (1998). Randomised controlled trial of sucrose by mouth for the relief of infant crying after immunisation. Archives of Disease in Childhood.
241 Lewis KDC, Dallas MJ, Victor JC, et al. (2012). Comparison of two clinical severity scoring systems in two multi-center, developing country rotavirus vaccine trials in Africa and Asia. Vaccine.
242 Lewis RF, Kisakye A, Gessner BD, et al. (2008). Action for child survival: elimination of Haemophilus influenzae type b menigitis in Uganda. Bulletin of the World Health Organization.
243 Liang X, Zhang Y, Xu W, et al. (2006). An outbreak of poliomyelitis caused by type 1 vaccine-derived poliovirus in China. Journal of Infectious Diseases.
244 Licciardi PV, Balloch A, Russell FM, et al. (2010). Antibodies to serotype 9V exhibit novel serogroup cross-reactivity following infant pneumococcal immunization. Vaccine.
245 Linhares AC, Gabbay YB, Mascarenhas JDP, et al. (1996). Immunogenicity, safety and efficacy of tetravalent rhesus-human, reassortant rotavirus vaccine in Belem, Brazil. Bulletin of the World Health Organization.
246 Linhares AC, Lanata CF, Hausdorff WP, et al. (1999). Reappraisal of the Peruvian and Brazilian lower titer tetravalent rhesus-human reassortant rotavirus vaccine efficacy trials: analysis by severity of diarrhea. Pediatric Infectious Disease Journal.
247 Linhares AC, Stupka JA, Ciapponi A, et al. (2011). Burden and typing of rotavirus group A in Latin America and the Caribbean: Systematic review and meta-analysis. Reviews in Medical Virology.
248 Liu H. (2007). The changing landscape of global vaccine development and market potential. BioPharm International.
249 Liu IF, Huang CC, Chan WL, et al. (2012). Effects of annual influenza vaccination on mortality and hospitalization in elderly patients with ischemic heart disease: A nationwide population-based study. Preventive Medicine.
250 Long CB, Ramos I, Rastogi D, et al. (2012). Humoral and cell-mediated immune responses to monovalent 2009 influenza A/H1N1 and seasonal trivalent influenza vaccines in high-risk children. Journal of Pediatrics.
251 Lopert R. (2010). Benefit and risks of trivalent 2010 seasonal influenza vaccine in Australian children. Eurosurveillance.
252 Lopez-Macias C. (2012). Virus-like particle (VLP)-based vaccines for pandemic influenza: Performance of a VLP vaccine during the 2009 influenza pandemic. Human Vaccines and Immunotherapeutics.
253 Louik C, Chambers C, Jacobs D, et al. (2013). Influenza vaccine safety in pregnancy: can we identify exposures?. Pharmacoepidemiology & Drug Safety.
254 Macartney KK, Porwal M, Dalton D, et al. (2011). Decline in rotavirus hospitalisations following introduction of Australia's national rotavirus immunisation programme. Journal of Paediatrics and Child Health.
255 Madhi SA, Kirsten M, Louw C, et al. (2012). Efficacy and immunogenicity of two or three dose rotavirus-vaccine regimen in South African children over two consecutive rotavirus-seasons: A randomized, double-blind, placebo-controlled trial. Vaccine.
256 Madhi SA, Kuwanda L, Cutland C, et al. (2005). Quantitative and qualitative antibody response to pneumococcal conjugate vaccine among African human immunodeficiency virus-infected and uninfected children. Pediatric Infectious Disease Journal.
257 Magnus MC, Vestrheim DF, Nystad W, et al. (2012). Decline in Early Childhood Respiratory Tract Infections in the Norwegian Mother and Child Cohort Study After Introduction of Pneumococcal Conjugate Vaccination. Pediatric Infectious Disease Journal.
258 Malakoff D. (2000). Aluminum is put on trial as a vaccine booster. Science.
259 Mangtani P, Shah A, Roberts JA. (2007). Validation of influenza and pneumococcal vaccine status in adults based on self-report. Epidemiology & Infection.
260 Manoff SB, Liss C, Caulfield MJ, et al. (2010). Revaccination with a 23-valent pneumococcal polysaccharide vaccine induces elevated and persistent functional antibody responses in adults aged 65 > or = years. J Infect Dis.
261 Mansoor O. (1994). DTPH vaccine. N Z Med J.
262 Marchetti F, Assael B, Gabutti G, et al. (2009). Monitoring the rate of hospitalization before rotavirus immunization in Italy utilizing ICD9-CM regional databases. Human Vaccines.
263 Marlow RD, Finn A. (2012). The promise of immunisation against rotavirus. Archives of Disease in Childhood.
264 Maruyama T, Taguchi O, Niederman MS, et al. (2010). Efficacy of 23-valent pneumococcal vaccine in preventing pneumonia and improving survival in nursing home residents: double blind, randomised and placebo controlled trial. BMJ.
265 Mascarenhas JDP, Leite JPG, Gabbay YB, et al. (2002). Tetravalent rhesus-human rotavirus vaccine (RRV-TV) in Belem, Brazil: Efficacy against prevailing P and G genotypes. Journal of Tropical Pediatrics.
266 Mato SP, Perrin K, Scardino D, et al. (2002). Evaluation of rotavirus vaccine effectiveness in a pediatric group practice. American Journal of Epidemiology.
267 Matys K, Mallary S, Bautista O, et al. (2012). Mother-infant transfer of anti-human papillomavirus (HPV) antibodies following vaccination with the quadrivalent HPV (type 6/11/16/18) virus-like particle vaccine. Clinical & Vaccine Immunology: CVI.
268 Mazzone PJ, Mossad SB, Mawhorter SD, et al. (2001). The humoral immune response to influenza vaccination in lung transplant patients. European Respiratory Journal.
269 McKenney D, Pouliot KL, Wang Y, et al. (1999). Broadly protective vaccine for Staphylococcus aureus based on an in vivo-expressed antigen. Science.
270 Meier P. (1990). Polio trial: An early efficient clinical trial. Statistics in Medicine.
271 Merlo HC, Vaid SK, Meyer A, et al. (2011). Is it safe to vaccinate children against varicella while they're in close contact with a pregnant woman?. Journal of Family Practice.
272 Meszner Z, Balogh A, Banyai K, et al. (2008). The clinical burden of rotavirus disease: Retrospective analysis of infant and childhood gastroenteritis in seven countries in central and eastern Europe. Pediatric Infectious Disease Journal.
273 Migasena S, Simasathien S, Samakoses R, et al. (1995). Simultaneous administration of oral rhesus-human reassortant tetravalent (RRV-TV) rotavirus vaccine and oral poliovirus vaccine (OPV) in Thai infants. Vaccine.
274 Milanovic M, Stojanovich L, Djokovic A, et al. (2013). Influenza vaccination in autoimmune rheumatic disease patients. Tohoku Journal of Experimental Medicine.
275 Mills OF, Rhoads GG. (1996). The contribution of the case-control approach to vaccine evaluation: Pneumococcal and Haemophilus influenzae type B PRP vaccines. Journal of Clinical Epidemiology.
276 Mishra D, John TJ. (2000). Hib, measles and varicella vaccine. Indian Pediatrics.
277 Moberley S, Holden J, Tatham DP, et al. (2013). Vaccines for preventing pneumococcal infection in adults. Cochrane Database of Systematic Reviews.
278 Moore SR, Lima AAM, Guerrant RL. (2011). Preventing 5 million child deaths from diarrhea in the next 5 years. Nature Reviews Gastroenterology and Hepatology.
279 Moore SW, Kirsten M, Muller EW, et al. (2010). Retrospective Surveillance of Intussusception in South Africa, 1998-2003. Journal of Infectious Diseases.
280 Morris SK, Awasthi S, Khera A, et al. (2012). La mortalite du rotavirus en Inde: Estimations fondaes sur une enquete nationale representative des deces par diarrheae. Bulletin of the World Health Organization.
281 Moss SJ, Fenton AC, Toomey JA, et al. (2010). Responses to a Conjugate Pneumococcal Vaccine in Preterm Infants Immunized at 2, 3, and 4 Months of Age. Clinical and Vaccine Immunology.
282 Moulton LH, Staat MA, Santosham M, et al. (1998). The protective effectiveness of natural rotavirus infection in an American Indian population. Journal of Infectious Diseases.
283 Moyo S, Hawkridge T, Mahomed H, et al. (2007). Determining causes of mortality in children enrolled in a vaccine field trial in a rural area in the Western Cape Province of South Africa. Journal of Paediatrics & Child Health.
284 Mrozek-Budzyn D, Kieltyka A, Majewska R, et al. (2013). Measles, mumps and rubella (MMR) vaccination has no effect on cognitive development in children - The results of the Polish prospective cohort study. Vaccine.
285 Muhsen K, Chodick G, Goren S, et al. (2010). The uptake of rotavirus vaccine and its effectiveness in preventing acute gastroenteritis in the community. Vaccine.
286 Muhsen K, Shulman L, Kasem E, et al. (2010). Effectiveness of rotavirus vaccines for prevention of rotavirus gastroenteritis-associated hospitalizations in Israel A case-control study. Human Vaccines.
287 Mulholland K, Hilton S, Adegbola R, et al. (1997). Randomised trial of Haemophilus influenzae type-b tetanus protein conjugate for prevention of pneumonia and meningitis in Gambian infants. Lancet.
288 Munos MK, Fischer Walker CL, Black RE. (2010). The effect of rotavirus vaccine on diarrhoea mortality. International Journal of Epidemiology.
289 Munoz N, Kjaer SK, Sigurdsson K, et al. (2010). Impact of Human Papillomavirus (HPV)-6/11/16/18 Vaccine on All HPV-Associated Genital Diseases in Young Women. Journal of theNational Cancer Institute.
290 Musawi MA, Alhindi SJ, Abu-Elyazeed R, et al. (2010). Incidence of intussusception: Five-year hospital-based retrospective review. Bahrain Medical Bulletin.
291 Musher DM, Rueda AM, Nahm MH, et al. (2008). Initial and subsequent response to pneumococcal polysaccharide and protein-conjugate vaccines administered sequentially to adults who have recovered from pneumococcal pneumonia. Journal of Infectious Diseases.
292 Naidus E, Damon L, Schwartz BS, et al. (2012). Experience with use of Zostavax (R) in patients with hematologic malignancy and hematopoietic cell transplant recipients. American Journal of Hematology.
293 Nates SV, Frias M, Belfiore S, et al. (2011). Effect on seroprevalence of anti-poliovirus antibodies and on vaccination coverage of the implementation of a DTwP-IPV-Hib vaccination programme in a South American city. Epidemiology and Infection.
294 Navar-Boggan AM, Halsey NA, Golden WC, et al. (2010). Risk of fever and sepsis evaluations after routine immunizations in the neonatal intensive care unit. Journal of Perinatology.
295 Nelson CM, Sutanto A, Gessner BD, et al. (2000). Age- and cause-specific childhood mortality in Lombok, Indonesia, as a factor for determining the appropriateness of introducing Haemophilus influenzae type b and pneumococcal vaccines. Journal of Health, Population & Nutrition.
296 Ng SC, Woodrow S, Patel N, et al. (2012). Role of genetic and environmental factors in British twins with inflammatory bowel disease. Inflammatory Bowel Diseases.
297 Nichol KL. (1998). Ten-year durability and success of an organized program to increase influenza and pneumococcal vaccination rates among high-risk adults. American Journal of Medicine.
298 Nichol KL, MacDonald R, Hauge M. (1997). Side effects associated with pneumococcal vaccination. American Journal of Infection Control.
299 Nightingale SL. (1993). Two new child vaccines licenced: Combination DTP and Haemophilus b conjugate vaccine. Journal of the American Medical Association.
300 Nokleby H. (2006). Vaccination and anaphylaxis. Current Allergy and Asthma Reports.
301 Novadzki IM, Rosario Filho N. (2010). Anaphylaxis associated with the vaccine against measles, mumps and rubella. Revista de Saude Publica.
302 Novadzki IM, Rosario N, Zanoni G, et al. (2010). Hypersensitivity reactions following measles-mumps-rubella vaccine and dextran-specific IgG response. Allergologia et Immunopathologia.
303 Obaro S. (2010). Rotavirus vaccine efficacy in African and Asian countries. The Lancet.
304 Offit P, Plotkin SA, Halsey NA. (2000). Preventing harm from thimerosal in vaccines [3] (multiple letter). Journal of the American Medical Association.
305 Offit PA. (1998). The rotavirus vaccine. Journal of Clinical Virology.
306 Offit PA, Clark HF. (1999). The rotavirus vaccine. Current Opinion in Pediatrics.
307 O'Grady KAF, Lee KJ, Carlin JB, et al. (2010). Increased risk of hospitalization for acute lower respiratory tract infection among australian indigenous infants 5-23 months of age following pneumococcal vaccination: A cohort study. Clinical Infectious Diseases.
308 Okabayashi T, Hanazaki K. (2008). Overwhelming postsplenectomy infection syndrome in adults - A clinically preventable disease. World Journal of Gastroenterology.
309 Ortqvist A, Berggren I, Insulander M, et al. (2011). Effectiveness of an adjuvanted monovalent vaccine against the 2009 pandemic strain of influenza A(H1N1)v, in Stockholm county, Sweden. Clinical Infectious Diseases.
310 Ortqvist A, Granath F, Askling J, et al. (2007). Influenza vaccination and mortality: prospective cohort study of the elderly in a large geographical area. European Respiratory Journal.
311 Ortqvist A, Hedlund J, Burman LA, et al. (1998). Randomised trial of 23-valent pneumococcal capsular polysaccharide vaccine in prevention of pneumonia in middle-aged and elderly people. Swedish Pneumococcal Vaccination Study Group. Lancet.
312 Osendarp SJM, Fuchs GJ, van Raaij JMA, et al. (2006). The effect of zinc supplementation during pregnancy on immune response to hib and BCG vaccines in Bangladesh. Journal of Tropical Pediatrics.
313 Osterholm MT, Kelley NS, Sommer A, et al. (2012). Efficacy and effectiveness of influenza vaccines: A systematic review and meta-analysis. The Lancet Infectious Diseases.
314 Ott U, Sauerbrei A, Lange J, et al. (2012). Serological response to influenza A H1N1 vaccine (Pandemrix) and seasonal influenza vaccine 2009/2010 in renal transplant recipients and in hemodialysis patients. Medical Microbiology & Immunology.
315 Otto S, Mahner B, Kadow I, et al. (2000). General non-specific morbidity is reduced after vaccination within the third month of life--the Greifswald study. Journal of Infection.
316 Ozkaya E, Cambaz N, Kolsuz LD, et al. (2011). Vaccination coverage and risk factors for incomplete vaccination in children with recurrent wheeze. Allergologia et Immunopathologia.
317 Pang XL, Joensuu J, Hoshino Y, et al. (1999). Rotaviruses detected by reverse transcription polymerase chain reaction in acute gastroenteritis during a trial of rhesus-human reassortant rotavirus tetravalent vaccine: implications for vaccine efficacy analysis. Journal of Clinical Virology.
318 Parashar UD, Bresee JS, Gentsch JR, et al. (1998). Rotavirus. Emerging Infectious Diseases.
319 Parashar UD, Glass RI. (2009). Rotavirus vaccines--early success, remaining questions. New England Journal of Medicine.
320 Parashar UD, Holman RC, Cummings KC, et al. (2000). Trends in intussusception-associated hospitalizations and deaths among US infants. Pediatrics.
321 Parke JC, Schneerson R, Reimer C, et al. (1991). Clinical and Immunological Responses to Haemophilus-Influenzae Type-B-Tetanus Toxoid Conjugate Vaccine in Infants Injected at 3, 5, 7, and 18 Months of Age. Journal of Pediatrics.
322 Parsons HK, Metcalf SC, Tomlin K, et al. (2007). Invasive pneumococcal disease and the potential for prevention by vaccination in the United Kingdom. Journal of Infection.
323 Patel M, Pedreira C, De Oliveira LH, et al. (2009). Association between pentavalent rotavirus vaccine and severe rotavirus diarrhea among children in Nicaragua. JAMA - Journal of the American Medical Association.
324 Patel M, Pedreira C, De Oliveira LH, et al. (2012). Duration of protection of pentavalent rotavirus vaccination in Nicaragua. Pediatrics.
325 Paulke-Korinek M, Rendi-Wagner P, Kundi M, et al. (2010). Universal mass vaccination against rotavirus gastroenteritis: Impact on hospitalization rates in Austrian children. Pediatric Infectious Disease Journal.
326 Pavli A, Maltezou HC. (2011). Travelling to Greece for the summer 2011 Special Olympics. Travel Medicine and Infectious Disease.
327 Paximadi E, Karakasiliotis I, Mamuris Z, et al. (2006). Genomic analysis of recombinant Sabin clinical isolates. Virus Genes.
328 Peltola H. (1997). Haemophilus influenzae type b disease and vaccination in Latin America and the Caribbean. Pediatric Infectious Disease Journal.
329 Percheson PB, Trepanier P, Dugre R, et al. (1999). A Phase I, randomized controlled clinical trial to study the reactogenicity and immunogenicity of a new split influenza vaccine derived from a non-tumorigenic cell line. Dev Biol Stand.
330 Perez N, Iannicelli JC, Girard-Bosch C, et al. (2010). Effect of probiotic supplementation on immunoglobulins, isoagglutinins and antibody response in children of low socio-economic status. European Journal of Nutrition.
331 Perez-Schael I, Blanco M, Vilar M, et al. (1990). Clinical studies of a quadrivalent rotavirus vaccine in Venezuelan infants. Journal of Clinical Microbiology.
332 Petersen J. (2011). HBV treatment and pregnancy. Journal of Hepatology.
333 Phrommintikul A, Kuanprasert S, Wongcharoen W. (2011). Influenza vaccination reduced cardiovascular events in patients hospitalized with an acute coronary syndrome. Annals of Internal Medicine.
334 Phrommintikul A, Kuanprasert S, Wongcharoen W, et al. (2011). Influenza vaccination reduces cardiovascular events in patients with acute coronary syndrome. European Heart Journal.
335 Pierson DL, Mehta SK, Gilden D, et al. (2011). Varicella zoster virus DNA at inoculation sites and in saliva after Zostavax immunization. Journal of Infectious Diseases.
336 Pilishvili T, Zell ER, Farley MM, et al. (2010). Risk factors for invasive pneumococcal disease in children in the era of conjugate vaccine use. Pediatrics.
337 Pittman PR, Coonan KM, Gibbs PH, et al. (2004). Long-term health effects of repeated exposure to multiple vaccines. Vaccine.
338 Pliaka V, Dedepsidis E, Kyriakopoulou Z, et al. (2010). Growth kinetic analysis of bi-recombinant poliovirus vaccine strains. Virus Genes.
339 Pluta RM, Lynm C, Golub RM. (2011). Guillain-Barre syndrome. JAMA - Journal of the American Medical Association.
340 Pool V, Braun MM, Kelso JM, et al. (2002). Prevalence of anti-gelatin IgE antibodies in people with anaphylaxis after measles-mumps rubella vaccine in the United States. Pediatrics.
341 Powell ND, Allen RG, Hufnagle AR, et al. (2011). Stressor-Induced Alterations of Adaptive Immunity to Vaccination and Viral Pathogens. Immunology and Allergy Clinics of North America.
342 Puig-Barbera J, Diez-Domingo J, Hoyos SP, et al. (2004). Effectiveness of the MF59-adjuvanted influenza vaccine in preventing emergency admissions for pneumonia in the elderly over 64 years of age. Vaccine.
343 Rabbone I, Scaramuzza AE, Iafusco D, et al. (2011). Pandemic influenza vaccination coverage in children with type 1 diabetes: analysis from seven Italian centers. Human Vaccines.
344 Ratajczak HV. (2011). Theoretical aspects of autism: Causes-A review. Journal of Immunotoxicology.
345 Rhorer J, Ambrose CS, Dickinson S, et al. (2009). Efficacy of live attenuated influenza vaccine in children: A meta-analysis of nine randomized clinical trials. Vaccine.
346 Robinson CG, Hernanz-Schulman M, Zhu Y, et al. (2004). Evaluation of anatomic changes in young children with natural rotavirus infection: is intussusception biologically plausible?. Journal of Infectious Diseases.
347 Robke JT, Woods M, Heitz S. (2002). Pharmacist impact on pneumococcal vaccination rates through incorporation of immunization assessment into critical pathways in an acute care setting. Hospital Pharmacy.
348 Rodenburg GD, van Gils EJM, Veenhoven RH, et al. (2010). Comparability of antibody response to a booster dose of 7-valent pneumococcal conjugate vaccine in infants primed with either 2 or 3 doses. Vaccine.
349 Rogalewski A, Kraus J, Hasselblatt M, et al. (2007). Improvement of advanced postvaccinal demyelinating encephalitis due to plasmapheresis. Neuropsychiatric Disease and Treatment.
350 Rojas OL, Caicedo L, Guzman C, et al. (2007). Evaluation of circulating intestinally committed memory B cells in children vaccinated with attenuated human rotavirus vaccine. Viral Immunology.
351 Rose J, Hawthorn RL, Watts B, et al. (2009). Public health impact and cost effectiveness of mass vaccination with live attenuated human rotavirus vaccine (RIX4414) in India: Model based analysis. BMJ.
352 Rowe IA, Parker R, Armstrong MJ, et al. (2012). Hepatitis A virus vaccination in persons with hepatitis C virus infection: Consequences of quality measure implementation. Hepatology.
353 Ruggeberg JU, Collins C, Clarke P, et al. (2007). Immunogenicity and induction of immunological memory of the heptavalent pneumococcal conjugate vaccine in preterm UK infants. Vaccine.
354 Russell FM, Balloch A, Tang MLK, et al. (2009). Immunogenicity following one, two, or three doses of the 7-valent pneumococcal conjugate vaccine. Vaccine.
355 Saaka M, Okoko BJ, Kohberger RC, et al. (2008). Immunogenicity and serotype-specific efficacy of a 9-valent pneumococcal conjugate vaccine (PCV-9) determined during an efficacy trial in The Gambia. Vaccine.
356 Santosham M, Rivin B, Wolff M, et al. (1992). Prevention of Haemophilus-Influenzae Type-B Infections in Apache and Navajo Children. Journal of Infectious Diseases.
357 Schaffer SA, Husain S, Delgado DH, et al. (2011). Impact of Adjuvanted H1N1 Vaccine on Cell-Mediated Rejection in Heart Transplant Recipients. American Journal of Transplantation.
358 Scheifele D, Bjornsen GL, Arcand T, et al. (1989). Antigenuria after receipt of Haemophilus b diphtheria toxoid conjugate vaccine. Pediatric Infectious Disease Journal.
359 Schneider L, Weinberg A, Boguniewicz M, et al. (2010). Immune response to varicella vaccine in children with atopic dermatitis compared with nonatopic controls. Journal of Allergy & Clinical Immunology.
360 Schneider LC, Insel RA, Howie G, et al. (1990). Response to a Haemophilus influenzae type b diphtheria CRM(197) conjugate vaccine in children with a defect of antibody production to Haemophilus influenzae type b polysaccharide. Journal of Allergy and Clinical Immunology.
361 Schonbeck Y, Sanders EAM, Hoes AW, et al. (2005). Rationale and design of the prevention of respiratory infections and management in children (PRIMAKid) study - A randomized controlled trial on the effectiveness and costs of combined influenza and pneumococcal vaccination in pre-school children with recurrent respiratory tract infections. Vaccine.
362 Schutz K, Hughes RG, Parker A, et al. (2012). Kinetics of IgM and IgA Antibody Response to 23-Valent Pneumococcal Polysaccharide Vaccination in Healthy Subjects. Journal of Clinical Immunology.
363 Schwartz JL. (2012). The first rotavirus vaccine and the politics of acceptable risk. Milbank Quarterly.
364 Scott JAG, Ojal J, Ashton L, et al. (2011). Pneumococcal conjugate vaccine given shortly after birth stimulates effective antibody concentrations and primes immunological memory for sustained infant protection. Clinical Infectious Diseases.
365 Scott JR, Millar EV, Lipsitch M, et al. (2012). Impact of more than a decade of pneumococcal conjugate vaccine use on carriage and invasive potential in native American communities. Journal of Infectious Diseases.
366 Shankar S, Dhiman P, Kumar PG. (2010). Early undifferentiated arthritis in India: A six month follow up study. Indian Journal of Rheumatology.
367 Sharts-Hopko NC. (1994). HIB: a new conjugate and a combination vaccine. MCN Am J Matern Child Nurs.
368 Shaw RD, Fong KJ, Losonsky GA, et al. (1987). Epitope-specific immune responses to rotavirus vaccination. Gastroenterology.
369 Shehab ZM, Azimi P, Asmar BI, et al. (1991). Immunogenicity and reactogenicity of Haemophilus influenzae Type b - meningococcus group B outer membrane protein conjugate vaccine in children 2-60 months of age. Scandinavian Journal of Infectious Diseases.
370 Shih A, Quinley J, Lee TK, et al. (2002). Assessing pneumococcal revaccination safety among New York State Medicare beneficiaries. Public Health Reports.
371 Shin S, Anh DD, Zaman K, et al. (2012). Immunogenicity of the pentavalent rotavirus vaccine among infants in two developing countries in Asia, Bangladesh and Vietnam. Vaccine.
372 Shinefield HR, Black S. (2000). Efficacy of pneumococcal conjugate vaccines in large scale field trials. Pediatric Infectious Disease Journal.
373 Shinefield HR, Pichichero ME. (2006). Rotavirus vaccine (RotaTeq(registered trademark)): Profile report. Drugs and Therapy Perspectives.
374 Short JA, Van Der Walt JH, Zoanetti DC. (2006). Immunization and anesthesia - An international survey. Paediatric Anaesthesia.
375 Siber GR, Chang I, Baker S, et al. (2007). Estimating the protective concentration of anti-pneumococcal capsular polysaccharide antibodies. Vaccine.
376 Silfverdal SA, Berg S, Hemlin C, et al. (2009). The cost-burden of paediatric pneumococcal disease in Sweden and the potential cost-effectiveness of prevention using 7-valent pneumococcal vaccine. Vaccine.
377 Silk H, Zora J, Goldstein J, et al. (1998). Response to pneumococcal immunization in children with and without recurrent infections. Journal of Asthma.
378 Silvers LE, Ellenberg SS, Wise RP, et al. (2001). The epidemiology of fatalities reported to the Vaccine Adverse Event Reporting System 1990-1997. Pharmacoepidemiology and Drug Safety.
379 Simon JK, Ramirez K, Cuberos L, et al. (2011). Mucosal IgA responses in healthy adult volunteers following intranasal spray delivery of a live attenuated measles vaccine. Clinical and Vaccine Immunology.
380 Simpson CR, Ritchie LD, Robertson C, et al. (2012). Effectiveness of H1N1 vaccine for the prevention of pandemic influenza in Scotland, UK: a retrospective observational cohort study. The Lancet Infectious Diseases.
381 Sinisalo M, Vilpo J, Itala M, et al. (2007). Antibody response to 7-valent conjugated pneumococcal vaccine in patients with chronic lymphocytic leukaemia. Vaccine.
382 Siscovick DS, Raghunathan TE, Lin D, et al. (2000). Influenza vaccination and the risk of primary cardiac arrest. Am J Epidemiol.
383 Skowronski DM, de Serres G, Crowcroft NS, et al. (2010). Association between the 2008-09 seasonal influenza vaccine and pandemic H1N1 illness during spring-summer 2009: Four observational studies from Canada. PLoS Medicine.
384 Smith LM, Brassard P, Kwong JC, et al. (2011). Factors associated with initiation and completion of the quadrivalent human papillomavirus vaccine series in an ontario cohort of grade 8 girls. BMC Public Health.
385 Smith-Norowitz TA, Wong D, Kusonruksa M, et al. (2011). Long term persistence of IgE anti-influenza virus antibodies in pediatric and adult serum post vaccination with influenza virus vaccine. International Journal of Medical Sciences.
386 Sood SK, Daum RS. (1990). Disease caused by Haemophilus influenzae type b in the immediate period after homologous immunization: Immunologic investigation. Pediatrics.
387 Spackova M, Wiese-Posselt M, Dehnert M, et al. (2010). Comparative varicella vaccine effectiveness during outbreaks in day-care centres. Vaccine.
388 Staat MA, Cortese MM, Bresee JS, et al. (2006). Rhesus rotavirus vaccine effectiveness and factors associated with receipt of vaccine. Pediatric Infectious Disease Journal.
389 Stanley M. (2007). Prophylactic HPV vaccines: prospects for eliminating ano-genital cancer. Br J Cancer.
390 Stassen PM, Sanders JS, Kallenberg CG, et al. (2008). Influenza vaccination does not result in an increase in relapses in patients with ANCA-associated vasculitis. Nephrol Dial Transplant.
391 Steele AD, Neuzil KM, Cunliffe NA, et al. (2012). Human rotavirus vaccine Rotarix(trademark) provides protection against diverse circulating rotavirus strains in African infants: a randomized controlled trial. BMC Infectious Diseases.
392 Stenius-Aarniala B, Huttunen JK, Pyhala R, et al. (1986). Lack of clinical exacerbations in adults with chronic asthma after immunization with killed influenza virus. Chest.
393 Stojanovich L. (2006). Influenza vaccination of patients with systemic lupus erythematosus (SLE) and rheumatoid arthritis (RA). Clin Dev Immunol.
394 Svanstrm H, Callrus T, Hviid A. (2010). Temporal data mining for adverse events following immunization in nationwide danish healthcare databases. Drug Safety.
395 Swingler GH, Michaels D, Hussey GG. (2009). WITHDRAWN: Conjugate vaccines for preventing Haemophilus influenzae type B infections. Cochrane Database of Systematic Reviews.
396 Taddio A, Ilersich AL, Ipp M, et al. (2009). Physical interventions and injection techniques for reducing injection pain during routine childhood immunizations: Systematic review of randomized controlled trials and quasi-randomized controlled trials. Clinical Therapeutics.
397 Takahashi K, Ohkusa Y, Kim JY. (2011). The economic disease burden of measles in Japan and a benefit cost analysis of vaccination, a retrospective study. BMC Health Services Research.
398 Tan TQ, Gerbie MV. (2010). Pertussis and patient safety: implementing Tdap vaccine recommendations in hospitals. Joint Commission Journal on Quality & Patient Safety.
399 Temte JL. (2006). Should all children be immunised against hepatitis A?. British Medical Journal.
400 Tenembaum S, Chitnis T, Ness J, et al. (2007). Acute disseminated encephalomyelitis. Neurology.
401 Tessmer A, Welte T, Schmidt-Ott R, et al. (2011). Influenza vaccination is associated with reduced severity of community-acquired pneumonia. European Respiratory Journal.
402 Tomljenovic L, Shaw CA. (2012). No autoimmune safety signal after vaccination with quadrivalent HPV vaccine Gardasil?. Journal of Internal Medicine.
403 Tseng YT, Sun HY, Chang SY, et al. (2012). Seroprevalence of hepatitis virus infection in men who have sex with men aged 18-40 years in Taiwan. Journal of the Formosan Medical Association.
404 Usen S, Adegbola R, Mulholland K, et al. (1998). Epidemiology of invasive pneumococcal disease in the Western Region, The Gambia. Pediatric Infectious Disease Journal.
405 Valente C, Hinds J, Pinto F, et al. (2012). Decrease in Pneumococcal Co-Colonization following Vaccination with the Seven-Valent Pneumococcal Conjugate Vaccine. PLoS ONE.
406 van den Biggelaar AHJ, Pomat W, Bosco A, et al. (2011). Pneumococcal conjugate vaccination at birth in a high-risk setting: No evidence for neonatal T-cell tolerance. Vaccine.
407 van Gils EJM, Hak E, Veenhoven RH, et al. (2011). Effect of Seven-Valent Pneumococcal Conjugate Vaccine on Staphylococcus aureus Colonisation in a Randomised Controlled Trial. PLoS ONE.
408 Van Holle L, Zeinoun Z, Bauchau V, et al. (2012). Using time-to-onset for detecting safety signals in spontaneous reports of adverse events following immunization: A proof of concept study. Pharmacoepidemiology and Drug Safety.
409 Vandenbruaene M, Colebunders R, Mascartlemone F, et al. (1995). Equal Igg Antibody-Response to Pneumococcal Vaccination in All Stages of Human-Immunodeficiency-Virus Disease. Journal of Infectious Diseases.
410 Verstraeten T, DeStefano F, Chen RT, et al. (2003). Vaccine safety surveillance using large linked databases: Opportunities, hazards and proposed guidelines. Expert Review of Vaccines.
411 Vesikari T. (1993). Clinical trials of live oral rotavirus vaccines: the Finnish experience. Vaccine.
412 Vesikari T. (1999). Rotavirus vaccine studies in Europe. Acta Paediatrica, International Journal of Paediatrics, Supplement.
413 Vesikari T, Itzler R, Matson DO, et al. (2007). Efficacy of a pentavalent rotavirus vaccine in reducing rotavirus-associated health care utilization across three regions (11 countries). International Journal of Infectious Diseases.
414 Vesikari T, Karvonen A, Ferrante SA, et al. (2010). Efficacy of the pentavalent rotavirus vaccine, RotaTeq[REGISTERED], in Finnish infants up to 3[NON-BREAKING SPACE]years of age: the Finnish Extension Study. European Journal of Pediatrics.
415 Vesikari T, Karvonen A, Prymula R, et al. (2007). Efficacy of human rotavirus vaccine against rotavirus gastroenteritis during the first 2 years of life in European infants: randomised, double-blind controlled study. Lancet.
416 Vesikari T, Prymula R, Schuster V, et al. (2012). Efficacy and Immunogenicity of Live-attenuated Human Rotavirus Vaccine in Breast-fed and Formula-fed European Infants. Pediatric Infectious Disease Journal.
417 Vesikari T, Ruuska T, Green KY, et al. (1992). Protective efficacy against serotype 1 rotavirus diarrhea by live oral rhesus-human reassortant rotavirus vaccines with human rotavirus VP7 serotype 1 or 2 specificity. Pediatric Infectious Disease Journal.
418 Viboud C, Simonsen L. (2011). Does seasonal influenza vaccination increase the risk of illness with the 2009 A/H1N1 pandemic virus?. International Journal of Risk and Safety in Medicine.
419 Vidal K, Bucheli P, Gao Q, et al. (2012). Immunomodulatory effects of dietary supplementation with a milk-based wolfberry formulation in healthy elderly: A randomized, double-blind, placebo-controlled trial. Rejuvenation Research.
420 Vila-Corcoles A, Hospital-Guardiola I, Ochoa-Gondar O, et al. (2010). Rationale and design of the CAPAMIS study: effectiveness of pneumococcal vaccination against community-acquired pneumonia, acute myocardial infarction and stroke. BMC Public Health.
421 Vila-Corcoles A, Ochoa-Gondar O, Rodriguez-Blanco T, et al. (2013). Ineffectiveness of Pneumococcal Vaccination in Cardiovascular Prevention: The CAPAMIS Study. JAMA Intern Med.
422 Visser A, Hoosen A. (2012). Combination vaccines in the South African setting. Vaccine.
423 Vlachopoulos C, Xaplanteris P, Sambatakou H, et al. (2011). Acute systemic inflammation induced by influenza A (H1N1) vaccination causes a deterioration in endothelial function in HIV-infected patients. HIV Medicine.
424 Vondracek TG, Pham TP, Huycke MM. (1998). A hospital-based pharmacy intervention program for pneumococcal vaccination. Archives of Internal Medicine.
425 Vos BD, Delem A, Hardt K, et al. (2006). A short report on clinical evaluation of RIX4414: highlights of world-wide development. Vaccine.
426 Vu DM, De Boer AW, Danzig L, et al. (2006). Priming for immunologic memory in adults by meningococcal group C conjugate vaccination. Clinical and Vaccine Immunology.
427 Vzquez-Lvarez MDC, Medrano-Lpez C, Camino-Lpez M. (2010). H1N1 influenza vaccination and infection in pediatric heart transplants. Journal of Heart and Lung Transplantation.
428 Waites KB, Canupp KC, Edwards K, et al. (1998). Immunogenicity of pneumococcal vaccine in persons with spinal cord injury. Archives of Physical Medicine and Rehabilitation.
429 Wang FT, Mast TC, Glass RJ, et al. (2010). Effectiveness of the pentavalent rotavirus vaccine in preventing gastroenteritis in the United States. Pediatrics.
430 Wang TJ, Hu CC, Lin HC. (2012). Increased risk of anterior uveitis following herpes zoster: A nationwide population-based study. Archives of Ophthalmology.
431 Ward J, Brenneman G, Letson GW, et al. (1990). Limited efficacy of Haemophilus influenzae type b conjugate vaccine in Alaska native infants. New England Journal of Medicine.
432 Ward RL, Bernstein DI, Smith VE, et al. (2004). Rotaviras immunoglobulin A responses stimulated by each of 3 doses of a quadrivalent human/bovine reassortant rotaviras vaccine. Journal of Infectious Diseases.
433 Warne G. (2007). Letter from Australia [2]. National Medical Journal of India.
434 Wehrle PF. (1985). Injury associated with the use of vaccines. Clinical Therapeutics.
435 Weinberg A, Song LY, Walker R, et al. (2010). Anti-Influenza Serum and Mucosal Antibody Responses After Administration of Live Attenuated or Inactivated Influenza Vaccines to HIV-Infected Children. Jaids-Journal of Acquired Immune Deficiency Syndromes.
436 Weinberg GA, Murphy TV, Granoff DM. (1990). Haemophilus influenzae type b polysaccharide-diphtheria toxoid conjugate vaccine in vaccinated children who developed Haemophilus disease. Pediatrics.
437 Weinberg SH, Butchart AT, Davis MM. (2012). Size of clinical trials and introductory prices of prophylactic vaccine series. Human Vaccines and Immunotherapeutics.
438 Weir E. (2002). Meningococcal disease: Oh no, not another childhood vaccine. Canadian Medical Association Journal.
439 Wenger JD, Pierce R, Deaver KA, et al. (1991). Efficacy of Haemophilus-Influenzae Type-B Polysaccharide-Diphtheria Toxoid Conjugate Vaccine in United-States Children Aged 18-59 Months. Lancet.
440 Whitney CG, Pilishvili T, Farley MM, et al. (2006). Effectiveness of seven-valent pneumococcal conjugate vaccine against invasive pneumococcal disease: a matched case-control study. Lancet.
441 Widdowson MA, Steele D, Vojdani J, et al. (2009). Global rotavirus surveillance: Determining the need and measuring the impact of rotavirus vaccines. Journal of Infectious Diseases.
442 Wilson K, Hawken S, Kwong JC, et al. (2011). Impact of birth weight at term on rates of emergency room visits and hospital admissions following vaccination at 2 months of age. Vaccine.
443 Winston CA, Wortley PM, Lees KA. (2006). Factors associated with vaccination of medicare beneficiaries in five US Communities: Results from the racial and ethnic adult disparities in immunization initiative survey, 2003. Journal of the American Geriatrics Society.
444 Wiwanitkit V. (2010). MR finding in vaccine-associated paralytic poliomyelitis. Pediatric Radiology.
445 Wolfe MS. (1999). Travel medicine. Current Opinion in Infectious Diseases.
446 Wong CM, Yang L, Chan KP, et al. (2006). Influenza-associated hospitalization in a subtropical city. PLoS Medicine / Public Library of Science.
447 Wood N, McIntyre P, Marshall H, et al. (2010). Acellular pertussis vaccine at birth and one month induces antibody responses by two months of age. Pediatric Infectious Disease Journal.
448 Wortley PM, Farizo KM, Sorillo F, et al. (1994). Pneumococcal and Influenza Vaccination Levels among Hiv-Infected Adolescents and Adults Receiving Medical-Care in the United-States. AIDS.
449 Wymann MN, Richard JL, Vidondo B, et al. (2011). Prospective pertussis surveillance in Switzerland, 1991-2006. Vaccine.
450 Yalcin SS, Kondolot M, Albayrak N, et al. (2010). Serological response to influenza vaccine after hematopoetic stem cell transplantation. Annals of Hematology.
451 Yao X, Hamilton RG, Weng NP, et al. (2011). Frailty is associated with impairment of vaccine-induced antibody response and increase in post-vaccination influenza infection in community-dwelling older adults. Vaccine.
452 Yawn BP, Wollan P, St Sauver J. (2011). Comparing shingles incidence and complication rates from medical record review and administrative database estimates: how close are they?. American Journal of Epidemiology.
453 Ye Y, Wang W, Wang X, et al. (2011). The clinical epidemiology of pediatric patients with measles from 2000 to 2009 in shanghai, china. Clinical Pediatrics.
454 Yen C, Figueroa JR, Uribe ES, et al. (2011). Monovalent rotavirus vaccine provides protection against An emerging fully heterotypic G9P[4] rotavirus strain in Mexico. Journal of Infectious Diseases.
455 Zerr DM, Blume HK, Berg AT, et al. (2005). Nonfebrile illness seizures: A unique seizure category?. Epilepsia.
456 Zhang J, Delzell E, Xie F, et al. (2011). The use, safety, and effectiveness of herpes zoster vaccination in individuals with inflammatory and autoimmune diseases: a longitudinal observational study. Arthritis Research & Therapy.
457 Zhang Q, Pettitt E, Burkinshaw R, et al. (2002). Mucosal immune responses to meningococcal conjugate polysaccharide vaccines in infants. Pediatric Infectious Disease Journal.
458 Zwiauer KF, Weinzettel R, Zwiauer VM. (2011). Clinical manifestation of intusseption before and after introduction of an oral rotavirus vaccine in austria. Journal of Pediatric Gastroenterology and Nutrition.

## Rejected for Design (Individual Case Report, No Comparison Group, Commentary, Non-Systematic Review, Passive Surveillance) – 1,549

1 (1967). Polio vaccine and congenital defects. British Medical Journal.
2 (1982). Pneumococcal polysaccharide vaccine. Recommendation of the Immunization Practices Advisory Committee. Annals of Internal Medicine.
3 (1986). Pneumococcal vaccine. Health and Public Policy Committee, American College of Physicians. Annals of Internal Medicine.
4 (1993). Immunization during pregnancy. ACOG technical bulletin number 160--October 1991. International Journal of Gynaecology & Obstetrics.
5 (1994). Facts about pertussis and DTP vaccine. EPI Newsletter.
6 (1998). WHO meeting on maternal and neonatal pneumococcal immunization. Weekly Epidemiological Record.
7 From the Centers for Disease Control and Prevention. (1999). Withdrawal of rotavirus vaccine recommendation. JAMA.
8 (1999). Measles immunization in HIV-infected children. American Academy of Pediatrics. Committee on Infectious Diseases and Committee on Pediatric AIDS. Pediatrics.
9 (2000). Pneumococcal vaccination for elderly subjects: license extension. Still no proof of clinical efficacy. Prescrire International.
10 (2002). 7-valent pneumococcal conjugate vaccine: new preparation. Prevents rare invasive infections in infants. Prescrire International.
11 (2004). Rotavirus vaccine ready for licensing. WHO Drug Information.
12 (2006). CDC's advisory committee recommends new vaccine to prevent rotavirus. Indian Journal of Medical Sciences.
13 (2006). Global Advisory Committee on Vaccine Safety, 1-2 December 2005. Weekly Epidemiological Record.
14 (2006). New rotavirus vaccine is likely on its way. Child Health Alert.
15 (2006). Infant immunisation with a pneumococcal conjugate vaccine: from the age of two months, for all infants. Prescrire International.
16 (2006). RotaTeq: A new oral rotavirus vaccine. Medical Letter on Drugs and Therapeutics.
17 (2006). New rotavirus vaccines safe and effective in large clinical trials. Gastroenterology.
18 (2007). Rotavirus vaccine and intussusception. WHO Drug Information.
19 (2007). Safety updates on rotavirus vaccine. Expert Review of Vaccines.
20 (2008). Adjuvanted hepatitis B vaccine: new drug. Patients with renal failure: similar response rate but fewer boosters needed. Prescrire International.
21 (2010). Risk levels for febrile seizures with combined measles-mumps-rubella-varicella vaccine. Expert Review of Vaccines.
22 (2010). Herpes zoster vaccine (Zostavax) revisited. Medical Letter on Drugs and Therapeutics.
23 (2010). Adverse effects of papillomavirus vaccination: 2009 data. Prescrire International.
24 (2011). Safety of rotavirus vaccines: postmarketing surveillance in the WHO Region of the Americas. Weekly Epidemiological Record.
25 Aaby P, Benn C, Nielsen J, et al. (2012). Testing the hypothesis that diphtheria-tetanus-pertussis vaccine has negative non-specific and sex-differential effects on child survival in high-mortality countries. BMJ Open.
26 Aaby P, Jensen H, Samb B, et al. (2003). Differences in female-male mortality after high-titre measles vaccine and association with subsequent vaccination with diphtheria-tetanus-pertussis and inactivated poliovirus: reanalysis of West African studies. Lancet.
27 Aaby P, Knudsen K, Whittle H, et al. (1993). Long-term survival after Edmonston-Zagreb measles vaccination in Guinea-Bissau: increased female mortality rate. Journal of Pediatrics.
28 Aaby P, Martins C, Bale C, et al. (2010). Sex Differences in the Effect of Vaccines on the Risk of Hospitalization Due to Measles in Guinea-Bissau. Pediatric Infectious Disease Journal.
29 Aagaard L, Hansen EW, Hansen EH. (2011). Adverse events following immunization in children: Retrospective analysis of spontaneous reports over a decade. European Journal of Clinical Pharmacology.
30 Aagaard L, Weber CB, Hansen EH. (2010). Adverse drug reactions in the paediatric population in denmark: A retrospective analysis of reports made to the danish medicines agency from 1998 to 2007. Drug Safety.
31 Abarca K, Ibanez I, de la Fuente P, et al. (2011). Immunogenicity and tolerability of a paediatric presentation of a virosomal hepatitis A vaccine in Chilean children aged 1-16 years. Vaccine.
32 Abedi GR, Mutuc JD, Lawler J, et al. (2012). Adverse events following a third dose of measles, mumps, and rubella vaccine in a mumps outbreak. Vaccine.
33 Abramson JS, Baker CJ, Fisher MC, et al. (1999). Possible association of intussusception with rotavirus vaccination. Pediatrics.
34 Abzug MJ, Nachman SA, Muresan P, et al. (2013). Safety and immunogenicity of 2009 pH1N1 vaccination in HIV-infected pregnant women. Clinical Infectious Diseases.
35 Abzug MJ, Pelton SI, Song LY, et al. (2006). Immunogenicity, safety, and predictors of response after a pneumococcal conjugate and pneumococcal polysaccharide vaccine series in human immunodeficiency virus-infected children receiving highly active antiretroviral therapy. Pediatric Infectious Disease Journal.
36 Abzug MJ, Qin M, Levin MJ, et al. (2012). Immunogenicity, immunologic memory, and safety following measles revaccination in HIV-infected children receiving highly active antiretroviral therapy. Journal of Infectious Diseases.
37 Acharya D, Desai A, Nanavaty N, et al. (1995). Evaluation of immunogenicity and tolerance of single dose haemophilus influenzae type B (PRP-T) vaccine. Indian Pediatrics.
38 Adam D, Fehnle K. (2008). Safety and effectiveness against respiratory tract infections for pneumococcal conjugate vaccine co-administered with routine vaccine combinations. Vaccine.
39 Adunsky A, Bernheim J. (1980). Pneumococcal vaccine in systemic lupus erythematosus. Arthritis & Rheumatism.
40 Agergaard J, Nante E, Poulstrup G, et al. (2011). Diphtheria-tetanus-pertussis vaccine administered simultaneously with measles vaccine is associated with increased morbidity and poor growth in girls. A randomised trial from Guinea-Bissau. Vaccine.
41 Aguilar-Betancourt A, Gonzalez-Delgado CA, Cinza-Estevez Z, et al. (2008). Safety and immunogenicity of a combined hepatitis B virus-Haemophilus influenzae type B vaccine comprising a synthetic antigen in healthy adults. Human Vaccines.
42 Aguilar-Betancourt A, Gonzalez-Delgado CA, Cinza-Estevez Z, et al. (2008). Safety and immunogenicity of a combined hepatitis B virus Haemophilus influenzae type B vaccine comprising a synthetic antigen in healthy adults. Human Vaccines.
43 Ahman H, Kayhty H, Tamminen P, et al. (1996). Pentavalent pneumococcal oligosaccharide conjugate vaccine PncCRM is well- tolerated and able to induce an antibody response in infants. Pediatric Infectious Disease Journal.
44 Ahmed F, Steinhoff MC, Rodriguez-Barradas MC, et al. (1996). Effect of human immunodeficiency virus type 1 infection on the antibody response to a glycoprotein conjugate pneumococcal vaccine: Results from a randomized trial. Journal of Infectious Diseases.
45 Ahonkhai VI, Lukacs LJ, Jonas LC, et al. (1991). Clinical experience with PedvaxHIB, a conjugate vaccine of Haemophilus influenzae type b polysaccharide--Neisseria meningitidis outer membrane protein. Vaccine.
46 Ahonkhai VI, Lukacs LJ, Jonas LC, et al. (1990). Haemophilus influenzae type b conjugate vaccine (meningococcal protein conjugate) (PedvaxHIB(registered trademark)): Clinical evaluation. Pediatrics.
47 Aikawa NE, Campos LM, Goldenstein-Schainberg C, et al. (2013). Effective seroconversion and safety following the pandemic influenza vaccination (anti-H1N1) in patients with juvenile idiopathic arthritis. Scandinavian Journal of Rheumatology.
48 Aikawa NE, Campos LMA, Silva CA, et al. (2012). Glucocorticoid: major factor for reduced immunogenicity of 2009 influenza A (H1N1) vaccine in patients with juvenile autoimmune rheumatic disease. Journal of Rheumatology.
49 Aikawa NE, Campos LMA, Silva CA, et al. (2011). Glucocorticoid: Major factor for reduced immunogenicity of 2009 influenza A (H1N1) vaccine in juvenile autoimmune rheumatic diseases patients. Arthritis and Rheumatism.
50 Alavian SM, Tabatabaei SV. (2010). Effects of Oral Levamisole as an Adjuvant to Hepatitis B Vaccine in Adults With End-Stage Renal Disease: A Meta-Analysis of Controlled Clinical Trials. Clinical Therapeutics.
51 al-Eissa YA. (1994). Reactogenicity and safety of meningococcal A and C vaccine in Saudi children. Annals of Tropical Paediatrics.
52 Allwinn R, Gauer S, Hofeld H, et al. (2011). Efficacy and side effects of H1N1 vaccination in renal transplant and dialysis patients. Transplant International.
53 Al-Mazrou Y, Khalil M, Findlow H, et al. (2012). Immunogenicity and Safety of a Meningococcal Quadrivalent Conjugate Vaccine in Saudi Arabian Adolescents Previously Vaccinated with One Dose of Bivalent and Quadrivalent Meningococcal Polysaccharide Vaccines: a Phase III, Controlled, Randomized, and Modified Blind-Observer Study. Clinical & Vaccine Immunology: CVI.
54 Almeida VDC, Mussi-Pinhata MM, De Souza CBS, et al. (2009). Immunogenicity of 23-valent pneumococcal polysaccharide vaccine in HIV-infected pregnant women and kinetics of passively acquired antibodies in young infants. Vaccine.
55 Al-Mendalawi MD. (2011). Post varicella zoster virus myelitis in immunocompetent patients. Neurosciences.
56 Al-Sukaiti N, Reid B, Lavi S, et al. (2010). Safety and efficacy of measles, mumps, and rubella vaccine in patients with DiGeorge syndrome. Journal of Allergy & Clinical Immunology.
57 Amanna IJ. (2012). Balancing the efficacy and safety of vaccines in the elderly. Open Longevity Science.
58 Ambrosch F, Wiedermann G, Crooy P, et al. (1983). Immunogenicity and side-effects of a new tetravalent meningococcal polysaccharide vaccine. Bulletin of the World Health Organization.
59 Amendola A, Tanzi E, Zappa A, et al. (2002). Safety and immunogenicity of 23-valent pneumococcal polysaccharide vaccine in HIV-1 infected former drug users. Vaccine.
60 Amir J, Melamed R, Bader J, et al. (1997). Immunogenicity and safety of a liquid combination of DTP-PRP-T [corrected] vs lyophilized PRP-T reconstituted with DTP. Vaccine.
61 Andersen DV, Jorgensen IM. (2013). MMR vaccination of children with egg allergy is safe. Danish Medical Journal.
62 Anderson EJ. (2008). Rotavirus vaccines: viral shedding and risk of transmission. The Lancet Infectious Diseases.
63 Anderson EL, Decker MD, Englund JA, et al. (1995). Interchangeability of conjugated Haemophilus influenzae type b vaccines in infants. JAMA.
64 Anderson P, Pichichero M, Edwards K, et al. (1987). Priming and induction of Haemophilus influenzae type b capsular antibodies in early infancy by Dpo20, an oligosaccharide-protein conjugate vaccine. Journal of Pediatrics.
65 Anderson P, Pichichero ME. (1989). Haemophilus influenzae type b vaccine. Pediatrics.
66 Andrade D, Seguro L, Ribeiro A, et al. (2012). Is H1N1 influenza vaccine safe and effective in patients with SSc?. Rheumatology.
67 Andre FE, D'Hondt E, Delem A, et al. (1992). Clinical assessment of the safety and efficacy of an inactivated hepatitis A vaccine: Rationale and summary of findings. Vaccine.
68 Andrews NJ, Walker WT, Finn A, et al. (2011). Predictors of immune response and reactogenicity to AS03B-adjuvanted split virion and non-adjuvanted whole virion H1N1 (2009) pandemic influenza vaccines. Vaccine.
69 Andrisani G, Frasca D, Armuzzi A, et al. (2011). Response to the 2009 vaccine for influenza A/H1N1 in patients with inflammatory bowel disease on anti TNF(alpha) therapy. Journal of Crohn's and Colitis.
70 Andrisani G, Frasca D, Romero M, et al. (2012). Immune response to influenza A/H1N1 vaccine in inflammatory bowel disease patients treated with anti TNF-(alpha) agents: Effects of combined therapy with immunosuppressants. Journal of Crohn's and Colitis.
71 Anh DD, Carlos CC, Thiem DV, et al. (2011). Immunogenicity, reactogenicity and safety of the human rotavirus vaccine RIX4414 (Rotarix (TM)) oral suspension (liquid formulation) when co-administered with expanded program on immunization (EPI) vaccines in Vietnam and the Philippines in 2006-2007. Vaccine.
72 Ankrah DN, Mantel-Teeuwisse AK, De Bruin ML, et al. (2013). Incidence of adverse events among healthcare workers following H1N1 Mass immunization in Ghana: a prospective study. Drug Safety.
73 Annunziata P, Carnicelli N, Galluzzi P, et al. (2012). Miller-Fisher syndrome following vaccination against influenza virus A/H1N1 in an AIDS patient. Infection.
74 Ansari F, Baker RD, Patel R, et al. (2011). Varicella immunity in inflammatory bowel disease. Journal of Pediatric Gastroenterology & Nutrition.
75 Aplasca-De Los Reyes MR, Dimaano E, Macalalad N, et al. (2012). The investigational meningococcal serogroups A, C, W-135, Y tetanus toxoid conjugate vaccine (ACWY-TT) and the seasonal influenza virus vaccine are immunogenic and well-tolerated when co-administered in adults. Human Vaccines and Immunotherapeutics.
76 Arguedas A, Soley C, Abdelnour A, et al. (2011). Assessment of the safety, tolerability and kinetics of the immune response to A/H1N1v vaccine formulations with and without adjuvant in healthy pediatric subjects from 3 through 17 years of age. Human Vaccines.
77 Arguedas A, Soley C, Lindert K. (2010). Responses to 2009 H1N1 vaccine in children 3 to 17 years of age. N Engl J Med.
78 Aristegui J, Dal-Re R, Diez-Delgado J, et al. (2003). Comparison of the reactogenicity and immunogenicity of a combined diphtheria, tetanus, acellular pertussis, hepatitis B, inactivated polio (DTPa-HBV-IPV) vaccine, mixed with the Haemophilus influenzae type b (Hib) conjugate vaccine and administered as a single injection, with the DTPa-IPV/Hib and hepatitis B vaccines administered in two simultaneous injections to infants at 2, 4 and 6 months of age. Vaccine.
79 Aristegui J, Dal-Re R, Garrote E, et al. (1998). Assessment of the immunogenicity and reactogenicity of a quadrivalent diphtheria, tetanus, acellular pertussis and hepatitis B (DTPa-HBV) vaccine administered in a single injection with Haemophilus influenzae type b conjugate vaccine, to infants at 2, 4 and 6 months of age. Vaccine.
80 Arnold WC, Steele RW, Rastogi SP, et al. (1985). Response to pneumococcal vaccine in renal allograft recipients. American Journal of Nephrology.
81 Arnou R, Eavis P, Pardo JRDJ, et al. (2010). Immunogenicity, large scale safety and lot consistency of an intradermal influenza vaccine in adults aged 18-60 years: Randomized, controlled, phase III trial. Human Vaccines.
82 Arnou R, Fiquet A, Thomas S, et al. (2011). Immunogenicity and safety of ZOSTAVAX([REGISTERED]) approaching expiry potency in individuals aged >=50 years. Human Vaccines.
83 Arya LS, Ghai OP, Saraya AK. (1993). Thrombocytopenic purpura following DPT vaccination. Pediatr Hematol Oncol.
84 Asahina N, Matsunami Y, Sueda K, et al. (2010). Vaccine-associated paralytic poliomyelitis in a non-immunocompromised infant. Pediatrics International.
85 Asante KP, Abdulla S, Agnandji S, et al. (2011). Safety and efficacy of the RTS,S/AS01E candidate malaria vaccine given with expanded-programme-on-immunisation vaccines: 19 month follow-up of a randomised, open-label, phase 2 trial. The Lancet Infectious Diseases.
86 Ashok G, Rajendran P, Jayam S, et al. (2011). Assessment of immune response and safety of two recombinant hepatitis B vaccines in healthy infants in India. African Journal of Biotechnology.
87 Ashok G, Rajendran P, Jayam S, et al. (2011). Assessment of immune response and safety of two recombinant hepatitis B vaccines in healthy infants in India. African Journal of Biotechnology.
88 Asindi AA, Bell EJ, Browning MJ, et al. (1988). Vaccine-induced polioencephalomyelitis in Scotland. Scottish Medical Journal.
89 Aspinall S, Traynor D, Bedford P, et al. (2012). Lot-to-lot consistency study of the fully liquid pentavalent DTwP-HepB-Hib vaccine Quinvaxem(registered trademark) demonstrating clinical equivalence, suitability of the vaccine as a booster and concomitant administration with measles vaccine. Human Vaccines and Immunotherapeutics.
90 Atanasovski M, Dele-Michael A, Dasgeb B, et al. (2011). A case report of Gianotti-Crosti post vaccination with MMR and dTaP. International Journal of Dermatology.
91 Auriel E, Regev K, Dori A, et al. (2011). Safety of influenza and H1N1 vaccinations in patients with myasthenia gravis, and patient compliance. Muscle & Nerve.
92 Austrian R. (1977). Prevention of pneumococcal infection by immunization with capsular polysaccharides of Streptococcus pneumoniae: current status of polyvalent vaccines. Journal of Infectious Diseases.
93 Autret-Leca E, Grimaldi-Bensouda L, Daubin C, et al. (2011). Heptavalent pneumococcal conjugate vaccine (PCV7): French survey of serious adverse reactions. Therapie.
94 Avdicova M, Prikazsky V, Hudeckova H, et al. (2002). Immunogenicity and reactogenicity of a novel hexavalent DTPa-HBV-IPV/Hib vaccine compared to separate concomitant injections of DTPa-IPV/Hib and HBV vaccines, when administered according to a 3, 5 and 11 month vaccination schedule. European Journal of Pediatrics.
95 Avery RK. (2012). Influenza vaccines in the setting of solid-organ transplantation: Are they safe?. Current Opinion in Infectious Diseases.
96 Awaidy SA, Bawikar S, Prakash KP, et al. (2010). Surveillance des manifestations postvaccinales indesirables: Dix ans d'experience a Oman. Eastern Mediterranean Health Journal.
97 Bader MS. (2007). Immunization for the elderly. American Journal of the Medical Sciences.
98 Badsha H, Daher M, Edwards CJ. (2010). Live polio vaccine exposure while receiving anti-TNF therapy for reactive arthritis. International Journal of Rheumatic Diseases.
99 Bagatin D, Augustin G, Bagatin T. (2009). Post-vaccination dermatolipomyonecrosis. Wiener Klinische Wochenschrift.
100 Bakare N, Menschik D, Tiernan R, et al. (2010). Severe combined immunodeficiency (SCID) and rotavirus vaccination: reports to the Vaccine Adverse Events Reporting System (VAERS). Vaccine.
101 Baker CJ, Kasper DL. (1985). Group B streptococcal vaccines. Reviews of Infectious Diseases.
102 Baker CJ, Rench MA, Edwards MS, et al. (1988). Immunization of pregnant women with a polysaccharide vaccine of group B streptococcus. New England Journal of Medicine.
103 Ball R, Ball LK, Wise RP, et al. (2001). Stevens-Johnson syndrome and toxic epidermal necrolysis after vaccination: Reports to the Vaccine Adverse Event Reporting System. Pediatric Infectious Disease Journal.
104 Banda R, Yambayamba V, Lalusha BD, et al. (2012). Safety of live, attenuated oral vaccines in HIV-infected Zambian adults: Oral vaccines in HIV. Vaccine.
105 Banzhoff A, Haertel S, Praus M. (2011). Passive surveillance of adverse events of an MF59-adjuvanted H1N1v vaccine during the pandemic mass vaccinations. Human Vaccines.
106 Banzhoff A, Stoddard JJ. (2012). Effective influenza vaccines for children: A critical unmet medical need and a public health priority. Human Vaccines and Immunotherapeutics.
107 Barbaud A, Deschildre A, Waton J, et al. (2013). Hypersensitivity and vaccines: an update. European Journal of Dermatology.
108 Barnes G. (1999). Intussusception and rotavirus vaccine. Journal of Pediatric Gastroenterology and Nutrition.
109 Barnes G, Srivastava A, Carlin J, et al. (2003). Delta-F508 cystic fibrosis mutation is not linked to intussusception: implications for rotavirus vaccine. Journal of Paediatrics & Child Health.
110 Barnett ED, Pelton SI, Cabral HJ, et al. (1999). Immune response to pneumococcal conjugate and polysaccharide vaccines in otitis-prone and otitis-free children. Clinical Infectious Diseases.
111 Bartlett BL, Tyring SK. (2009). Safety and efficacy of vaccines. Dermatologic Therapy.
112 Barton M, Wasfy S, Dipchand AI, et al. (2009). Seven-valent pneumococcal conjugate vaccine in pediatric solid organ transplant recipients: a prospective study of safety and immunogenicity. Pediatric Infectious Disease Journal.
113 Basilico FC, Bernat JL. (1978). Vaccine-associated poliomyelitis in a contact. Journal of the American Medical Association.
114 Bassily S, Kotkat A, Gray G, et al. (1995). Comparative study of the immunogenicity and safety of two dosing schedules of hepatitis B vaccine in neonates. American Journal of Tropical Medicine & Hygiene.
115 Bassis AV, Fairley JA, Ameln RT, et al. (2011). Cutaneous Rosai-Dorfman disease following pneumococcal vaccination. Journal of the American Academy of Dermatology.
116 Batista-Duharte A, Lindblad EB, Oviedo-Orta E. (2011). Progress in understanding adjuvant immunotoxicity mechanisms. Toxicology Letters.
117 Bavdekar SB, Maiya PP, Subba Rao SD, et al. (2007). Immunogenicity and safety of combined diphtheria tetanus whole cell pertussis hepatitis B/ Haemophilus influenzae type b vaccine in Indian infants. Indian Pediatrics.
118 Baxter D. (2010). Impaired functioning of immune defences to infection in premature and term infants and their implications for vaccination. Human Vaccines.
119 Baxter R, Baine Y, Ensor K, et al. (2011). Immunogenicity and safety of an investigational quadrivalent meningococcal ACWY tetanus toxoid conjugate vaccine in healthy adolescents and young adults 10 to 25 years of age. Pediatric Infectious Disease Journal.
120 Baxter R, Jeanfreau R, Block SL, et al. (2010). A Phase III evaluation of immunogenicity and safety of two trivalent inactivated seasonal influenza vaccines in US children. Pediatric Infectious Disease Journal.
121 Baxter R, Patriarca PA, Ensor K, et al. (2011). Evaluation of the safety, reactogenicity and immunogenicity of FluBlok[REGISTERED] trivalent recombinant baculovirus-expressed hemagglutinin influenza vaccine administered intramuscularly to healthy adults 50-64 years of age. Vaccine.
122 Beck CR, McKenzie BC, Hashim AB, et al. (2012). Influenza vaccination for immunocompromised patients: systematic review and meta-analysis by etiology. Journal of Infectious Diseases.
123 Begg NT, Miller E, Fairley CK, et al. (1995). Antibody responses and symptoms after DTP and either tetanus or diphtheria Haemophilus influenzae type B conjugate vaccines given for primary immunisation by separate or mixed injection. Vaccine.
124 Begg NT, Miller E, Fairley CK, et al. (1995). Antibody-Responses and Symptoms after Dtp and Either Tetanus or Diphtheria Haemophilus-Influenzae Type-B Conjugate Vaccines Given for Primary Immunization by Separate or Mixed Injection. Vaccine.
125 Begue P, Stagnara J, Vie-Le-Sage F, et al. (1997). Immunogenicity and reactogenicity of a booster dose of diphtheria, tetanus, acellular pertussis and inactivated poliomyelitis vaccines given concurrently with Haemophilus type b conjugate vaccine or as pentavalent vaccine. Pediatric Infectious Disease Journal.
126 Belec L, Authier FJ, Gherardi RK. (2011). Safety and immunogenicity of hepatitis B vaccine regimens in adults with HIV-1. JAMA.
127 Bell F, Heath P, MacLennan J, et al. (1999). Adverse effects and sero-responses to an acellular pertussis/diphtheria/tetanus vaccine when combined with Haemophilus influenzae type b vaccine in an accelerated schedule. European Journal of Pediatrics.
128 Bell F, Heath P, Shackley F, et al. (1998). Effect of combination with an acellular pertussis, diphtheria, tetanus vaccine on antibody response to Hib vaccine (PRP-T). Vaccine.
129 Bell F, Martin A, Blondeau C, et al. (1996). Combined diphtheria, tetanus, pertussis, and Haemophilus influenzae type b vaccines for primary immunisation. Archives of Disease in Childhood.
130 Belliveau MJ, Kratky V, Evans GA, et al. (2011). Acute orbital inflammatory syndrome following H1N1 immunization. Canadian Journal of Ophthalmology.
131 Belongia EA, Irving SA, Shui IM, et al. (2010). Real-time surveillance to assess risk of intussusception and other adverse events after pentavalent, bovine-derived rotavirus vaccine. Pediatric Infectious Disease Journal.
132 Belshe RB, Frey SE, Graham I, et al. (2011). Safety and immunogenicity of influenza A H5 subunit vaccines: effect of vaccine schedule and antigenic variant. Journal of Infectious Diseases.
133 Benn CS. (2012). Combining vitamin A and vaccines: convenience or conflict?. Danish Medical Journal.
134 Benn CS, Aaby P. (2012). Diphtheria-tetanus-pertussis vaccination administered after measles vaccine: Increased female mortality?. Pediatric Infectious Disease Journal.
135 Benn CS, Lund S, Fisker A, et al. (2009). Should infant girls receive micronutrient supplements?. International Journal of Epidemiology.
136 Bennett JV, Fernandez de Castro J, Poblete RM, et al. (2009). A new, rapid, and promising approach to aerosol immunization: inflatable bags and valved masks. Vaccine.
137 Bentsi-Enchill AD, Zongo I, Khamassi S, et al. (2007). Monitoring of adverse events during the 2003 mass vaccination campaign with a trivalent meningococcal A/C/W135 polysaccharide vaccine in Burkina Faso. Vaccine.
138 Beran J, Beutels M, Levie K, et al. (2000). A single dose, combined vaccine against typhoid fever and hepatitis A: consistency, immunogenicity and reactogenicity. Journal of Travel Medicine.
139 Beran J, Hobzova L, Wertzova V, et al. (2010). Safety and immunogenicity of an investigational adjuvanted hepatitis B vaccine (HB-AS02(V)) in healthy adults. Human Vaccines.
140 Beran J, Kervyn D, Wertzova V, et al. (2010). Comparison of long-term (10 years) immunogenicity of two- and three-dose regimens of a combined hepatitis A and B vaccine in adolescents. Vaccine.
141 Bergfors E, Trollfors B, Inerot A. (2003). Unexpectedly high incidence of persistent itching nodules and delayed hypersensitivity to aluminium in children after the use of adsorbed vaccines from a single manufacturer. Vaccine.
142 Berkowitz CD, Ward JI, Meier K, et al. (1987). Safety and immunogenicity of Haemophilus influenzae type b polysaccharide and polysaccharide diphtheria toxoid conjugate vaccines in children 15 to 24 months of age. Journal of Pediatrics.
143 Bermal N, Huang LM, Dubey AP, et al. (2011). Safety and immunogenicity of a tetravalent meningococcal serogroups A, C, W-135 and Y conjugate vaccine in adolescents and adults. Human Vaccines.
144 Bermal N, Szenborn L, Edison A, et al. (2011). Safety and immunogenicity of a booster dose of the 10-valent pneumococcal nontypeable Haemophilus influenzae protein D conjugate vaccine coadministered with DTPw-HBV/Hib and poliovirus vaccines. Pediatric Infectious Disease Journal.
145 Berner R, Boisnard F, Thomas S, et al. (2012). Safety and immunogenicity of fully liquid DTaP(5)-IPV-Hib pediatric combination vaccine (Pediacel((registered trademark))) compared to DTaP(3)-HBV-IPV/Hib (Infanrix((registered trademark)) Hexa) when coadministered with heptavalent pneumococcal conjugate vaccine (PCV7) as a booster at 11-18 months of age: A phase III, modified double-blind, randomized, controlled, multicenter study. Vaccine.
146 Berner R, Boisnard F, Thomas S, et al. (2012). Safety and immunogenicity of fully liquid DTaP(5)-IPV-Hib pediatric combination vaccine (Pediacel([REGISTERED])) compared to DTaP(3)-HBV-IPV/Hib (Infanrix([REGISTERED]) Hexa) when coadministered with heptavalent pneumococcal conjugate vaccine (PCV7) as a booster at 11-18 months of age: A phase III, modified double-blind, randomized, controlled, multicenter study. Vaccine.
147 Bernier RH, Frank JA, Dondero TJ, et al. (1982). Diphtheria-tetanus toxoids-pertussis vaccination and sudden infant deaths in Tennessee. Journal of Pediatrics.
148 Bernsen RM, van der Wouden JC. (2007). Is childhood immunisation associated with atopic disease from age 7 to 32 years?. Thorax.
149 Bernsen RMD, Van Der Wouden JC. (2005). Re: No epidemiological evidence for infant vaccinations to cause allergic disease. Vaccine.
150 Bernstein D. (2008). Efficacy of the pentavalent rotavirus vaccine in subjects after 1 or 2 doses in the rotavirus efficacy and safety trial. Pediatrics.
151 Bernstein DI, Glass RI, Rodgers G, et al. (1995). Evaluation of rhesus rotavirus monovalent and tetravalent reassortant vaccines in US children. US Rotavirus Vaccine Efficacy Group. JAMA.
152 Bernstein DI, Ward RL. (2006). Rotarix: development of a live attenuated monovalent human rotavirus vaccine. Pediatric Annals.
153 Bernstein HH, Noriega F. (2011). Immunogenicity and safety of a combined diphtheria, tetanus, 5-component acellular pertussis, inactivated poliomyelitis, Haemophilus type b conjugate vaccine when administered concurrently with a pneumococcal conjugate vaccine: A randomized, open-label, phase 3 study. Vaccine.
154 Bewley KM, Schwab JG, Ballanco GA, et al. (1996). Interchangeability of Haemophilus influenzae type b vaccines in the primary series: evaluation of a two-dose mixed regimen. Pediatrics.
155 Bhandari N, Sharma P, Taneja S, et al. (2009). A dose-escalation safety and immunogenicity study of live attenuated oral rotavirus vaccine 116E in infants: a randomized, double-blind, placebo-controlled trial. Journal of Infectious Diseases.
156 Biai S, Rodrigues A, Nielsen J, et al. (2011). Vaccination status and sequence of vaccinations as risk factors for hospitalisation among outpatients in a high mortality country. Vaccine.
157 Billal DS, Hotomi M, Yamanaka N. (2008). Rotavirus vaccine for developing countries. The Lancet.
158 Bines J. (2006). Intussusception and rotavirus vaccines. Vaccine.
159 Bines JE. (2005). Rotavirus vaccines and intussusception risk. Current Opinion in Gastroenterology.
160 Bingham CO, Looney RJ, Deodhar A, et al. (2010). Immunization responses in rheumatoid arthritis patients treated with rituximab: results from a controlled clinical trial. Arthritis & Rheumatism.
161 Bird SM. (2011). Febrile convulsions after seasonal influenza immunisation in UK. Lancet.
162 Bissantz N, Jenke AC, Trampisch M, et al. (2011). Hospital-based, prospective, multicentre surveillance to determine the incidence of intussusception in children aged below 15 years in Germany. Bmc Gastroenterology.
163 Bjune G, Closs O, Froholm LO, et al. (1991). Design of clinical trials with an outer membrane vesicle vaccine against systemic serogroup B meningococcal disease in Norway. NIPH Annals.
164 Black S. (1999). The clinical impact of pneumococcal conjugate vaccines. American Journal of Managed Care.
165 Black S, Friedland LR, Ensor K, et al. (2008). Diphtheria-tetanus-acellular pertussis and inactivated poliovirus vaccines given separately or combined for booster dosing at 4-6 years of age. Pediatric Infectious Disease Journal.
166 Black S, Shinefield H. (2002). Safety and efficacy of the seven-valent pneumococcal conjugate vaccine: evidence from Northern California. European Journal of Pediatrics.
167 Black S, Shinefield H, Fireman B, et al. (2000). Efficacy, safety and immunogenicity of heptavalent pneumococcal conjugate vaccine in children. Northern California Kaiser Permanente Vaccine Study Center Group. Pediatric Infectious Disease Journal.
168 Black S, Shinefield H, Ray P, et al. (1999). Postmarketing evaluation of the safety and effectiveness of varicella vaccine. Pediatric Infectious Disease Journal.
169 Black SB, Cimino CO, Hansen J, et al. (2006). Immunogenicity and safety of measles-mumps-rubella, varicella and Haemophilus influenzae type b vaccines administered concurrently with a fourth dose of heptavalent pneumococcal conjugate vaccine compared with the vaccines administered without heptavalent pneumococcal conjugate vaccine. Pediatric Infectious Disease Journal.
170 Black SB, Shinefield HR. (1987). b-CAPSA I Haemophilus influenzae, type b, capsular polysaccharide vaccine safety. Pediatrics.
171 Black SB, Shinefield HR, Fireman B, et al. (1992). Safety, immunogenicity, and efficacy in infancy of oligosaccharide conjugate Haemophilus influenzae type b vaccine in a United States population: possible implications for optimal use. Journal of Infectious Diseases.
172 Black SB, Shinefield HR, Ray P, et al. (1993). Safety of combined oligosaccharide conjugate Haemophilus influenzae type b (HbOC) and whole cell diphtheria-tetanus toxoids-pertussis vaccine in infancy. The Kaiser Permanente Pediatric Vaccine Study Group. Pediatric Infectious Disease Journal.
173 Blatter M, Friedland LR, Weston WM, et al. (2009). Immunogenicity and safety of a tetanus toxoid, reduced diphtheria toxoid and three-component acellular pertussis vaccine in adults 19-64 years of age. Vaccine.
174 Blatter MM, Klein NP, Shepard JS, et al. (2012). Immunogenicity and Safety of two tetravalent (measles, mumps, rubella, varicella) vaccines coadministered with hepatitis a and pneumococcal conjugate vaccines to children twelve to fourteen months of age. Pediatric Infectious Disease Journal.
175 Blitshteyn S. (2010). Postural tachycardia syndrome after vaccination with Gardasil. European Journal of Neurology.
176 Block SL, Falloon J, Hirschfield JA, et al. (2012). Immunogenicity and safety of a quadrivalent live attenuated influenza vaccine in children. Pediatric Infectious Disease Journal.
177 Block SL, Ruiz-Palacios GM, Guerrero ML, et al. (2012). Dose-range Study of MF59-adjuvanted Versus Nonadjuvanted Monovalent A/H1N1 Pandemic Influenza Vaccine in Six- to Less Than Thirty-Six-month-old Children. Pediatric Infectious Disease Journal.
178 Block SL, Yi T, Sheldon E, et al. (2011). A randomized, double-blind noninferiority study of quadrivalent live attenuated influenza vaccine in adults. Vaccine.
179 Boccara F, Benhaiem-Sigaux N, Cohen A. (2001). Acute myopericarditis after diphtheria, tetanus, and polio vaccination. Chest.
180 Bocchini JA. (2008). Efficacy of the pentavalent rotavirus vaccine in subjects after 1 or 2 doses in the rotavirus efficacy and safety trial: In reply [6]. Pediatrics.
181 Boghani DC, Ali QK. (2000). Patient with probable side effect of hepatitis vaccination. CME Journal Ophthalmology.
182 Booy R, Richmond P, Nolan T, et al. (2011). Immediate and longer term immunogenicity of a single dose of the combined Haemophilus influenzae type b-Neisseria meningitidis serogroup c-tetanus toxoid conjugate vaccine in primed toddlers 12 to 18 months of age. Pediatric Infectious Disease Journal.
183 Booy R, Taylor SA, Dobson SRM, et al. (1992). Immunogenicity and Safety of Prp-T Conjugate Vaccine Given According to the British Accelerated Immunization Schedule. Archives of Disease in Childhood.
184 Borba EF, Saad CGS, Pasoto SG, et al. (2012). Influenza A/H1N1 vaccination of patients with SLE: can antimalarial drugs restore diminished response under immunosuppressive therapy?. Rheumatology.
185 Borner N, Muhlberger N, Jelinek T. (2003). Tolerability of multiple vaccinations in travel medicine. Journal of Travel Medicine.
186 Botet Asensi FI, Veronese A, Del Carmen Otero M, et al. (2003). Immunogenicity and safety in infants of a DTwPHib full liquid vaccine. Acta Paediatrica.
187 Botham SJ, Isaacs D. (1994). Incidence of apnoea and bradycardia in preterm infants following triple antigen immunization. J Paediatr Child Health.
188 Botham SJ, Isaacs D, Henderson-Smart DJ. (1997). Incidence of apnoea and bradycardia in preterm infants following DTP(w) and Hib immunization: A prospective study. Journal of Paediatrics and Child Health.
189 Boudville IC, Phua KB, Quak SH, et al. (2006). The epidemiology of paediatric intussusception in Singapore: 1997 to 2004. Annals of the Academy of Medicine, Singapore.
190 Bouree P. (2003). Immunity and immunization in elderly. Pathologie Biologie.
191 Bradley SF. (1996). Influenza in the elderly: Prevention is the best strategy in high-risk populations. Postgraduate Medicine.
192 Brakemeier S, Schweiger B, Lachmann N, et al. (2012). Immune response to an adjuvanted influenza A H1N1 vaccine (Pandemrix(registered trademark)) in renal transplant recipients. Nephrology Dialysis Transplantation.
193 Breiman RF, Brooks WA, Goswami D, et al. (2009). A multinational, randomized, placebo-controlled trial to assess the immunogenicity, safety, and tolerability of live attenuated influenza vaccine coadministered with oral poliovirus vaccine in healthy young children. Vaccine.
194 Bridy-Pappas AE, Margolis MB, Center KJ, et al. (2005). Streptococcus pneumoniae: description of the pathogen, disease epidemiology, treatment, and prevention. Pharmacotherapy:The Journal of Human Pharmacology & Drug Therapy.
195 Broeders NE, Hombrouck A, Lemy A, et al. (2011). Influenza A/H1N1 vaccine in patients treated by kidney transplant or dialysis: a cohort study. Clinical Journal of The American Society of Nephrology: CJASN.
196 Brookhart MA, Walker AM, Lu Y, et al. (2012). Characterizing vaccine-associated risks using cubic smoothing splines. American Journal of Epidemiology.
197 Brophy JC, Ward BJ, Samson L, et al. (2011). Immunogenicity of AS03-adjuvanted H1N1 pandemic influenza vaccine in HIV-infected children. Canadian Journal of Infectious Diseases and Medical Microbiology.
198 Bryan P, Seabroke S. (2011). No increased risk of febrile convulsions after seasonal influenza immunisation in UK. Lancet.
199 Bryant KA, Block SL, Baker SA, et al. (2010). Safety and immunogenicity of a 13-valent pneumococcal conjugate vaccine. Pediatrics.
200 Bryant KA, Marshall GS, Marchant CD, et al. (2011). Immunogenicity and safety of H influenzae type b-N meningitidis C/Y conjugate vaccine in infants. Pediatrics.
201 Buettcher M, Heininger U, Braun M, et al. (2007). Hypotonic-hyporesponsive episode (HHE) as an adverse event following immunization in early childhood: Case definition and guidelines for data collection, analysis, and presentation. Vaccine.
202 Bulkow LR, McMahon BJ, Wainwright RB, et al. (1993). Safety and immunogenicity of a combined hepatitis B virus-Haemophilus influenzae type B vaccine formulation in healthy adults. Arctic Medical Research.
203 Bults M, Kemmeren JM, van der Maas NAT. (2007). Adverse events following booster doses of diphtheria-tetanus-inactivated poliovirus and acellular pertussis vaccines for 4-year-old children in The Netherlands. Vaccine.
204 Bunupuradah T, Ananworanich J, Pancharoen C, et al. (2011). Randomized study of intradermal compared to intramuscular hepatitis B vaccination in HIV-infected children without severe immunosuppression. Vaccine.
205 Burwen DR, Sandhu SK, MaCurdy TE, et al. (2012). Surveillance for Guillain-Barre syndrome after influenza vaccination among the Medicare population, 2009-2010. American Journal of Public Health.
206 Busse WW, Peters SP, Fenton MJ, et al. (2011). Vaccination of patients with mild and severe asthma with a 2009 pandemic H1N1 influenza virus vaccine. Journal of Allergy & Clinical Immunology.
207 Cadorna-Carlos J, Vidor E, Bonnet MC. (2012). Randomized controlled study of fractional doses of inactivated poliovirus vaccine administered intradermally with a needle in the Philippines. International Journal of Infectious Diseases.
208 Cadoz M, Armand J, Arminjon F, et al. (1985). A new 23 valent pneumococcal vaccine: immunogenicity and reactogenicity in adults. Journal of Biological Standardization.
209 Caillet C, Durrieu G, Jacquet A, et al. (2011). Safety surveillance of influenza A(H1N1)v monovalent vaccines during the 2009-2010 mass vaccination campaign in France. European Journal of Clinical Pharmacology.
210 Cakir FB, Timur C, Yoruk A, et al. (2012). Seroconversion status after single dose and double doses of varicella vaccination in children with leukemia. Pediatric Hematology & Oncology.
211 Calbo F, Dal-Re R, Diez-Delgado J, et al. (2002). Comparative trial to assess the reactogenicity of the diphtheria-tetanusacellular pertussis (DTPa) vaccine plus Haemophilus influenza type b (Hib) conjugate vaccine and that of the diphtheria-tetanus-whole cell pertussis (DTPw) vaccine plus Hib conjugate vaccine, administered in single injection as a booster dose to 14-20 months-old children. Medicina Clinica.
212 Cale CM, Klein NJ. (2002). The link between rotavirus vaccination and intussusception: implications for vaccine strategies. Gut.
213 Calmy A, Bel M, Nguyen A, et al. (2012). Strong serological responses and HIV RNA increase following AS03-adjuvanted pandemic immunization in HIV-infected patients. HIV Medicine.
214 Campagne G, Garba A, Fabre P, et al. (2000). Safety and immunogenicity of three doses of a Neisseria meningitidis A + C diphtheria conjugate vaccine in infants from Niger. Pediatric Infectious Disease Journal.
215 Campbell AL, Bryant KA. (2001). Routine childhood immunizations. Primary Care; Clinics in Office Practice.
216 Campbell H, Byass P, Ahonkhai VI, et al. (1990). Serologic responses to an Haemophilus influenzae type b polysaccharide-Neisseria meningitidis outer membrane protein conjugate vaccine in very young Gambian infants. Pediatrics.
217 Campbell JD, Chambers CV, Brady RC, et al. (2011). Immunologic non-inferiority of a newly licensed inactivated trivalent influenza vaccine versus an established vaccine: a randomized study in US adults. Human Vaccines.
218 Campbell WN, Hendrix E, Cryz S, et al. (1996). Immunogenicity of a 24-valent Klebsiella capsular polysaccharide vaccine and an eight-valent Pseudomonas O-polysaccharide conjugate vaccine administered to victims of acute trauma. Clinical Infectious Diseases.
219 Caniza MA, Hunger SP, Schrauder A, et al. (2012). The controversy of varicella vaccination in children with acute lymphoblastic leukemia. Pediatric Blood and Cancer.
220 Caniza MA, Hunger SP, Schrauder A, et al. (2012). The controversy of varicella vaccination in children with acute lymphoblastic leukemia. Pediatric Blood & Cancer.
221 Cao H, Lavange LM, Heyse JF, et al. (2013). Medical records-based postmarketing safety evaluation of rare events with uncertain status. Journal of Biopharmaceutical Statistics.
222 Capeding MR, Cadorna-Carlos J, Book-Montellano M, et al. (2008). Immunogenicity and safety of a DTaP-IPV//PRP approximately T combination vaccine given with hepatitis B vaccine: a randomized open-label trial. Bulletin of the World Health Organization.
223 Capeding MZR, Puumalainen T, Gepanayao CP, et al. (2003). Safety and immunogenicity of three doses of an eleven-valent diphtheria toxoid and tetanus protein--conjugated pneumococcal vaccine in Filipino infants. BMC Infectious Diseases.
224 Cappelletti M, Taddeo A, Colombo E, et al. (2012). Immunogenicity and Safety of Seasonal Influenza Vaccination in Patients with Classic Kaposi's Sarcoma. Journal of Investigative Dermatology.
225 Carcione D, Blyth CC, Richmond PC, et al. (2013). Safety surveillance of influenza vaccine in pregnant women. Australian & New Zealand Journal of Obstetrics & Gynaecology.
226 Carlsson RM, Claesson BA, Selstam U, et al. (1998). Safety and immunogenicity of a combined diphtheria-tetanus-acellular pertussis-inactivated polio vaccine-Haemophilus influenzae type b vaccine administered at 2-4-6-13 or 3-5-12 months of age. Pediatric Infectious Disease Journal.
227 Carmona A, Miranda M, Barrio F, et al. (2010). Reactogenicity and immunogenicity of combined haemophilus influenzae type B-meningococcal serogroup C conjugate vaccine booster dose coadministered with measles, mumps, and rubella vaccinehib-menc-TT booster with routine MMR vaccine. Pediatric Infectious Disease Journal.
228 Carmona A, Omenaca F, Tejedor JC, et al. (2010). Immunogenicity and safety of AS03-adjuvanted 2009 influenza A H1N1 vaccine in children 6-35 months. Vaccine.
229 Carniel EF, Antonio MARGM, Zanolli ML, et al. (2012). Estrategias de campo em ensaios clinicos com novas vacinas produzidas no Brasil. Revista Paulista de Pediatria.
230 Carr S, Allison KJ, Van De Velde LA, et al. (2011). Safety and immunogenicity of live attenuated and inactivated influenza vaccines in children with cancer. Journal of Infectious Diseases.
231 Carraro G, Naso A, Montomoli E, et al. (2012). Thymosin-alpha 1 (Zadaxin) enhances the immunogenicity of an adjuvated pandemic H1N1v influenza vaccine (Focetria) in hemodialyzed patients: a pilot study. Vaccine.
232 Cartwright K, Morris R, Rumke H, et al. (1999). Immunogenicity and reactogenicity in UK infants of a novel meningococcal vesicle vaccine containing multiple class 1 (PorA) outer membrane proteins. Vaccine.
233 Carvajal A, Ortega PG, Sainz M, et al. (2011). Adverse events associated with pandemic influenza vaccines: comparison of the results of a follow-up study with those coming from spontaneous reporting. Vaccine.
234 Castro JF, Bennett JV, Rincon HG, et al. (2005). Evaluation of immunogenicity and side effects of triple viral vaccine (MMR) in adults, given by two routes: subcutaneous and respiratory (aerosol). Vaccine.
235 Center KJ, Hansen JR, Lewis E, et al. (2009). Lack of association of Kawasaki disease after immunization in a cohort of infants followed for multiple autoimmune diagnoses in a large, phase-4 observational database safety study of 7-valent pneumococcal conjugate vaccine: lack of association between Kawasaki disease and seven-valent pneumococcal conjugate vaccine. Pediatric Infectious Disease Journal.
236 Center KJ, Strauss A. (2009). Safety experience with heptavalent pneumococcal CRM197-conjugate vaccine (Prevenar) since vaccine introduction. Vaccine.
237 Centers for Disease C, Prevention. (2004). Suspension of rotavirus vaccine after reports of intussusception--United States, 1999. MMWR - Morbidity & Mortality Weekly Report.
238 Centers for Disease C, Prevention. (2007). Postmarketing monitoring of intussusception after RotaTeq vaccination--United States, February 1, 2006-February 15, 2007. MMWR - Morbidity & Mortality Weekly Report.
239 Centers for Disease C, Prevention. (2011). Addition of history of intussusception as a contraindication for rotavirus vaccination. MMWR - Morbidity & Mortality Weekly Report.
240 Centers for Disease C, Prevention. (2012). Licensure of 13-valent pneumococcal conjugate vaccine for adults aged 50 years and older. MMWR - Morbidity & Mortality Weekly Report.
241 Centers for Disease C, Prevention, Advisory Committee on Immunization P. (2008). Update: recommendations from the Advisory Committee on Immunization Practices (ACIP) regarding administration of combination MMRV vaccine. MMWR Morb Mortal Wkly Rep.
242 Cerbino-Neto J, Santos AT, Gouvea MI, et al. (2012). Comparison of adverse events following immunization with pandemic influenza A (H1N1)pdm09 vaccine with or without adjuvant among health professionals in Rio de Janeiro, Brazil. Memorias do Instituto Oswaldo Cruz.
243 Chaibou MS, Bako H, Salisou L, et al. (2012). Monitoring adverse events following immunization with a new conjugate vaccine against group A meningococcus in Niger, September 2010. Vaccine.
244 Chandramohan D, Hodgson A, Coleman P, et al. (2007). An evaluation of the immunogenicity and safety of a new trivalent meningococcal polysaccharide vaccine. Vaccine.
245 Chandran A, Santosham M. (2008). RotaTeq: a three-dose oral pentavalent reassortant rotavirus vaccine. Expert Review of Vaccines.
246 Chandwani S, Beeler J, Li H, et al. (2011). Safety and immunogenicity of early measles vaccination in children born to HIV-infected mothers in the United States: results of Pediatric AIDS Clinical Trials Group (PACTG) protocol 225. Journal of Infectious Diseases.
247 Chang HG, Smith PF, Ackelsberg J, et al. (2001). Intussusception, rotavirus diarrhea, and rotavirus vaccine use among children in New York state. Pediatrics.
248 Chang S, Ball R, Braun MM. (2008). Elective termination of pregnancy after vaccination reported to the Vaccine Adverse Event Reporting System (VAERS): 1990-2006. Vaccine.
249 Chang S, O'Connor PM, Slade BA, et al. (2013). U.S. Postlicensure safety surveillance for adolescent and adult tetanus, diphtheria and acellular pertussis vaccines: 2005-2007. Vaccine.
250 Chang YT, Guo CY, Tsai MS, et al. (2012). Poor immune response to a standard single dose non-adjuvanted vaccination against 2009 pandemic H1N1 influenza virus A in the adult and elder hemodialysis patients. Vaccine.
251 Charkoudian LD, Kaiser GM, Steinmetz RL, et al. (2011). Acute retinal necrosis after herpes zoster vaccination. Archives of Ophthalmology.
252 Charman T. (2011). The highs and lows of counting autism. American Journal of Psychiatry.
253 Chatterjee A, O'Keefe C, Varman M, et al. (2012). Comparative immunogenicity and safety of different multivalent component pertussis vaccine formulations and a 5-component acellular pertussis vaccine in infants and toddlers: A randomized, controlled, open-label, multicenter study. Vaccine.
254 Chatterjee S, Rego SJ, D'Souza F, et al. (2010). The immunogenicity and safety of a reduced PRP-content DTPw-HBV/Hib vaccine when administered according to the accelerated EPI schedule. BMC Infectious Diseases.
255 Chavant F, Favreliere S, Lafay-Chebassier C, et al. (2011). Memory disorders associated with consumption of drugs: Updating through a case/noncase study in the French PharmacoVigilance Database. British Journal of Clinical Pharmacology.
256 Chavant F, Ingrand I, Jonville-Bera AP, et al. (2013). The PREGVAXGRIP Study: a Cohort Study to Assess Foetal and Neonatal Consequences of In Utero Exposure to Vaccination Against A(H1N1)v2009 Influenza. Drug Safety.
257 Chazono M, Hirota T, Yoshida I, et al. (1991). Safety follow-up in a cohort of Biken acellular DPT vaccine recipients in Japan. Developments in Biological Standardization.
258 Chen J, Heyse JF, Heaton P, et al. (2010). Age dependence of the risk of intussusception following [corrected] rhesus-human reassortant rotavirus tetravalent vaccine: is it beyond doubt?. American Journal of Epidemiology.
259 Chen J, Heyse JF, Heaton P, et al. (2010). Re: “Age Dependence of the Risk of Intussusception Following Tetravalent Rhesus-Human Reassortant Rotavirus Tetravalent Vaccine: Is It Beyond Doubt?” Reply. American Journal of Epidemiology.
260 Chen RT. (2004). Evaluation of vaccine safety after the events of 11 September 2001: Role of cohort and case-control studies. Vaccine.
261 Chen RT, Glasser JW, Rhodes PH, et al. (1997). Vaccine Safety Datalink project: a new tool for improving vaccine safety monitoring in the United States. The Vaccine Safety Datalink Team. Pediatrics.
262 Chen RT, Pool V, Takahashi H, et al. (2001). Combination vaccines: Postlicensure safety evaluation. Clinical Infectious Diseases.
263 Chen WH, Winokur PL, Edwards KM, et al. (2012). Phase 2 assessment of the safety and immunogenicity of two inactivated pandemic monovalent H1N1 vaccines in adults as a component of the U.S. pandemic preparedness plan in 2009. Vaccine.
264 Chen WH, Winokur PL, Edwards KM, et al. (2012). Phase 2 assessment of the safety and immunogenicity of two inactivated pandemic monovalent H1N1 vaccines in adults as a component of the U.S. pandemic preparedness plan in 2009. Vaccine.
265 Cheng HK, Rajadurai VS, Amin Z, et al. (2004). Immunogenicity and reactogenicity of two regimens of diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated polio and Haemophilus influenzae type b vaccines administered to infants primed at birth with hepatitis B vaccine. Southeast Asian Journal of Tropical Medicine & Public Health.
266 Cheong HJ, Song JY, Heo JY, et al. (2011). Immunogenicity and safety of influenza A (H1N1) 2009 monovalent inactivated split vaccine in Korea. Vaccine.
267 Cheong HJ, Song JY, Heo JY, et al. (2011). Immunogenicity and safety of the influenza A/H1N1 2009 inactivated split-virus vaccine in young and older adults: MF59-adjuvanted vaccine versus nonadjuvanted vaccine. Clinical & Vaccine Immunology: CVI.
268 Cherian T, Thomas N, Raghupathy P, et al. (2002). Safety and immunogenicity of Haemophilus influenzae type B vaccine given in combination with DTwP at 6, 10 and 14 weeks of age. Indian Pediatrics.
269 Chevallier B, Vesikari T, Brzostek J, et al. (2009). Safety and reactogenicity of the 10-valent pneumococcal non-typeable Haemophilus influenzae protein D conjugate vaccine (PHiD-CV) when coadministered with routine childhood vaccines. Pediatric Infectious Disease Journal.
270 Chi RC, Rock MT, Neuzil KM. (2010). Immunogenicity and safety of intradermal influenza vaccination in healthy older adults. Clinical Infectious Diseases.
271 Chioato A, Noseda E, Felix SD, et al. (2010). Influenza and meningococcal vaccinations are effective in healthy subjects treated with the interleukin-1 beta-blocking antibody canakinumab: results of an open-label, parallel group, randomized, single-center study. Clinical & Vaccine Immunology: CVI.
272 Chippaux JP, Garba A, Ethevenaux C, et al. (2004). Immunogenicity, safety, and memory of different schedules of Neisseria meningitidis A/C-diphtheria toxoid conjugate vaccine in infants in Niger. Vaccine.
273 Chiu HH, Huang LM, Lee PI, et al. (1998). Diphtheria, tetanus and whole cell pertussis vaccine combined with hepatitis B vaccines: A comparison of two doses (10 (mu)g and 5 (mu)g). Pediatric Infectious Disease Journal.
274 Choe YJ, Cho H, Bae GR, et al. (2011). Guillain-Barre syndrome following receipt of influenza A (H1N1) 2009 monovalent vaccine in Korea with an emphasis on Brighton Collaboration case definition. Vaccine.
275 Choe YJ, Cho H, Kim SN, et al. (2011). Serious adverse events following receipt of trivalent inactivated influenza vaccine in Korea, 2003-2010. Vaccine.
276 Choe YJ, Cho H, Song KM, et al. (2011). Active surveillance of adverse events following immunization against pandemic influenza A (H1N1) in Korea. Japanese Journal of Infectious Diseases.
277 Choi JH, Choo EJ, Huh A, et al. (2010). Immunogenicity and safety of diphtheria-tetanus vaccine in adults. Journal of Korean Medical Science.
278 Choi U, Lee SY, Kwak GY, et al. (2011). Immunogenicity and safety of primary and secondary DTaP booster vaccination. Journal of the Korean Medical Association.
279 Choo S, Zuckerman J, Goilav C, et al. (2000). Immunogenicity and reactogenicity of a group C meningococcal conjugate vaccine compared with a group A+C meningococcal polysaccharide vaccine in adolescents in a randomised observer-blind controlled trial. Vaccine.
280 Chou JF, Kernan NA, Prockop S, et al. (2011). Safety and immunogenicity of the live attenuated varicella vaccine following T replete or T cell-depleted related and unrelated allogeneic hematopoietic cell transplantation (alloHCT). Biology of Blood & Marrow Transplantation.
281 Chouraqui JP, Van Egroo LD, Fichot MC. (2004). Acidified milk formula supplemented with bifidobacterium lactis: Impact on infant diarrhea in residential care settings. Journal of Pediatric Gastroenterology and Nutrition.
282 Christenson B, Lundbergh P, Hedlund J, et al. (2001). Effects of a large-scale intervention with influenza and 23-valent pneumococcal vaccines in adults aged 65 years or older: a prospective study. Lancet.
283 Christie CDC, Duncan ND. (2012). Rotavirus vaccine trial in Jamaica. West Indian Medical Journal.
284 Christou EM, Wargon O. (2012). Stevens-Johnson syndrome after varicella vaccination. Medical Journal of Australia.
285 Chu DWS, Kwong ASK, Tsui WWS, et al. (2011). Cross-clade immunogenicity and safety of an AS03A-adjuvanted prepandemic H5N1 influenza vaccine in Hong Kong. Hong Kong Medical Journal.
286 Ciarlet M, He S, Lai S, et al. (2009). Concomitant use of the 3-dose oral pentavalent rotavirus vaccine with a 3-dose primary vaccination course of a diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated polio-Haemophilus influenzae type b vaccine: immunogenicity and reactogenicity. Pediatric Infectious Disease Journal.
287 Ciarlet M, Sani-Grosso R, Yuan G, et al. (2008). Concomitant use of the oral pentavalent human-bovine reassortant rotavirus vaccine and oral poliovirus vaccine. Pediatric Infectious Disease Journal.
288 Ciarlet M, Schodel F. (2009). Development of a rotavirus vaccine: clinical safety, immunogenicity, and efficacy of the pentavalent rotavirus vaccine, RotaTeq. Vaccine.
289 Citron ML, Moss BM. (1982). Pneumococcal-vaccine-induced thrombocytopenia. JAMA.
290 Claesson BA, Trollfors B, Lagergard T, et al. (1988). Clinical and immunologic responses to the capsular polysaccharide of Haemophilus influenzae type b alone or conjugated to tetanus toxoid in 18- to 23-month-old children. Journal of Pediatrics.
291 Clarke M, Marshall H. (2012). Rotavirus vaccination for prevention of serious acute gastroenteritis and the importance of postlicensure safety monitoring. Journal of Infectious Diseases.
292 Clarke SC. (2006). Control of pneumococcal disease in the United Kingdom - The start of a new era. Journal of Medical Microbiology.
293 Clarkson A, Conroy S, Burroughs K, et al. (2004). Surveillance for adverse drug reactions in children: A paediatric regional monitoring centre. Paediatric and Perinatal Drug Therapy.
294 Classen JB, Classen DC. (1999). Association between type 1 diabetes and hib vaccine. Causal relation is likely. BMJ.
295 Clements KM, Chancellor J, Nichol K, et al. (2011). Cost-effectiveness of a recommendation of universal mass vaccination for seasonal influenza in the United States. Value in Health.
296 Clements-Mann ML, Wright PF, Hoshino Y, et al. (1999). Safety and immunogenicity of live attenuated human-bovine (UK) reassortant rotavirus vaccines with VP7-specificity for serotypes 1, 2, 3 or 4 in adults, children and infants. Vaccine.
297 Clerici M, Rizzardini G, Cossu MV, et al. (2011). Probiotic strains BB-12(registered trademark) and L. casei 431(registered trademark) increase the immune response to an influenza vaccine: A randomized, double-blind, placebo-controlled study. European Journal of Pharmacology.
298 Clifford V, Crawford NW, Royle J, et al. (2011). Recurrent apnoea post immunisation: Informing re-immunisation policy. Vaccine.
299 Clothier HJ, Lee KJ, Sundararajan V, et al. (2013). Human papillomavirus vaccine in boys: background rates of potential adverse events. Medical Journal of Australia.
300 Cohen J. (2001). Medicine. Rethinking a vaccine's risk. Science.
301 Coleman BL, McGeer AJ, Halperin SA, et al. (2012). A randomized control trial comparing immunogenicity, safety, and preference for self- versus nurse-administered intradermal influenza vaccine. Vaccine.
302 Collignon P, Doshi P, Jefferson T. (2010). Ramifications of adverse events in children in Australia. BMJ.
303 Collins CL, Salt P, McCarthy N, et al. (2004). Immunogenicity and safety of a low-dose diphtheria, tetanus and acellular pertussis combination vaccine with either inactivated or oral polio vaccine as a pre-school booster in UK children. Vaccine.
304 Committee on Obstetric P. (2012). ACOG Committee Opinion No. 521: Update on immunization and pregnancy: tetanus, diphtheria, and pertussis vaccination. Obstetrics & Gynecology.
305 Conlin AM, Bukowinski AT, Sevick CJ, et al. (2013). Safety of the pandemic H1N1 influenza vaccine among pregnant U.S. military women and their newborns. Obstetrics & Gynecology.
306 Cook IF, Pond D, Hartel G. (2007). Comparative reactogenicity and immunogenicity of 23 valent pneumococcal vaccine administered by intramuscular or subcutaneous injection in elderly adults. Vaccine.
307 Cook J. (2010). Australian experience with non-adjuvant H1N1 vaccine (Panvax and Panvax Junior). Australian Prescriber.
308 Cook KM, Evans G. (2011). The national vaccine injury compensation program. Pediatrics.
309 Cooper C, Klein M, Walmsley S, et al. (2012). High-level immunogenicity is achieved vaccine with adjuvanted pandemic H1N1(2009) and improved with booster dosing in a randomized trial of HIV-infected adults. HIV Clinical Trials.
310 Cooper C, Mackie D. (2011). Hepatitis B surface antigen-1018 ISS adjuvant-containing vaccine: a review of HEPLISAV (TM) safety and efficacy. Expert Review of Vaccines.
311 Cooper C, Thorne A, Canadian Institutes of Health Research-Canadian HIVTNIVRG. (2011). Influenza vaccine oculorespiratory syndrome incidence is reduced in HIV. Vaccine.
312 Cooper C, Thorne A, Klein M, et al. (2011). Immunogenicity is not improved by increased antigen dose or booster dosing of seasonal influenza vaccine in a randomized trial of HIV infected adults. PLoS ONE.
313 Cooper PA, Madhi SA, Huebner RE, et al. (2008). Apnea and its possible relationship to immunization in ex-premature infants. Vaccine.
314 Cordero E, Perez-Ordonez A, Aydillo TA, et al. (2011). Therapy with m-TOR inhibitors decreases the response to the pandemic influenza A H1N1 vaccine in solid organ transplant recipients. American Journal of Transplantation.
315 Cordonnier C, Labopin M, Chesnel V, et al. (2010). Immune response to the 23-valent polysaccharide pneumococcal vaccine after the 7-valent conjugate vaccine in allogeneic stem cell transplant recipients: Results from the EBMT IDWP01 trial. Vaccine.
316 Correia O, Nunes JP, Vaz-da-Silva MJ, et al. (1993). Acute exanthematous pustular dermatitis after pneumococcal vaccine [3]. Dermatology.
317 Coursaget P, Bringer L, Sarr G, et al. (1992). Comparative immunogenicity in children of mammalian cell-derived recombinant hepatitis B vaccine and plasma-derived hepatitis B vaccine. Vaccine.
318 Couzin-Frankel J. (2010). New network to track drugs and vaccines in pregnancy. Science.
319 Crawford N. (2012). Immunizations in children with cancer. Paediatrics and Child Health.
320 Crespo M, Collado S, Mir M, et al. (2011). Efficacy of influenza A H1N1/2009 vaccine in hemodialysis and kidney transplant patients. Clinical Journal of The American Society of Nephrology: CJASN.
321 Cristiani C, Tuccori M, Pepe P, et al. (2011). Safety of MF-59 adjuvanted vaccine for pandemic influenza: results of the vaccination campaign in an Italian health district. Vaccine.
322 Cronin J, Scorr A, Russell S, et al. (2012). A review of a paediatric emergency department vaccination programme for patients at risk of allergy/anaphylaxis. Acta Paediatrica.
323 Croxtall JD, Dhillon S. (2012). Meningococcal quadrivalent (serogroups A, C, W135 and Y) tetanus toxoid conjugate vaccine (NimenrixTM). Drugs.
324 Crum-Cianflone NF, Eberly LE, Duplessis C, et al. (2011). Immunogenicity of a monovalent 2009 influenza a (H1N1) vaccine in an immunocompromised population: A prospective study comparing HIV-infected adults with HIV-uninfected adults. Clinical Infectious Diseases.
325 Crum-Cianflone NF, Hullsiek KH, Roediger M, et al. (2010). A randomized clinical trial comparing revaccination with pneumococcal conjugate vaccine to polysaccharide vaccine among HIV-infected adults. Journal of Infectious Diseases.
326 Cserti-Gazdewich CM, Pendergrast JM, Reis M. (2009). Postvaccination hyperhemolysis coinciding with remission of Epstein Barr virus (EBV)-associated immune thrombocytopenic purpura (ITP). American Journal of Hematology.
327 Cuba IPVSCG. (2007). Randomized, placebo-controlled trial of inactivated poliovirus vaccine in Cuba. New England Journal of Medicine.
328 Cullen G, Baden RP, Cheifetz AS. (2011). Vaccination in inflammatory bowel disease. American Journal of Gastroenterology.
329 Cunningham CK, Rudy BJ, Xu J, et al. (2010). Randomized trial to determine safety and immunogenicity of two strategies for hepatitis B vaccination in healthy urban adolescents in the United States. Pediatric Infectious Disease Journal.
330 Cutts FT, Franceschi S, Goldie S, et al. (2007). Human papillomavirus and HPV vaccines: A review. Bulletin of the World Health Organization.
331 Czajka H, Volker S, Fred Z, et al. (2012). A combined measles, mumps, rubella and varicella vaccine (Priorix-Tetra(trademark)): Immunogenicity and safety profile. Vaccine.
332 D'Acremont V, Tremblay S, Genton B. (2008). Impact of vaccines given during pregnancy on the offspring of women consulting a travel clinic: a longitudinal study. Journal of Travel Medicine.
333 Dagan R. (2002). Immunisation with a pneumococcal 7-valent conjugate vaccine. International Journal of Clinical Practice.
334 Dagan R, Amir J, Livni G, et al. (2007). Concomitant administration of a virosome-adjuvanted hepatitis a vaccine with routine childhood vaccines at age twelve to fifteen months: a randomized controlled trial. Pediatric Infectious Disease Journal.
335 Dagan R, Igbaria K, Piglansky L, et al. (1997). Safety and immunogenicity of a combined pentavalent diphtheria, tetanus, acellular pertussis, inactivated poliovirus and Haemophilus influenzae type b-tetanus conjugate vaccine in infants, compared with a whole cell pertussis pentavalent vaccine. Pediatric Infectious Disease Journal.
336 Dagan R, Kayhty H, Wuorimaa T, et al. (2004). Tolerability and immunogenicity of an eleven valent mixed carrier Streptococcus pneumoniae capsular polysaccharide-diphtheria toxoid or tetanus protein conjugate vaccine in Finnish and Israeli infants. Pediatric Infectious Disease Journal.
337 D'Alessandro D, Ciriminna S, Rossini A, et al. (2004). Requests of medical examinations after pneumococcal & influenza vaccination in the elderly. Indian Journal of Medical Research.
338 Dallar Y, Bostanci I, Bozdayi G, et al. (2009). Rotavirus-associated intussusception followed by spontaneous resolution. Turkish Journal of Gastroenterology.
339 Damm O, Rose MA, Greiner W, et al. (2011). Cost-effectiveness of vaccinating children aged 2-17 years with intranasal live attenuated influenza vaccine (LAIV) in germany. Value in Health.
340 Daum RS, Hogerman D, Rennels MB, et al. (1997). Infant immunization with pneumococcal CRM197 vaccines: effect of saccharide size on immunogenicity and interactions with simultaneously administered vaccines. Journal of Infectious Diseases.
341 David S, Vermeer-de Bondt PE, van der Maas NAT. (2008). Reactogenicity of infant whole cell pertussis combination vaccine compared with acellular pertussis vaccines with or without simultaneous pneumococcal vaccine in the Netherlands. Vaccine.
342 Davidson G, Elliott EJ, Kirkwood C, et al. (2007). Preventing rotavirus gastroenteritis: do you have the facts?. Journal of Paediatrics & Child Health.
343 Davidson LE, Fiorino AM, Snydman DR, et al. (2011). Lactobacillus GG as an immune adjuvant for live-attenuated influenza vaccine in healthy adults: a randomized double-blind placebo-controlled trial. European Journal of Clinical Nutrition.
344 Davis RL, Marcuse E, Black S, et al. (1997). MMR2 immunization at 4 to 5 years and 10 to 12 years of age: a comparison of adverse clinical events after immunization in the Vaccine Safety Datalink project. The Vaccine Safety Datalink Team. Pediatrics.
345 Dayan GH, Thorley M, Yamamura Y, et al. (2007). Serologic response to inactivated poliovirus vaccine: A randomized clinical trial comparing 2 vaccination schedules in Puerto Rico. Journal of Infectious Diseases.
346 Dbaibo G, Van der Wielen M, Reda M, et al. (2012). The tetravalent meningococcal serogroups A, C, W-135, and Y tetanus toxoid conjugate vaccine is immunogenic with a clinically acceptable safety profile in subjects previously vaccinated with a tetravalent polysaccharide vaccine. International Journal of Infectious Diseases.
347 D'Cruz OF, Shapiro ED, Spiegelman KN, et al. (1989). Acute inflammatory demyelinating polyradiculoneuropathy (Guillain-Barre syndrome) after immunization with Haemophilus influenzae type b conjugate vaccine. Journal of Pediatrics.
348 De Aristegui Fernandez J, Cos Arregui B, Zurimendi Carril A, et al. (2005). Evaluation of the safety and immunogenicity of pneumococcal seven-valent conjugate vaccine (Prevenar(registered trademark)) administered in previously unvaccinated Spanish children aged 24 to 36 months. Vaccine.
349 de Aristegui Fernandez J, Cos Arregui B, Zurimendi Carril A, et al. (2005). Evaluation of the safety and immunogenicity of pneumococcal seven-valent conjugate vaccine (Prevenar) administered in previously unvaccinated Spanish children aged 24 to 36 months. Vaccine.
350 de Carvalho JF, Shoenfeld Y. (2008). Status epilepticus and lymphocytic pneumonitis following hepatitis B vaccination. European Journal of Internal Medicine.
351 De Roux A, Schmoele-Thoma B, Siber GR, et al. (2008). Comparison of pneumococcal conjugate polysaccharide and free polysaccharide vaccines in elderly adults: Conjugate vaccine elicits improved antibacterial immune responses and immunological memory. Clinical Infectious Diseases.
352 de Roux A, Schmole-Thoma B, Siber GR, et al. (2008). Comparison of pneumococcal conjugate polysaccharide and free polysaccharide vaccines in elderly adults: conjugate vaccine elicits improved antibacterial immune responses and immunological memory. Clinical Infectious Diseases.
353 De Schryver A, Verstrepen K, Vandersmissen L, et al. (2011). Comparative immunogenicity of two vaccination schedules of a combined hepatitis A and B vaccine in healthy volunteers. Journal of Viral Hepatitis.
354 de Serres G, Gariepy MC, Coleman B, et al. (2012). Short and long-term safety of the 2009 AS03-adjuvanted pandemic vaccine. PLoS ONE.
355 De Sousa A, Rabarijaona LP, Tenkorang O, et al. (2012). Pharmacovigilance of malaria intermittent preventive treatment in infants coupled with routine immunizations in 6 African countries. Journal of Infectious Diseases.
356 De Wals P, Black S, Borrow R, et al. (2009). Modeling the impact of a new vaccine on pneumococcal and nontypable Haemophilus influenzae diseases: A new simulation model. Clinical Therapeutics.
357 de Whalley P, Walker W, Snape MD, et al. (2011). A 1-year follow-on study from a randomised, head-to-head, multicentre, open-label study of two pandemic influenza vaccines in children. Health Technology Assessment (Winchester, England).
358 deBruyn JC, Hilsden R, Fonseca K, et al. (2012). Immunogenicity and safety of influenza vaccination in children with inflammatory bowel disease. Inflammatory Bowel Diseases.
359 deBruyn JCC, Hilsden R, Fonseca K, et al. (2012). Immunogenicity and safety of influenza vaccination in children with inflammatory bowel disease. Inflammatory Bowel Diseases.
360 Decker MD, Edwards KM, Bradley R, et al. (1992). Comparative trial in infants of four conjugate Haemophilus influenzae type b vaccines. Journal of Pediatrics.
361 Deeks SL, Lim GH, Simpson MA, et al. (2011). Estimating background rates of Guillain-Barre Syndrome in Ontario in order to respond to safety concerns during pandemic H1N1/09 immunization campaign. BMC Public Health.
362 Deforest A, Long SS, Lischner HW, et al. (1988). Simultaneous administration of measles-mumps-rubella vaccine with booster doses of diphtheria-tetanus-pertussis and poliovirus vaccines. Pediatrics.
363 Deivanayagam N, Nedunchelian K, Ahamed SS, et al. (1993). Intramuscular injection as a provoking factor for paralysis in acute poliomyelitis. A case control study. Indian Pediatrics.
364 Della Cioppa G, Nicolay U, Lindert K, et al. (2012). Superior immunogenicity of seasonal influenza vaccines containing full dose of MF59 ([REGISTERED]) adjuvant: results from a dose-finding clinical trial in older adults. Human vaccines & Immunotherapeutics.
365 Della Cioppa G, Nicolay U, Lindert K, et al. (2012). Superior immunogenicity of seasonal influenza vaccines containing full dose of MF59 () adjuvant: results from a dose-finding clinical trial in older adults. Human vaccines & Immunotherapeutics.
366 Della Cioppa G, Vesikari T, Sokal E, et al. (2011). Trivalent and quadrivalent MF59((registered trademark))-adjuvanted influenza vaccine in young children: A dose- and schedule-finding study. Vaccine.
367 Dell'Era L, Corona F, Daleno C, et al. (2012). Immunogenicity, safety and tolerability of MF59-adjuvanted seasonal influenza vaccine in children with juvenile idiopathic arthritis. Vaccine.
368 Delong G. (2011). A positive association found between autism prevalence and childhood vaccination uptake across the U.S. population. Journal of Toxicology and Environmental Health - Part A: Current Issues.
369 Deng MP, Hu ZH, Wang HL, et al. (2012). Developments of subunit and VLP vaccines against influenza a virus. Virologica Sinica.
370 Denholm JT, Neal A, Yan B, et al. (2010). Acute encephalomyelitis syndromes associated with H1N1 09 influenza vaccination. Neurology.
371 Dennehy PH, North American Human Rotavirus Vaccine Study G. (2006). A short report on the highlights of world-wide development of RIX4414: a North American experience comparative evaluation of safety and immunogenicity of two dosages of an oral live attenuated human rotavirus vaccine (RIX4414) in infants in the United States and Canada. Vaccine.
372 Desai R, Cortese MM, Meltzer MI, et al. (2012). Potential intussusception risk versus benefits of rotavirus vaccination in the United States. Pediatric Infectious Disease Journal.
373 Desai R, Parashar UD, Lopman B, et al. (2012). Potential intussusception risk versus health benefits from rotavirus vaccination in Latin America. Clinical Infectious Diseases.
374 DeStefano F, Vaccine Safety Datalink Research G. (2001). The Vaccine Safety Datalink project. Pharmacoepidemiology & Drug Safety.
375 DeStefano F, Weintraub ES, Chen RT. (2005). Recombinant hepatitis B vaccine and the risk of multiple sclerosis: a prospective study. Neurology.
376 DeWilde S, Carey IM, Richards N, et al. (2001). Do children who become autistic consult more often after MMR vaccination?. Br J Gen Pract.
377 DeWolfe Miller F. (2001). Intussusception and an oral rotavirus vaccine. New England Journal of Medicine.
378 Dhingra MS, Rao R, Bhat S, et al. (2010). Evaluation of the immunogenicity and safety of an indigenously developed DTwP-Hib tetravalent combination vaccine (Shan 4) with EasyFourTM in Indian infants administered per EPI schedule: a phase III trial. Human Vaccines.
379 Di Lernia V, Ricci C. (2006). Skin manifestations with Rotavirus infections. International Journal of Dermatology.
380 DiazGranados CA, Dunning AJ, Jordanov E, et al. (2013). High-dose trivalent influenza vaccine compared to standard dose vaccine in elderly adults: safety, immunogenicity and relative efficacy during the 2009-2010 season. Vaccine.
381 Diaz-Mitoma F, Halperin SA, Tapiero B, et al. (2011). Safety and immunogenicity of three different formulations of a liquid hexavalent diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae b conjugate-hepatitis B vaccine at 2, 4, 6 and 12-14 months of age. Vaccine.
382 Diaz-Ortega JL, Bennett JV, Castaneda D, et al. (2010). Successful seroresponses to measles and rubella following aerosolized Triviraten vaccine, but poor response to aerosolized mumps (Rubini) component: Comparisons with injected MMR. Vaccine.
383 Diaz-Ortega JL, Bennett JV, Castaneda D, et al. (2012). Aerosolized MMR vaccine: Evaluating potential transmission of components to vaccine administrators and contacts of vaccinees. Biologicals.
384 Dicko A, Odusanya OO, Diallo AI, et al. (2011). Primary vaccination with the 10-valent pneumococcal non-typeable Haemophilus influenzae protein D conjugate vaccine (PHiD-CV) in infants in Mali and Nigeria: a randomized controlled trial. BMC Public Health.
385 Diez-Domingo J, Cantarino MVP, Torrenti JMB, et al. (2010). A randomized, multicenter, open-label clinical trial to assess the immunogenicity of a meningococcal C vaccine booster dose administered to children aged 14 to 18 months. Pediatric Infectious Disease Journal.
386 Diez-Domingo J, Delgado JD, Ballester A, et al. (2005). Immunogenicity and reactogenicity of a combined adsorbed tetanus toxoid, low dose diphtheria toxoid, five component acellular pertussis and inactivated polio vaccine in six-year-old children. Pediatric Infectious Disease Journal.
387 Diez-Domingo J, Flores SA, Martin JC, et al. (2010). A Randomized, Multicenter, Open-Label Clinical Trial to Assess the Anamnestic Immune Response 4 to 8 Years after a Primary Hepatitis B Vaccination Series. Pediatric Infectious Disease Journal.
388 Dinleyici EC, Yargic ZA. (2009). Pneumococcal conjugated vaccine: PHiD-CV. Expert Review of Antiinfective Therapy.
389 Dip RM, Cabrera MAS. (2010). Influenza vaccination in non-institutionalized elderly: a population-based study in a medium-sized city in Southern Brazil. Cadernos de Saude Publica.
390 Domachowske JB, Blatter M, Chandrasekaran V, et al. (2012). A Randomized, Controlled Trial in Children to Assess the Immunogenicity and Safety of a Thimerosal-free Trivalent Seasonal Influenza Vaccine. Pediatric Infectious Disease Journal.
391 Domachowske JB, Pankow-Culot H, Bautista M, et al. (2013). A Randomized Trial of Candidate Inactivated Quadrivalent Influenza Vaccine versus Trivalent Influenza Vaccines in Children Aged 3-17 Years. Journal of Infectious Diseases.
392 Donalisio MR, Rodrigues SMCP, Mendes ET, et al. (2007). Adverse events after pneumococcal vaccination. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia.
393 Donato CM, Ch'Ng LS, Boniface KF, et al. (2012). Identification of strains of rotateq rotavirus vaccine in infants with gastroenteritis following routine vaccination. Journal of Infectious Diseases.
394 Donnini I, Scappini B, Guidi S, et al. (2012). Acquired severe aplastic anemia after H1N1 influenza virus vaccination successfully treated with allogeneic bone marrow transplantation. Annals of Hematology.
395 Dransfield MT, Harnden S, Burton RL, et al. (2012). Long-term comparative immunogenicity of protein conjugate and free polysaccharide pneumococcal vaccines in chronic obstructive pulmonary disease. Clinical Infectious Diseases.
396 Dransfield MT, Nahm MH, Han MK, et al. (2009). Superior immune response to protein-conjugate versus free pneumococcal polysaccharide vaccine in chronic obstructive pulmonary disease. American Journal of Respiratory and Critical Care Medicine.
397 Drees M, Tambourelli B, Denstman A, et al. (2013). Sustained high influenza vaccination rates and decreased safety concerns among pregnant women during the 2010-2011 influenza season. Vaccine.
398 Drucker J. (1991). Poliomyelitis in France: epidemiology and vaccination status. Pediatric Infectious Disease Journal.
399 Duff P. (2013). Influenza vaccine: a safe bet for mother and baby. Obstetrics & Gynecology.
400 Duggan ST. (2012). Pneumococcal polysaccharide conjugate vaccine (13-valent, adsorbed) [Prevenar 13([REGISTERED])]: profile report. Paediatric Drugs.
401 Duggan ST, Plosker GL. (2010). Intanza(registered trademark) 15(mu)g intradermal seasonal influenza vaccine: In older adults (aged (greater-than or equal to)60 Years). Drugs and Aging.
402 Durando P, Alicino C, De Florentiis D, et al. (2012). Improving the protection against Streptococcus pneumoniae with the new generation 13-valent pneumococcal conjugate vaccine. Journal of Preventive Medicine and Hygiene.
403 Dutta AK, Verghese VP, Pemde HK, et al. (2009). Immunogenicity and safety of a pentavalent diphtheria, tetanus, acellular pertussis, inactivated poliovirus, Haemophilus influenzae type B conjugate combination vaccine (Pentaxim) with hepatitis B vaccine. Indian Pediatrics.
404 Edelman R. (1987). Perspective on the development and deployment of rotavirus vaccines. Pediatric Infectious Disease Journal.
405 Ehrlich HJ, Muller M, Kollaritsch H, et al. (2012). Pre-vaccination immunity and immune responses to a cell culture-derived whole-virus H1N1 vaccine are similar to a seasonal influenza vaccine. Vaccine.
406 Einstein MH, Baron M, Levin MJ, et al. (2011). Comparative immunogenicity and safety of human papillomavirus (HPV)-16/18 vaccine and HPV-6/11/16/18 vaccine: follow-up from months 12-24 in a Phase III randomized study of healthy women aged 18-45 years. Human Vaccines.
407 El Bashir H, Heath PT, Papa T, et al. (2006). Antibody responses to meningococcal (groups A, C, Y and W135) polysaccharide diphtheria toxoid conjugate vaccine in children who previously received meningococcal C conjugate vaccine. Vaccine.
408 El Sahly H. (2010). MF59(trademark) as a vaccine adjuvant: A review of safety and immunogenicity. Expert Review of Vaccines.
409 El Sahly HM, Davis C, Kotloff K, et al. (2012). Higher antigen content improves the immune response to 2009 H1N1 influenza vaccine in HIV-infected adults: A randomized clinical trial. Journal of Infectious Diseases.
410 El-Darouti MA, Hegazy RA, Abdel Hay RM, et al. (2012). Live attenuated varicella vaccine: A new effective adjuvant weapon in the battlefield against severe resistant psoriasis, a pilot randomized controlled trial. Journal of the American Academy of Dermatology.
411 Elkayam O, Ablin J, Caspi D. (2007). Safety and efficacy of vaccination against streptococcus pneumonia in patients with rheumatic diseases. Autoimmunity Reviews.
412 Elkayam O, Amir S, Mendelson E, et al. (2011). Efficacy and safety of vaccination against pandemic 2009 influenza A (H1N1) virus among patients with rheumatic diseases. Arthritis care & research.
413 Elkayam O, Paran D, Caspi D, et al. (2002). Immunogenicity and safety of pneumococcal vaccination in patients with rheumatoid arthritis or systemic lupus erythematosus. Clinical Infectious Diseases.
414 Ellenberg SS, Foulkes MA, Midthun K, et al. (2005). Evaluating the safety of new vaccines: Summary of a workshop. American Journal of Public Health.
415 Ellison VJ, Davis PG, Doyle LW. (2005). Adverse reactions to immunization with newer vaccines in the very preterm infant. Journal of Paediatrics & Child Health.
416 Engels EA, Chen J, Viscidi RP, et al. (2004). Poliovirus vaccination during pregnancy, maternal seroconversion to simian virus 40, and risk of childhood cancer. American Journal of Epidemiology.
417 Englund JA, Glezen WP. (2000). Passive immunization for the prevention of otitis media. Vaccine.
418 Englund JA, Walter EB, Gbadebo A, et al. (2006). Immunization with trivalent inactivated influenza vaccine in partially immunized toddlers. Pediatrics.
419 Eriksson KaH, Jan. (2002). Recent advances in mucosal vaccines and adjuvants. Current Opinion in Immunology.
420 Escolano S, Farrington CP, Hill C, et al. (2011). Intussusception after rotavirus vaccination--spontaneous reports. New England Journal of Medicine.
421 Eskola J, Kilpi T, Palmu A, et al. (2001). Efficacy of a pneumococcal conjugate vaccine against acute otitis media. New England Journal of Medicine.
422 Eskola J, Olander RM, Hovi T, et al. (1996). Randomised trial of the effect of co-administration with acellular pertussis DTP vaccine on immunogenicity of Haemophilus influenzae type b conjugate vaccine. Lancet.
423 Espinosa-Padilla SE, Murata C, Estrada-Parra S, et al. (2012). Immunogenicity of A 23-Valent Pneumococcal Polysaccharide Vaccine Among Mexican Children. Archives of Medical Research.
424 Esposito S, Daleno C, Picciolli I, et al. (2011). Immunogenicity and safety of intradermal influenza vaccine in children. Vaccine.
425 Esposito S, D'Angelo E, Daleno C, et al. (2010). Immunogenicity, safety and tolerability of monovalent 2009 pandemic influenza A/H1N1 MF59-adjuvanted vaccine in patients with beta-thalassemia major. Vaccine.
426 Esposito S, Marchisio P, Ansaldi F, et al. (2010). A randomized clinical trial assessing immunogenicity and safety of a double dose of virosomal-adjuvanted influenza vaccine administered to unprimed children aged 6-35 months. Vaccine.
427 Esposito S, Meregalli E, Daleno C, et al. (2011). An open-label, randomized clinical trial assessing immunogenicity, safety and tolerability of pandemic influenza A/H1N1 MF59-adjuvanted vaccine administered sequentially or simultaneously with seasonal virosomal-adjuvanted influenza vaccine to paediatric kidney transplant recipients. Nephrology Dialysis Transplantation.
428 Esposito S, Pugni L, Bosis S, et al. (2005). Immunogenicity, safety and tolerability of heptavalent pneumococcal conjugate vaccine administered at 3, 5 and 11 months post-natally to pre- and full-term infants. Vaccine.
429 Esposito S, Pugni L, Daleno C, et al. (2011). Influenza A/H1N1 MF59-adjuvanted vaccine in preterm and term children aged 6 to 23 months. Pediatrics.
430 Esposito S, Selicorni A, Daleno C, et al. (2011). Immunogenicity, safety and tolerability of monovalent 2009 pandemic influenza A/H1N1 MF59-adjuvanted vaccine in children and adolescents with Williams or Cornelia De Lange syndrome. Human Vaccines.
431 Esposito S, Tagliaferri L, Daleno C, et al. (2011). Pandemic influenza A/H1N1 vaccine administered sequentially or simultaneously with seasonal influenza vaccine to HIV-infected children and adolescents. Vaccine.
432 Esposito S, Tansey S, Thompson A, et al. (2010). Safety and immunogenicity of a 13-valent pneumococcal conjugate vaccine compared to those of a 7-valent pneumococcal conjugate vaccine given as a three-dose series with routine vaccines in healthy infants and toddlers. Clinical & Vaccine Immunology: CVI.
433 Esteghamati A, Keshtkar A, Heshmat R, et al. (2011). Adverse reactions following immunization with MMR vaccine in children at selected provinces of Iran. Archives of Iranian Medicine.
434 Estivariz CF, Molnar Z, Venczel L, et al. (2011). Paralytic poliomyelitis associated with Sabin monovalent and bivalent oral polio vaccines in Hungary. American Journal of Epidemiology.
435 Fabrizi F, Dixit V, Messa P, et al. (2011). Intradermal vs intramuscular vaccine against hepatitis B infection in dialysis patients: a meta-analysis of randomized trials. Journal of Viral Hepatitis.
436 Fabrizi F, Dixit V, Messa P, et al. (2012). Hepatitis B virus vaccine in chronic kidney disease: Improved immunogenicity by adjuvants? A meta-analysis of randomized trials. Vaccine.
437 Faingezicht I, Avila-Aguerro ML, Cervantes Y, et al. (2002). Primary and booster vaccination with DTPw-HB/Hib pentavalent vaccine in Costa Rican children who had received a birth dose of hepatitis B vaccine. Pan American Journal of Public Health.
438 Fairley CK, Begg N, Borrow R, et al. (1996). Conjugate meningococcal serogroup A and C vaccine: reactogenicity and immunogenicity in United Kingdom infants. Journal of Infectious Diseases.
439 Faldella G, Galletti S, Corvaglia L, et al. (2007). Safety of DTaP-IPV-HIb-HBV hexavalent vaccine in very premature infants. Vaccine.
440 Falvo C, Horowitz H. (1994). Adverse reactions associated with simultaneous administration of multiple vaccines to travelers. Journal of General Internal Medicine.
441 Farr C. (2007). Intussusception alert. Nursing.
442 Farrell RA. (2012). Comment: Human papillomavirus vaccination, induced autoimmunity, and neuromyelitis optica. Neurology.
443 Feikin DR, Elie CM, Goetz MB, et al. (2001). Randomized trial of the quantitative and functional antibody responses to a 7-valent pneumococcal conjugate vaccine and/or 23-valent polysaccharide vaccine among HIV-infected adults. Vaccine.
444 Felldin M, Studahl M, Svennerholm B, et al. (2012). The antibody response to pandemic H1N1 2009 influenza vaccine in adult organ transplant patients. Transplant International.
445 Ferguson M, Risi G, Davis M, et al. (2012). Safety and long-term humoral immune response in adults after vaccination with an H1N1 2009 pandemic influenza vaccine with or without AS03 adjuvant. Journal of Infectious Diseases.
446 Fernandes P, Jorge S, Lopes JA. (2010). Relapse of Nephrotic Syndrome Following the Use of 2009 Pandemic Influenza A(H1N1) Vaccine. American Journal of Kidney Diseases.
447 Fernandez JD, Arregui BC, Carril AZ, et al. (2005). Evaluation of the safety and immunogenicity of pneumococcal seven-valent conjugate vaccine (Prevenar (R)) administered in previously unvaccinated Spanish children aged 24 to 36 months. Vaccine.
448 Ferraz-Filho JRL, dos Santos Torres U, de Oliveira EP, et al. (2010). MRI findings in an infant with vaccine-associated paralytic poliomyelitis. Pediatric Radiology.
449 Ferrera G, Cuccia M, Mereu G, et al. (2012). Booster vaccination of pre-school children with reduced-antigen-content diphtheria-tetanus-acellular pertussis-inactivated poliovirus vaccine co-administered with measles-mumps-rubella-varicella vaccine: A randomized, controlled trial in children primed according to a 2+1 schedule in infancy. Human Vaccines and Immunotherapeutics.
450 Findlow H, Borrow R, Andrews N, et al. (2012). Immunogenicity of a single dose of meningococcal group C conjugate vaccine given at 3 months of age to healthy infants in the United Kingdom. Pediatric Infectious Disease Journal.
451 Fine HF, Kim E, Flynn TE, et al. (2010). Acute posterior multifocal placoid pigment epitheliopathy following varicella vaccination. British Journal of Ophthalmology.
452 Fisher JPH, Bate J, Hambleton S. (2011). Preventing varicella in children with malignancies: what is the evidence?. Current Opinion in Infectious Diseases.
453 Fisker AB, Bale C, Jorgensen MJ, et al. (2013). High-dose vitamin A supplementation administered with vaccinations after 6 months of age: Sex-differential adverse reactions and morbidity. Vaccine.
454 Fleming JD, Fogo AJ, Creamer DJ. (2011). Stevens-Johnson syndrome triggered by seasonal influenza vaccination and flucloxacillin: A pathogenetic hypothesis. European Journal of Dermatology.
455 Fletcher MA, Fabre P, Debois H, et al. (2004). Vaccines administered simultaneously: directions for new combination vaccines based on an historical review of the literature. International Journal of Infectious Diseases.
456 Flynn PM, Cunningham CK, Rudy B, et al. (2011). Hepatitis B vaccination in HIV-infected youth: A randomized trial of three regimens. Journal of Acquired Immune Deficiency Syndromes.
457 Flynn PM, Nachman S, Muresan P, et al. (2012). Safety and immunogenicity of 2009 pandemic H1N1 influenza vaccination in perinatally HIV-1-infected children, adolescents, and young adults. Journal of Infectious Diseases.
458 Folkenberg M, Callreus T, Svanstrom H, et al. (2011). Spontaneous reporting of adverse events following immunisation against pandemic influenza in Denmark November 2009-March 2010. Vaccine.
459 Fombonne E, Chakrabarti S. (2001). No evidence for a new variant of measles-mumps-rubella-induced autism. Pediatrics.
460 Forrest BD, Steele AD, Hiemstra L, et al. (2011). A prospective, randomized, open-label trial comparing the safety and efficacy of trivalent live attenuated and inactivated influenza vaccines in adults 60 years of age and older. Vaccine.
461 Fortner KB, Kuller JA, Rhee EJ, et al. (2012). Influenza and tetanus, diphtheria, and acellular pertussis vaccinations during pregnancy. Obstetrical and Gynecological Survey.
462 Fox BC, Peterson A. (1998). Leukocytoclastic vasculitis after pneumococcal vaccination. American Journal of Infection Control.
463 Fox RI, Fox CM. (2011). Sjogren's syndrome: Infections that may play a role in pathogenesis, mimic the disease, or complicate the patient's course. Indian Journal of Rheumatology.
464 Frampton JE. (2011). DTaP(5)-IPV-Hib vaccine (Pediacel[REGISTERED]). Paediatric Drugs.
465 Frank AL, Labotka RJ, Rao S, et al. (1988). Haemophilus influenzae type b immunization of children with sickle cell diseases. Pediatrics.
466 Frasch CE, Preziosi MP, LaForce FM. (2012). Development of a group A meningococcal conjugate vaccine, MenAfriVac (TM). Human Vaccines & Immunotherapeutics.
467 Fraunfelder FW, Suhler EB, Fraunfelder FT. (2010). Hepatitis B vaccine and uveitis: an emerging hypothesis suggested by review of 32 case reports. Cutaneous and Ocular Toxicology.
468 Frayha HH, Dent P, Shannon HS, et al. (1991). Safety and immunogenicity of subcutaneous H. influenzae vaccines in 15-17 month-old children. Clinical & Investigative Medicine - Medecine Clinique et Experimentale.
469 Frayha HH, Shaheen H, Ganelin RS, et al. (1993). Clinical and Serologic Responses of Saudi Children to Haemophilus-Influenzae Type-B Capsular Polysaccharide Diphtheria Toxoid Conjugate Vaccine. Annals of Saudi Medicine.
470 Freedman SB, Reed J, Burwen DR, et al. (2005). Transient bulging fontanelle after vaccination: case report and review of the vaccine adverse event reporting system. Journal of Pediatrics.
471 Fregnani JH, Carvalho AL, Eluf-Neto J, et al. (2013). A school-based human papillomavirus vaccination program in barretos, Brazil: final results of a demonstrative study. PLoS ONE.
472 Frenck RW, Gurtman A, Rubino J, et al. (2012). Randomized, controlled trial of a 13-valent pneumococcal conjugate vaccine administered concomitantly with an influenza vaccine in healthy adults. Clinical and Vaccine Immunology.
473 Frenck R, Thompson A, Yeh SH, et al. (2011). Immunogenicity and safety of 13-valent pneumococcal conjugate vaccine in children previously immunized with 7-valent pneumococcal conjugate vaccine. Pediatric Infectious Disease Journal.
474 Frenck RW, Belshe R, Brady RC, et al. (2011). Comparison of the immunogenicity and safety of a split-virion, inactivated, trivalent influenza vaccine (Fluzone[REGISTERED]) administered by intradermal and intramuscular route in healthy adults. Vaccine.
475 Frenck RW, Gurtman A, Rubino J, et al. (2012). Randomized, controlled trial of a 13-valent pneumococcal conjugate vaccine administered concomitantly with an influenza vaccine in healthy adults. Clinical & Vaccine Immunology: CVI.
476 Frey SE, Bernstein DI, Gerber MA, et al. (2012). Safety and immune responses in children after concurrent or sequential 2009 H1N1 and 2009-2010 seasonal trivalent influenza vaccinations. Journal of Infectious Diseases.
477 Fridman D, Monti A, Bonnet MC, et al. (2011). Safety of a second dose of varicella vaccine administered at 4 to 6 years of age in healthy children in Argentina. Human Vaccines.
478 Fu C, Xu J, Tan H, et al. (2011). Serious adverse reactions should be further monitored after influenza A (H1N1) vaccination among children: postmarketing experience with 570,000 vaccinations between October 2009 and August 2010 in Guangzhou, China. Pediatric Infectious Disease Journal.
479 Fuchshuber A, Kuhnemund O, Keuth B, et al. (1996). Pneumococcal vaccine in children and young adults with chronic renal disease. Nephrology Dialysis Transplantation.
480 Fujii T, Naganuma M, Kunisaki R, et al. (2011). Prevalence of influenza infection and safety of human infection with influenza a (H1N1) vaccine in patients with IBD patients treated with immunomodulators and biologics. Gastroenterology.
481 Fukase H, Furuie H, Yasuda Y, et al. (2012). Assessment of the immunogenicity and safety of varying doses of an MF59([REGISTERED])-adjuvanted cell culture-derived A/H1N1 pandemic influenza vaccine in Japanese paediatric, adult and elderly subjects. Vaccine.
482 Fukuda K, Thompson WW, Cox N. (2001). Vaccinating Japanese schoolchildren against influenza. New England Journal of Medicine.
483 Funkhouser AW, Wassilak SG, Orenstein WA, et al. (1987). Estimated effects of a delay in the recommended vaccination schedule for diphtheria and tetanus toxoids and pertussis vaccine. JAMA.
484 Furck AK, Richter JW, Kattner E. (2010). Very low birth weight infants have only few adverse events after timely immunization. Journal of Perinatology.
485 Gabay C, Bel M, Combescure C, et al. (2011). Impact of synthetic and biologic disease-modifying antirheumatic drugs on antibody responses to the AS03-adjuvanted pandemic influenza vaccine: a prospective, open-label, parallel-cohort, single-center study. Arthritis & Rheumatism.
486 Gabutti G, Zepp F, Schuerman L, et al. (2004). Evaluation of the immunogenicity and reactogenicity of a DTPa-HBV-IPV combination vaccine co-administered with a hib conjugate vaccine either as a single injection of a hexavalent combination or as two separate injections at 3, 5 and 11 months of age. Scandinavian Journal of Infectious Diseases.
487 Gadzinowski J, Albrecht P, Hasiec B, et al. (2011). Phase 3 trial evaluating the immunogenicity, safety, and tolerability of manufacturing scale 13-valent pneumococcal conjugate vaccine. Vaccine.
488 Gadzinowski J, Tansey S, Mellelieu T, et al. (2008). A phase 3 trial evaluating the safety, tolerability and immunogenicity of manufacturing scale 13-valent pneumococcal conjugate vaccine. Vaccine.
489 Gaebler JW, Kleiman MB, French MLV. (1986). Neurologic complications in oral polio vaccine recipients. Journal of Pediatrics.
490 Gaglani MJ, Piedra PA, Riggs M, et al. (2008). Safety of the intranasal, trivalent, live attenuated influenza vaccine (LAIV) in children with intermittent wheezing in an open-label field trial. Pediatr Infect Dis J.
491 Gagneur A, Nowak E, Lemaitre T, et al. (2011). Impact of rotavirus vaccination on hospitalizations for rotavirus diarrhea: The IVANHOE study. Vaccine.
492 Gajdos V, Soubeyrand B, Vidor E, et al. (2011). Immunogenicity and safety of combined adsorbed low-dose diphtheria, tetanus and inactivated poliovirus vaccine (REVAXIS (R)) versus combined diphtheria, tetanus and inactivated poliovirus vaccine (DT Polio (R)) given as a booster dose at 6 years of age. Human Vaccines.
493 Gajdos V, Soubeyrand B, Vidor E, et al. (2011). Immunogenicity and safety of combined adsorbed low-dose diphtheria, tetanus and inactivated poliovirus vaccine (REVAXIS ([REGISTERED])) versus combined diphtheria, tetanus and inactivated poliovirus vaccine (DT Polio ([REGISTERED])) given as a booster dose at 6 years of age. Human Vaccines.
494 Galindo BM, Concepcion D, Galindo MA, et al. (2012). Vaccine-related adverse events in Cuban children, 1999-2008. MEDICC review.
495 Galindo Santana BM, Concepcion D, Galindo MA, et al. (2012). Vaccine-related adverse events in Cuban children, 1999-2008. MEDICC Review.
496 Galiza EP, Heath PT. (2007). Pneumococcal conjugate vaccines. A review. Minerva Medica.
497 Gall SA. (2012). Prevention of Pertussis, Tetanus, and Diphtheria Among Pregnant, Postpartum Women, and Infants. Clinical Obstetrics and Gynecology.
498 Garcia-Sicilia J, Gillard P, Carmona A, et al. (2011). Immunogenicity and safety of AS03-adjuvanted H1N1 pandemic vaccines in children and adolescents. Vaccine.
499 Gargiullo PM, Murphy TV, Davis RL. (2006). Is there a safe age for vaccinating infants with tetravalent rhesus-human reassortant rotavirus vaccine?. Journal of Infectious Diseases.
500 Gasparini R, Amicizia D, Lai PL, et al. (2012). Aflunov(registered trademark): A prepandemic influenza vaccine. Expert Review of Vaccines.
501 Gasparini R, Conversano M, Bona G, et al. (2010). Randomized trial on the safety, tolerability, and immunogenicity of MenACWY-CRM, an investigational quadrivalent meningococcal glycoconjugate vaccine, administered concomitantly with a combined tetanus, reduced diphtheria, and acellular pertussis vaccine in adolescents and young adults. Clinical & Vaccine Immunology: CVI.
502 Gasparini R, Lai P. (2010). Utility of virosomal adjuvated influenza vaccines: A review of the literature. Journal of Preventive Medicine and Hygiene.
503 Gasparini R, Schioppa F, Lattanzi M, et al. (2010). Impact of prior or concomitant seasonal influenza vaccination on MF59-adjuvanted H1N1v vaccine (Focetria) in adult and elderly subjects. International Journal of Clinical Practice.
504 Gatchalian S, Reyes M, Bernal N, et al. (2005). A new DTPw-HBV/Hib vaccine is immunogenic and safe when administered according to the EPI (Expanded Programme for Immunization) schedule and following hepatitis B vaccination at birth. Human Vaccines.
505 Gatchalian S, Yao Y, Zhou B, et al. (2008). Comparison of the immunogenicity and safety of measles vaccine administered alone or with live, attenuated Japanese encephalitis SA 14-14-2 vaccine in Philippine infants. Vaccine.
506 Gatchalian SR, Ramakrishnan G, Bock HL, et al. (2010). Immunogenicity, reactogenicity and safety of three-dose primary and booster vaccination with combined diphtheria-tetanus-whole-cell pertussis-hepatitis B-reduced antigen content Haemophilus influenzae type b vaccine in Filipino children. Human Vaccines.
507 Gatchatian S, Patestroque E, De Vleeschauwer I, et al. (2008). The development of a new heptavalent diphtheria-tetanus-whole cell pertussis-hepatitis B-Hoemophilus influenzae type b-Neisseria meningitidis serogroups A and C vaccine: a randomized dose-ranging trial of the conjugate vaccine components. International Journal of Infectious Diseases.
508 Gaughran F, Walwyn R, Lambkin-Williams R, et al. (2007). Flu: effect of vaccine in elderly care home residents: a randomized trial. J Am Geriatr Soc.
509 Gay N, Ramsay M, Waight P. (1999). Rotavirus vaccination and intussusception [12]. Lancet.
510 Geier DA, Geier MR. (2006). An evaluation of the effects of thimerosal on neurodevelopmental disorders reported following DTP and Hib vaccines in comparison to DTPH vaccine in the United States. Journal of Toxicology & Environmental Health Part A.
511 Geier DA, King PG, Sykes LK, et al. (2008). RotaTeq vaccine adverse events and policy considerations. Medical Science Monitor.
512 Geier DA, King PG, Sykes LK, et al. (2012). The temporal relationship between RotaTeq immunization and intussusception adverse events in the Vaccine Adverse Event Reporting System (VAERS). Medical Science Monitor.
513 Gensicke H, Datta AN, Dill P, et al. (2012). Increased incidence of Guillain-Barre Syndrome after surgery. European Journal of Neurology.
514 Gentile A, Umido V, Czerniuk P, et al. (2011). Immunogenicity and reactogenicity of a combined fully liquid DTPw-HepB-Hib pentavalent vaccine in healthy infants: no clinically relevant impact of a birth dose of hepatitis B vaccine. International Journal of Infectious Diseases.
515 Gershon AA, Levin MJ, Weinberg A, et al. (2009). A phase I-II study of live attenuated varicella-zoster virus vaccine to boost immunity in human immunodeficiency virus-infected children with previous varicella. Pediatr Infect Dis J.
516 Gervaix A, Caflisch M, Suter S, et al. (1993). Guillain-Barre-Syndrome Following Immunization with Haemophilus-Influenzae Type-B Conjugate Vaccine. European Journal of Pediatrics.
517 Gidudu J, Sack DA, Pina M, et al. (2011). Diarrhea: Case definition and guidelines for collection, analysis, and presentation of immunization safety data. Vaccine.
518 Gilbert CL, Klopfer SO, Martin JC, et al. (2011). Safety and immunogenicity of a modified process hepatitis B vaccine in healthy adults >= 50 years. Human Vaccines.
519 Gil-Bistes D, Kluger N, Bessis D, et al. (2012). Pityriasis lichenoides chronic after measles-mumps-rubella vaccination. Journal of Dermatology.
520 Gilca R, Deceuninck G, De Serres G, et al. (2011). Effectiveness of pandemic H1N1 vaccine against influenza-related hospitalization in children. Pediatrics.
521 Gilderman LI, Lawless JF, Nolen TM, et al. (2008). A double-blind, randomized, controlled, multicenter safety and immunogenicity study of a refrigerator-stable formulation of Zostavax. Clin Vaccine Immunol.
522 Gillberg C, Heijbel H. (1998). MMR and autism. Autism.
523 Gimenez-Sanchez F, Kieninger DM, Kueper K, et al. (2011). Immunogenicity of a combination vaccine containing diphtheria toxoid, tetanus toxoid, three-component acellular pertussis, hepatitis B, inactivated polio virus, and Haemophilus influenzae type b when given concomitantly with 13-valent pneumococcal conjugate vaccine. Vaccine.
524 Girgis CM, Russo RR, Benson K. (2010). Subacute thyroiditis following the H1N1 vaccine. Journal of Endocrinological Investigation.
525 Gisbert JP, Menchen L, Garcia-Sanchez V, et al. (2012). Comparison of the effectiveness of two protocols for vaccination (standard and double dosage) against hepatitis B virus in patients with inflammatory bowel disease. Alimentary Pharmacology and Therapeutics.
526 Givon-Lavi N, Greenberg D, Dagan R. (2010). Immunogenicity of alternative regimens of the conjugated 7-valent pneumococcal vaccine: A randomized controlled trial. Pediatric Infectious Disease Journal.
527 Glass RI. (2006). New hope for defeating rotavirus. Scientific American.
528 Glass RI, Bresee J, Jiang B, et al. (2006). Rotavirus and rotavirus vaccines. Advances in Experimental Medicine & Biology.
529 Glass RI, Bresee JS, Parashar UD, et al. (2004). The future of rotavirus vaccines: a major setback leads to new opportunities. Lancet.
530 Glass RI, Parashar UD. (2006). Rotavirus vaccines - Reply. New England Journal of Medicine.
531 Glass RI, Parashar UD, Bresee JS, et al. (2006). Rotavirus vaccines: current prospects and future challenges. Lancet.
532 Glezen WP, Simonsen L. (2006). Commentary: benefits of influenza vaccine in US elderly--new studies raise questions. Int J Epidemiol.
533 Gloriani NG, Srinivasa K, Bock HL, et al. (2010). Immunogenicity of Hbv Vaccine during Stated Shelf-Life. Southeast Asian Journal of Tropical Medicine and Public Health.
534 Gold R, Artenstein MS. (1971). Meningococcal infections. 2. Field trial of group C meningococcal polysaccharide vaccine in 1969-70. Bulletin of the World Health Organization.
535 Gold R, Barreto L, Ferro S, et al. (2007). Safety and immunogenicity of a fully liquid vaccine containing five-component pertussis-diphtheria-tetanus-inactivated poliomyelitis-Haemophilus influenzae type b conjugate vaccines administered at two, four, six and 18 months of age. The Canadian Journal of Infectious Diseases & Medical Microbiology.
536 Gold R, Scheifele D, Barreto L, et al. (1994). Safety and immunogenicity of Haemophilus influenzae vaccine (tetanus toxoid conjugate) administered concurrently or combined with diphtheria and tetanus toxoids, pertussis vaccine and inactivated poliomyelitis vaccine to healthy infants at two, four and six months of age. Pediatric Infectious Disease Journal.
537 Goldblatt D, Southern J, Andrews N, et al. (2009). The immunogenicity of 7-valent pneumococcal conjugate vaccine versus 23-valent polysaccharide vaccine in adults aged 50-80 years. Clinical Infectious Diseases.
538 Goldblatt D, Southern J, Ashton L, et al. (2006). Immunogenicity and boosting after a reduced number of doses of a pneumococcal conjugate vaccine in infants and toddlers. Pediatric Infectious Disease Journal.
539 Goldman G. (2013). Comparison of VAERS fetal-loss reports during three consecutive influenza seasons: Was there a synergistic fetal toxicity associated with the two-vaccine 2009/2010 season?. Human & Experimental Toxicology.
540 Goldstein GL. (1982). Pneumococcal vaccine in asthmatics. New England Journal of Medicine.
541 Gomber S, Sharma R, Ramachandran VG. (2004). Immunogenicity of low dose intradermal hepatitis B vaccine and its comparison with standard dose intramuscular vaccination. Indian Pediatrics.
542 Goodman MJ, Nordin JD, Belongia EA, et al. (2010). Henoch-Schonlein Purpura and Polysaccharide Meningococcal Vaccine. Pediatrics.
543 Goodman MJ, Nordin JD, Belongia EA, et al. (2010). Henoch-Scholein purpura and polysaccharide meningococcal vaccine. Pediatrics.
544 Gordon DL, Sajkov D, Woodman RJ, et al. (2012). Randomized clinical trial of immunogenicity and safety of a recombinant H1N1/2009 pandemic influenza vaccine containing AdvaxTM polysaccharide adjuvant. Vaccine.
545 Gordon DL, Sajkov D, Woodman RJ, et al. (2012). Randomized clinical trial of immunogenicity and safety of a recombinant H1N1/2009 pandemic influenza vaccine containing Advax(trademark) polysaccharide adjuvant. Vaccine.
546 Gordon SB, Malamba R, Mthunthama N, et al. (2008). Inhaled delivery of 23-valent pneumococcal polysaccharide vaccine does not result in enhanced pulmonary mucosal immunoglobulin responses. Vaccine.
547 Gorse GJ, Falsey AR, Fling JA, et al. (2013). Intradermally-administered influenza virus vaccine is safe and immunogenic in healthy adults 18-64 years of age. Vaccine.
548 Gottfredsson M, Reynisson IK, Ingvarsson RF, et al. (2011). Comparative long-term adverse effects elicited by invasive group B and C meningococcal infections. Clinical Infectious Diseases.
549 Goulleret N, Mauvisseau E, Essevaz-Roulet M, et al. (2010). Safety profile of live varicella virus vaccine (Oka/Merck): five-year results of the European Varicella Zoster Virus Identification Program (EU VZVIP). Vaccine.
550 Grabenstein JD, Manoff SB. (2012). Pneumococcal polysaccharide 23-valent vaccine: long-term persistence of circulating antibody and immunogenicity and safety after revaccination in adults. Vaccine.
551 Granoff DM, Osterholm MT. (1987). Safety and efficacy of Haemophilus influenzae type b polysaccharide vaccine. Pediatrics.
552 Greenberg DP, Vadheim CM, Marcy SM, et al. (1996). Safety and immunogenicity of a recombinant hepatitis B vaccine administered to infants at 2, 4 and 6 months of age. The Kaiser-UCLA Vaccine Study Group. Vaccine.
553 Greenberg DP, Vadheim CM, Wong VK, et al. (1996). Comparative safety and immunogenicity of two recombinant hepatitis B vaccines given to infants at two, four and six months of age. Pediatric Infectious Disease Journal.
554 Greenberg DP, Ward JI, Burkart K, et al. (1987). Factors influencing immunogenicity and safety of two Haemophilus influenzae type b polysaccharide vaccines in children 18 and 24 months of age. Pediatric Infectious Disease Journal.
555 Greenberg DP, Wong VK, Partridge S, et al. (2000). Immunogenicity of a Haemophilus influenzae type b-tetanus toxoid conjugate vaccine when mixed with a diphtheria-tetanus-acellular pertussis-hepatitis B combination vaccine. Pediatric Infectious Disease Journal.
556 Greenberg DP, Wong VK, Partridge S, et al. (2002). Safety and immunogenicity of a combination diphtheria-tetanus toxoids-acellular pertussis-hepatitis B vaccine administered at two, four and six months of age compared with monovalent hepatitis B vaccine administered at birth, one month and six months of age. Pediatric Infectious Disease Journal.
557 Greenhawt MJ, Chernin AS, Howe L, et al. (2010). The safety of the H1N1 influenza A vaccine in egg allergic individuals. Annals of Allergy, Asthma, & Immunology.
558 Griffiss JM, Brandt BL, Altieri PL, et al. (1981). Safety and immunogenicity of group Y and group W135 meningococcal capsular polysaccharide vaccines in adults. Infection & Immunity.
559 Griffiss JM, Brandt BL, Altieri PL, et al. (1983). Safety and immunogenicity of a group 29E meningococcal capsular polysaccharide vaccine in adults. Infection & Immunity.
560 Grilli G, Fuiano L, Biasio LR, et al. (1997). Simultaneous influenza and pneumococcal vaccination in elderly individuals. European Journal of Epidemiology.
561 Grimprel E, Laudat F, Patterson S, et al. (2011). Immunogenicity and safety of a 13-valent pneumococcal conjugate vaccine (PCV13) when given as a toddler dose to children immunized with PCV7 as infants. Vaccine.
562 Grimprel E, Wysocki J, Boisnard F, et al. (2011). Immunogenicity and safety of fully liquid DTaP5-IPV-Hib compared with DTaP3-IPV/Hib when both coadministered with a heptavalent pneumococcal conjugate vaccine (PCV7) at 2, 3, 4, and 12 to 18 months of age: a phase III, single-blind, randomised, controlled, multicentre study. Vaccine.
563 Grimwood K. (2005). Unraveling rotaviruses, oral vaccines and intussusception. Journal of Paediatrics & Child Health.
564 Gross TP, Hayes SW. (1991). Haemophilus conjugate vaccine and Guillain-Barre syndrome. Journal of Pediatrics.
565 Groth N, Montomoli E, Gentile C, et al. (2009). Safety, tolerability and immunogenicity of a mammalian cell-culture-derived influenza vaccine: a sequential Phase I and Phase II clinical trial. Vaccine.
566 Guerra FA, Blatter MM, Greenberg DP, et al. (2009). Safety and immunogenicity of a pentavalent vaccine compared with separate administration of licensed equivalent vaccines in US infants and toddlers and persistence of antibodies before a preschool booster dose: a randomized, clinical trial. Pediatrics.
567 Guerra FA, Gress J, Werzberger A, et al. (2006). Safety, tolerability and immunogenicity of VAQTA given concomitantly versus nonconcomitantly with other pediatric vaccines in healthy 12-month-old children. Pediatric Infectious Disease Journal.
568 Gumede N, Muthambi V, Schoub BD. (2012). Immunodeficiency-associated vaccine-derived poliovirus type 3 in infant, South Africa, 2011. Emerging Infectious Diseases.
569 Guo B, Page A, Wang H, et al. (2013). Systematic review of reporting rates of adverse events following immunization: an international comparison of post-marketing surveillance programs with reference to China. Vaccine.
570 Gupta A, Agarwal SK. (2010). Immunization in Renal Transplant Recipients: Where Do We Stand?. Hong Kong Journal of Nephrology.
571 Gustafsson L, Hallander HO, Olin P, et al. (1996). A controlled trial of a two-component acellular, a five-component acellular, and a whole-cell pertussis vaccine. N Engl J Med.
572 Gyhrs A, Lyngholm E, Larsen SO, et al. (1999). Immunogenicity and safety of a tetravalent diphtheria-tetanus-acellular pertussis-inactivated poliovirus vaccine. Scandinavian Journal of Infectious Diseases.
573 Haber P, Iskander J, Walton K, et al. (2011). Internet-based reporting to the vaccine adverse event reporting system: A more timely and complete way for providers to support vaccine safety. Pediatrics.
574 Haber P, Patel M, Iskander J, et al. (2008). Importance of On-time RotaTeq Vaccination and Long-term Active Surveillance In Reply. Pediatrics.
575 Haber P, Patel M, Izurieta HS, et al. (2008). Postlicensure monitoring of intussusception after RotaTeq vaccination in the United States, February 1, 2006, to September 25, 2007. Pediatrics.
576 Haber P, Patel M, Pan Y, et al. (2013). Intussusception After Rotavirus Vaccines Reported to US VAERS, 2006-2012. Pediatrics.
577 Hajiabdolbaghi M, Jam S, SeyedAlinaghi S, et al. (2010). Adverse reactions of trivalent influenza vaccine in HIV-infected individuals. Acta Medica Iranica.
578 Hak E, van Loon S, Buskens E, et al. (2003). Design of the Dutch prevention of influenza, surveillance and management (PRISMA) study. Vaccine.
579 Hakim H, Allison KJ, Van De Velde LA, et al. (2012). Immunogenicity and safety of inactivated monovalent 2009 H1N1 influenza A vaccine in immunocompromised children and young adults. Vaccine.
580 Halasa NB, Gerber MA, Chen Q, et al. (2008). Safety and immunogenicity of trivalent inactivated influenza vaccine in infants. J Infect Dis.
581 Hales K, Barriere SL. (1979). Polyvalent pneumococcal vaccines: a review. American Journal of Hospital Pharmacy.
582 Hall AJ. (2001). Ecological studies and debate on rotavirus vaccine and intussusception. Lancet.
583 Halperin BA, Halperin SA, McGrath P, et al. (2002). Use of lidocaine-prilocaine patch to decrease intramuscular injection pain does not adversely affect the antibody response to diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae type b conjugate and hepatitis B vaccines in infants from birth to six months of age. Pediatric Infectious Disease Journal.
584 Halperin SA, Barreto L, Eastwood BJ, et al. (1997). Safety and immunogenicity of an acellular pertussis diphtheria tetanus vaccine given as a single injection with Haemophilus influenzae b conjugate vaccine. Vaccine.
585 Halperin SA, Davies HD, Barreto L, et al. (1997). Safety and immunogenicity of two inactivated poliovirus vaccines in combination with an acellular pertussis vaccine and diphtheria and tetanus toxoids in seventeen- to nineteen-month-old infants. Journal of Pediatrics.
586 Halperin SA, Diaz-Mitoma F, Dull P, et al. (2010). Safety and immunogenicity of an investigational quadrivalent meningococcal conjugate vaccine after one or two doses given to infants and toddlers. European Journal of Clinical Microbiology & Infectious Diseases.
587 Halperin SA, Gupta A, Jeanfreau R, et al. (2010). Comparison of the safety and immunogenicity of an investigational and a licensed quadrivalent meningococcal conjugate vaccine in children 2-10 years of age. Vaccine.
588 Halperin SA, King J, Law B, et al. (1999). Safety and immunogenicity of Haemophilus influenzae-tetanus toxoid conjugate vaccine given separately or in combination with a three-component acellular pertussis vaccine combined with diphtheria and tetanus toxoids and inactivated poliovirus vaccine for the first four doses. Clinical Infectious Diseases.
589 Halperin SA, Langley JM, Hesley TM, et al. (2005). Safety and immunogenicity of two formulations of a hexavalent diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae conjugate-hepatitis B vaccine in 15 to 18-month-old children. Human Vaccines.
590 Halperin SA, McDonald J, Samson L, et al. (2002). Simultaneous administration of meningococcal C conjugate vaccine and diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae type b conjugate vaccine in children: a randomized double-blind study. Clinical & Investigative Medicine - Medecine Clinique et Experimentale.
591 Halperin SA, McNeil S, Langley J, et al. (2011). Tolerability and antibody response in adolescents and adults revaccinated with tetanus toxoid, reduced diphtheria toxoid, and acellular pertussis vaccine adsorbed (Tdap) 4-5 years after a previous dose. Vaccine.
592 Halperin SA, Scheifele D, Barreto L, et al. (1999). Comparison of a fifth dose of a five-component acellular or a whole cell pertussis vaccine in children four to six years of age. Pediatric Infectious Disease Journal.
593 Halperin SA, Scheifele D, Mills E, et al. (2003). Nature, evolution, and appraisal of adverse events and antibody response associated with the fifth consecutive dose of a five-component acellular pertussis-based combination vaccine. Vaccine.
594 Halperin SA, Smith B, Mabrouk T, et al. (2002). Safety and immunogenicity of a trivalent, inactivated, mammalian cell culture-derived influenza vaccine in healthy adults, seniors, and children. Vaccine.
595 Halperin SA, Smith B, Russell M, et al. (2000). Adult formulation of a five component acellular pertussis vaccine combined with diphtheria and tetanus toxoids and inactivated poliovirus vaccine is safe and immunogenic in adolescents and adults. Pediatric Infectious Disease Journal.
596 Halperin SA, Tapiero B, Diaz-Mitoma F, et al. (2009). Safety and immunogenicity of a hexavalent diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae b conjugate-hepatitis B vaccine at 2, 3, 4, and 12-14 months of age. Vaccine.
597 Halperin SA, Tapiero B, Law B, et al. (2006). Interchangeability of two diphtheria and tetanus toxoids, acellular pertussis, inactivated poliovirus, Haemophilus influenzae type b conjugate vaccines as a fourth dose in 15-20-month-old toddlers. Vaccine.
598 Halperin SA, Ward B, Cooper C, et al. (2012). Comparison of safety and immunogenicity of two doses of investigational hepatitis B virus surface antigen co-administered with an immunostimulatory phosphorothioate oligodeoxyribonucleotide and three doses of a licensed hepatitis B vaccine in healthy adults 18-55 years of age. Vaccine.
599 Halperin SA, Ward B, Cooper C, et al. (2012). Comparison of safety and immunogenicity of two doses of investigational hepatitis B virus surface antigen co-administered with an immunostimulatory phosphorothioate oligodeoxyribonucleotide and three doses of a licensed hepatitis B vaccine in healthy adults 18-55 years of age. Vaccine.
600 Halsey NA. (2003). A causal association between Haemophilus influenzae type b (Hib) vaccine and diabetes. Autoimmunity.
601 Halsey NA, Blatter M, Bader G, et al. (1997). Inactivated poliovirus vaccine alone or sequential inactivated and oral poliovirus vaccine in two-, four- and six-month-old infants with combination Haemophilus influenzae type b hepatitis B vaccine. Pediatric Infectious Disease Journal.
602 Halsey NA, Spika JS, Lum GM, et al. (1982). Adverse reactions to pneumococcal polysaccharide vaccine in children. Pediatric Infectious Disease.
603 Halvorsen S. (1991). The meningococcal serogroup B vaccine protection trial in Norway 1988-1991: trial surveillance by an independent group. NIPH Annals.
604 Hammitt LL, Bulkow LR, Singleton RJ, et al. (2011). Repeat revaccination with 23-valent pneumococcal polysaccharide vaccine among adults aged 55-74 years living in Alaska: No evidence of hyporesponsiveness. Vaccine.
605 Han F, Lin L, Warby SC, et al. (2011). Narcolepsy onset is seasonal and increased following the 2009 H1N1 pandemic in China. Annals of Neurology.
606 Hao L, Toyokawa S, Kobayashi Y. (2008). Poisson-model analysis of the risk of vaccine-associated paralytic poliomyelitis in Japan between 1971 and 2000. Japanese Journal of Infectious Diseases.
607 Harmark L, van Hunsel F, Hak E, et al. (2011). Monitoring the safety of influenza A (H1N1) vaccine using web-based intensive monitoring. Vaccine.
608 Harris G, Nolan T, Hartman L. (1995). Clinical signs associated with triple antigen (DTP) vaccination in infants. Journal of Paediatrics and Child Health.
609 Harrison BJ, Thomson W, Pepper L, et al. (1997). Patients who develop inflammatory polyarthritis (IP) after immunization are clinically indistinguishable from other patients with IP. Br J Rheumatol.
610 Hasan S, Yousef M, Shridharani S. (2005). Severe febrile systemic reaction to pneumococcal vaccine. Journal of the National Medical Association.
611 Hatz C, Cramer JP, Vertruyen A, et al. (2012). A randomised, single-blind, dose-range study to assess the immunogenicity and safety of a cell-culture-derived A/H1N1 influenza vaccine in adult and elderly populations. Vaccine.
612 Hatz C, von Sonnenburg F, Casula D, et al. (2012). A randomized clinical trial to identify the optimal antigen and MF59([REGISTERED]) adjuvant dose of a monovalent A/H1N1 pandemic influenza vaccine in healthy adult and elderly subjects. Vaccine.
613 Hatz C, von Sonnenburg F, Casula D, et al. (2012). A randomized clinical trial to identify the optimal antigen and MF59() adjuvant dose of a monovalent A/H1N1 pandemic influenza vaccine in healthy adult and elderly subjects. Vaccine.
614 Haupt RM, Sings HL. (2011). The efficacy and safety of the quadrivalent human papillomavirus 6/11/16/18 vaccine Gardasil. Journal of Adolescent Health.
615 Hawcutt DB, Mainie P, Riordan A, et al. (2012). Reported paediatric adverse drug reactions in the UK 2000-2009. British Journal of Clinical Pharmacology.
616 Heath PT, McVernon J. (2002). The UK hib vaccine experience. Archives of Disease in Childhood.
617 Heaton PM, Goveia MG, Miller JM, et al. (2005). Development of a pentavalent rotavirus vaccine against prevalent serotypes of rotavirus gastroenteritis. Journal of Infectious Diseases.
618 Heijbel H, Jefferson T. (2001). Vaccine safety - Improving monitoring. Vaccine.
619 Heininger U, Group D-H-I-S, Sanger R, et al. (2007). Booster immunization with a hexavalent diphtheria, tetanus, acellular pertussis, hepatitis B, inactivated poliovirus vaccine and Haemophilus influenzae type b conjugate combination vaccine in the second year of life: safety, immunogenicity and persistence of antibody responses. Vaccine.
620 Helle EPJ, Koskenvuo K, Heikkila J. (1978). Myocardial complications of immunisations. Annals of Clinical Research.
621 Hengge UR, Scharf RE, Kroon FP, et al. (2006). Severe serum sickness following pneumococcal vaccination in an AIDS patient. International Journal of Std & Aids.
622 Herberts C, Melgert B, Van Der Laan JW, et al. (2010). New adjuvanted vaccines in pregnancy: What is known about their safety?. Expert Review of Vaccines.
623 Herceg A. (1993). Haemophilus influenzae type b vaccination [13]. Medical Journal of Australia.
624 Hernandez-Bernal F, Aguilar-Betancourt A, Aljovin V, et al. (2011). Comparison of four recombinant hepatitis B vaccines applied on an accelerated schedule in healthy adults. Human Vaccines.
625 Hernandez-Bernal F, Aguilar-Betancourt A, Aljovin V, et al. (2011). Comparison of four recombinant hepatitis B vaccines applied on an accelerated schedule in healthy adults. Human Vaccines.
626 Hesley TM, Reisinger KS, Sullivan BJ, et al. (2004). Concomitant administration of a bivalent Haemophilus influenzae type b-hepatitis B vaccine, measles-mumps-rubella vaccine and varicella vaccine: safety, tolerability and immunogenicity. Pediatric Infectious Disease Journal.
627 Hessel L, Guenaneche F, Biasio LR, et al. (2007). Reply to “Panico MG, Caporale V, Attena F. Adverse events following hexavalent vaccine (Hexavac): knowledge and information sources”. Vaccine.
628 Higashigawa M, Maegawa K, Honma H, et al. (2010). Vaccine-associated paralytic poliomyelitis in an infant with perianal abscesses. Journal of Infection & Chemotherapy.
629 Hilleman MR, Carlson AJ, McLean AA, et al. (1981). Streptococcus pneumoniae polysaccharide vaccine: age and dose responses, safety, persistence of antibody, revaccination, and simultaneous administration of pneumococcal and influenza vaccines. Reviews of Infectious Diseases.
630 Hirtz DG, Nelson KB, Ellenberg JH. (1983). Seizures following childhood immunizations. Journal of Pediatrics.
631 Hirve S, Bavdekar A, Juvekar S, et al. (2011). A comparative study to evaluate the safety and immunogenicity of two lots of Haemophilus influenzae type-B conjugate vaccine manufactured at different scales. Vaccine.
632 Hirve S, Bavdekar A, Pandit A, et al. (2012). Immunogenicity and safety of a new meningococcal A conjugate vaccine in Indian children aged 2-10 years: A Phase II/III double-blind randomized controlled trial. Vaccine.
633 Ho CF, Lin TY. (2005). Pneumococcal vaccines. Chang Gung Medical Journal.
634 Hodgson A, Forgor AA, Chandramohan D, et al. (2008). A phase II, randomized study on an investigational DTPw-HBV/Hib-MenAC conjugate vaccine administered to infants in Northern Ghana. PLoS ONE.
635 Hofmann C, Baur MO, Schroten H. (2011). Anti-NMDA receptor encephalitis after TdaP-IPV booster vaccination: cause or coincidence?. Journal of Neurology.
636 Hojsak I, Avitzur Y, Mor E, et al. (2011). Antibody response to influenza vaccine in pediatric liver transplant recipients. Pediatric Infectious Disease Journal.
637 Holdiness MR. (2003). Rare systemic dermatologic reaction after pneumococcal vaccine administration. Southern Medical Journal.
638 Holmes SJ, Fritzell B, Guito KP, et al. (1993). Immunogenicity of Haemophilus influenzae type b polysaccharide-tetanus toxoid conjugate vaccine in infants. American Journal of Diseases of Children.
639 Holmlund E, Nohynek H, Quiambao B, et al. (2011). Mother-infant vaccination with pneumococcal polysaccharide vaccine: Persistence of maternal antibodies and responses of infants to vaccination. Vaccine.
640 Honkanen PO, Keistinen T, Kivela SL. (1996). Reactions following administration of influenza vaccine alone or with pneumococcal vaccine to the elderly. Archives of Internal Medicine.
641 Honkanen PO, Makela PH. (1999). Pneumococcal vaccination in the elderly: an underused option?. BioDrugs.
642 Hoppenbrouwers K, Kanra G, Roelants M, et al. (1999). Priming effect, immunogenicity and safety of an Haemophilus influenzae type b-tetanus toxoid conjugate (PRP-T) and diphtheria-tetanus-acellular pertussis (DTaP) combination vaccine administered to infants in Belgium and Turkey. Vaccine.
643 Hoppenbrouwers K, Lagos R, Swennen B, et al. (1998). Safety and immunogenicity of an Haemophilus influenzae type b-tetanus toxoid conjugate (PRP-T) and diphtheria-tetanus-pertussis (DTP) combination vaccine administered in a dual-chamber syringe to infants in Belgium and Chile. Vaccine.
644 Hoppenbrouwers K, Roelants M, Ethevenaux C, et al. (1999). The effect of reconstitution of an Haemophilus influenzae type b-tentanus toxoid conjugate (PRP-T) vaccine on the immune responses to a diphtheria-tetanus-whole cell pertussis (DTwP) vaccine: a five-year follow-up. Vaccine.
645 Hosoda M, Inoue H, Miyazawa Y, et al. (2012). Vaccine-associated paralytic poliomyelitis in Japan. Lancet.
646 Hottinger AF, George ACC, Bel M, et al. (2012). A prospective study of the factors shaping antibody responses to the AS03-adjuvanted influenza A/H1N1 vaccine in cancer outpatients. Oncologist.
647 Houston TP. (1983). Small-vessel vasculitis following simultaneous influenza and pneumococcal vaccination. New York State Journal of Medicine.
648 Hua L, Hongtao H, Shunqin W, et al. (2008). Simultaneous vaccination of Chinese applicants for a United States immigrant visa. Travel Medicine & Infectious Disease.
649 Hua W, Izurieta HS, Slade B, et al. (2009). Kawasaki disease after vaccination: reports to the vaccine adverse event reporting system 1990-2007. Pediatric Infectious Disease Journal.
650 Huang DT-N, Chiu NC, Chi H, et al. (2008). Protracted fever with cellulitis-like reaction in pneumococcal polysaccharide-vaccinated children. Pediatric Infectious Disease Journal.
651 Huang HH, Huang CC, Hsueh PY, et al. (2010). Bilateral sudden deafness following H1N1 vaccination. Otolaryngology - Head and Neck Surgery.
652 Huang LM, Lin TY, Juergens C. (2012). Immunogenicity and safety of a 13-valent pneumococcal conjugate vaccine given with routine pediatric vaccines in Taiwan. Vaccine.
653 Huang WT, Chen WC, Teng HJ, et al. (2011). Adverse events following pandemic A (H1N1) 2009 monovalent vaccines in pregnant women--Taiwan, November 2009-August 2010. PLoS ONE.
654 Huber BM, Goetschel P. (2011). Extensive limb swelling after vaccination. Journal of Pediatrics.
655 Hulbert-Powell E, Perez-Gaxiola G. (2012). Review: Flu vaccines provide a moderate risk reduction in healthy children. Archives of Disease in Childhood: Education and Practice Edition.
656 Huppertz HI, Soriano-Gabarro M, Grimprel E, et al. (2006). Intussusception among young children in Europe. Pediatric Infectious Disease Journal.
657 Hviid A. (2011). Measles-mumps-rubella-varicella combination vaccine increases risk of febrile seizure. Journal of Pediatrics.
658 Hwang SM, Choe KW, Cho SH, et al. (2011). The adverse events of influenza A (H1N1) vaccination and its risk factors in healthcare personnel in 18 military healthcare units in Korea. Japanese Journal of Infectious Diseases.
659 Hwang SM, Kim HL, Min KW, et al. (2012). Comparison of the Adverse Events Associated with MF59-Adjuvanted and Non-Adjuvanted H1N1 Vaccines in Healthy Young Male Korean Soldiers. Japanese Journal of Infectious Diseases.
660 Ichikawa T, Tsuji A, Fujino M, et al. (2013). Effect of early measles vaccination (AIK-C strain) for preterm infants. Pediatrics International.
661 Igari H, Segawa S, Watanabe A, et al. (2010). Immunogenicity of a monovalent pandemic influenza A H1N1 vaccine in health-care workers of a university hospital in Japan. Microbiology & Immunology.
662 Igari H, Watanabe A, Chiba H, et al. (2011). Effectiveness and safety of pandemic influenza A (H1N1) 2009 vaccine in healthcare workers at a university hospital in Japan. Japanese Journal of Infectious Diseases.
663 Ikematsu H, Nagai H, Kawashima M, et al. (2012). Characterization and long-term persistence of immune response following two doses of an AS03A-adjuvanted H1N1 influenza vaccine in healthy Japanese adults. Human vaccines & Immunotherapeutics.
664 Ikematsu H, Nagai H, Kawashima M, et al. (2010). Immunogenicity and safety of a novel AS03(A)-adjuvanted H1N1 2009 pandemic influenza vaccine in adults in Japan. Human Vaccines.
665 Inamadar AC, Palit A. (2004). Blue cellulitis: A rare entity in the era of Hib conjugate vaccine [3]. Pediatric Dermatology.
666 Ipp MM, Gold R, Goldbach M, et al. (1989). Adverse reactions to diphtheria, tetanus, pertussis-polio vaccination at 18 months of age: effect of injection site and needle length. Pediatrics.
667 Irving GJ, Holden J, Yang R, et al. (2012). Hepatitis A immunisation in persons not previously exposed to hepatitis. A Cochrane Database of Systematic Reviews.
668 Ishigami M, Kamei H, Nakamura T, et al. (2011). Different effect of HBV vaccine after liver transplantation between chronic HBV carriers and non-HBV patients who received HBcAb-positive grafts. Journal of Gastroenterology.
669 Issa NC, Marty FM, Gagne LS, et al. (2011). Seroprotective titers against 2009 H1N1 influenza A virus after vaccination in allogeneic hematopoietic stem cell transplantation recipients. Biology of Blood & Marrow Transplantation.
670 Izurieta HS, Sutter RW, Baughman AL, et al. (1995). Vaccine-associated paralytic poliomyelitis in the United States: no evidence of elevated risk after simultaneous intramuscular injections of vaccine. Pediatric Infectious Disease Journal.
671 Jackson LA, Baxter R, Reisinger K, et al. (2009). Phase III comparison of an investigational quadrivalent meningococcal conjugate vaccine with the licensed meningococcal ACWY conjugate vaccine in adolescents. Clin Infect Dis.
672 Jackson LA, Benson P, Sneller VP, et al. (1999). Safety of revaccination with pneumococcal polysaccharide vaccine. JAMA.
673 Jackson LA, Jacobson RM, Reisinger KS, et al. (2009). A randomized trial to determine the tolerability and immunogenicity of a quadrivalent meningococcal glycoconjugate vaccine in healthy adolescents. Pediatr Infect Dis J.
674 Jackson LA, Nelson JC, Whitney CG, et al. (2006). Assessment of the safety of a third dose of pneumococcal polysaccharide vaccine in the Vaccine Safety Datalink population. Vaccine.
675 Jackson LA, Neuzil KM, Nahm MH, et al. (2007). Immunogenicity of varying dosages of 7-valent pneumococcal polysaccharide-protein conjugate vaccine in seniors previously vaccinated with 23-valent pneumococcal polysaccharide vaccine. Vaccine.
676 Jackson LA, Neuzil KM, Whitney CG, et al. (2005). Safety of varying dosages of 7-valent pneumococcal protein conjugate vaccine in seniors previously vaccinated with 23-valent pneumococcal polysaccharide vaccine. Vaccine.
677 Jackson LA, Patel SM, Swamy GK, et al. (2011). Immunogenicity of an inactivated monovalent 2009 H1N1 influenza vaccine in pregnant women. Journal of Infectious Diseases.
678 Jacobsen SJ, Ackerson BK, Sy LS, et al. (2009). Observational safety study of febrile convulsion following first dose MMRV vaccination in a managed care setting. Vaccine.
679 Jacobson RM, Adegbenro A, Pankratz VS, et al. (2001). Adverse events and vaccination-the lack of power and predictability of infrequent events in pre-licensure study. Vaccine.
680 Jacquest D, Stout I. (1989). Reactions to Haemophilus influenzae type B vaccine. Canadian Journal of Public Health.
681 Jacquet JM, Begue P, Grimprel E, et al. (2006). Safety and immunogenicity of a combined DTPa-IPV vaccine administered as a booster from 4 years of age: a review. Vaccine.
682 Janow G, Ilowite NT. (2012). Pediatric rheumatic disease: Vaccination in pediatric rheumatic disease - Risks and benefits. Nature Reviews Rheumatology.
683 Jansen AGSC, Sanders EAM, Smulders S, et al. (2008). Adverse reactions to simultaneous influenza and pneumococcal conjugate vaccinations in children: randomized double-blind controlled trial. Pediatric Allergy & Immunology.
684 Jariwala S, Vernon N, Shliozberg J. (2011). Henoch-Schonlein Purpura after Hepatitis a Vaccination. Annals of Allergy Asthma & Immunology.
685 Javelle E, Soulier B, Brosset C, et al. (2011). Delayed focal lipoatrophy after AS03-adjuvanted influenza A (H1N1) 2009 vaccine. Vaccine.
686 Jefferson T, Demicheli V. (1998). No evidence that vaccines cause insulin dependent diabetes mellitus. J Epidemiol Community Health.
687 Jenkins DR, Rees JC, Hale JP, et al. (1996). Childhood neoplasia and Haemophilus influenzae type b vaccine failure [11]. Lancet.
688 Jilich D, Havlickova M, Vesely D, et al. (2012). Immunogenicity and safety of pandemic H1N1 2009 influenza vaccine for HIV-1 patients. Acta Virologica.
689 Jin LJ, Wang GY, Zhao XL, et al. (2010). Characterization and immune effect of the hepatitis B-BCG combined vaccine for using a needle innoculation. Vaccine.
690 Johann-Liang R, Josephs S, Dreskin SC. (2011). Analysis of anaphylaxis cases after vaccination: 10-year review from the national vaccine injury compensation program. Annals of Allergy, Asthma and Immunology.
691 Johns TL, Hutter GE. (2010). New combination vaccines: DTaP-IPV (Kinrix) and DTaP-IPV/Hib (Pentacel). Annals of Pharmacotherapy.
692 Jones CE, Naidoo S, De Beer C, et al. (2011). Maternal HIV Infection and Antibody Responses Against Vaccine-Preventable Diseases in Uninfected Infants. Jama-Journal of the American Medical Association.
693 Jones IG, Tyrrell H, Hill A, et al. (1998). Randomised controlled trial of combined diphtheria, tetanus, whole-cell pertussis vaccine administered in the same syringe and separately with Haemophilus influenzae type b vaccine at two, three and four months of age. Vaccine.
694 Jonville-Bera AP, Autret E, Galy-Eyraud C, et al. (1996). Thrombocytopenic purpura after measles, mumps and rubella vaccination: a retrospective survey by the French regional pharmacovigilance centres and pasteur-merieux serums et vaccins. Pediatr Infect Dis J.
695 Josefsberg JO, Buckland B. (2012). Vaccine process technology. Biotechnology and Bioengineering.
696 Junqueira ALN, Tavares VR, Martins RMB, et al. (2010). Safety and immunogenicity of hepatitis B vaccine administered into ventrogluteal vs. anterolateral thigh sites in infants: A randomised controlled trial. International Journal of Nursing Studies.
697 Juntunen-Backman K, Peltola H, Backman A, et al. (1987). Safe immunization of allergic children against measles, mumps, and rubella. American Journal of Diseases of Children.
698 Kallweit U, Hidalgo H, Engel A, et al. (2012). Post H1N1 vaccination narcolepsy-cataplexy with decreased CSF beta-amyloid. Sleep Medicine.
699 Kamboj KK, King CL, Greenspan NS, et al. (2001). Immunization with Haemophilus influenzae type b-CRM(197) conjugate vaccine elicits a mixed Th1 and Th2 CD(4+) T cell cytokine response that correlates with the isotype of antipolysaccharide antibody. Journal of Infectious Diseases.
700 Kang JH, Oh CE, Lee J, et al. (2011). Safety and immunogenicity of a new trivalent inactivated split-virus influenza vaccine in healthy Korean children: a randomized, double-blinded, active-controlled, phase III study. Journal of Korean Medical Science.
701 Kankawinpong O, Sangsajja C, Cholapand A, et al. (2012). Immunogenicity and safety of an inactivate pandemic H1N1 vaccine provided by the Thai ministry of public health as a routine public health service. Southeast Asian Journal of Tropical Medicine & Public Health.
702 Kanra G, Kara A, Demiralp O, et al. (2006). Safety and immunogenicity of a new fully liquid DTPw-HepB-Hib combination vaccine in infants. Human Vaccines.
703 Kanra G, Viviani S, Yurdakok K, et al. (2003). Effect of aluminum adjuvants on safety and immunogenicity of Haemophilus influenzae type b-CRM197 conjugate vaccine. Pediatrics International.
704 Kanra G, Viviani S, Yurdakok K, et al. (1999). Safety, tolerability and immunogenicity of a Haemophilus influenzae type b vaccine containing aluminum phosphate adjuvant administered at 2, 3 and 4 months of age. Turkish Journal of Pediatrics.
705 Kanra G, Yurdakok K, Ceyhan M, et al. (1997). Immunogenicity and safety of Haemophilus influenzae type b capsular polysaccharide tetanus conjugate vaccine (PRP-T) presented in a dual-chamber syringe with DTP. Acta Paediatrica Japonica.
706 Kapikian AZ. (2002). Ecological studies, rotavirus vaccination, and intussusception. Lancet.
707 Kapikian AZ, Simonsen L, Vesikari T, et al. (2005). A hexavalent human rotavirus-bovine rotavirus (UK) reassortant vaccine designed for use in developing countries and delivered in a schedule with the potential to eliminate the risk of intussusception. Journal of Infectious Diseases.
708 Kapusinszky B, Molnar Z, Szomor KN, et al. (2010). Molecular characterization of poliovirus isolates from children who contracted vaccine-associated paralytic poliomyelitis (VAPP) following administration of monovalent type 3 oral poliovirus vaccine in the 1960s in Hungary. FEMS Immunology & Medical Microbiology.
709 Karam AG, Cherry JD. (2007). Hypotonic and hyporesponsive episodes after diptheria-tetanus-acellular pertussis vaccination. Pediatric Infectious Disease Journal.
710 Karayiannis P, Main J, Thomas HC. (2004). Hepatitis vaccines. British Medical Bulletin.
711 Kattan JD, Konstantinou GN, Cox AL, et al. (2011). Anaphylaxis to diphtheria, tetanus, and pertussis vaccines among children with cow's milk allergy. Journal of Allergy and Clinical Immunology.
712 Katzenstein TL. (1997). Pneumococcal vaccination of HIV-infected individuals: safety and efficacy. AIDS Patient Care & Stds.
713 Kau L, Sadowski CA, Hughes C. (2011). Vaccinations in older adults: Focus on pneumococcal, influenza and herpes zoster infections. Canadian Pharmacists Journal.
714 Kaur S, Handa S. (2008). Erythema multiforme following vaccination in an infant. Indian Journal of Dermatology, Venereology and Leprology.
715 Kayhty H, Ahman H, Eriksson K, et al. (2005). Immunogenicity and tolerability of a heptavalent pneumococcal conjugate vaccine administered at 3, 5 and 12 months of age. Pediatric Infectious Disease Journal.
716 Kayhty H, Peltola H, Eskola J, et al. (1989). Immunogenicity of Haemophilus influenzae oligosaccharide-protein and polysaccharide-protein conjugate vaccination of children at 4, 6, and 14 months of age. Pediatrics.
717 Keating GM. (2006). Rotavirus vaccine (RotaTeq). Paediatric Drugs.
718 Keating GM. (2006). Rotavirus vaccine RIX4414 (Rotarix). Paediatric Drugs.
719 Keipp Talbot H, Rock MT, Johnson C, et al. (2010). Immunopotentiation of Trivalent Influenza Vaccine When Given with VAX102, a Recombinant Influenza M2e Vaccine Fused to the TLR5 Ligand Flagellin. PLoS ONE.
720 Kelen K, Ferenczi D, Jankovics I, et al. (2011). H1N1 vaccination in pediatric renal transplant patients. Transplantation Proceedings.
721 Kelley NS, Osterholm MT, Belongia EA. (2011). Safety and effectiveness of a 2009 H1N1 vaccine in Beijing. New England Journal of Medicine.
722 Kelly H. (2006). Evidence for a causal association between oral polio vaccine and transverse myelitis: A case history and review of the Literature. Journal of Paediatrics & Child Health.
723 Kelly H, Mercer G, Cowling BJ. (2012). The association of seasonal influenza vaccination with pandemic influenza H1N1 2009 infection. Vaccine.
724 Kelly H, Valenciano M. (2012). Estimating the effect of influenza vaccines. The Lancet Infectious Diseases.
725 Kelly HA, Skowronski DM, De Serres G, et al. (2011). Adverse events associated with 2010 CSL and other inactivated influenza vaccines. Medical Journal of Australia.
726 Kelly WN. (2001). Potential risks and prevention, part 4: Reports of significant adverse drug events. American Journal of Health-System Pharmacy.
727 Kelso JM, Greenhawt MJ, Li JT, et al. (2012). Adverse reactions to vaccines practice parameter 2012 update. Journal of Allergy and Clinical Immunology.
728 Kelton JG. (1981). Vaccination-Associated relapse of immune thrombocytopenia. JAMA.
729 Kemmeren JM, Timmer SS, van der Maas NAT, et al. (2011). Comparison of the tolerability of an acellular pertussis-containing vaccine given as the fifth booster dose in differently primed children. Vaccine.
730 Kemmeren JM, van der Maas NAT, de Melker HE. (2011). Parental reports of adverse events following simultaneously given dT-IPV and MMR vaccines in healthy 9-year-old children. European Journal of Pediatrics.
731 Kemmeren JM, Vermeer-de Bondt PE, van der Maas NAT. (2009). Discolored leg syndrome after vaccination--descriptive epidemiology. European Journal of Pediatrics.
732 Kemp ML, Hart MB. (2010). MMR vaccine and autism: is there a link?. JAAPA.
733 Kenter GG, Welters MJ, Valentijn AR, et al. (2009). Vaccination against HPV-16 oncoproteins for vulvar intraepithelial neoplasia. N Engl J Med.
734 Kerzner B, Murray AV, Cheng E, et al. (2007). Safety and immunogenicity profile of the concomitant administration of ZOSTAVAX and inactivated influenza vaccine in adults aged 50 and older. J Am Geriatr Soc.
735 Khalifa YM, Monahan PM, Acharya NR. (2010). Ampiginous choroiditis following quadrivalent human papilloma virus vaccine. British Journal of Ophthalmology.
736 Khan FS, Virant FS, Furukawa CT, et al. (2012). Influenza vaccine administration in egg allergic children. Journal of Allergy and Clinical Immunology.
737 Khare S, Kumari S, Nagpal IS, et al. (1993). Oral polio vaccination in infants: beneficial effect of additional dose at birth. Indian Journal of Pediatrics.
738 Khetsuriani N, Imnadze P, Baidoshvili L, et al. (2010). Impact of unfounded vaccine safety concerns on the nationwide measles-rubella immunization campaign, Georgia, 2008. Vaccine.
739 Kiefaber RW. (1981). Thrombocytopenic purpura after measles vaccination. N Engl J Med.
740 Kienast AK, Mentze D, Hoeger PH. (2008). Nicolau's syndrome induced by intramuscular vaccinations in children: Report of seven patients and review of the literature. Clinical and Experimental Dermatology.
741 Kieninger DM, Kueper K, Steul K, et al. (2010). Safety, tolerability, and immunologic noninferiority of a 13-valent pneumococcal conjugate vaccine compared to a 7-valent pneumococcal conjugate vaccine given with routine pediatric vaccinations in Germany. Vaccine.
742 Kilpi T, Ahman H, Jokinen J, et al. (2003). Protective Efficacy of a Second Pneumococcal Conjugate Vaccine against Pneumococcal Acute Otitis Media in Infants and Children: Randomized, Controlled Trial of a 7-Valent Pneumococcal Polysaccharide-Meningococcal Outer Membrane Protein Complex Conjugate Vaccine in 1666 Children. Clinical Infectious Diseases.
743 Kilpi TM, Silfverdal SA, Nilsson L, et al. (2009). Immunogenicity and reactogenicity of two diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated polio virus-Haemophilus influenzae type b vaccines administered at 3, 5 and 11-12 months of age. Human Vaccines.
744 Kim CH, Kim JS, Cha SH, et al. (2011). Response to primary and booster vaccination with 10-valent pneumococcal nontypeable Haemophilus influenzae protein D conjugate vaccine in Korean infants. Pediatric Infectious Disease Journal.
745 Kim DS, Shin SH, Lee HJ, et al. (2012). Immunogenicity and safety of 13-valent pneumococcal conjugate vaccine given to Korean children receiving routine pediatric vaccines. Pediatric Infectious Disease Journal.
746 Kim DS, Shin SH, Lee HJ, et al. (2013). Immunogenicity and safety of 13-valent pneumococcal conjugate vaccine given to korean children receiving routine pediatric vaccines. Pediatric Infectious Disease Journal.
747 Kim JH, Cho HY, Hennessey KA, et al. (2012). Adverse events following immunization (AEFI) with the novel influenza a (H1N1) 2009 vaccine: findings from the national registry of all vaccine recipients and AEFI and the passive surveillance system in South Korea. Japanese Journal of Infectious Diseases.
748 Kim KH, Kim YK, Kim NH, et al. (2012). Immunogenicity and safety of LBVH0101, a new Haemophilus influenzae type b tetanus toxoid conjugate vaccine, compared with Hiberix(trademark) in Korean infants and children: A randomized trial. Vaccine.
749 Kim KH, Lee H, Chung EH, et al. (2008). Immunogenicity and safety of two different Haemophilus influenzae type b conjugate vaccines in Korean infants. Journal of Korean Medical Science.
750 Kim SJ, Kim SH, Jee YM, et al. (2007). Vaccine-associated paralytic poliomyelitis: a case report of flaccid monoparesis after oral polio vaccine. Journal of Korean Medical Science.
751 Kim YJ, Kim KT, Kim JH, et al. (2010). Vaccination with a human papillomavirus (HPV)-16/18 AS04-adjuvanted cervical cancer vaccine in Korean girls aged 10-14 years. Journal of Korean Medical Science.
752 Kim YK, Eun BW, Kim NH, et al. (2013). Comparison of immunogenicity and reactogenicity of split versus subunit influenza vaccine in Korean children aged 6-35 months. Scandinavian Journal of Infectious Diseases.
753 Kimura A, Toneatto D, Kleinschmidt A, et al. (2011). Immunogenicity and safety of a multicomponent meningococcal serogroup B vaccine and a quadrivalent meningococcal CRM197 conjugate vaccine against serogroups A, C, W-135, and Y in adults who are at increased risk for occupational exposure to meningococcal isolates. Clinical & Vaccine Immunology: CVI.
754 King SD, Ramlal A, Wynter H, et al. (1981). Safety and immunogenicity of a new Haemophilus influenzae type b vaccine in infants under one year of age. Lancet.
755 Kitchin N, Southern J, Morris R, et al. (2006). A randomised controlled study of the reactogenicity of an acellular pertussis-containing pentavalent infant vaccine compared to a quadrivalent whole cell pertussis-containing vaccine and oral poliomyelitis vaccine, when given concurrently with meningococcal group C conjugate vaccine to healthy UK infants at 2, 3 and 4 months of age. Vaccine.
756 Kitchin NRE, Southern J, Morris R, et al. (2007). Evaluation of a diphtheria-tetanus-acellular pertussis-inactivated poliovirus-Haemophilus influenzae type b vaccine given concurrently with meningococcal group C conjugate vaccine at 2, 3 and 4 months of age. Archives of Disease in Childhood.
757 Klein NP, Fireman B, Yih WK, et al. (2010). Measles-mumps-rubella-varicella combination vaccine and the risk of febrile seizures. Pediatrics.
758 Klein NP, Gans HA, Sung P, et al. (2010). Preterm Infants'T Cell Responses to Inactivated Poliovirus Vaccine. Journal of Infectious Diseases.
759 Klein NP, Lewis E, Baxter R, et al. (2012). Measles-containing vaccines and febrile seizures in children age 4 to 6 years. Pediatrics.
760 Klein NP, Reisinger KS, Johnston W, et al. (2012). Safety and immunogenicity of a novel quadrivalent meningococcal CRM-conjugate vaccine given concomitantly with routine vaccinations in infants. Pediatric Infectious Disease Journal.
761 Klein NP, Shepard J, Bedell L, et al. (2012). Immunogenicity and safety of a quadrivalent meningococcal conjugate vaccine administered concomitantly with measles, mumps, rubella, varicella vaccine in healthy toddlers. Vaccine.
762 Klein NP, Weston WM, Kuriyakose S, et al. (2012). An open-label, randomized, multi-center study of the immunogenicity and safety of DTaP-IPV (KinrixTM) co-administered with MMR vaccine with or without varicella vaccine in healthy pre-school age children. Vaccine.
763 Klepper MJ, Edwards B. (2011). Individual case safety reports--how to determine the onset date of an adverse reaction: a survey. Drug Safety.
764 Klooster TMV, Kemmeren JM, Van Der Maas NAT, et al. (2011). Reported adverse events in girls aged 13-16 years after vaccination with the human papillomavirus (HPV)-16/18 vaccine in the Netherlands. Vaccine.
765 Klugman KP, Madhi SA, Huebner RE, et al. (2003). A trial of a 9-valent pneumococcal conjugate vaccine in children with and those without HIV infection. New England Journal of Medicine.
766 Knuf M, Faber J, Barth I, et al. (2008). A combination vaccine against measles, mumps, rubella and varicella. Drugs of Today.
767 Knuf M, Habermehl P, Cimino C, et al. (2006). Immunogenicity, reactogenicity and safety of a 7-valent pneumococcal conjugate vaccine (PCV7) concurrently administered with a DTPa-HBV-IPV/Hib combination vaccine in healthy infants. Vaccine.
768 Knuf M, Kieninger-Baum D, Habermehl P, et al. (2010). A dose-range study assessing immunogenicity and safety of one dose of a new candidate meningococcal serogroups A, C, W-135, Y tetanus toxoid conjugate (MenACWY-TT) vaccine administered in the second year of life and in young children. Vaccine.
769 Knuf M, Pankow-Culot H, Grunert D, et al. (2012). Induction of immunologic memory following primary vaccination with the 10-valent pneumococcal nontypeable haemophilus influenzae protein D conjugate vaccine in infants. Pediatric Infectious Disease Journal.
770 Knuf M, Pantazi-Chatzikonstantinou A, Pfletschinger U, et al. (2011). An investigational tetravalent meningococcal serogroups A, C, W-135 and Y-tetanus toxoid conjugate vaccine co-administered with Infanrix(trademark) hexa is immunogenic, with an acceptable safety profile in 12-23-month-old children. Vaccine.
771 Knuf M, Pantazi-Chatzikonstantinou A, Pfletschinger U, et al. (2011). An investigational tetravalent meningococcal serogroups A, C, W-135 and Y-tetanus toxoid conjugate vaccine co-administered with InfanrixTM hexa is immunogenic, with an acceptable safety profile in 12-23-month-old children. Vaccine.
772 Knuf M, Schmitt HJ, Wolter J, et al. (2008). Neonatal vaccination with an acellular pertussis vaccine accelerates the acquisition of pertussis antibodies in infants. Journal of Pediatrics.
773 Knuf M, Vetter V, Celzo F, et al. (2010). Repeated administration of a reduced-antigen-content diphtheria-tetanus-acellular pertussis and poliomyelitis vaccine (dTpa-IPV; BoostrixTM IPV). Human Vaccines.
774 Knuf M, Vetter V, Celzo F, et al. (2010). Repeated administration of a reduced-antigen-content diphtheria-tetanus-acellular pertussis and poliomyelitis vaccine (dTpa-IPV; Boostrix(trademark) IPV). Human Vaccines.
775 Knuf M, Zepp F, Helm K, et al. (2012). Antibody persistence for 3 years following two doses of tetravalent measles-mumps-rubella-varicella vaccine in healthy children. European Journal of Pediatrics.
776 Knuf M, Zepp F, Meyer CU, et al. (2010). Safety, immunogenicity and immediate pain of intramuscular versus subcutaneous administration of a measles-mumps-rubella-varicella vaccine to children aged 11-21 months. European Journal of Pediatrics.
777 Knutsson N, Trollfors B, Taranger J, et al. (2001). Immunogenicity and reactogenicity of diphtheria, tetanus and pertussis toxoids combined with inactivated polio vaccine, when administered concomitantly with or as a diluent for a Hib conjugate vaccine. Vaccine.
778 Kobayashi M, Ohfuji S, Fukushima W, et al. (2012). Immunogenicity and reactogenicity of a monovalent inactivated 2009 influenza A vaccine in adolescents: with special reference to pre-existing antibody. Journal of Pediatrics.
779 Koh KJ, Warren L, Moore L, et al. (2003). Wells' syndrome following thiomersal-containing vaccinations. Australasian Journal of Dermatology.
780 Kolivras A, Andre J. (2008). Gianotti-Crosti syndrome following hepatitis A vaccination. Pediatric Dermatology.
781 Kondo S, Abe K. (1991). The effects of influenza virus infection on FEV1 in asthmatic children. The time-course study. Chest.
782 Kong BP, Seng HQ, Fong SL, et al. (2008). Immunogenicity, reactogenicity and safety of a diphtheria-tetanus-acellular pertussis-inactivated polio and Haemophilus Influenzae type b combination vaccine in a placebo-controlled rotavirus vaccine study. Annals of the Academy of Medicine Singapore.
783 Konno R, Tamura S, Dobbelaere K, et al. (2010). Efficacy of human papillomavirus 16/18 AS04-adjuvanted vaccine in Japanese women aged 20 to 25 years: interim analysis of a phase 2 double-blind, randomized, controlled trial. International Journal of Gynecological Cancer.
784 Konno R, Tamura S, Dobbelaere K, et al. (2010). Efficacy of human papillomavirus type 16/18 AS04-adjuvanted vaccine in Japanese women aged 20 to 25 years: final analysis of a phase 2 double-blind, randomized controlled trial. International Journal of Gynecological Cancer.
785 Kosalaraksa P, Thisyakorn U, Benjaponpitak S, et al. (2011). Immunogenicity and safety study of a new DTaP-IPV-Hep B-PRP-T combined vaccine compared to a licensed DTaP-IPV-Hep B//PRP-T comparator, both concomitantly administered with a 7-valent pneumococcal conjugate vaccine at 2, 4, and 6 months of age in Thai infants. International Journal of Infectious Diseases.
786 Koskiniemi M, Vaheri A. (1989). Effect of measles, mumps, rubella vaccination on pattern of encephalitis in children. Lancet.
787 Kostianovsky A, Charles P, Alves JF, et al. (2012). Immunogenicity and safety of seasonal and 2009 pandemic A/H1N1 influenza vaccines for patients with autoimmune diseases: a prospective, monocentre trial on 199 patients. Clinical and Experimental Rheumatology.
788 Kovel A, Wald ER, Guerra N, et al. (1992). Safety and immunogenicity of acellular diphtheria-tetanus-pertussis and Haemophilus conjugate vaccines given in combination or at separate injection sites. Journal of Pediatrics.
789 Krairittichai U, Chittaganpitch M. (2013). Efficacy of the trivalent influenza vaccination in Thai patients with hemodialysis or kidney transplant compared with healthy volunteers. Journal of the Medical Association of Thailand.
790 Kubavat AH, Mittal R, Patel PM, et al. (2011). A clinical trial to assess the immunogenicity and safety of Inactivated Influenza Vaccine (Whole Virion) IP (Pandemic Influenza (H1N1) 2009 Monovalent Vaccine; VaxiFlu-STM) in healthy Indian adult population. Journal of Postgraduate Medicine.
791 Kuehn BM. (2011). IOM review finds vaccine adverse events are rare and usually reversible. JAMA - Journal of the American Medical Association.
792 Kulkarni PS, Manjunath K, Agarkhedkar S, et al. (2012). Safety and immunogenicity of an adjuvanted whole virion, inactivated A (H1N1) 2009 influenza vaccine in young and elderly adults, and children. Vaccine.
793 Kumar A, Dutta AK, Saili A, et al. (1997). Immunogenicity and tolerance of H. influenzae type b, tetanus toxoid conjugate vaccine given concurrently or in combination. Indian Journal of Pediatrics.
794 Kumar D, Chen MH, Wong G, et al. (2008). A randomized, double-blind, placebo-controlled trial to evaluate the prime-boost strategy for pneumococcal vaccination in adult liver transplant recipients. Clinical Infectious Diseases.
795 Kumar D, Rotstein C, Miyata G, et al. (2003). Randomized, double-blind, controlled trial of pneumococcal vaccination in renal transplant recipients. Journal of Infectious Diseases.
796 Kung HC, Huang KC, Kao TM, et al. (2010). A clinical study to assess the immunogenicity and safety of a monovalent 2009 influenza A (H1N1) vaccine in an area with low-level epidemics of pandemic influenza. Vaccine.
797 Kurikka S, Kayhty H, Peltola H, et al. (1995). Neonatal immunization: response to Haemophilus influenzae type b-tetanus toxoid conjugate vaccine. Pediatrics.
798 Kurikka S, Olander RM, Eskola J, et al. (1996). Passively acquired anti-tetanus and anti-Haemophilus antibodies and the response to Haemophilus influenzae type b-tetanus toxoid conjugate vaccine in infancy. Pediatric Infectious Disease Journal.
799 Kuronen T, Peltola H, Nors T, et al. (1977). Adverse reactions and endotoxin content of polysaccharide vaccines. Developments in Biological Standardization.
800 Kuruma KAM, Borba EF, Lopes MH, et al. (2007). Safety and efficacy of hepatitis B vaccine in systemic lupus erythematosus. Lupus.
801 Kussmaul SC, Horn BN, Dvorak CC, et al. (2010). Safety of the live, attenuated varicella vaccine in pediatric recipients of hematopoietic SCTs. Bone Marrow Transplantation.
802 Kuter BJ, Brown MLH, Hartzel J, et al. (2006). Safety and immunogenicity of a combination measles, mumps, rubella and varicella vaccine (ProQuad(registered trademark)). Human Vaccines.
803 Kwak GY, Kwon HJ, Kim JH, et al. (2012). The immunogenicity and safety of DTaP interchangeable immunization among Korean children. Vaccine.
804 Labriola L, Hombrouck A, Marechal C, et al. (2011). Immunogenicity of an adjuvanted 2009 pandemic influenza A (H1N1) vaccine in haemodialysed patients. Nephrology Dialysis Transplantation.
805 Lackmann GM. (2004). Comparative investigation of the safety of hexavalent vaccines for primary scheduled infant immunizations in Germany over a time period of 2 years. Medical Science Monitor.
806 Lackner TE, G Hamilton R, J Hill J, et al. (2003). Pneumococcal polysaccharide revaccination: immunoglobulin g seroconversion, persistence, and safety in frail, chronically ill older subjects. Journal of the American Geriatrics Society.
807 Lagler H, Wenisch JM, Tobudic S, et al. (2011). Pandemic influenza A H1N1 vaccine in recipients of solid organ transplants: immunogenicity and tolerability outcomes after vero cell derived, non-adjuvanted, whole-virion vaccination. Vaccine.
808 Lagos R, Munoz A, Levine MM, et al. (2009). Immunology of combining CRM(197) conjugates for Streptococcus pneumoniae, Neisseria meningitis and Haemophilus influenzae in Chilean infants. Vaccine.
809 Lagos RE, Munoz AE, Levine MM, et al. (2011). Safety and immunogenicity of the 10-valent pneumococcal nontypeable Haemophilus influenzae protein D conjugate vaccine (PHiD-CV) in Chilean children. Human Vaccines.
810 Lai YC, Yang KC, Hsieh SM, et al. (2012). Persistence of Immunogenicity of a Monovalent Influenza Virus A/H1N1 2009 Vaccine in Healthy Volunteers. Clinical and Vaccine Immunology.
811 Lalwani S, Chatterjee S, Chhatwal J, et al. (2012). Immunogenicity, safety, and reactogenicity of the 10-valent pneumococcal non-typeable Hemophilus influenzae protein D conjugate vaccine (PHiD-CV) when co-administered with the DTPw-HBV/Hib vaccine in Indian infants: A single-blind, randomized, controlled study. Human Vaccines and Immunotherapeutics.
812 Lang L. (2010). Rotavirus Vaccines Prove Powerful Against Diarrhea. Gastroenterology.
813 Langley JM, Halperin SA, Rubin E, et al. (2012). Safety and immunogenicity of 2 mixed primary infant immunization schedules of pentavalent diphtheria, tetanus, acellular pertussis, inactivated poliomyelitis, and Haemophilus influenzae Type B vaccines at 2, 4, and 6 months of age: a randomized controlled trial. Pediatric Infectious Disease Journal.
814 Langley JM, Predy G, Guasparini R, et al. (2007). An adolescent-adult formulation tetanus and diptheria toxoids adsorbed combined with acellular pertussis vaccine has comparable immunogenicity but less reactogenicity in children 4-6 years of age than a pediatric formulation acellular pertussis vaccine and diphtheria and tetanus toxoids adsorbed combined with inactivated poliomyelitis vaccine. Vaccine.
815 Langley JM, Scheifele DW, Quach C, et al. (2012). Safety and immunogenicity of 2010-2011 H1N12009-containing trivalent inactivated influenza vaccine in children 12-59 months of age previously given AS03-adjuvanted H1N12009 pandemic vaccine: a PHAC/CIHR Influenza Research Network (PCIRN) study. Vaccine.
816 Langue J, Ethevenaux C, Champsaur A, et al. (1999). Safety and immunogenicity of Haemophilus influenzae type b-tetanus toxoid conjugate, presented in a dual-chamber syringe with diphtheria-tetanus-pertussis and inactivated poliomyelitis combination vaccine. European Journal of Pediatrics.
817 Lapatsanis P, Lapatsanis D. (2007). Pertussis vaccine and infantile spasms. Vaccine.
818 Laroche P, Barrand M, Wood SC, et al. (1999). The immunogenicity and safety of a new combined diphtheria, tetanus and poliomyelitis booster vaccine (Td-eIPV). Infection.
819 Latipov R, Khudoyorov R, Flem E. (2011). Childhood intussusception in Uzbekistan: analysis of retrospective surveillance data. Bmc Pediatrics.
820 Launay O, Desaint C, Durier C, et al. (2011). Safety and immunogenicity of a monovalent 2009 influenza A/H1N1v vaccine adjuvanted with AS03A or unadjuvanted in HIV-infected adults: a randomized, controlled trial. Journal of Infectious Diseases.
821 Launay O, van der Vliet D, Rosenberg AR, et al. (2011). Safety and Immunogenicity of 4 Intramuscular Double Doses and 4 Intradermal Low Doses vs Standard Hepatitis B Vaccine Regimen in Adults With HIV-1 A Randomized Controlled Trial. Jama-Journal of the American Medical Association.
822 Lawrence G, Boyd I, McIntyre P, et al. (2006). Annual report: Surveillance of adverse events following immunisation in Australia, 2005. Communicable Diseases Intelligence.
823 Lawrence G, Gold MS, Hill R, et al. (2008). Annual report: surveillance of adverse events following immunisation in Australia, 2007. Communicable Diseases Intelligence.
824 Lawrence GL, Aratchige PE, Boyd I, et al. (2007). Annual report on surveillance of adverse events following immunisation in Australia, 2006. Communicable Diseases Intelligence.
825 Lazarov A, Attias O, Avinoach I, et al. (1995). Infantile acute hemorrhagic edema following vaccine application [2]. Journal of the European Academy of Dermatology and Venereology.
826 Lazarus R, Clutterbuck E, Yu LM, et al. (2011). A randomized study comparing combined pneumococcal conjugate and polysaccharide vaccination schedules in adults. Clinical Infectious Diseases.
827 Le Corre N, Thibault F, Pouteil Noble C, et al. (2012). Effect of two injections of non-adjuvanted influenza A H1N1pdm2009 vaccine in renal transplant recipients: INSERM C09-32 TRANSFLUVAC trial. Vaccine.
828 LeBaron CW, Bi D, Sullivan BJ, et al. (2006). Evaluation of potentially common adverse events associated with the first and second doses of measles-mumps-rubella vaccine. Pediatrics.
829 Lederman MM, Schiffman G, Rodman HM. (1981). Pneumococcal immunization in adult diabetics. Diabetes.
830 Lee A, Goyal R, Shan HY. (2006). Severe protracted fever following pneumococcal vaccine. American Journal of the Medical Sciences.
831 Lee AW, Vesikari T, Gilbert CL, et al. (2011). Immunogenicity and safety of a Haemophilus influenzae B (Hib)-hepatitis B vaccine with a modified process hepatitis B component administered with concomitant pneumococcal conjugate vaccine to infants. Vaccine.
832 Lee BY, Stalter RM, Bacon KM, et al. (2011). Cost-effectiveness of adjuvanted versus nonadjuvanted influenza vaccine in adult hemodialysis patients. American Journal of Kidney Diseases.
833 Lee CY, Lee PI, Huang LM, et al. (1997). A simplified schedule to integrate the hepatitis B vaccine into an expanded program of immunization in endemic countries. Journal of Pediatrics.
834 Lee CY, Thipphawong J, Huang LM, et al. (1999). An evaluation of the safety and immunogenicity of a five-component acellular pertussis, diphtheria, and tetanus toxoid vaccine (DTaP) when combined with a Haemophilus influenzae type b-tetanus toxoid conjugate vaccine (PRP-T) in Taiwanese infants. Pediatrics.
835 Lee H, Kim HW, Cho HK, et al. (2011). Reappraisal of MMR vaccines currently used in Korea. Pediatrics International.
836 Lee HJ, Kang JH, Henrichsen J, et al. (1995). Immunogenicity and safety of a 23-valent pneumococcal polysaccharide vaccine in healthy children and in children at increased risk of pneumococcal infection. Vaccine.
837 Lee SJ, Kim YO, Woo YJ, et al. (2012). Neurologic adverse events following influenza A (H1N1) vaccinations in children. Pediatrics International.
838 Lee SJ, Kim YO, Woo YJ, et al. (2012). Neurologic adverse events following influenza A (H1N1) vaccinations in children. Pediatrics International.
839 Lee SY, Hwang HS, Kim JH, et al. (2011). Immunogenicity and safety of a combined diphtheria, tetanus, acellular pertussis, and inactivated poliovirus vaccine (DTaP-IPV) compared to separate administration of standalone DTaP and IPV vaccines: a randomized, controlled study in infants in the Republic of Korea. Vaccine.
840 Lee SY, Hwang HS, Kim JH, et al. (2011). Immunogenicity and safety of a combined diphtheria, tetanus, acellular pertussis and inactivated poliovirus vaccine (DTaP-IPV) compared to separate administration of standalone DTaP and IPV vaccines: A randomized, controlled study in infants in the Republic of Korea. Vaccine.
841 Lee YY, Lee R, Yamamoto LG. (2005). Intussusception incidence relative to rotavirus vaccine use in Honolulu. Clinical Pediatrics.
842 Leeb A, Carcione D, Richmond PC, et al. (2011). Reactogenicity of two 2010 trivalent inactivated influenza vaccine formulations in adults. Vaccine.
843 Lehmann D, Kakazo M, Yarsley S, et al. (1998). Safety and immunogenicity of Haemophilus influenzae type b conjugate vaccine (PedvaxHIB) in Papua New Guinean children. Papua New Guinea Medical Journal.
844 Lehmann D, Pomat WS, Riley ID, et al. (2003). Studies of maternal immunisation with pneumococcal polysaccharide vaccine in Papua New Guinea. Vaccine.
845 Lehtinen M, Paavonen J, Wheeler CM, et al. (2012). Overall efficacy of HPV-16/18 AS04-adjuvanted vaccine against grade 3 or greater cervical intraepithelial neoplasia: 4-year end-of-study analysis of the randomised, double-blind PATRICIA trial. Lancet Oncology.
846 Lehtinen M, Paavonen J, Wheeler CM, et al. (2012). Overall efficacy of HPV-16/18 AS04-adjuvanted vaccine against grade 3 or greater cervical intraepithelial neoplasia: 4-year end-of-study analysis of the randomised, double-blind PATRICIA trial. Lancet Oncology.
847 Lennon D. (2007). Re: Immunogenicity and safety of a strain-specific MenB OMV vaccine delivered to under 5 year olds in New Zealand. Vaccine.
848 Leonardi M, Bromberg K, Baxter R, et al. (2011). Immunogenicity and safety of MMRV and PCV7 administered concomitantly in healthy children. Pediatrics.
849 Lepow M. (1987). Clinical trials of the Haemophilus influenzae type b capsular polysaccharide-diphtheria toxoid conjugate vaccine. Pediatric Infectious Disease Journal.
850 Lepow ML, Samuelson JS, Gordon LK. (1984). Safety and immunogenicity of Haemophilus influenzae type B polysaccharide-diphtheria toxoid conjugate vaccine in adults. Journal of Infectious Diseases.
851 Lepow ML, Samuelson JS, Gordon LK. (1985). Safety and immunogenicity of Haemophilus influenzae type b-polysaccharide diphtheria toxoid conjugate vaccine in infants 9 to 15 months of age. Journal of Pediatrics.
852 Leroux-Roels G, Haelterman E, Maes C, et al. (2011). Randomized trial of the immunogenicity and safety of the Hepatitis B vaccine given in an accelerated schedule coadministered with the human papillomavirus type 16/18 AS04-adjuvanted cervical cancer vaccine. Clinical & Vaccine Immunology: CVI.
853 Leroux-Roels I, Leroux-Roels G, Clement F, et al. (2012). A phase 1/2 clinical trial evaluating safety and immunogenicity of a varicella zoster glycoprotein e subunit vaccine candidate in young and older adults. Journal of Infectious Diseases.
854 Leroux-Roels I, Vets E, Freese R, et al. (2010). Seasonal influenza vaccine delivered by intradermal microinjection: A randomised controlled safety and immunogenicity trial in adults (vol 26, pg 6614, 2008). Vaccine.
855 Leroy Z, Broder K, Menschik D, et al. (2012). Febrile seizures after 2010-2011 influenza vaccine in young children, United States: a vaccine safety signal from the vaccine adverse event reporting system. Vaccine.
856 Lertdumrongluk P, Changsirikulchai S, Limkunakul C, et al. (2012). Safety and immunogenicity of a 2009 influenza A (H1N1) vaccine in hemodialysis patients. Vaccine.
857 Leung AK, Chiu AS, Siu TO. (1989). Subcutaneous versus intramuscular administration of Haemophilus influenzae type b vaccine. Journal of the Royal Society of Health.
858 Leung JSM. (2010). Adverse events after flu vaccination in patients with immune disorders. Hong Kong Medical Journal.
859 Leventhal JS, Berger EM, Brauer JA, et al. (2012). Hypersensitivity Reactions to Vaccine Constituents: A Case Series and Review of the Literature. Dermatitis.
860 Levin MJ, Gershon AA, Weinberg A, et al. (2006). Administration of live varicella vaccine to HIV-infected children with current or past significant depression of CD4(+) T cells. J Infect Dis.
861 Levine OS, Lagos R, Losonsky GA, et al. (1996). No adverse impact on protection against pertussis from combined administration of Haemophilus influenza type b conjugate and diphtheria-tetanus toxoid-pertussis vaccines in the same syringe. Journal of Infectious Diseases.
862 Lexchin J, Arya N, Singh S. (2010). Gardasil(registered trademark) - The new HPV vaccine: The right product, the right time? A commentary. Healthcare Policy.
863 Li G, Zhang H, Zhou W, et al. (2010). Safety and immunogenicity of a diphtheria, tetanus, acellular pertussis and Haemophilus influenzae Type b combination vaccine compared with separate administration of licensed equivalent vaccines in Chinese infants and toddlers for primary and booster immunization. Vaccine.
864 Li RC, Li FX, Li YP, et al. (2008). Safety and immunogenicity of a 7-valent pneumococcal conjugate vaccine (Prevenar): primary dosing series in healthy Chinese infants. Vaccine.
865 Li RC, Li FX, Li YP, et al. (2011). Antibody persistence at 18-20 months of age and safety and immunogenicity of a booster dose of a combined DTaP-IPV//PRP∼T vaccine compared to separate vaccines (DTaP, PRP∼T and IPV) following primary vaccination of healthy infants in the People's Republic of China. Vaccine.
866 Li RC, Li FX, Li YP, et al. (2011). Immunogenicity and safety of a pentavalent acellular pertussis combined vaccine including diphtheria, tetanus, inactivated poliovirus and conjugated Haemophilus Influenzae type b polysaccharide for primary vaccination at 2, 3, 4 or 3, 4, 5 months of age in infants in China. Vaccine.
867 Li RC, Li FX, Li YP, et al. (2011). Antibody persistence at 18-20 months of age and safety and immunogenicity of a booster dose of a combined DTaP-IPV//PRP approximately T vaccine compared to separate vaccines (DTaP, PRP approximately T and IPV) following primary vaccination of healthy infants in the People's Republic of China. Vaccine.
868 Li X, Wang WWB, Liu GF, et al. (2011). Handling missing data in vaccine clinical trials for immunogenicity and safety evaluation. Journal of Biopharmaceutical Statistics.
869 Liakou CD, Askiti V, Mitsioni A, et al. (2011). Safety, immunogenicity and kinetics of immune response to 7-valent pneumococcal conjugate vaccine in children with idiopathic nephrotic syndrome. Vaccine.
870 Liang XF, Li L, Liu DW, et al. (2011). Safety of influenza A (H1N1) vaccine in postmarketing surveillance in China. New England Journal of Medicine.
871 Liao G, Li R, Li C, et al. (2012). Safety and immunogenicity of inactivated poliovirus vaccine made from Sabin strains: a phase II, randomized, positive-controlled trial. Journal of Infectious Diseases.
872 Liese JG, Rieber N, Malzer T, et al. (2010). Reactogenicity of tetanus, diphtheria, 5-component acellular pertussis vaccine administered as a sixth consecutive acellular pertussis vaccine dose to adolescents. Pediatric Infectious Disease Journal.
873 Liese JG, Stojanov S, Berut F, et al. (2001). Large scale safety study of a liquid hexavalent vaccine (D-T-acP-IPV-PRP--T-HBs) administered at 2, 4, 6 and 12-14 months of age. Vaccine.
874 Lievano F, Galea SA, Thornton M, et al. (2012). Measles, mumps, and rubella virus vaccine (M-M-RTMII): a review of 32 years of clinical and postmarketing experience. Vaccine.
875 Lim BH, Mahmood TA. (2010). Pandemic H1N1 2009 (swine flu) and pregnancy. Obstetrics, Gynaecology and Reproductive Medicine.
876 Lim FS, Phua KB, Lee BW, et al. (2011). Safety and reactogenicity of DTPa-HBV-IPV/Hib and DTPa-IPV/I-Hib vaccines in a post-marketing surveillance setting. Southeast Asian Journal of Tropical Medicine & Public Health.
877 Lim SH, Lee JH, Kim BC, et al. (2010). Adverse reaction of influenza A (H1N1) 2009 virus vaccination in pregnant women and its effect on newborns. Vaccine.
878 Lin CS, Zhu JY, Zheng YB, et al. (2010). Effect of GM-CSF in combination with hepatitis B vaccine on revacination of healthy adult. Journal of Infection.
879 Lin CY, Peng CC, Liu HC, et al. (2011). Psychogenic movement disorder after H1N1 influenza vaccination. Journal of Neuropsychiatry and Clinical Neurosciences.
880 Lin PL, Michaels MG, Green M, et al. (2005). Safety and immunogenicity of the American Academy of Pediatrics--recommended sequential pneumococcal conjugate and polysaccharide vaccine schedule in pediatric solid organ transplant recipients. Pediatrics.
881 Lin SY, Wu ET, Lin CH, et al. (2013). The safety and immunogenicity of trivalent inactivated influenza vaccination: a study of maternal-cord blood pairs in taiwan. PLoS ONE.
882 Lin TY, Lu CY, Chang LY, et al. (2012). Immunogenicity and safety of 10-valent pneumococcal non-typeable Haemophilus influenzae protein D-conjugate vaccine (PHiD-CV) co-administered with routine childhood vaccines in Taiwan. Journal of the Formosan Medical Association.
883 Lin TY, Wang YH, Chang LY, et al. (2007). A fully liquid diphtheria-tetanus-five component acellular pertussis-inactivated poliomyelitis--Haemophilus influenzae type b conjugate vaccine: immunogenicity and safety of primary vaccination in Taiwanese infants. International Journal of Infectious Diseases.
884 Lin TY, Wang YH, Chang LY, et al. (2003). Safety and immunogenicity of a diphtheria, tetanus, and acellular pertussis-inactivated poliovirus vaccine/Haemophilus influenzae type B combination vaccine administered to Taiwanese infants at 2, 4, and 6 months of age. Chang Gung Medical Journal.
885 Lin TY, Wang YH, Huang YC, et al. (2008). Booster vaccination at 6-8 years of age with a reduced antigen content dTpa-IPV vaccine is immunogenic and safe after priming with whole-cell pertussis vaccine. Human Vaccines.
886 Lin TY, Wang YH, Huang YC, et al. (2007). One-year post-primary antibody persistence and booster immune response to a fully liquid five-component acellular pertussis, diphtheria, tetanus, inactivated poliomyelitis, Haemophilus influenzae type b conjugate vaccine. International Journal of Infectious Diseases.
887 Linchevski I, Klement E, Nir-Paz R. (2009). Mycoplasma pneumoniae vaccine protective efficacy and adverse reactions--Systematic review and meta-analysis. Vaccine.
888 Linhares AC, Velazquez FR. (2008). Rotavirus P[4]G2 in a vaccinated population, Brazil. Emerging Infectious Diseases.
889 Lisotti A, Roda G, Brillanti S, et al. (2010). Reactivation of Crohn's disease after pandemic aH1N1 and seasonal flu vaccinations. Digestive and Liver Disease.
890 Lloyd-Johnsen C, Justice F, Donath S, et al. (2012). Retrospective hospital based surveillance of intussusception in children in a sentinel paediatric hospital: benefits and pitfalls for use in post-marketing surveillance of rotavirus vaccines. Vaccine.
891 Lloyd-Puryear MA, Ball LK, Benor D. (1998). Should the vaccine injury compensation program be expanded to cover adults?. Public Health Reports.
892 Lode H, Schmoele-Thoma B, Gruber W, et al. (2011). Dose-ranging study of a single injection of pneumococcal conjugate vaccine (1 x, 2 x, or 4 x) in healthy subjects aged 70 years or older. Vaccine.
893 Lodolce AE. (2012). Shortened interval between tetanus vaccines. Annals of Pharmacotherapy.
894 Loebermann M, Anders G, Brestrich G, et al. (2011). Safety and immunogenicity of a trivalent single dose seasonal influenza vaccine containing pandemic A(H1N1) antigen in younger and elderly subjects: a phase III open-label single-arm study. Vaccine.
895 Lolekha S, Hiranchote A, Simasathien S. (2001). Safety and immunogenicity of combined or associated administration of PRP-T vaccine with diphtheria, tetanus and pertussis vaccine in Thai children. Journal of Tropical Pediatrics.
896 Loomba RS, Aggarwal S, Shah PH, et al. (2012). Influenza vaccination and cardiovascular morbidity and mortality: analysis of 292,383 patients. Journal of Cardiovascular Pharmacology & Therapeutics.
897 Lopert R, Nolan T. (2010). Panvax febrile reactions not a predictor. BMJ.
898 Lopman BA, Payne DC, Tate JE, et al. (2012). Post-licensure experience with rotavirus vaccination in high and middle income countries; 2006 to 2011. Current Opinion in Virology.
899 Lottenbach KR, Granoff DM, Barenkamp SJ, et al. (2004). Safety and immunogenicity of haemophilus influenzae type B polysaccharide or conjugate vaccines in an elderly adult population. Journal of the American Geriatrics Society.
900 Loughlin J, Mast TC, Doherty MC, et al. (2012). Postmarketing evaluation of the short-term safety of the pentavalent rotavirus vaccine. Pediatric Infectious Disease Journal.
901 Lu CC, Wang YC, Lai JH, et al. (2011). A/H1N1 influenza vaccination in patients with systemic lupus erythematosus: safety and immunity. Vaccine.
902 Lu CL, Hung CC, Chuang YC, et al. (2012). Comparison of serologic responses to vaccination with one dose or two doses of 7-valent pneumococcal conjugate vaccine in HIV-infected adult patients. Vaccine.
903 Lum LCS, Borja-Tabora CF, Breiman RF, et al. (2010). Influenza vaccine concurrently administered with a combination measles, mumps, and rubella vaccine to young children. Vaccine.
904 Macias M, Lanata CF, Zambrano B, et al. (2012). Safety and Immunogenicity of an Investigational Fully Liquid Hexavalent DTaP-IPV-Hep B-PRP-T Vaccine at Two, Four and Six Months of Age Compared With Licensed Vaccines in Latin America. Pediatric Infectious Disease Journal.
905 MacIntyre CR, Egerton T, McCaughey M, et al. (2010). Concomitant administration of zoster and pneumococcal vaccines in adults >=60 years old. Human Vaccines.
906 Mackay HJ, McGee J, Villa D, et al. (2011). Evaluation of pandemic H1N1 (2009) influenza vaccine in adults with solid tumor and hematological malignancies on active systemic treatment. Journal of Clinical Virology.
907 Mad'ar R, Benesova D, Brandejska D, et al. (2011). Vaccination of Patients with Diabetes Mellitus - a Retrospective Study. Central European Journal of Public Health.
908 Mad'ar R, Benesova D, Brandejska D, et al. (2011). Vaccination of patients with diabetes mellitus--a retrospective study. Central European Journal of Public Health.
909 Madhi SA, Cutland C, Jones S, et al. (2011). Immunogenicity and safety of an acellular pertussis, diphtheria, tetanus, inactivated poliovirus, Hib-conjugate combined vaccine (Pentaxim) and monovalent hepatitis B vaccine at 6, 10 and 14 weeks of age in infants in South Africa. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde.
910 Madhi SA, Cutland C, Jones S, et al. (2011). One-year post-primary antibody persistence and booster immune response to a DTaP-IPV//PRP∼T vaccine (Pentaxim) given at 18 - 19 months of age in South African children primed at 6, 10 and 14 weeks of age with the same vaccine. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde.
911 Madhun AS, Akselsen PE, Sjursen H, et al. (2010). An adjuvanted pandemic influenza H1N1 vaccine provides early and long term protection in health care workers. Vaccine.
912 Madore DV, Johnson CL, Phipps DC, et al. (1990). Safety and immunogenicity of Haemophilus influenzae type b oligosaccharide-CRM197 conjugate vaccine in infants aged 15 to 23 months. Pediatrics.
913 Madore DV, Johnson CL, Phipps DC, et al. (1990). Safety and Immunological Response to Haemophilus-Influenzae Type-B Oligosaccharide-Crm197 Conjugate Vaccine in 1-Month-Old to 6-Month-Old Infants. Pediatrics.
914 Mahadevan U, Cucchiara S, Hyams JS, et al. (2011). The London position statement of the World Congress of gastroenterology on biological therapy for IBD with the European Crohn's and Colitis Organisation: Pregnancy and pediatrics. American Journal of Gastroenterology.
915 Mahajan D, Cook J, Dey A, et al. (2012). Annual report: Surveillance of adverse events following immunisation in Australia, 2011. Communicable Diseases Intelligence Quarterly Report.
916 Mahajan D, Reid S, Cook J, et al. (2012). NSW annual report describing adverse events following immunisation, 2011. New South Wales Public Health Bulletin.
917 Mair S, Fiquet A, Meghlaoui G, et al. (2009). Immunogenicity and safety of PNEUMOVAX II manufactured by a new process in older adults. Human Vaccines.
918 Mallet E, Brachet E, Fernsten P, et al. (2011). Immunogenicity and safety of CRM197 conjugated 9-valent pneumococcal and meningococcal C combination vaccine in healthy infants. Vaccine.
919 Mallory RM, Yi T, Ambrose CS. (2011). Shedding of Ann Arbor strain live attenuated influenza vaccine virus in children 6-59 months of age. Vaccine.
920 Maltezou HC. (2010). Novel (pandemic) influenza A H1N1 in healthcare facilities: implications for prevention and control. Scandinavian Journal of Infectious Diseases.
921 Mangay-Angara A, Fulgencio L, Casabal G, et al. (1978). A two-dose schedule for immunization of infants using a more concentrated DPT-vaccine. Developments in Biological Standardization.
922 Mantadakis E, Farmaki E, Buchanan GR. (2010). Thrombocytopenic purpura after measles-mumps-rubella vaccination: a systematic review of the literature and guidance for management. Journal of Pediatrics.
923 Manuel O, Humar A, Berutto C, et al. (2011). Low-dose intradermal versus intramuscular trivalent inactivated seasonal influenza vaccine in lung transplant recipients. Journal of Heart & Lung Transplantation.
924 Manuel O, Pascual M, Hoschler K, et al. (2011). Humoral response to the influenza A H1N1/09 monovalent AS03-adjuvanted vaccine in immunocompromised patients. Clinical Infectious Diseases.
925 Manzoli L, Ioannidis JP, Flacco ME, et al. (2012). Effectiveness and harms of seasonal and pandemic influenza vaccines in children, adults and elderly: a critical review and re-analysis of 15 meta-analyses. Human vaccines & Immunotherapeutics.
926 Marchant CD, Miller JM, Marshall GS, et al. (2010). Randomized trial to assess immunogenicity and safety of Haemophilus influenzae type b and Neisseria meningitidis serogroups C and Y-tetanus toxoid conjugate vaccine in infants. Pediatric Infectious Disease Journal.
927 Marcinak JF, Frank AL, Labotka RL, et al. (1991). Immunogenicity of Haemophilus-Influenzae Type-B Polysaccharide-Diphtheria Toxoid Conjugate Vaccine in 3-Month-Old to 17-Month-Old Infants with Sickle-Cell Diseases. Journal of Pediatrics.
928 Marin LF, Abrahao A, Carvalho FA, et al. (2010). Guillain-Barre syndrome associated with H1N1 vaccination. Arquivos de Neuro-Psiquiatria.
929 Marra F, Young F, Richardson K, et al. (2013). A Meta-analysis of intradermal versus intramuscular influenza vaccines: Immunogenicity and Adverse Events. Influenza & Other Respiratory Viruses.
930 Marshall GS, Marchant CD, Blatter M, et al. (2010). Immune response and one-year antibody persistence after a fourth dose of a novel Haemophilus influenzae type b and Neisseria meningitidis serogroups C and Y-tetanus toxoid conjugate vaccine (HibMenCY) at 12 to 15 months of age. Pediatric Infectious Disease Journal.
931 Marshall GS, Marchant CD, Blatter M, et al. (2011). Co-administration of a novel Haemophilus influenzae type b and Neisseria meningitidis serogroups C and Y-tetanus toxoid conjugate vaccine does not interfere with the immune response to antigens contained in infant vaccines routinely used in the United States. Human Vaccines.
932 Marshall H, McIntyre P, Roberton D, et al. (2010). Primary and booster immunization with a diphtheria, tetanus, acellular pertussis, hepatitis B (DTPa-HBV) and Haemophilus influenzae type b (Hib) vaccine administered separately or together is safe and immunogenic. International Journal of Infectious Diseases.
933 Marshall H, Nolan T, Roberton D, et al. (2006). A comparison of booster immunisation with a combination DTPa-IPV vaccine or DTPa plus IPV in separate injections when co-administered with MMR, at age 4-6 years. Vaccine.
934 Martinez-Mir I, Garcia LM, Palop V, et al. (1996). A prospective study of adverse drug reactions as a cause of admission to a paediatric hospital. British Journal of Clinical Pharmacology.
935 Martinon-Torres F, Gimenez-Sanchez F, Gurtman A, et al. (2012). 13-valent pneumococcal conjugate vaccine given with meningococcal C-tetanus toxoid conjugate and other routine pediatric vaccinations: immunogenicity and safety. Pediatric Infectious Disease Journal.
936 Martins RdM, Camacho LAB, Marcovistz R, et al. (2008). Immunogenicity, reactogenicity and consistency of production of a Brazilian combined vaccine against diphtheria, tetanus, pertussis and Haemophilus influenzae type b. Memorias do Instituto Oswaldo Cruz.
937 Mathian A, Devilliers H, Krivine A, et al. (2011). Factors influencing the efficacy of two injections of a pandemic 2009 influenza A (H1N1) nonadjuvanted vaccine in systemic lupus erythematosus. Arthritis & Rheumatism.
938 Matjila MJ, Phohu TC, Banzhoff A, et al. (2004). Safety and immunogenicity of two Haemophilus influenzae type b conjugate vaccines. Suid-Afrikaanse Tydskrif Vir Geneeskunde.
939 Matson DO. (2001). Letter to the editor. Vaccine.
940 Mayet A, Ligier C, Gache K, et al. (2011). Adverse events following pandemic influenza vaccine Pandemrix[REGISTERED] reported in the French military forces--2009-2010. Vaccine.
941 Mayet A, Nivoix P, Haus-Cheymol R, et al. (2012). Increase in reported adverse events following seasonal influenza vaccination among the French armed forces, 2008-2009: possible role of stimulated reporting and background cases of influenza-like infection. Public Health.
942 Mazurat N. (2010). Vaccines and acute myocardial infarction. Journal (Canadian Dental Association).
943 McColgan BP, Borschke FA. (2007). Pseudoseptic arthritis after accidental intra-articular deposition of the pneumococcal polyvalent vaccine: a case report. American Journal of Emergency Medicine.
944 McCormack PL, Joura EA. (2011). Spotlight on quadrivalent human papillomavirus(Types 6, 11, 16, 18) recombinant vaccine(Gardasil(registered trademark)) in the prevention of premalignant-genital lesions, genital cancer, and genital warts in women. Biodrugs.
945 McCue JD. (1981). Adverse reactions to simultaneous influenza and pneumococcal vaccination. Journal of Family Practice.
946 McEvoy SP. (2012). A retrospective survey of the safety of trivalent influenza vaccine among adults working in healthcare settings in south metropolitan Perth, Western Australia, in 2010. Vaccine.
947 McGann M, O'Rourke DJ, Peake D, et al. (2012). Narcolepsy in close temporal relationship to H1N1 vaccination in Irish children. Developmental Medicine and Child Neurology.
948 McIntosh AM, McMahon J, Dibbens LM, et al. (2010). Effects of vaccination on onset and outcome of Dravet syndrome: a retrospective study. Lancet Neurology.
949 McKenzie K. (1997). Italians ban Hib vaccine in BSE scare. BMJ.
950 McKittrick N, Frank I, Jacobson JM, et al. (2013). Improved immunogenicity with high-dose seasonal influenza vaccine in HIV-infected persons: a single-center, parallel, randomized trial. Annals of Internal Medicine.
951 McMahon AW, Iskander J, Haber P, et al. (2005). Adverse events after inactivated influenza vaccination among children less than 2 years of age: Analysis of reports from the Vaccine Adverse Event Reporting System, 1990-2003. Pediatrics.
952 McNeil MM, Arana J, Stewart B, et al. (2012). A cluster of nonspecific adverse events in a military reserve unit following pandemic influenza A (H1N1) 2009 vaccination-possible stimulated reporting?. Vaccine.
953 McNicholas N, Chataway J. (2011). Relapse risk in patients with multiple sclerosis after H1N1 vaccination, with or without seasonal influenza vaccination. Journal of Neurology.
954 McVernon J, Nolan T, Richmond P, et al. (2012). A randomized trial to assess safety and immunogenicity of alternative formulations of a quadrivalent meningococcal (A, C, Y, and W-135) tetanus protein conjugate vaccine in toddlers. Pediatric Infectious Disease Journal.
955 Medeiros RH, Figueiredo AEP, Poli-de-Figueiredo CE, et al. (2011). Low response to intradermal hepatitis B vaccination in incident hemodialysis patients. Jornal Brasileiro de Nefrologia.
956 Medina DMR, Valencia A, de Velasquez A, et al. (2010). Safety and immunogenicity of the HPV-16/18 AS04-adjuvanted vaccine: a randomized, controlled trial in adolescent girls. Journal of Adolescent Health.
957 Meier S, Bel M, L'Huillier A, et al. (2011). Antibody responses to natural influenza A/H1N1/09 disease or following immunization with adjuvanted vaccines, in immunocompetent and immunocompromised children. Vaccine.
958 Meisel R, Kuypers L, Dirksen U, et al. (2007). Pneumococcal conjugate vaccine provides early protective antibody responses in children after related and unrelated allogeneic hematopoietic stem cell transplantation. Blood.
959 Meloni A, Locci D, Frau G, et al. (2011). Epidemiology and prevention of rotavirus infection: An underestimated issue?. Journal of Maternal-Fetal and Neonatal Medicine.
960 Melton L. (2000). Lifesaving vaccine caught in an ethical minefield. Lancet.
961 Memish ZA, Dbaibo G, Montellano M, et al. (2011). Immunogenicity of a single dose of tetravalent meningococcal serogroups A, C, W-135, and Y conjugate vaccine administered to 2- to 10-year-olds is noninferior to a licensed-ACWY polysaccharide vaccine with an acceptable safety profile. Pediatric Infectious Disease Journal.
962 Mendelman PM, Feeley L, Bird S, et al. (1997). Immunogenicity and safety of Haemophilus influenzae type b polysaccharide-Neisseria meningitidis conjugate vaccine in 7.5 micrograms liquid formulation: a comparison of three lots with the 15.0 micrograms lyophilized formulation. Study Group for 7.5 micrograms Liquid PedvaxHIB. Vaccine.
963 Menge T, Cree B, Saleh A, et al. (2012). Neuromyelitis optica following human papillomavirus vaccination. Neurology.
964 Menge T, Cree B, Saleh A, et al. (2012). Neuromyelitis optica following human papillomavirus vaccination. Neurology.
965 Menzies R, Mahajan D, Gold MS, et al. (2009). Annual report: surveillance of adverse events following immunisation in Australia, 2008. Communicable Diseases Intelligence.
966 Meriste S, Jacquet JM, Willems P, et al. (2008). Immunologic response to Hib tetanus toxoid conjugated vaccine coadministered with DTPa either mixed or in two separate injections in toddlers not primed with Hib vaccine. Human Vaccines.
967 Meriste S, Lutsar I, Tamm E, et al. (2006). Safety and immunogenicity of a primary course and booster dose of a combined diphtheria, tetanus, acellular pertussis, hepatitis B and inactivated poliovirus vaccine. Scandinavian Journal of Infectious Diseases.
968 Meriste S, Tamm E, Willems P, et al. (1999). Safety and immunogenicity of combined Dtpa-IPV vaccine for primary and booster vaccination. Scandinavian Journal of Infectious Diseases.
969 Mertsola J, Van Der Meeren O, He Q, et al. (2010). Decennial administration of a reduced antigen content diphtheria and tetanus toxoids and acellular pertussis vaccine in young adults. Clinical Infectious Diseases.
970 Metanat M, Salehi M, Sharifi-Mood B, et al. (2010). Serum antibody responses after intradermal injection of influenza vaccine. International Journal of Virology.
971 Micheletti F, Moretti U, Tridente G, et al. (2011). Consultancy and surveillance of post-immunisation adverse events in the Veneto region of Italy for 1992-2008. Human Vaccines.
972 Miernyk KM, Butler JC, Bulkow LR, et al. (2009). Immunogenicity and Reactogenicity of Pneumococcal Polysaccharide and Conjugate Vaccines in Alaska Native Adults 55-70 Years of Age. Clinical Infectious Diseases.
973 Miles Braun M, Patriarca PA, Ellenberg SS. (1997). Syncope after immunization. Archives of Pediatrics and Adolescent Medicine.
974 Miller E. (1999). Overview of recent clinical trials of acellular pertussis vaccines. Biologicals.
975 Miller E, Andrews N, Waight P, et al. (2011). Safety and immunogenicity of coadministering a combined meningococcal serogroup C and Haemophilus influenzae type b conjugate vaccine with 7-valent pneumococcal conjugate vaccine and measles, mumps, and rubella vaccine at 12 months of age. Clinical & Vaccine Immunology: CVI.
976 Miller E, Batten B, Hampton L, et al. (2011). Tracking vaccine-safety inquiries to detect signals and monitor public concerns. Pediatrics.
977 Miller E, Waight P, Laurichesse H, et al. (2001). Immunogenicity and reactogenicity of acellular diphtheria/tetanus/pertussis vaccines given as a pre-school booster: effect of simultaneous administration of MMR. Vaccine.
978 Miller FD, Nakagom T, Murphy TV, et al. (2001). Intussusception and an oral rotavirus vaccine [1]. New England Journal of Medicine.
979 Miller MA, Meschievitz CK, Ballanco GA, et al. (1995). Safety and immunogenicity of PRP-T combined with DTP: excretion of capsular polysaccharide and antibody response in the immediate post-vaccination period. Pediatrics.
980 Mills E, Gold R, Thipphawong J, et al. (1998). Safety and immunogenicity of a combined five-component pertussis-diphtheria-tetanus-inactivated poliomyelitis-Haemophilus B conjugate vaccine administered to infants at two, four and six months of age. Vaccine.
981 Milstien JB, Gross TP, Kuritsky JN. (1987). Adverse reactions reported following receipt of Haemophilus influenzae type b vaccine: an analysis after 1 year of marketing. Pediatrics.
982 Minervini G, McCarson BJ, Reisinger KS, et al. (2012). Safety and immunogenicity of a modified process hepatitis B vaccine in healthy neonates. Vaccine.
983 Miraglia JL, Abdala E, Hoff PM, et al. (2011). Immunogenicity and reactogenicity of 2009 influenza A (H1N1) inactivated monovalent non-adjuvanted vaccine in elderly and immunocompromised patients. PLoS ONE.
984 Miranzi SDC, de Moraes SA, de Freitas ICM. (2007). Impact of the Haemophilus influenzae type b vaccination program on HIB meningitis in Brazil. Cadernos de Saude Publica.
985 Miriam Pina L, Bassily E, Machmer A, et al. (2012). Safety and immunogenicity of a quadrivalent meningococcal polysaccharide diphtheria-toxoid-conjugate vaccine in infants and toddlers: Three multicenter Phase III studies. Pediatric Infectious Disease Journal.
986 Mizuno Y, Kano S, Urashima M, et al. (2007). Simultaneous vaccination in Japanese travelers. Travel Medicine & Infectious Disease.
987 Mofleh JA, Akbarian Z, Muserat N, et al. (2012). Study of adverse events of A/H1N1 vaccine among health care staff in selected provinces of Afghanistan, 2010. Eastern Mediterranean Health Journal.
988 Mohammed AJ, AlAwaidy S, Bawikar S, et al. (2010). Fractional doses of inactivated poliovirus vaccine in Oman. New England Journal of Medicine.
989 Mohty B, Bel M, Vukicevic M, et al. (2011). Graft-versus-host disease is the major determinant of humoral responses to the AS03-adjuvanted influenza A/09/H1N1 vaccine in allogeneic hematopoietic stem cell transplant recipients. Haematologica.
990 Mok CC, Ho LY, Fong LS, et al. (2012). Immunogenicity and safety of a quadrivalent human papillomavirus vaccine in patients with systemic lupus erythematosus: A case-control study. Annals of the Rheumatic Diseases.
991 Mok CC, Ho LY, Fong LS, et al. (2013). Immunogenicity and safety of a quadrivalent human papillomavirus vaccine in patients with systemic lupus erythematosus: a case-control study. Annals of the Rheumatic Diseases.
992 Mollah AH, Naher N, Rahman S, et al. (2012). Antibody titre against 3 doses of hepatitis B vaccine among preterm and term babies. Mymensingh Medical Journal: MMJ.
993 Moore D, Nelson M, Henderson D. (1998). Pneumococcal vaccination and HIV infection. International Journal of Std & Aids.
994 Moore DL, Le Saux N, Scheifele D, et al. (2004). Lack of evidence of encephalopathy related to pertussis vaccine: Active surveillance by IMPACT, Canada, 1993-2002. Pediatric Infectious Disease Journal.
995 Moraes JCd, Luna EJdA, Grimaldi RA. (2010). Immunogenicity of the Brazilian hepatitis B vaccine in adults. Revista de Saude Publica.
996 Morales-Olivas FJ, Martinez-Mir I, Ferrer JM, et al. (2000). Adverse drug reactions in children reported by means of the yellow card in Spain. Journal of Clinical Epidemiology.
997 Morelon E, Pouteil Noble C, Daoud S, et al. (2010). Immunogenicity and safety of intradermal influenza vaccination in renal transplant patients who were non-responders to conventional influenza vaccination. Vaccine.
998 Morgan R, King D. (1996). Influenza vaccination in the elderly. Postgraduate Medical Journal.
999 Morley SL, Pollard AJ. (2001). Vaccine prevention of meningococcal disease, coming soon?. Vaccine.
1000 Moro PL, Arana J, Cano M, et al. (2012). Postlicensure safety surveillance for high-dose trivalent inactivated influenza vaccine in the Vaccine Adverse Event Reporting System, 1 July 2010-31 December 2010. Clinical Infectious Diseases.
1001 Moro PL, Broder K, Zheteyeva Y, et al. (2011). Adverse events following administration to pregnant women of influenza A (H1N1) 2009 monovalent vaccine reported to the Vaccine Adverse Event Reporting System. American Journal of Obstetrics & Gynecology.
1002 Moro PL, Broder K, Zheteyeva Y, et al. (2011). Adverse events in pregnant women following administration of trivalent inactivated influenza vaccine and live attenuated influenza vaccine in the Vaccine Adverse Event Reporting System, 1990-2009. American Journal of Obstetrics & Gynecology.
1003 Moro PL, Yue X, Lewis P, et al. (2011). Adverse events after Tetanus Toxoid, Reduced Diphtheria Toxoid and Acellular Pertussis (Tdap) Vaccine administered to adults 65 years of age and older reported to the Vaccine Adverse Event Reporting System (VAERS), 2005-2010. Vaccine.
1004 Morris AMS, Elliott EJ, D'souza RM, et al. (2003). Acute flaccid paralysis in Australian children. Journal of Paediatrics & Child Health.
1005 Moulis G, Pugnet G, Bagheri H, et al. (2010). Acquired factor VIII haemophilia following influenza vaccination. European Journal of Clinical Pharmacology.
1006 Mulholland EK, Ahonkhai VI, Greenwood AM, et al. (1993). Safety and immunogenicity of Haemophilus influenzae type B-Neisseria meningitidis group B outer membrane protein complex conjugate vaccine mixed in the syringe with diphtheria-tetanus-pertussis vaccine in young Gambian infants. Pediatric Infectious Disease Journal.
1007 Munch JS, Johnsen BH, Birkeland I, et al. (2010). A study of side-effects of Pandemrix[REGISTERED] influenza (H1N1) vaccine on board a Norwegian naval vessel. International Maritime Health.
1008 Munoz FM, Englund JA. (2000). A step ahead. Infant protection through maternal immunization. Pediatric Clinics of North America.
1009 Munoz FM, Englund JA, Cheesman CC, et al. (2001). Maternal immunization with pneumococcal polysaccharide vaccine in the third trimester of gestation. Vaccine.
1010 Murphy TV, Gargiullo PM, Livengood JR. (2001). Intussusception and an oral rotavirus vaccine - Reply. New England Journal of Medicine.
1011 Murphy TV, Gargiullo PM, Wharton M. (2002). More on rotavirus vaccination and intussusception. New England Journal of Medicine.
1012 Murray DK. (2010). Men who have sex with men … And hepatitis B immunisation. Bmj.
1013 Musher DM, Manof SB, Liss C, et al. (2010). Safety and antibody response, including antibody persistence for 5 years, after primary vaccination or revaccination with pneumococcal polysaccharide vaccine in middle-aged and older adults. Journal of Infectious Diseases.
1014 Musher DM, Manoff SB, McFetridge RD, et al. (2011). Antibody persistence ten years after first and second doses of 23-valent pneumococcal polysaccharide vaccine, and immunogenicity and safety of second and third doses in older adults. Human Vaccines.
1015 Nahar K, Jahan M, Nessa A, et al. (2011). Antibody responses after hepatitis B vaccination among maintenance haemodialysis patients. Bangladesh Medical Research Council Bulletin.
1016 Nailescu C, Xu X, Zhou H, et al. (2011). Influenza vaccine after pediatric kidney transplant: a Midwest Pediatric Nephrology Consortium study. Pediatric Nephrology.
1017 Nakada H, Narimatsu H, Tsubokura M, et al. (2010). Risk of fatal adverse events after H1N1 influenza vaccination. Clinical Infectious Diseases.
1018 Nakagomi O, Cunliffe NA. (2007). Rotavirus vaccines: entering a new stage of deployment. Current Opinion in Infectious Diseases.
1019 Nakagomi T. (2001). Intussusception and an oral rotavirus vaccine. New England Journal of Medicine.
1020 Nakano T. (2011). Japanese vaccinations and practices, with particular attention to polio and pertussis. Travel Medicine & Infectious Disease.
1021 Narayan A, Ganesan S, Shenoy UV, et al. (2011). Provocative poliomyelitis causing postpolio residual paralysis among select communities of two remote villages of North Karnataka in India: a community survey. Indian Journal of Public Health.
1022 Nascimento Silva JR, Camacho LAB, Siqueira MM, et al. (2011). Mutual interference on the immune response to yellow fever vaccine and a combined vaccine against measles, mumps and rubella. Vaccine.
1023 Neuzil KM, Dupont WD, Wright PF, et al. (2001). Efficacy of inactivated and cold-adapted vaccines against influenza A infection, 1985 to 1990: the pediatric experience. Pediatr Infect Dis J.
1024 Nicholson KG, Abrams KR, Batham S, et al. (2010). A randomised, partially observer blind, multicentre, head-to-head comparison of a two-dose regimen of Baxter and GlaxoSmithKline H1N1 pandemic vaccines, administered 21 days apart. Health Technology Assessment (Winchester, England).
1025 Nicholson KG, Abrams KR, Batham S, et al. (2011). Immunogenicity and safety of a two-dose schedule of whole-virion and AS03A-adjuvanted 2009 influenza A (H1N1) vaccines: a randomised, multicentre, age-stratified, head-to-head trial. The Lancet Infectious Diseases.
1026 Nicol M, Huebner R, Mothupi R, et al. (2002). Haemophilus influenzae type b conjugate vaccine diluted tenfold in diphtheria-tetanus-whole cell pertussis vaccine: a randomized trial. Pediatric Infectious Disease Journal.
1027 Niederman LG, Marcinak JF. (1990). Haemophilus influenzae type b abscess after diphtheria-tetanus toxoids-pertussis immunization. Pediatric Infectious Disease Journal.
1028 Nilsson L, Faldella G, Jacquet JM, et al. (2005). A fourth dose of DTPa-IPV vaccine given to 4-6 year old children in Italy and Sweden following primary vaccination at 3, 5 and 11-12 months of age. Scandinavian Journal of Infectious Diseases.
1029 Nilsson L, Kjellman NI, Bjorksten B. (2003). Allergic disease at the age of 7 years after pertussis vaccination in infancy: results from the follow-up of a randomized controlled trial of 3 vaccines. Arch Pediatr Adolesc Med.
1030 Nishi J, Tokuda K, Imuta N, et al. (2013). Prospective Safety Monitoring of Haemophilus influenzae Type b and Heptavalent Pneumococcal Conjugate Vaccines in Kagoshima, Japan. Japanese Journal of Infectious Diseases.
1031 Nolan T, Hogg G, Darcy MA, et al. (1998). A combined liquid Hib (PRP-OMP), hepatitis B, diphtheria, tetanus and whole-cell pertussis vaccine: uncontrolled preliminary clinical trial of immunogenicity and reactogenicity. Vaccine.
1032 Nolan T, Hogg G, Darcy MA, et al. (2001). A combined liquid Hib (PRP-OMPC), hepatitis B, diphtheria, tetanus and whole-cell pertussis vaccine: Controlled studies of immunogenicity and reactogenicity. Vaccine.
1033 Nolan T, Hogg G, Darcy MA, et al. (1997). Primary course immunogenicity and reactogenicity of a new diphtheria-tetanus whole cell pertussis vaccine (DTPw). Journal of Paediatrics and Child Health.
1034 Nolan T, Lambert S, Roberton D, et al. (2007). DTPa-HBV-IPV vaccine for primary vaccination of infants. Journal of Paediatrics & Child Health.
1035 Nolan T, Lambert S, Roberton D, et al. (2007). A novel combined Haemophilus influenzae type b-Neisseria meningitidis serogroups C and Y-tetanus-toxoid conjugate vaccine is immunogenic and induces immune memory when co-administered with DTPa-HBV-IPV and conjugate pneumococcal vaccines in infants. Vaccine.
1036 Nolan T, McVernon J, Skeljo M, et al. (2010). Immunogenicity of a monovalent 2009 influenza A(H1N1) vaccine in infants and children: a randomized trial. JAMA.
1037 Nolan T, Richmond P, Marshall H, et al. (2011). Immunogenicity and safety of an investigational combined haemophilus influenzae type B-Neisseria meningitidis serogroups C and Y-tetanus toxoid conjugate vaccine. Pediatric Infectious Disease Journal.
1038 Nolan T, Richmond PC, McVernon J, et al. (2009). Safety and immunogenicity of an inactivated thimerosal-free influenza vaccine in infants and children. Influenza Other Respi Viruses.
1039 Nurkka A, Joensuu J, Henckaerts I, et al. (2004). Immunogenicity and safety of the eleven valent pneumococcal polysaccharide-protein D conjugate vaccine in infants. Pediatric Infectious Disease Journal.
1040 Obaro SK, Adegbola RA, Chang I, et al. (2000). Safety and immunogenicity of a nonavalent pneumococcal vaccine conjugated to CRM197 administered simultaneously but in a separate syringe with diphtheria, tetanus and pertussis vaccines in Gambian infants. Pediatric Infectious Disease Journal.
1041 Obert J, Burgel PR. (2012). Pneumococcal infections: association with asthma and COPD. Medecine et Maladies Infectieuses.
1042 O'Brien KL, Moulton LH, Reid R, et al. (2003). Efficacy and safety of seven-valent conjugate pneumococcal vaccine in American Indian children: group randomised trial. Lancet.
1043 O'Brien KL, Swift AJ, Winkelstein JA, et al. (2000). Safety and immunogenicity of heptavalent pneumococcal vaccine conjugated to CRM(197) among infants with sickle cell disease. Pneumococcal Conjugate Vaccine Study Group. Pediatrics.
1044 Occhionero M, Usai G, Di Martino M, et al. (1991). Serum antibodies to capsular polysaccharide vaccine of group A and C Neisseria meningitidis in military recruits in Italy. Allergologia et Immunopathologia.
1045 Offit PA. (2002). The future of rotavirus vaccines. Seminars in Pediatric Infectious Diseases.
1046 Offit PA. (2006). Rotavirus vaccines: round two. Human Vaccines.
1047 Offit PA. (2007). Thimerosal and vaccines - A cautionary tale. New England Journal of Medicine.
1048 Offit PA, Clark HF. (2006). RotaTeq: a pentavalent bovine--human reassortant rotavirus vaccine. Pediatric Annals.
1049 Ogimi C, Tanaka R, Saitoh A, et al. (2011). Immunogenicity of influenza vaccine in children with pediatric rheumatic diseases receiving immunosuppressive agents. Pediatric Infectious Disease Journal.
1050 Oh CE, Lee J, Kang JH, et al. (2010). Safety and immunogenicity of an inactivated split-virus influenza A/H1N1 vaccine in healthy children from 6 months to <18 years of age: a prospective, open-label, multi-center trial. Vaccine.
1051 Okada K, Komiya T, Yamamoto A, et al. (2010). Safe and effective booster immunization using DTaP in teenagers. Vaccine.
1052 Okada K, Miyazaki C, Kino Y, et al. (2013). Phase II and III Clinical Studies of Diphtheria-Tetanus-Acellular Pertussis Vaccine Containing Inactivated Polio Vaccine Derived from Sabin Strains (DTaP-sIPV). Journal of Infectious Diseases.
1053 Okais C, Gay C, Seon F, et al. (2011). Disease-specific adverse events following nonlive vaccines: a paradoxical placebo effect or a nocebo phenomenon?. Vaccine.
1054 Okike IO, Yung C, Ladhani S, et al. (2011). The immunogenicity of a novel A (H1N1) vaccine in HIV-infected children. Vaccine.
1055 Okuda B, Uetani E, Okamoto K. (2006). Vaccine-associated paralytic poliomyelitis caused by contact infection. Internal Medicine.
1056 Olin P, Rasmussen F, Gottfarb P. (1997). Schedules and protection, simultaneous vaccination and safety: Experiences from recent controlled trials. International Journal of Infectious Diseases.
1057 Olivier C, Belohradsky BH, Stojanov S, et al. (2008). Immunogenicity, reactogenicity, and safety of a seven-valent pneumococcal conjugate vaccine (PCV7) concurrently administered with a fully liquid DTPa-IPV-HBV-Hib combination vaccine in healthy infants. Vaccine.
1058 Omenaca F, Aristegui J, Tejedor JC, et al. (2011). Combined Haemophilus Influenzae type B-Neisseria meningitidis serogroup C vaccine is immunogenic and well tolerated in preterm infants when coadministered with other routinely recommended vaccines. Pediatric Infectious Disease Journal.
1059 Omenaca F, Dal-Re R, D'Apuzzo V, et al. (2001). Reactogenicity of DTPa-HBV/Hib vaccine administered as a single injection vs DTPa-HBV and Hib vaccines administered simultaneously at separate sites, to infants at 2, 4 and 6 months of age. Vaccine.
1060 Omenaca F, Garcia-Sicilia J, Boceta R, et al. (2010). Hepatitis B response of premature infants after primary and booster immunisation with a diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated poliovirus/haemophilus influenzae type B vaccine. Infectious Diseases in Obstetrics & Gynecology.
1061 Omenaca F, Merino JM, Tejedor JC, et al. (2011). Immunization of preterm infants with 10-valent pneumococcal conjugate vaccine. Pediatrics.
1062 Omon E, Damase-Michel C, Hurault-Delarue C, et al. (2011). Non-adjuvanted 2009 influenza A (H1N1)v vaccine in pregnant women: the results of a French prospective descriptive study. Vaccine.
1063 Ortalda V, Tomei P, Yabarek T, et al. (2012). Immunogenicity and seroconversion after hepatitis B vaccination in haemodialysis patients: Results of two different vaccination schedules. Nephrology Dialysis Transplantation.
1064 Ortiz Arjona MA, Abd Elaziz KM, Caballero Lanzas JM, et al. (2011). Coverage and side effects of influenza A(H1N1) 2009 monovalent vaccine among primary health care workers. Vaccine.
1065 O'Ryan M. (2006). Reply. Gastroenterology.
1066 O'Ryan M. (2007). Reply. Journal of Pediatrics.
1067 O'Ryan M, Lucero Y, Linhares AC. (2011). Rotarix[REGISTERED]: vaccine performance 6 years postlicensure. Expert Review of Vaccines.
1068 O'Ryan ML, Matson DO. (1998). A quadrivalent rotavirus vaccine. New England Journal of Medicine.
1069 Ostergaard L, Silfverdal SA, Berglund J, et al. (2012). A tetravalent meningococcal serogroups A, C, W-135, and Y tetanus toxoid conjugate vaccine is immunogenic and well-tolerated when co-administered with Twinrix([REGISTERED]) in subjects aged 11-17 years: an open, randomised, controlled trial. Vaccine.
1070 Ota MO, Akinsola A, Townend J, et al. (2011). The immunogenicity and impact on nasopharyngeal carriage of fewer doses of conjugate pneumococcal vaccine immunization schedule. Vaccine.
1071 Ottaviani G, Lavezzi AM, Matturri L. (2006). Sudden infant death syndrome (SIDS) shortly after hexavalent vaccination: another pathology in suspected SIDS?. Virchows Archiv.
1072 Overton ET, Kang M, Peters MG, et al. (2010). Immune response to hepatitis B vaccine in HIV-infected subjects using granulocyte-macrophage colony-stimulating factor (GM-CSF) as a vaccine adjuvant: ACTG study 5220. Vaccine.
1073 Ozdemir O, Yazgan H, Demirdoven M, et al. (2010). Rotavirus infection rate after two types of rotavirus vaccination observed in a private research/training hospital in anatolian part of Istanbul, Turkey. Journal of Allergy and Clinical Immunology.
1074 Pace D, Snape M, Westcar S, et al. (2007). A new combination haemophilus influenzae type B and Neisseria meningitidis serogroup C-tetanus toxoid conjugate vaccine for primary immunization of infants. Pediatric Infectious Disease Journal.
1075 Pace D, Snape M, Westcar S, et al. (2008). A novel combined Hib-MenC-TT glycoconjugate vaccine as a booster dose for toddlers: A phase 3 open randomised controlled trial. Archives of Disease in Childhood.
1076 Pahud BA, Williams SE, Dekker CL, et al. (2013). Clinical assessment of serious adverse events in children receiving 2009 H1N1 vaccination. Pediatric Infectious Disease Journal.
1077 Palache AM, Scheepers HS, de Regt V, et al. (1999). Safety, reactogenicity and immunogenicity of Madin Darby Canine Kidney cell-derived inactivated influenza subunit vaccine. A meta-analysis of clinical studies. Dev Biol Stand.
1078 Palma P, Romiti ML, Bernardi S, et al. (2012). Safety and immunogenicity of a monovalent MF59[REGISTERED]-adjuvanted A/H1N1 vaccine in HIV-infected children and young adults. Biologicals.
1079 Palma P, Romiti ML, Bernardi S, et al. (2012). Safety and immunogenicity of a monovalent MF59-adjuvanted A/H1N1 vaccine in HIV-infected children and young adults. Biologicals.
1080 Palumbo A, Davies F, Kropff M, et al. (2010). Consensus guidelines for the optimal management of adverse events in newly diagnosed, transplant-ineligible patients receiving melphalan and prednisone in combination with thalidomide (MPT) for the treatment of multiple myeloma. Annals of Hematology.
1081 Paradiso PR. (2011). Advances in pneumococcal disease prevention: 13-valent pneumococcal conjugate vaccine for infants and children. Clinical Infectious Diseases.
1082 Park SJ, Shin JI. (2011). Henoch-Schonlein purpura after hepatitis a vaccination: The role of interleukin 10?. Annals of Allergy, Asthma and Immunology.
1083 Park SW, Lee JH, Kim ES, et al. (2011). Adverse events associated with the 2009 H1N1 influenza vaccination and the vaccination coverage rate in health care workers. American Journal of Infection Control.
1084 Parke JC, Schneerson R, Reimer C, et al. (1991). Clinical and immunologic responses to Haemophilus influenzae type b-tetanus toxoid conjugate vaccine in infants injected at 3, 5, 7, and 18 months of age. Journal of Pediatrics.
1085 Parretta E, Ianniello B, Ferrazin F, et al. (2011). Italian post-marketing surveillance for adverse event reports after MF59-adjuvanted H1N1v vaccination. Vaccine.
1086 Partinen M, Saarenpaa-Heikkila O, Ilveskoski I, et al. (2012). Increased incidence and clinical picture of childhood narcolepsy following the 2009 H1N1 pandemic vaccination campaign in Finland. PLoS ONE.
1087 Partridge S, Alvey J, Bernstein H, et al. (2007). Safety of a combination diphtheria, tetanus toxoid, acellular pertussis, hepatitis B, and inactivated polio vaccine coadministered with a 7-valent pneumococcal conjugate vaccine and a Haemophilus influenzae type b conjugate vaccine. Vaccine.
1088 Partridge S, Yeh SH. (2003). Clinical evaluation of a DTaP-HepB-IPV combined vaccine. American Journal of Managed Care.
1089 Parvaneh N, Shahmahmoudi S, Tabatabai H, et al. (2007). Vaccine-associated paralytic poliomyelitis in a patient with MHC class II deficiency. Journal of Clinical Virology.
1090 Patel MK, Patel TK, Tripathi CB. (2012). Diphtheria, pertussis (whooping cough), and tetanus vaccine induced recurrent seizures and acute encephalopathy in a pediatric patient: Possibly due to pertussis fraction. Journal of Pharmacology & Pharmacotherapeutics.
1091 Patel MM. (2011). Intussusception Risk of Rotavirus Vaccination REPLY. New England Journal of Medicine.
1092 Patel MM, Clark AD, Glass RI, et al. (2009). Broadening the age restriction for initiating rotavirus vaccination in regions with high rotavirus mortality: benefits of mortality reduction versus risk of fatal intussusception. Vaccine.
1093 Patel NC, Hertel PM, Estes MK, et al. (2010). Vaccine-acquired rotavirus in infants with severe combined immunodeficiency. New England Journal of Medicine.
1094 Patel NC, Palmer WC, Krishna M, et al. (2011). Lack of an association between autoimmune pancreatitis and Varicella Zoster Virus. Jop: Journal of the Pancreas.
1095 Patel SR, Ortin M. (2005). Varicella-zoster reactivation in a patient receiving routine revaccinations after an allogeneic hemopoietic progenitors transplant. Journal of Pediatric Hematology/Oncology.
1096 Patja A, Davidkin I, Kurki T, et al. (2000). Serious adverse events after measles-mumps-rubella vaccination during a fourteen-year prospective follow-up. Pediatr Infect Dis J.
1097 Payne DC, Edwards KM, Bowen MD, et al. (2010). Sibling transmission of vaccine-derived rotavirus (RotaTeq) associated with rotavirus gastroenteritis. Pediatrics.
1098 Pedersen C, Breindahl M, Aggarwal N, et al. (2012). Randomized trial: Immunogenicity and safety of coadministered human papillomavirus-16/18 AS04-adjuvanted vaccine and combined hepatitis A and B vaccine in girls. Journal of Adolescent Health.
1099 Pedersen C, Breindahl M, Aggarwal N, et al. (2012). Randomized trial: immunogenicity and safety of coadministered human papillomavirus-16/18 AS04-adjuvanted vaccine and combined hepatitis A and B vaccine in girls. Journal of Adolescent Health.
1100 Pedersen C, Breindahl M, Aggarwal N, et al. (2012). Randomized trial: immunogenicity and safety of coadministered human papillomavirus-16/18 AS04-adjuvanted vaccine and combined hepatitis A and B vaccine in girls. Journal of Adolescent Health.
1101 Pedersen C, Petaja T, Strauss G, et al. (2007). Immunization of early adolescent females with human papillomavirus type 16 and 18 L1 virus-like particle vaccine containing AS04 adjuvant. J Adolesc Health.
1102 Peltola H, Kayhty H, Kuronen T, et al. (1978). Meningococcus group A vaccine in children three months to five years of age. Adverse reactions and immunogenicity related to endotoxin content and molecular weight of the polysaccharide. Journal of Pediatrics.
1103 Peltola H, Makela PH, Elo O, et al. (1976). Vaccination against meningococcal group A disease in Finland 1974-75. Scandinavian Journal of Infectious Diseases.
1104 Peng LA, Liu J, Gao ZL, et al. (2011). Inoculation effects of recombinant yeast hepatitis B vaccine used in neonates. Scientific Research and Essays.
1105 Perez Schael I, O'Ryan M, Saez-Llorens X, et al. (2012). Clinical development, registration, and introduction of human rotavirus vaccine: The Latin American experience. Trials in Vaccinology.
1106 Perrett KP, Snape MD, Ford KJ, et al. (2009). Immunogenicity and Immune Memory of a Nonadjuvanted Quadrivalent Meningococcal Glycoconjugate Vaccine in Infants. Pediatric Infectious Disease Journal.
1107 Perucchini E, Consonni S, Sandrini MC, et al. (2004). Adverse reactions to influenza vaccine alone or with pneumococcal vaccine in the elderly. Journal of the American Geriatrics Society.
1108 Petousis-Harris H, Poole T, Turner N, et al. (2012). Febrile events including convulsions following the administration of four brands of 2010 and 2011 inactivated seasonal influenza vaccine in NZ infants and children: The importance of routine active safety surveillance. Vaccine.
1109 Petridou E, Kouri N, Vadala H, et al. (2004). Frequency and nature of recorded childhood immunization-related errors in Greece. Journal of Toxicology - Clinical Toxicology.
1110 Phongsamart W, Sirisanthana V, Wittawatmongkol O, et al. (2011). Immunogenicity and safety of monovalent influenza A (H1N1) 2009 in HIV-infected Thai children. Vaccine.
1111 Phua KB, Emmanuel SC, Goh P, et al. (2006). A rotavirus vaccine for infants: The Asian experience. Annals of the Academy of Medicine Singapore.
1112 Phua KB, Quak SH, Lim FS, et al. (2008). Immunogenicity, reactogenicity and safety of a diphtheria-tetanus-acellular pertussis-inactivated polio and Haemophilus influenzae type b vaccine in a placebo-controlled rotavirus vaccine study. Annals of the Academy of Medicine, Singapore.
1113 Pichichero M, Papa T, Blatter M, et al. (2006). Immune memory in children previously vaccinated with an experimental quadrivalent meningococcal polysaccharide diphtheria toxoid conjugate vaccine. Pediatric Infectious Disease Journal.
1114 Pichichero ME. (2005). Meningococcal conjugate vaccines. Expert Opinion on Biological Therapy.
1115 Pichichero ME, Bernstein H, Blatter MM, et al. (2007). Immunogenicity and safety of a combination diphtheria, tetanus toxoid, acellular pertussis, hepatitis B, and inactivated poliovirus vaccine coadministered with a 7-valent pneumococcal conjugate vaccine and a Haemophilus influenzae type b conjugate vaccine. Journal of Pediatrics.
1116 Pichichero ME, Blatter MM, Reisinger KS, et al. (2002). Impact of a birth dose of hepatitis B vaccine on the reactogenicity and immunogenicity of diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated poliovirus-Haemophilus influenzae type b combination vaccination. Pediatric Infectious Disease Journal.
1117 Pichichero ME, Green JL, Francis AB, et al. (1996). Antibody response and reactions to completion of a four-dose series with a two- or three-component acellular pertussis vaccine compared to whole cell pertussis vaccine. Scandinavian Journal of Infectious Diseases.
1118 Pichichero ME, Latiolais T, Bernstein DI, et al. (1997). Vaccine antigen interactions after a combination diphtheria-tetanus toxoid-acellular pertussis/purified capsular polysaccharide of Haemophilus influenzae type b-tetanus toxoid vaccine in two-, four- and six-month-old infants. Pediatric Infectious Disease Journal.
1119 Pier GB. (1982). Safety and immunogenicity of high molecular weight polysaccharide vaccine from immunotype 1 Pseudomonas aeruginosa. Journal of Clinical Investigation.
1120 Pietrzyk JJ, Wysocki J, Pejcz J, et al. (2008). Safety and immunogenicity of a DTaP-IPV(Vero) (serum-free) combination vaccine in comparison to DTaP-IPV(Mkc) when administered simultaneously with Haemophilus influenzae type B conjugate vaccine (PRP-T) in children at 2, 3.5, 5 and 16 months of age. Vaccine.
1121 Pileggi GS, de Souza CBS, Ferriani VPL. (2010). Safety and Immunogenicity of Varicella Vaccine in Patients With Juvenile Rheumatic Diseases Receiving Methotrexate and Corticosteroids. Arthritis Care & Research.
1122 Pirofski LA, Casadevall A. (1998). Use of licensed vaccines for active immunization of the immunocompromised host. Clinical Microbiology Reviews.
1123 Plennevaux E, Blatter M, Cornish MJ, et al. (2011). Influenza A (H1N1) 2009 two-dose immunization of US children: an observer-blinded, randomized, placebo-controlled trial. Vaccine.
1124 Plennevaux E, Sheldon E, Blatter M, et al. (2010). Immune response after a single vaccination against 2009 influenza A H1N1 in USA: a preliminary report of two randomised controlled phase 2 trials. Lancet.
1125 Pliaka V, Kyriakopoulou Z, Markoulatos P. (2012). Risks associated with the use of live-attenuated vaccine poliovirus strains and the strategies for control and eradication of paralytic poliomyelitis. Expert Review of Vaccines.
1126 Plichta AM. (1996). Immunization: protecting older patients from infectious disease. Geriatrics.
1127 Plosker GL. (2010). Pentavalent rotavirus vaccine (RotaTeq): a review of its use in the prevention of rotavirus gastroenteritis in Europe. Drugs.
1128 Pomat WS, van den Biggelaar AH, Phuanukoonnon S, et al. (2013). Safety and immunogenicity of neonatal pneumococcal conjugate vaccination in Papua New Guinean children: a randomised controlled trial. PLoS ONE.
1129 Ponka A, Leinonen M. (1982). Adverse reactions to polyvalent pneumococcal vaccine. Scandinavian Journal of Infectious Diseases.
1130 Popejoy LA, Rivera AI, Gonzales-Torres I. (1989). Side-effects and immunogenicity of Haemophilus influenzae type B polysaccharide vaccine in a multi-ethnic pediatric population. Military Medicine.
1131 Potter RC, Gonik B. (2009). Prevention of influenza in mothers and infants. Expert Review of Vaccines.
1132 Poullin P, Gabriel B. (1994). Thrombocytopenic purpura after recombinant hepatitis B vaccine. Lancet.
1133 Precioso AR, Miraglia JL, Campos LMA, et al. (2011). A phase I randomized, double-blind, controlled trial of 2009 influenza A (H1N1) inactivated monovalent vaccines with different adjuvant systems. Vaccine.
1134 Prosser LA, Lavelle TA, Fiore AE, et al. (2011). Cost-effectiveness of 2009 Pandemic influenza A(H1N1) vaccination in the United States. PLoS ONE.
1135 Prymula R, Chlibek R, Splino M, et al. (2008). Safety of the 11-valent pneumococcal vaccine conjugated to non-typeable Haemophilus influenzae-derived protein D in the first 2 years of life and immunogenicity of the co-administered hexavalent diphtheria, tetanus, acellular pertussis, hepatitis B, inactivated polio virus, Haemophilus influenzae type b and control hepatitis A vaccines. Vaccine.
1136 Prymula R, Peeters P, Chrobok V, et al. (2006). Pneumococcal capsular polysaccharides conjugated to protein D for prevention of acute otitis media caused by both Streptococcus pneumoniae and non-typable Haemophilus influenzae: A randomised double-blind efficacy study. Lancet.
1137 Prymula R, Plisek S. (2008). Clinical experience with DTPw-HBV and DTPw-HBV/Hib combination vaccines. Expert Opinion on Biological Therapy.
1138 Prymula R, Schuerman L. (2009). 10-valent pneumococcal nontypeable Haemophilus influenzae PD conjugate vaccine: Synflorix. Expert Review of Vaccines.
1139 Prymula R, Siegrist CA, Chlibek R, et al. (2009). Effect of prophylactic paracetamol administration at time of vaccination on febrile reactions and antibody responses in children: two open-label, randomised controlled trials. Lancet.
1140 Punjabi NH, Richie EL, Simanjuntak CH, et al. (2006). Immunogenicity and safety of four different doses of Haemophilus influenzae type b-tetanus toxoid conjugated vaccine, combined with diphtheria-tetanus-pertussis vaccine (DTP-Hib), in Indonesian infants. Vaccine.
1141 Qian L, Tseng HF, Sy LS, et al. (2013). Confounder adjustment in vaccine safety studies: comparing three offset terms for case-centered approach. Vaccine.
1142 Quiambao B, Van der Meeren O, Kolhe D, et al. (2012). A randomized, dose-ranging assessment of the immunogenicity and safety of a booster dose of a combined diphtheria-tetanus-whole cell pertussis-hepatitis B-inactivated poliovirus-Hemophilus influenzae type b (DTPw-HBV-IPV/Hib) vaccine vs. co-administration of DTPw-HBV/Hib and IPV vaccines in 12 to 24 months old Filipino toddlers. Human Vaccines & Immunotherapeutics.
1143 Radzikowski A, Banaszkiewicz A, Lazowska-Przeorek I, et al. (2011). Immunogenecity of Hepatitis A Vaccine in Pediatric Patients with Inflammatory Bowel Disease. Inflammatory Bowel Diseases.
1144 Rahier JF, Papay P, Salleron J, et al. (2011). H1N1 vaccines in a large observational cohort of patients with inflammatory bowel disease treated with immunomodulators and biological therapy. Gut.
1145 Rajantie J, Zeller B, Treutiger I, et al. (2007). Vaccination associated thrombocytopenic purpura in children. Vaccine.
1146 Ramkissoon A, Coovadia HM, Jugnundan P, et al. (2001). A new combined DTP-HBV-HIB vaccine - Strategy for incorporation of Hib vaccination into childhood immunisation programmes. South African Medical Journal.
1147 Rasigade JP, Sicot N, Laurent F, et al. (2011). A history of Panton-Valentine leukocidin (PVL)-associated infection protects against death in PVL-associated pneumonia. Vaccine.
1148 Ravanfar P, Satyaprakash A, Creed R, et al. (2009). Existing antiviral vaccines. Dermatologic Therapy.
1149 Rayani A, Bode U, Habas E, et al. (2007). Rotavirus infections in paediatric oncology patients: A matched-pairs analysis. Scandinavian Journal of Gastroenterology.
1150 Reinert P, Benkerrou M, de Montalembert M, et al. (2007). Immunogenicity and safety of a pneumococcal conjugate 7-valent vaccine in infants with sickle cell disease. Pediatric Infectious Disease Journal.
1151 Reinert P, Cinquetti S, Soubeyrand B, et al. (2010). Challenge with hepatitis B vaccine in children previously vaccinated with a hepatitis B-containing combination vaccine. Advances in Therapy.
1152 Reinert P, Fiquet A, Thomas S, et al. (2006). Fever as a marker of reactogenicity of an acellular pertussis-containing hexavalent vaccine (HEXAVAC) in a large-scale, open, randomized safety study in healthy French infants. Human Vaccines.
1153 Reisinger KS, Baxter R, Block SL, et al. (2009). Quadrivalent meningococcal vaccination of adults: phase III comparison of an investigational conjugate vaccine, MenACWY-CRM, with the licensed vaccine, Menactra. Clin Vaccine Immunol.
1154 Reisinger KS, Block SL. (2008). Characteristics of an ideal rotavirus vaccine. Clinical Pediatrics.
1155 Rennels M, King J, Ryall R, et al. (2002). Dose escalation, safety and immunogenicity study of a tetravalent meninogococcal polysaccharide diphtheria conjugate vaccine in toddlers. Pediatric Infectious Disease Journal.
1156 Rennels M, King J, Ryall R, et al. (2004). Dosage escalation, safety and immunogenicity study of four dosages of a tetravalent meninogococcal polysaccharide diphtheria toxoid conjugate vaccine in infants. Pediatric Infectious Disease Journal.
1157 Rennels MB. (1991). Pediatric gastrointestinal infections. Current Opinion in Infectious Diseases.
1158 Rennels MB, Edwards KM, Keyserling HL, et al. (2001). Safety and immunogenicity of four doses of Neisseria meningitidis group C vaccine conjugated to CRM197 in United States infants. Pediatric Infectious Disease Journal.
1159 Rennels MB, Hohenboken MJ, Reisinger KS, et al. (1998). Comparison of acellular pertussis-diphtheria-tetanus toxoids and Haemophilus influenzae type b vaccines administered separately vs. combined in younger vs. older toddlers. Pediatric Infectious Disease Journal.
1160 Rennels MB, Parashar UD, Holman RC, et al. (1998). Lack of an apparent association between intussusception and wild or vaccine rotavirus infection. Pediatric Infectious Disease Journal.
1161 Rennels MB, Reed GF, Decker MD, et al. (1995). Simultaneous administration of Haemophilus influenzae type b vaccine with acellular or whole-cell pertussis vaccine: effects on reactogenicity and immune responses to pertussis vaccines. Pediatrics.
1162 Resik S, Tejeda A, Lago PM, et al. (2010). Randomized Controlled Clinical Trial of Fractional Doses of Inactivated Poliovirus Vaccine Administered Intradermally by Needle-Free Device in Cuba. Journal of Infectious Diseases.
1163 Reuman PD, Sawyer MH, Kuter BJ, et al. (1997). Safety and immunogenicity of concurrent administration of measles-mumps-rubella-varicella vaccine and PedvaxHIB vaccines in healthy children twelve to eighteen months old. The MMRV Study Group. Pediatric Infectious Disease Journal.
1164 Reuman PD, Sawyer MH, Kuter BJ, et al. (1997). Safety and immunogenicity of concurrent administration of measles-mumps-rubella-varicella vaccine and PedvaxHIB(R) vaccines in healthy children twelve to eighteen months old. Pediatric Infectious Disease Journal.
1165 Reygrobellet C, Viala-Danten M, Meunier J, et al. (2010). Perception and acceptance of intradermal influenza vaccination: Patient reported outcomes from phase 3 clinical trials. Human Vaccines.
1166 Reynales H, Astudillo P, de Valliere S, et al. (2012). A prospective observational safety study on MF59() adjuvanted cell culture-derived vaccine, Celtura() during the A/H1N1 (2009) influenza pandemic. Vaccine.
1167 Ribeiro ACM, Guedes LKN, Moraes JCB, et al. (2011). Reduced seroprotection after pandemic H1N1 influenza adjuvant-free vaccination in patients with rheumatoid arthritis: implications for clinical practice. Annals of the Rheumatic Diseases.
1168 Richardson V, Parashar U, Patel M. (2011). Childhood diarrhea deaths after rotavirus vaccination in Mexico. New England Journal of Medicine.
1169 Richie E, Punjabi NH, Harjanto SJ, et al. (1999). Safety and immunogenicity of combined diphtheria-tetanus-pertussis (whole cell and acellular)-Haemophilus influenzae-b conjugate vaccines administered to Indonesian children. Vaccine.
1170 Richmond P, Goldblatt D, Fusco PC, et al. (1999). Safety and immunogenicity of a new Neisseria meningitidis serogroup C-tetanus toxoid conjugate vaccine in healthy adults. Vaccine.
1171 Ridda I, Seale H, Katelaris AL, et al. (2011). Pneumococcal colonisation following influenza infection. Vaccine.
1172 Riddell A, Buttery JP, McVernon J, et al. (2007). A randomized study comparing the safety and immunogenicity of a conjugate vaccine combination containing meningococcal group C and pneumococcal capsular polysaccharide--CRM197 with a meningococcal group C conjugate vaccine in healthy infants: challenge phase. Vaccine.
1173 Riddell A, Buttery JP, McVernon J, et al. (2007). A randomized study comparing the safety and immunogenicity of a conjugate vaccine combination containing meningococcal group C and pneumococcal capsular polysaccharide-CRM(197) with a meningococcal group C conjugate vaccine in healthy infants: Challenge phase. Vaccine.
1174 Riedemann S, Reinhardt G, Jara J, et al. (2002). Immunogenicity and reactogenicity of combined versus separately administered DTPw-HBV and Hib vaccines given to healthy infants at 2, 4 and 6 months of age, with a booster at 18 months. International Journal of Infectious Diseases.
1175 Ries K, Shemonsky NK. (1981). Acute lupus erythematosus (SLE) following polyvalent pneumococcal vaccine. South Dakota Journal of Medicine.
1176 Rinderknecht S, Bryant K, Nolan T, et al. (2012). The safety profile of Haemophilus influenzae type b-Neisseria meningitidis serogroups C and Y tetanus toxoid conjugate vaccine (HibMenCY). Human Vaccines and Immunotherapeutics.
1177 Rinderknecht S, Michaels MG, Blatter M, et al. (2011). Immunogenicity and safety of an inactivated hepatitis A vaccine when coadministered with measles-mumps-rubella and varicella vaccines in children less than 2 years of age. Pediatric Infectious Disease Journal.
1178 Rivera L, Mazara S, Vargas M, et al. (2012). Phase III, randomized controlled trial to evaluate lot consistency of a trivalent subunit egg-based influenza vaccine in adults. Vaccine.
1179 Robbins JB, Schneerson R. (1990). Evaluating the Haemophilus influenzae type b conjugate vaccine PRP-D. N Engl J Med.
1180 Rodrigues LC, Smith PG. (1999). Use of the case-control approach in vaccine evaluation: Efficacy and adverse effects. Epidemiologic Reviews.
1181 Rodriguez R, Dyer PD. (1995). Safety of pneumococcal revaccination. Journal of General Internal Medicine.
1182 Roman F, Vaman T, Gerlach B, et al. (2010). Immunogenicity and safety in adults of one dose of influenza A H1N1v 2009 vaccine formulated with and without AS03A-adjuvant: preliminary report of an observer-blind, randomised trial. Vaccine.
1183 Roman F, Vaman T, Kafeja F, et al. (2010). AS03(A)-adjuvanted influenza A (H1N1) 2009 vaccine for adults up to 85 years of age. Clinical Infectious Diseases.
1184 Romano L, Zanetti AR. (2011). Safety and immunogenicity of a recombinant hepatitis B vaccine manufactured by a modified process in healthy infants. Expert Review of Vaccines.
1185 Romano L, Zanetti AR. (2011). Safety and immunogenicity of a recombinant hepatitis B vaccine manufactured by a modified process in healthy infants. Expert Review of Vaccines.
1186 Roscelli JD, Bass JW, Pang L. (1991). Guillain-Barre syndrome and influenza vaccination in the US Army, 1980-1988. Am J Epidemiol.
1187 Rose MA, Gruendler M, Schubert R, et al. (2009). Safety and immunogenicity of sequential pneumococcal immunization in preschool asthmatics. Vaccine.
1188 Rose MA, Schubert R, Strnad N, et al. (2005). Priming of immunological memory by pneumococcal conjugate vaccine in children unresponsive to 23-valent polysaccharide pneumococcal vaccine. Clinical and Diagnostic Laboratory Immunology.
1189 Rose NR. (2011). Conjugate vaccines and autism. Medical Hypotheses.
1190 Rosenblum H, Shoenfeld Y, Amital H. (2011). The Common Immunogenic Etiology of Chronic Fatigue Syndrome: From Infections to Vaccines via Adjuvants to the ASIA Syndrome. Infectious Disease Clinics of North America.
1191 Rosenfeld RM, Bluestone CD, Casselbrant ML, et al. (2005). Treatment. Annals of Otology, Rhinology and Laryngology.
1192 Rothstein EP, Bernstein HH, Glode MP, et al. (1993). Simultaneous administration of a diphtheria and tetanus toxoids and acellular pertussis vaccine with measles-mumps-rubella and oral poliovirus vaccines. American Journal of Diseases of Children.
1193 Rottem M, Shoenfeld Y. (2004). Vaccination and allergy. Current Opinion in Otolaryngology & Head & Neck Surgery.
1194 Rowhani-Rahbar A, Klein NP, Baxter R. (2012). Assessing the safety of influenza vaccination in specific populations: children and the elderly. Expert Review of Vaccines.
1195 Ruiz LP. (2010). Re: “Age dependence of the risk of intussusception following tetravalent rhesus-human reassortant rotavirus tetravalent vaccine: is it beyond doubt?”. American Journal of Epidemiology.
1196 Ruiz LP. (2011). Intussusception risk of rotavirus vaccination. New England Journal of Medicine.
1197 Rumke HC, Loch HP, Hoppenbrouwers K, et al. (2011). Immunogenicity and safety of a measles-mumps-rubella-varicella vaccine following a 4-week or a 12-month interval between two doses. Vaccine.
1198 Rupp ME, Holley HP, Lutz J, et al. (2007). Phase II, randomized, multicenter, double-blind, placebo-controlled trial of a polyclonal anti-Staphylococcus aureus capsular polysaccharide immune globulin in treatment of Staphylococcus aureus bacteremia. Antimicrobial Agents & Chemotherapy.
1199 Russell FM, Licciardi PV, Balloch A, et al. (2010). Safety and immunogenicity of the 23-valent pneumococcal polysaccharide vaccine at 12 months of age, following one, two, or three doses of the 7-valent pneumococcal conjugate vaccine in infancy. Vaccine.
1200 Russell M, Pool V, Kelso JM, et al. (2004). Vaccination of persons allergic to latex: A review of safety data in the Vaccine Adverse Event Reporting System (VAERS). Vaccine.
1201 Rutherford EJ, Livengood J, Higginbotham M, et al. (1995). Efficacy and safety of pneumococcal revaccination after splenectomy for trauma. Journal of Trauma-Injury Infection & Critical Care.
1202 Ruuskanen O, Salmi TT, Stenvik M, et al. (1980). Inactivated poliovaccine: adverse reactions and antibody responses. Acta Paediatrica Scandinavica.
1203 Ruuskanen O, Viljanen MK, Salmi TT, et al. (1980). DTP and DTP-inactivated polio vaccines: comparison of adverse reactions and IGG, IGM and IGA antibody responses to DTP. Acta Paediatrica Scandinavica.
1204 Ryan MAK, McKeehan JA, Gray GC. (2001). Pneumococcal vaccine to counter emerging infectious disease threat in the military. Military Medicine.
1205 Saad CGS, Borba EF, Aikawa NE, et al. (2011). Immunogenicity and safety of the 2009 non-adjuvanted influenza A/H1N1 vaccine in a large cohort of autoimmune rheumatic diseases. Annals of the Rheumatic Diseases.
1206 Sabitha P, Prabha Adhikari MR, Chowdary A, et al. (2004). Comparison of the immunogenicity and safety of two different brands of Salmonella typhi Vi capsular polysaccharide vaccine. Indian Journal of Medical Sciences.
1207 Sablan BP, Kim DJ, Barzaga NG, et al. (2012). Demonstration of safety and enhanced seroprotection against hepatitis B with investigational HBsAg-1018 ISS vaccine compared to a licensed hepatitis B vaccine. Vaccine.
1208 Sacarlal J, Aponte JJ, Aide P, et al. (2008). Safety of the RTS,S/AS02A malaria vaccine in Mozambican children during a Phase IIb trial. Vaccine.
1209 Saenger R, Maechler G, Potreck M, et al. (2005). Booster vaccination with hexavalent DTPa-HBV-IPV/Hib vaccine in the second year of life is as safe as concomitant DTPa-IPV/Hib + HBV administered separately. Vaccine.
1210 Saez-Llorens X, Guevara JN. (2004). Intussusception and rotavirus vaccines: what is the background risk?. Pediatric Infectious Disease Journal.
1211 Sakano T, Kittaka E, Tanaka Y. (1980). Vaccine-associated poliomyelitis in an infant with agammaglobulinemia. Acta Paediatrica Scandinavica.
1212 Saksawad R, Likitnukul S, Warachit B, et al. (2011). Immunogenicity and safety of a pediatric dose virosomal hepatitis A vaccine in Thai HIV-infected children. Vaccine.
1213 Salemi S, Picchianti-Diamanti A, Germano V, et al. (2010). Influenza vaccine administration in rheumatoid arthritis patients under treatment with TNFalpha blockers: safety and immunogenicity. Clinical Immunology.
1214 Sandbu S, Feiring B, Oster P, et al. (2007). Immunogenicity and safety of a combination of two serogroup B meningococcal outer membrane vesicle vaccines. Clinical & Vaccine Immunology: CVI.
1215 Sanders R, Dabbagh A, Featherstone D. (2011). Risk Analysis for Measles Reintroduction After Global Certification of Eradication. Journal of Infectious Diseases.
1216 Sanger R, Behre U, Krause KH, et al. (2007). Booster vaccination and 1-year follow-up of 4-8-year-old children with a reduced-antigen-content dTpa-IPV vaccine. European Journal of Pediatrics.
1217 Sankilampi U, Honkanen PO, Pyhala R, et al. (1997). Associations of prevaccination antibody levels with adverse reactions to pneumococcal and influenza vaccines administered simultaneously in the elderly. Vaccine.
1218 Santini-Oliveira M, Camacho LA, Souza TM, et al. (2012). H1N1pdm09 adjuvanted vaccination in HIV-infected adults: a randomized trial of two single versus two double doses. PLoS ONE.
1219 Santini-Oliveira M, Camacho LAB, Souza TML, et al. (2012). H1N1pdm09 adjuvanted vaccination in HIV-infected adults: A randomized trial of two single versus two double doses. PLoS ONE.
1220 Santosham M, Englund JA, McInnes P, et al. (2001). Safety and antibody persistence following Haemophilus influenzae type b conjugate or pneumococcal polysaccharide vaccines given before pregnancy in women of childbearing age and their infants. Pediatric Infectious Disease Journal.
1221 Santosham M, Hill J, Wolff M, et al. (1991). Safety and immunogenicity of a Haemophilus influenzae type b conjugate vaccine in a high risk American Indian population. Pediatric Infectious Disease Journal.
1222 Sarntivijai S, Xiang Z, Shedden KA, et al. (2012). Ontology-based combinatorial comparative analysis of adverse events associated with killed and live influenza vaccines. PLoS ONE.
1223 Sato HK, Sanajotta AT, Moraes JC, et al. (2011). Rubella vaccination of unknowingly pregnant women: the Sao Paulo experience, 2001. Journal of Infectious Diseases.
1224 Sauve LJ, Bettinger J, Scheifele D, et al. (2010). Postvaccination thrombocytopenia in Canada. Pediatric Infectious Disease Journal.
1225 Savy M, Edmond K, Fine PEM, et al. (2009). Landscape analysis of interactions between nutrition and vaccine responses in children. Journal of Nutrition.
1226 Schatz M, Chambers CD, Jones KL, et al. (2011). Safety of influenza immunizations and treatment during pregnancy: the Vaccines and Medications in Pregnancy Surveillance System. American Journal of Obstetrics & Gynecology.
1227 Scheifele D, Barreto L, Meekison W, et al. (1993). Can Haemophilus influenzae type b-tetanus toxoid conjugate vaccine be combined with diphtheria toxoid-pertussis vaccine-tetanus toxoid?. CMAJ Canadian Medical Association Journal.
1228 Scheifele D, Bjornson G, Barreto L, et al. (1992). Controlled trial of Haemophilus influenzae type B diphtheria toxoid conjugate combined with diphtheria, tetanus and pertussis vaccines, in 18-month-old children, including comparison of arm versus thigh injection. Vaccine.
1229 Scheifele DW, Bjornson GL, Meekison WG, et al. (1994). Evaluation of Haemophilus influenzae type b conjugate vaccine (meningococcal protein conjugate) in Canadian infants. Canadian Journal of Infectious Diseases.
1230 Scheifele DW, Guasparini R, Lavigne P. (1999). A comparative study of PENTA vaccine booster doses given at 12, 15, or 18 months of age. Vaccine.
1231 Scheifele DW, Halperin SA, Ochnio JJ, et al. (2005). A modified vaccine reduces the rate of large injection site reactions to the preschool booster dose of diphtheria-tetanus-acellular pertussis vaccine: Results of a randomized, controlled trial. Pediatric Infectious Disease Journal.
1232 Scheifele DW, Halperin SA, Ochnio JJ, et al. (2007). Immunologic considerations for the timing of the booster dose of 7-valent pneumococcal conjugate vaccine in young children. Pediatric Infectious Disease Journal.
1233 Scheifele DW, Halperin SA, Rubin E, et al. (2005). Safety and immunogenicity of a pentavalent combination vaccine (diphtheria, tetanus, acellular pertussis, polio, and haemophilus influenzae type B conjugate) when administered as a fourth dose at 15 to 18 months of age. Human Vaccines.
1234 Scheifele DW, Meekison W, Guasparini R, et al. (1995). Evaluation of booster doses of Haemophilus influenzae type b-tetanus toxoid conjugate vaccine in 18-month-old children. Vaccine.
1235 Scheifele DW, Ward BJ, Dionne M, et al. (2012). Compatibility of ASO3-adjuvanted H1N1pdm09 and seasonal trivalent influenza vaccines in adults: Results of a randomized, controlled trial. Vaccine.
1236 Schessl J, Luther B, Kirschner J, et al. (2006). Infections and vaccinations preceding childhood Guillain-Barre syndrome: A prospective study. European Journal of Pediatrics.
1237 Schiller JT, Castellsague X, Garland SM. (2012). A review of clinical trials of human papillomavirus prophylactic vaccines. Vaccine.
1238 Schmeink CE, Bekkers RLM, Josefsson A, et al. (2011). Co-administration of human papillomavirus-16/18 AS04-adjuvanted vaccine with hepatitis B vaccine: Randomized study in healthy girls. Vaccine.
1239 Schmitt HJ, Knuf M, Ortiz E, et al. (2000). Primary vaccination of infants with diphtheriatetanus-acellular pertussis-hepatitis B virus-inactivated polio virus and Haemophilus influenzae type b vaccines given as either separate or mixed injections. Journal of Pediatrics.
1240 Schmitt HJ, Maechler G, Habermehl P, et al. (2007). Immunogenicity, reactogenicity, and immune memory after primary vaccination with a novel Haemophilus influenzae-Neisselia meningitidis serogroup C conjugate vaccine. Clinical and Vaccine Immunology.
1241 Schmitt HJ, Wirsing von Konig CH, Zepp F, et al. (1997). Immunogenicity and reactogenicity of HbOC vaccine administered simultaneously with acellular pertussis vaccine (DTaP) into either arms or thighs of infants. Infection.
1242 Schmitt HJ, Zepp F, Muschenborn S, et al. (1998). Immunogenicity and reactogenicity of a Haemophilus influenzae type b tetanus conjugate vaccine when administered separately or mixed with concomitant diphtheria-tetanus-toxoid and acellular pertussis vaccine for primary and for booster immunizations. European Journal of Pediatrics.
1243 Schmitt HJ, Maechler G, Habermehl P, et al. (2007). Immunogenicity, reactogenicity, and immune memory after primary vaccination with a novel Haemophilus influenzae-Neisseria meningitidis serogroup C conjugate vaccine. Clinical & Vaccine Immunology: CVI.
1244 Schmitt HJ, Siegrist CA, Salmaso S, et al., Zinka B. (2006). Unexplained cases of sudden infant death shortly after hexavalent vaccination. Vaccine.
1245 Schmitt HJ, Steul KS, Borkowski A, et al. (2008). Two versus three doses of a meningococcal C conjugate vaccine concomitantly administered with a hexavalent DTaP-IPV-HBV/Hib vaccine in healthy infants. Vaccine.
1246 Schonbeck Y, Sanders EAM, Hoes AW, et al. (2005). Rationale and design of the prevention of respiratory infections and management in children (PRIMAKid) study: a randomized controlled trial on the effectiveness and costs of combined influenza and pneumococcal vaccination in pre-school children with recurrent respiratory tract infections. Vaccine.
1247 Schonberger LB, McGowan Jr JE, Gregg MB. (1976). Vaccine associated poliomyelitis in the United States, 1961-1972. American Journal of Epidemiology.
1248 Schooling CM, McGhee SM, Cowling BJ, et al. (2012). Influenza vaccination and hospitalisation in Elderly Health Centres. Hong Kong Medical Journal.
1249 Schuerman L, Borys D, Hoet B, et al. (2009). Prevention of otitis media: Now a reality?. Vaccine.
1250 Schulzke S, Heininger U, Lucking-Famira M, et al. (2005). Apnoea and bradycardia in preterm infants following immunisation with pentavalent or hexavalent vaccines. European Journal of Pediatrics.
1251 Schumacher Z, Bourquin C, Heininger U. (2010). Surveillance for adverse events following immunization (AEFI) in Switzerland-1991-2001. Vaccine.
1252 Schuurmans MM, Tini GM, Dalar L, et al. (2011). Pandemic 2009 H1N1 influenza virus vaccination in lung transplant recipients: coverage, safety and clinical effectiveness in the Zurich cohort (vol 30, pg 685, 2011). Journal of Heart and Lung Transplantation.
1253 Schwartz HJ, Terr AI. (1971). The immune response of allergic and normal subjects to pneumococcal polysaccharide. International Archives of Allergy & Applied Immunology.
1254 Schwarz TF, Flamaing J, Rumke HC, et al. (2011). A randomized, double-blind trial to evaluate immunogenicity and safety of 13-valent pneumococcal conjugate vaccine given concomitantly with trivalent influenza vaccine in adults aged >=65 years. Vaccine.
1255 Scott DA, Komjathy SF, Hu BT, et al. (2007). Phase 1 trial of a 13-valent pneumococcal conjugate vaccine in healthy adults. Vaccine.
1256 Scudellari M. (2010). Vaccine contamination prompts safety review. Nature Medicine.
1257 Selman S, Hayes D, Perin LA, et al. (2000). Pneumococcal conjugate vaccine for young children. Managed Care.
1258 Seltsam A, Shukry-Schulz S, Salama A. (2000). Vaccination-associated immune hemolytic anemia in two children. Transfusion.
1259 Shafrir Y. (2010). Vaccination and Dravet syndrome. Lancet Neurology.
1260 Shahgholi E, Ehsani MA, Salamati P, et al. (2010). Immunogenicity of trivalent influenza vaccine in children with acute lymphoblastic leukemia during maintenance therapy. Pediatric Blood and Cancer.
1261 Shahmahmoodi S, Mamishi S, Aghamohammadi A, et al. (2010). Vaccine-associated paralytic poliomyelitis in immunodeficient children, Iran, 1995-2008. Emerging Infectious Diseases.
1262 Shann F. (2011). The nonspecific effects of vaccines and the expanded program on immunization. Journal of Infectious Diseases.
1263 Shao PL, Lu CY, Hsieh YC, et al. (2011). Immunogenicity and Reactogenicity of Diphtheria-Tetanus-Acellular Pertussis-Hepatitis B-Inactivated Poliovirus and Haemophilus influenzae Type B Vaccines Administered Concomitantly to Infants as a Three-dose Primary Course. Journal of the Formosan Medical Association.
1264 Shao PL, Lu CY, Chang LY, et al. (2006). Safety and immunogenicity of heptavalent pneumococcal conjugate vaccine booster in taiwanese toddlers. Journal of the Formosan Medical Association.
1265 Shao PL, Lu CY, Chang LY, et al. (2004). Safety and immunogenicity of heptavalent pneumococcal conjugate vaccine in Taiwanese infants. Journal of the Formosan Medical Association.
1266 Shao PL, Lu CY, Hsieh YC, et al. (2011). Immunogenicity and reactogenicity of diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated poliovirus and Haemophilus influenzae type B. Journal of the Formosan Medical Association.
1267 Shapiro ED, Capobianco LA, Berg AT, et al. (1989). The immunogenicity of Hemophilus influenzae type B polysaccharide-Neisseria meningitidis group B outer membrane protein complex vaccine in infants and young children. Journal of Infectious Diseases.
1268 Sharma A, Agarwal D, Kapoor S, et al. (2011). Vaccination as a triggering agent for the development of rheumatoid arthritis. International Journal of Rheumatic Diseases.
1269 Sharma H, Yadav S, Lalwani S, et al. (2011). A phase III randomized, controlled study to assess the immunogenicity and tolerability of DTPw-HBV-Hib, a liquid pentavalent vaccine in Indian infants. Vaccine.
1270 Sharma H, Yadav S, Patil V, et al. (2011). A phase III randomized, controlled study to assess and compare the immunogenicity and tolerability of single and multi-dose vials of DTwP-Hib, a fully liquid quadravalent vaccine and their comparison with TETRAct-Hib vaccine in Indian infants aged 6-14 weeks. Vaccine.
1271 Sharma HJ, Multani AS, Dutta AK, et al. (2009). Safety and immunogenicity of an indigenously developed Haemophilus influenzae type b conjugate vaccine through various phases of clinical trials. Human Vaccines.
1272 Sharma HJ, Patil VD, Lalwani SK, et al. (2012). Assessment of safety and immunogenicity of two different lots of diphtheria, tetanus, pertussis, hepatitis B and Haemophilus influenzae type b vaccine manufactured using small and large scale manufacturing process. Vaccine.
1273 Sharma HJ, Yadav S, Lalwani SK, et al. (2011). Immunogenicity and safety of an indigenously manufactured reconstituted pentavalent (DTwP-HBV+Hib) vaccine in comparison with a foreign competitor following primary and booster immunization in Indian children. Human Vaccines.
1274 Sharrar RG, LaRussa P, Galea SA, et al. (2000). The postmarketing safety profile of varicella vaccine. Vaccine.
1275 Shatsky M. (2006). Rotavirus vaccine, live, oral, pentavalent (RotaTeq) for prevention of rotavirus gastroenteritis. American Family Physician.
1276 Sheffield JS, Hickman A, Tang J, et al. (2011). Efficacy of an Accelerated Hepatitis B Vaccination Program During Pregnancy. Obstetrics and Gynecology.
1277 Sheikh A, Alves B, Dhami S. (2002). Pneumococcal vaccine for asthma. Cochrane Database of Systematic Reviews.
1278 Sheldon EA, Schwartz H, Jiang Q, et al. (2012). A Phase 1, randomized, open-label, active-controlledtrial to assess the safety of a meningococcal serogroup B bivalent rLP2086 vaccine in healthy adults. Human Vaccines and Immunotherapeutics.
1279 Shibazaki K, Murakami T, Kushida R, et al. (2006). Acute disseminated encephalomyelitis associated with oral polio vaccine. Internal Medicine.
1280 Shields WD, Nielsen C, Buch D, et al. (1988). Relationship of pertussis immunization to the onset of neurologic disorders: A retrospective epidemiologic study. Journal of Pediatrics.
1281 Shin SY, Lee SW, Cho YH, et al. (2011). Blood-borne transmission of the measles, mumps, and rubella vaccine virus. Transfusion.
1282 Shinefield H, Black S, Ray P, et al. (2002). Efficacy, immunogenicity and safety of heptavalent pneumococcal conjugate vaccine in low birth weight and preterm infants. Pediatric Infectious Disease Journal.
1283 Shinefield H, Black S, Thear M, et al. (2006). Safety and immunogenicity of a measles, mumps, rubella and varicella vaccine given with combined Haemophilus influenzae type b conjugate/hepatitis B vaccines and combined diphtheria-tetanus-acellular pertussis vaccines. Pediatric Infectious Disease Journal.
1284 Shinefield HR, Black S, Ray P, et al. (1999). Safety and immunogenicity of heptavalent pneumococcal CRM197 conjugate vaccine in infants and toddlers. Pediatric Infectious Disease Journal.
1285 Shinoki T, Hara R, Kaneko U, et al. (2012). Safety and response to influenza vaccine in patients with systemic-onset juvenile idiopathic arthritis receiving tocilizumab. Modern Rheumatology.
1286 Shneyer E, Strulov A, Rosenfeld Y. (2009). Reduced rate of side effects associated with separate administration of MMR and DTaP-Hib-IPV vaccinations. Israel Medical Association Journal: Imaj.
1287 Shoda A, Hayashi M, Takayama N, et al. (2011). Maternal screening and postpartum vaccination for measles infection in Japan: a cohort study. BJOG: An International Journal of Obstetrics & Gynaecology.
1288 Shu M, Liu Q, Wang J, et al. (2011). Measles vaccine adverse events reported in the mass vaccination campaign of Sichuan province, China from 2007 to 2008. Vaccine.
1289 Shuster J. (2010). Ciprofloxacin-induced immunoglobulin a disease; Palonosetron-induced anaphylaxis; Guillain-Barre Syndrome following H1N1 immunization; Acute profound thrombocytopenia following eptifibatide administration; Clozapine-associated cerebral venous thrombosis; Three excellent reviews: Drug-induced black hairy tongue, Increased C. difficile infections with PPI prophylaxis. Hospital Pharmacy.
1290 Siberry GK, Warshaw MG, Williams PL, et al. (2012). Safety and immunogenicity of quadrivalent meningococcal conjugate vaccine in 2- to 10-year-old human immunodeficiency virus-infected children. Pediatric Infectious Disease Journal.
1291 Siddiqui AH, Chitlur MB. (2010). Immune thrombocytopenic purpura in a 5-month-old female with rotavirus infection. Pediatric Blood & Cancer.
1292 Siebert JN, Posfay-Barbe KM, Habre W, et al. (2007). Influence of anesthesia on immune responses and its effect on vaccination in children: Review of evidence. Paediatric Anaesthesia.
1293 Sigurdardottir ST, Davidsdottir K, Arason VA, et al. (2008). Safety and immunogenicity of CRM197-conjugated pneumococcal-meningococcal C combination vaccine (9vPnC-MnCC) whether given in two or three primary doses. Vaccine.
1294 Sigurdardottir ST, Ingolfsdottir G, Davidsdottir K, et al. (2002). Immune response to octavalent diphtheria- and tetanus-conjugated pneumococcal vaccines is serotype- and carrier-specific: the choice for a mixed carrier vaccine. Pediatric Infectious Disease Journal.
1295 Silfverdal SA, Flodmark CE, Rombo L, et al. (2013). 13-Valent pneumococcal conjugate vaccine (PCV13) in children partially immunized with 7-valent pneumococcal conjugate vaccine (PCV7): a phase 3, open-label trial. Vaccine.
1296 Simoes EA, Balraj V, Selvakumar R, et al. (1988). Antibody response of children to measles vaccine mixed with diphtheria-pertussis-tetanus or diphtheria-pertussis-tetanus-poliomyelitis vaccine. American Journal of Diseases of Children.
1297 Simon JK, Carter M, Pasetti MF, et al. (2011). Safety, tolerability, and immunogenicity of inactivated trivalent seasonal influenza vaccine administered with a needle-free disposable-syringe jet injector. Vaccine.
1298 Simonsen L, Morens D, Elixhauser A, et al. (2001). Effect of rotavirus vaccination programme on trends in admission of infants to hospital for intussusception. Lancet.
1299 Simonsen L, Morens DM, Blackwelder WC. (2002). Ecological studies, rotavirus vaccination, and intussusception. Lancet.
1300 Simonsen L, Taylor RJ, Kapikian AZ. (2006). Rotavirus vaccines. New England Journal of Medicine.
1301 Singleton R, Wenger J, Klejka JA, et al. (2012). The 13-valent pneumococcal conjugate vaccine for invasive pneumococcal disease in alaska native children: Results of a clinical trial. Pediatric Infectious Disease Journal.
1302 Singleton R, Wenger J, Klejka JA, et al. (2013). The 13-valent pneumococcal conjugate vaccine for invasive pneumococcal disease in Alaska native children: results of a clinical trial. Pediatric Infectious Disease Journal.
1303 Siwek J. (1991). Hemophilus b conjugate vaccines: good news, bad news. American Family Physician.
1304 Skowronski DM, Hottes TS, Chong M, et al. (2011). Randomized controlled trial of dose response to influenza vaccine in children aged 6 to 23 months. Pediatrics.
1305 Skowronski DM, Janjua NZ, Hottes TS, et al. (2009). Pneumococcal vaccination and myocardial infarction. CMAJ Canadian Medical Association Journal.
1306 Skowronski DM, Strauss B, De Serres G, et al. (2003). Oculo-respiratory syndrome: a new influenza vaccine-associated adverse event?. Clin Infect Dis.
1307 Slack MH, Schapira C, Thwaites RJ, et al. (2003). Acellular pertussis and meningococcal C vaccines: Cardio-respiratory events in preterm infants. European Journal of Pediatrics.
1308 Slade BA, Leidel L, Vellozzi C, et al. (2009). Postlicensure safety surveillance for quadrivalent human papillomavirus recombinant vaccine. JAMA.
1309 Snape MD, Dawson T, Oster P, et al. (2010). Immunogenicity of two investigational serogroup B meningococcal vaccines in the first year of life: A randomized comparative trial. Pediatric Infectious Disease Journal.
1310 Snape MD, Klinger CL, Daniels ED, et al. (2010). Immunogenicity and reactogenicity of a 13-valent-pneumococcal conjugate vaccine administered at 2, 4, and 12 months of age: A double-blind randomized active-controlled trial. Pediatric Infectious Disease Journal.
1311 Soares RC, Siqueira MM, Toscano CM, et al. (2012). Follow-up study of unknowingly pregnant women vaccinated against rubella in Brazil, 2001-2002. Obstetrical and Gynecological Survey.
1312 Soares-Weiser K, Goldberg E, Tamimi G, et al. (2004). Rotavirus vaccine for preventing diarrhoea. Cochrane Database of Systematic Reviews.
1313 Socan M, Frelih T, Janet E, et al. (2004). Reactions after pneumococcal vaccine alone or in combination with influenza vaccine. Vaccine.
1314 Sonder G, Van den Hoek A. (2010). Hepatitis B immunization coverage and risk behaviour among Danish travellers: Are immunization strategies based on single journey itineraries rational?. Journal of Infection.
1315 Song JY, Cheong HJ, Woo HJ, et al. (2011). Immunogenicity and safety of trivalent inactivated influenza vaccine: a randomized, double-blind, multi-center, phase 3 clinical trial in a vaccine-limited country. Journal of Korean Medical Science.
1316 Sou T, Meeusen EN, de Veer M, et al. (2011). New developments in dry powder pulmonary vaccine delivery. Trends in Biotechnology.
1317 Souayah N, Michas-Martin PA, Nasar A, et al. (2011). Guillain-Barre syndrome after Gardasil vaccination: data from Vaccine Adverse Event Reporting System 2006-2009. Vaccine.
1318 Souayah N, Nasar A, Suri MFK, et al. (2009). Guillain-barre syndrome after vaccination in United States: Data from the centers for disease control and prevention/food and drug administration vaccine adverse event reporting system (1990-2005). Journal of Clinical Neuromuscular Disease.
1319 Souayah N, Yacoub HA, Khan HM, et al. (2012). Analysis of data from the CDC/FDA vaccine adverse event reporting system (1990-2009) on Guillain-Barre syndrome after hepatitis vaccination in the USA. Journal of Clinical Neuroscience.
1320 Souayah N, Yacoub HA, Khan HM, et al. (2012). Guillain-Barre syndrome after influenza vaccination in the United States, a report from the CDC/FDA vaccine adverse event reporting system (1990-2009). Journal of Clinical Neuromuscular Disease.
1321 Souayah N, Yacoub HA, Khan HM, et al. (2012). Guillain-Barre syndrome after H1N1 vaccination in the United States: a report using the CDC/FDA Vaccine Adverse Event Reporting System (2009). Neuroepidemiology.
1322 Souayah N, Yacoub HA, Khan HMR, et al. (2012). Guillain-Barre Syndrome after H1N1 Vaccination in the United States: A Report Using the CDC/FDA Vaccine Adverse Event Reporting System (2009). Neuroepidemiology.
1323 Southern J, Deane S, Ashton L, et al. (2004). Effects of prior polysaccharide vaccination on magnitude, duration, and quality of immune responses to and safety profile of a meningococcal serogroup C tetanus toxoid conjugate vaccination in adults. Clinical & Diagnostic Laboratory Immunology.
1324 Souza AR, Braga JAP, de Paiva TM, et al. (2010). Immunogenicity and tolerability of a virosome influenza vaccine compared to split influenza vaccine in patients with sickle cell anemia. Vaccine.
1325 Sow SO, Okoko BJ, Diallo A, et al. (2011). Immunogenicity and safety of a meningococcal A conjugate vaccine in Africans. New England Journal of Medicine.
1326 Sox C. (2011). Acute otitis media: antibiotics are moderately effective and mildly increase the risk of adverse effects; prevalence of different causative bacteria changed after introduction of the heptavalent pneumococcal conjugate vaccine. Evidence Based Medicine.
1327 Spinola SM, Sheaffer CI, Gilligan PH. (1986). Antigenuria after Haemophilus influenzae type b polysaccharide vaccination. Journal of Pediatrics.
1328 Spinola SM, Sheaffer CI, Philbrick KB, et al. (1986). Antigenuria after Haemophilus influenzae type b polysaccharide immunization: A prospective study. Journal of Pediatrics.
1329 Spitaleri G, Delmonte A, Toffalorio F, et al. (2010). Safety of concomitant administration of seasonal and/or H1N1 flu vaccination in patients receiving erlotinib for advanced non-small cell lung cancer. Journal of Thoracic Oncology: Official Publication of the International Association for the Study of Lung Cancer.
1330 Stangenberg S, John G, Healy H, et al. (2011). Response of renal transplant recipients to the monovalent pandemic H1N1 vaccine. Nephrology.
1331 Stanley PJ, Ellis CJ. (1989). New vaccines. British Journal of Hospital Medicine.
1332 Stavrikj K, Peova S, Petlickovski A, et al. (2011). Safe measles, mumps and rubella vaccine administration in atopic children with high levels of egg white-specific IgE antibody. Macedonian Journal of Medical Sciences.
1333 Stavroulopoulos A, Stamogiannos G, Aresti V. (2010). Pandemic 2009 influenza H1N1 virus vaccination: compliance and safety in a single hemodialysis center. Renal Failure.
1334 Steele AD, De Vos B, Tumbo J, et al. (2010). Co-administration study in South African infants of a live-attenuated oral human rotavirus vaccine (RIX4414) and poliovirus vaccines. Vaccine.
1335 Steele AD, Madhi SA, Louw CE, et al. (2011). Safety, Reactogenicity, and Immunogenicity of Human Rotavirus Vaccine RIX4414 in Human Immunodeficiency Virus-positive Infants in South Africa. Pediatric Infectious Disease Journal.
1336 Steele RW. (1998). Safety and immunogenicity of heptavalent pneumococcal vaccine conjugated to CRM197 in United States infants. Clinical Pediatrics.
1337 Steentoft J, Konradsen HB, Hilskov J, et al. (2006). Response to pneumococcal vaccine in chronic obstructive lung disease - The effect of ongoing, systemic steroid treatment. Vaccine.
1338 Stojanov S, Liese JG, Belohradsky BH, et al. (2007). Administration of hepatitis A vaccine at 6 and 12 months of age concomitantly with hexavalent (DTaP-IPV-PRP∼T-HBs) combination vaccine. Vaccine.
1339 Stojanov S, Liese JG, Bendjenana H, et al. (2000). Immunogenicity and safety of a trivalent tetanus, low dose diphtheria, inactivated poliomyelitis booster compared with a standard tetanus, low dose diphtheria booster at six to nine years of age. Munich Vaccine Study Group. Pediatric Infectious Disease Journal.
1340 Stratton KR, Howe CJ, Johnston RB. (1994). Adverse events associated with childhood vaccines other than pertussis and rubella. Summary of a report from the Institute of Medicine. JAMA.
1341 Su EL, Snape MD. (2011). A combination recombinant protein and outer membrane vesicle vaccine against serogroup B meningococcal disease. Expert Review of Vaccines.
1342 Suarez E, Asturias EJ, Hilbert AK, et al. (2010). A fully liquid DTPw-HepB-Hib combination vaccine for booster vaccination of toddlers in El Salvador. Pan American Journal of Public Health.
1343 Surquin M, Tielemans C, Nortier J, et al. (2011). Anti-HBs antibody persistence following primary vaccination with an investigational AS02(v)-adjuvanted hepatitis B vaccine in patients with renal insufficiency. Human Vaccines.
1344 Surquin M, Tielemans CL, Kulcsar I, et al. (2010). Rapid, enhanced, and persistent protection of patients with renal insufficiency by AS02(V)-adjuvanted hepatitis B vaccine. Kidney International.
1345 Sutradhar SC, Wang WW, Schlienger K, et al. (2009). Comparison of the levels of immunogenicity and safety of Zostavax in adults 50 to 59 years old and in adults 60 years old or older. Clin Vaccine Immunol.
1346 Sutter RW, John TJ, Jain H, et al. (2010). Immunogenicity of bivalent types 1 and 3 oral poliovirus vaccine: a randomised, double-blind, controlled trial. Lancet.
1347 Szarewski A, Poppe WAJ, Skinner SR, et al. (2012). Efficacy of the human papillomavirus (HPV)-16/18 AS04-adjuvanted vaccine in women aged 15-25 years with and without serological evidence of previous exposure to HPV-16/18. International Journal of Cancer.
1348 Szymczakiewicz-Multanowska A, Groth N, Bugarini R, et al. (2009). Safety and immunogenicity of a novel influenza subunit vaccine produced in mammalian cell culture. J Infect Dis.
1349 Szymczakiewicz-Multanowska A, Lattanzi M, Izu A, et al. (2012). Safety assessment and immunogenicity of a cell-culture-derived influenza vaccine in adults and elderly subjects over three successive influenza seasons. Human vaccines & Immunotherapeutics.
1350 Szynczewska E, Chlebna-Sokol D. (2011). Immunogenicity and safety of heptavalent conjugate vaccine against Streptococcus pneumoniae in pre-term Polish infants. Vaccine.
1351 Tager A. (1974). Preliminary report on the treatment of recurrent herpes simplex with poliomyelitis vaccine (Sabin's). Dermatologica.
1352 Talbot EA, Brown KH, Kirkland KB, et al. (2010). The safety of immunizing with tetanus-diphtheria-acellular pertussis vaccine (Tdap) less than 2 years following previous tetanus vaccination: Experience during a mass vaccination campaign of healthcare personnel during a respiratory illness outbreak. Vaccine.
1353 Tamm E, Veronese A, Contorni M, et al. (2005). Double-blind study comparing the immunogenicity of a licensed DTwPHib-CRM197 conjugate vaccine (Quattvaxem) with three investigational, liquid formulations using lower doses of Hib-CRM197 conjugate. Vaccine.
1354 Tandale BV, Pawar SD, Mishra AC. (2012). Immunogenicity and safety of pandemic H1N1 2009 vaccine among adults in field use, India. Vaccine.
1355 Tantawy AAG, Algohary EAM, El-Ghany SMA, et al. (2012). Haemophilia A patients are not at increased risk of hepatitis A virus infection: An Egyptian experience. Egyptian Journal of Medical Human Genetics.
1356 Tate JE, Simonsen L, Viboud C, et al. (2008). Trends in intussusception hospitalizations among US infants, 1993-2004: implications for monitoring the safety of the new rotavirus vaccination program. Pediatrics.
1357 Tate JE, Steele AD, Bines JE, et al. (2012). Research priorities regarding rotavirus vaccine and intussusception: a meeting summary. Vaccine.
1358 Tauber T, Lahat E, Dolinsky G, et al. (2001). Haemophilus influenza type b vaccine in Israel: Experience in a paediatric ambulatory clinic. Annals of Tropical Paediatrics.
1359 Tavana S, Argani H, Gholamin S, et al. (2012). Influenza vaccination in patients with pulmonary sarcoidosis: efficacy and safety. Influenza & Other Respiratory Viruses.
1360 Tavares F, Delaigle A, Slavin D, et al. (2011). Anaphylaxis following H1N1 pandemic vaccines: safety data in perspective. Vaccine.
1361 Taweesith W, Puthanakit T, Kowitdamrong E, et al. (2011). The immunogenicity and safety of live attenuated varicella-zoster virus vaccine in human immunodeficiency virus-infected children. Pediatric Infectious Disease Journal.
1362 Taylor B, Lingam R, Simmons A, et al. (2002). Autism and MMR vaccination in North London; no causal relationship. Mol Psychiatry.
1363 Tejedor JC, Moro M, Merino JM, et al. (2008). Immunogenicity and reactogenicity of a booster dose of a novel combined Haemophilus influenzae type b-Neisseria meningitidis serogroup C-tetanus toxoid conjugate vaccine given to toddlers of 13-14 months of age with antibody persistence up to 31 months of age. Pediatric Infectious Disease Journal.
1364 Tejedor JC, Moro M, Ruiz-Contreras J, et al. (2007). Immunogenicity and reactogenicity of primary immunization with a novel combined Haemophilus influenzae Type b and Neisseria meningitidis Serogroup C-tetanus toxoid conjugate vaccine coadministered with a Diphtheria-tetanus-acellular Pertussis-hepatitis B-inactivated poliovirus vaccine at 2, 4 and 6 months. Pediatric Infectious Disease Journal.
1365 Tejedor JC, Moro M, Ruiz-Contreras J, et al. (2006). Immunogenicity and reactogenicity of primary immunization with a hexavalent diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated polio-Haemophilus influenzae type B vaccine coadministered with two doses of a meningococcal C-tetanus toxoid conjugate vaccine. Pediatric Infectious Disease Journal.
1366 Tejedor JC, Omenaca F, Garcia-Sicilia J, et al. (2006). Antibody persistence after primary vaccination with a hexavalent DTPa-HBV-IPV/HiB vaccine coadministered with a meningococcal C-CRM197 vaccine and response to a DTPa-IPV/HiB booster at 18 months of age. Pediatric Infectious Disease Journal.
1367 Tennis P, Toback SL, Andrews E, et al. (2011). A postmarketing evaluation of the frequency of use and safety of live attenuated influenza vaccine use in nonrecommended children younger than 5 years. Vaccine.
1368 Tennis P, Toback SL, Andrews EB, et al. (2012). A US postmarketing evaluation of the frequency and safety of live attenuated influenza vaccine use in nonrecommended children younger than 5 years: 2009-2010 season. Vaccine.
1369 Tennis P, Toback SL, Andrews EB, et al. (2012). A US postmarketing evaluation of the frequency and safety of live attenuated influenza vaccine use in nonrecommended children younger than 5 years: 2009-2010 season. Vaccine.
1370 Tesng HF, Smith N, Sy LS, et al. (2011). Evaluation of the incidence of herpes zoster after concomitant vaccination of a polysaccharide pneumococcal vaccine and a zoster vaccine. American Journal of Epidemiology.
1371 Thakur V, Pati NT, Gupta RC, et al. (2010). Efficacy of Shanvac-B recombinant DNA hepatitis B vaccine in health care workers of Northern India. Hepatobiliary & Pancreatic Diseases International.
1372 Thaler A. (2008). Miller Fisher syndrome in a 66-year-old female after flu and pneumovax vaccinations. Journal of the American Medical Directors Association.
1373 Thanee C, Pancharoen C, Likitnukul S, et al. (2011). The immunogenicity and safety of pneumococcal conjugate vaccine in human immunodeficiency virus-infected Thai children. Vaccine.
1374 Theeten H, Rumke H, Hoppener FJP, et al. (2007). Primary vaccination of adults with reduced antigen-content diphtheria-tetanus-acellular pertussis or dTpa-inactivated poliovirus vaccines compared to diphtheria-tetanus-toxoid vaccines. Current Medical Research and Opinion.
1375 Thiem VD, Danovaro-Holliday MC, Canh DG, et al. (2006). The feasibility of a school-based VI polysaccharide vaccine mass immunization campaign in Hue City, central Vietnam: streamlining a typhoid fever preventive strategy. Southeast Asian Journal of Tropical Medicine & Public Health.
1376 Thierry-Carstensen B, Jordan K, Uhlving HH, et al. (2012). A randomised, double-blind, non-inferiority clinical trial on the safety and immunogenicity of a tetanus, diphtheria and monocomponent acellular pertussis (TdaP) vaccine in comparison to a tetanus and diphtheria (Td) vaccine when given as booster vaccinations to healthy adults. Vaccine.
1377 Thisyakorn U, Chotpitayasunondh T, Pancharoen C, et al. (2010). Evaluation of an acellular pertussis, diphtheria, tetanus, inactivated poliovirus, Hib-conjugate combined vaccine (Pentaxim) at 2, 4, and 6 months of age plus hepatitis B vaccine at birth, 2, and 6 months of age in infants in Thailand. Southeast Asian Journal of Tropical Medicine & Public Health.
1378 Thisyakorn U, Pancharoen C, Chuenkitmongkol S, et al. (2009). Immunogenicity and safety of a DTaP-IPV//PRP-T vaccine (Pentaxim) booster during the second year of life in Thai children primed with an acellular pertussis combined vaccine. Southeast Asian Journal of Tropical Medicine & Public Health.
1379 Thomas C, Moridani M. (2010). Interindividual variations in the efficacy and toxicity of vaccines. Toxicology.
1380 Thompson DF, Montarella KE. (2007). Drug-induced Sweet's syndrome. Annals of Pharmacotherapy.
1381 Tichmann I, Preidel H, Grunert D, et al. (2005). Comparison of the immunogenicity and reactogenicity of two commercially available hexavalent vaccines administered as a primary vaccination course at 2, 4 and 6 months of age. Vaccine.
1382 Tichmann-Schumann I, Soemantri P, Behre U, et al. (2005). Immunogenicity and reactogenicity of four doses of diphtheria-tetanus-three-component acellular pertussis-hepatitis B-inactivated polio virus-Haemophilus influenzae type b vaccine coadministered with 7-valent pneumococcal conjugate Vaccine. Pediatric Infectious Disease Journal.
1383 Tielemans CL, Vlasak J, Kosa D, et al. (2011). Immunogenicity and safety of an investigational AS02(v)-adjuvanted hepatitis B vaccine in patients with renal insufficiency who failed to respond or to maintain antibody levels after prior vaccination: Results of two open, randomized, comparative trials. Vaccine.
1384 Toback SL, Ambrose CS, Eaton A, et al. (2013). A postlicensure evaluation of the safety of Ann Arbor strain live attenuated influenza vaccine in children 24-59 months of age. Vaccine.
1385 Tomljenovic L, Shaw CA. (2011). Aluminum Vaccine Adjuvants: Are they Safe?. Current Medicinal Chemistry.
1386 Tomljenovic L, Spinosa JP, Shaw CA. (2013). Human papillomavirus (HPV) vaccines as an option for preventing cervical malignancies: (how) effective and safe?. Current Pharmaceutical Design.
1387 Toneatto D, Ismaili S, Ypma E, et al. (2011). The first use of an investigational multicomponent meningococcal serogroup B vaccine (4CMenB) in humans. Human Vaccines.
1388 Toneatto D, Oster P, deBoer ACW, et al. (2011). Early clinical experience with a candidate meningococcal B recombinant vaccine (rMenB) in healthy adults. Human Vaccines.
1389 Toniolo-Neto J, Weckx LW, Halker E, et al. (1999). Safety of simultaneous pneumococcal and influenza vaccination in elderly patients in Brazil. Drugs & Aging.
1390 Torano G, Toledo ME, Baly A, et al. (2006). Phase I clinical evaluation of a synthetic oligosaccharide-protein conjugate vaccine against Haemophilus influenzae type b in human adult volunteers. Clinical & Vaccine Immunology: CVI.
1391 Torling J, Hedlund J, Konradsen HB, et al. (2003). Revaccination with the 23-valent pneumococcal polysaccharide vaccine in middle-aged and elderly persons previously treated for pneumonia. Vaccine.
1392 Touma Z, Gladman DD, Urowitz MB. (2013). Vaccination and auto-immune rheumatic diseases: lessons learnt from the 2009 H1N1 influenza virus vaccination campaign. Current Opinion in Rheumatology.
1393 Traversa G, Spila-Alegiani S, Bianchi C, et al. (2011). Sudden unexpected deaths and vaccinations during the first two years of life in Italy: A case series study. PLoS ONE.
1394 Treanor J, Nolan C, O'Brien D, et al. (2006). Intranasal administration of a proteosome-influenza vaccine is well-tolerated and induces serum and nasal secretion influenza antibodies in healthy human subjects. Vaccine.
1395 Tregnaghi M, Zambrano B, Santos-Lima E. (2012). Antibody persistence after a primary series of a new DTaP-IPV-Hep B-PRP-T combined vaccine or separate DTaP-IPV//PRP-T and hepatitis B vaccines at 2, 4, and 6 months of age and the effect of a subsequent DTaP-IPV//PRP-T booster vaccination at 18 months of age in healthy Argentinean infants. Pediatric Infectious Disease Journal.
1396 Tregnaghi MW, Stamboulian D, Vanadia PC, et al. (2012). Immunogenicity, Safety, and Tolerability of Two Trivalent Subunit Inactivated Influenza Vaccines: A Phase III, Observer-Blind, Randomized, Controlled Multicenter Study. Viral Immunology.
1397 Tregnaghi MW, Voelker R, Santos-Lima E, et al. (2010). Immunogenicity and safety of a novel yeast Hansenula polymorpha-derived recombinant Hepatitis B candidate vaccine in healthy adolescents and adults aged 10-45 years. Vaccine.
1398 Tregnaghi MW, Zambrano B, Santos-Lima E. (2011). Immunogenicity and safety of an investigational hexavalent diphtheria-tetanus-acellular pertussis-inactivated poliovirus-hepatitis B-haemophilus influenzae B conjugate combined vaccine in healthy 2-, 4-, and 6-month-old argentinean infants. Pediatric Infectious Disease Journal.
1399 Tro-Baumann B, von Spiczak S, Lotte J, et al. (2011). A retrospective study of the relation between vaccination and occurrence of seizures in Dravet syndrome. Epilepsia.
1400 Trofa AF, Klein NP, Paul IM, et al. (2011). Immunogenicity and safety of an inactivated hepatitis A vaccine when coadministered with Diphtheria-tetanus-acellular pertussis and haemophilus influenzae type B vaccines in children 15 months of age. Pediatric Infectious Disease Journal.
1401 Trofa AF, Levin M, Marchant CD, et al. (2008). Immunogenicity and safety of an inactivated hepatitis a vaccine administered concomitantly with a pneumococcal conjugate vaccine in healthy children 15 months of age. Pediatric Infectious Disease Journal.
1402 Trollfors B, Taranger J, Lagergard T, et al. (1995). A placebo-controlled trial of a pertussis-toxoid vaccine. N Engl J Med.
1403 Tsai T, Kyaw MH, Novicki D, et al. (2010). Exposure to MF59-adjuvanted influenza vaccines during pregnancy--a retrospective analysis. Vaccine.
1404 Tseng HF, Smith N, Sy LS, et al. (2011). Evaluation of the incidence of herpes zoster after concomitant administration of zoster vaccine and polysaccharide pneumococcal vaccine. Vaccine.
1405 Tseng HF, Sy LS, Liu IL, et al. (2013). Postlicensure surveillance for pre-specified adverse events following the 13-valent pneumococcal conjugate vaccine in children. Vaccine.
1406 Tudor-Williams G, Frankland J, Isaacs D, et al. (1989). Haemophilus influenzae type b conjugate vaccine trial in Oxford: implications for the United Kingdom. Archives of Disease in Childhood.
1407 Tung J, Carlisle E, Smieja M, et al. (2010). A randomized clinical trial of immunization with combined hepatitis A and B versus hepatitis B alone for hepatitis B seroprotection in hemodialysis patients. American Journal of Kidney Diseases.
1408 Tuttle J, Chen RT, Rantala H, et al. (1997). The risk of Guillain-Barre syndrome after tetanus-toxoid-containing vaccines in adults and children in the United States. Am J Public Health.
1409 Tyring SK, Diaz-Mitoma F, Padget LG, et al. (2007). Safety and tolerability of a high-potency zoster vaccine in adults >/= 50 or years of age. Vaccine.
1410 Upton JE, Hummel DB, Kasprzak A, et al. (2012). No systemic reactions to influenza vaccination in egg-sensitized tertiary-care pediatric patients. Allergy, Asthma, & Clinical Immunology : Official Journal of the Canadian Society of Allergy & Clinical Immunology.
1411 Urschel S, Rieck BD, Birnbaum J, et al. (2011). Impaired cellular immune response to diphtheria and tetanus vaccines in children after thoracic transplantation. Pediatric Transplantation.
1412 Usonis V, Bakasenas V. (1999). Does concomitant injection of a combined diphtheria-tetanus-acellular pertussis - Hepatitis B virus - Inactivated polio virus vaccine influence the reactogenicity and immunogenicity of commercial Haemophilus influenzae type b conjugate vaccines?. European Journal of Pediatrics.
1413 Uygungil B, Bleesing JJ, Risma KA, et al. (2010). Persistent rotavirus vaccine shedding in a new case of severe combined immunodeficiency: A reason to screen. Journal of Allergy and Clinical Immunology.
1414 Vadheim CM, Greenberg DP, Marcy SM, et al. (1990). Safety evaluation of PRP-D Haemophilus influenzae type b conjugate vaccine in children immunized at 18 months of age and older: follow-up study of 30,000 children. Pediatric Infectious Disease Journal.
1415 Vadheim CM, Greenberg DP, Partridge S, et al. (1993). Effectiveness and safety of an Haemophilus influenzae type b conjugate vaccine (PRP-T) in young infants. Kaiser-UCLA Vaccine Study Group. Pediatrics.
1416 Vajo Z, Tamas F, Jankovics I. (2012). A reduced-dose seasonal trivalent influenza vaccine is safe and immunogenic in adult and elderly patients in a randomized controlled trial. Clinical & Vaccine Immunology: CVI.
1417 Vajo Z, Tamas F, Sinka L, et al. (2010). Safety and immunogenicity of a 2009 pandemic influenza A H1N1 vaccine when administered alone or simultaneously with the seasonal influenza vaccine for the 2009-10 influenza season: a multicentre, randomised controlled trial. Lancet.
1418 Valenzuela MTB, Altuzarra RH, Trucco OA, et al. (2007). Immunogenicity of a 23-valent pneumococcal polysaccharide vaccine in elderly residents of a long-term care facility. Brazilian Journal of Infectious Diseases.
1419 Van Buynder PG, Frosst G, Van Buynder JL, et al. (2013). Increased reactions to pediatric influenza vaccination following concomitant pneumococcal vaccination. Influenza & Other Respiratory Viruses.
1420 Van Damme P, Leroux-Roels G, Crasta P, et al. (2012). Antibody persistence and immune memory in adults, 15 years after a three-dose schedule of a combined hepatitis A and B vaccine. Journal of Medical Virology.
1421 Van Damme P, Moiseeva A, Marichev I, et al. (2010). Five years follow-up following two or three doses of a hepatitis B vaccine in adolescents aged 11-15 years: a randomised controlled study. BMC Infectious Diseases.
1422 Van De Geijn EJ, Tukkie R, Van Philips LAM, et al. (1994). Bilateral optic neuritis with branch retinal artery occlusion associated with vaccination. Documenta Ophthalmologica.
1423 Van Der Velden AMT, Van Velzen-Blad H, Claessen AME, et al. (2007). The effect of ranitidine on antibody responses to polysaccharide vaccines in patients with B-cell chronic lymphocytic leukaemia. European Journal of Haematology.
1424 Van Der Vliet D, Pepin S, Lambert M, et al. (2010). Similar immunogenicity and safety of the A/H1N1 2009 pandemic influenza strain when used as a monovalent or a trivalent vaccine. Human Vaccines.
1425 Van der Wielen M, Van Damme P. (2008). Pentavalent human-bovine (WC3) reassortant rotavirus vaccine in special populations: a review of data from the Rotavirus Efficacy and Safety Trial. European Journal of Clinical Microbiology & Infectious Diseases.
1426 Van Heerbeek N, Straetemans M, Wiertsema SP, et al. (2006). Effect of combined pneumococcal conjugate and polysaccharide vaccination on recurrent otitis media with effusion. Pediatrics.
1427 Vanderkooi OG, Scheifele DW, Girgenti D, et al. (2012). Safety and immunogenicity of a 13-valent pneumococcal conjugate vaccine in healthy infants and toddlers given with routine pediatric vaccinations in Canada. Pediatric Infectious Disease Journal.
1428 Vanderkooi OG, Scheifele DW, Girgenti D, et al. (2012). Safety and immunogenicity of a 13-valent pneumococcal conjugate vaccine in healthy infants and toddlers given with routine pediatric vaccinations in Canada. Pediatric Infectious Disease Journal.
1429 Velickovic Z, Jankovic D, Perovic M, et al. (2010). Problems in surveillance on safe immunization conducting in everyday practice. Medicinski Arhiv.
1430 Venuta A. (2012). Acute arthritis associated with rotavirus gastroenteritis: An unusual extraintestinal manifestation of a common enteric pathogen. Journal of Clinical Rheumatology.
1431 Verbeek NE, van der Maas NA, Jansen FE, et al. (2013). Prevalence of SCN1A-Related Dravet Syndrome among Children Reported with Seizures following Vaccination: A Population-Based Ten-Year Cohort Study. PLoS ONE.
1432 Verdijk P, Rots NY, Bakker WAM. (2011). Clinical development of a novel inactivated poliomyelitis vaccine based on attenuated Sabin poliovirus strains. Expert Review of Vaccines.
1433 Verity CM, Stellitano LS, Winstone AM. (2011). The PIND study found no association between vaccination and autism in mitochondrial disease - correction. Developmental Medicine and Child Neurology.
1434 Vermeer-De Bondt PE, Van Der Maas NAT. (2008). The effect of age and dose number on the risk of collapse (hypotonic-hyporesponsive episode) after pertussis vaccination. Pediatric Infectious Disease Journal.
1435 Vernacchio L, Bernstein H, Pelton S, et al. (2002). Effect of monophosphoryl lipid A (MPL(registered trademark)) on T-helper cells when administered as an adjuvant with pneumocococcal-CRM(197) conjugate vaccine in healthy toddlers. Vaccine.
1436 Vernacchio L, Neufeld EJ, MacDonald K, et al. (1998). Combined schedule of 7-valent pneumococcal conjugate vaccine followed by 23-valent pneumococcal vaccine in children and young adults with sickle cell disease. Journal of Pediatrics.
1437 Verstraeten T, Davis RL, DeStefano F, et al. (2003). Safety of Thimerosal-Containing Vaccines: A Two-Phased Study of Computerized Health Maintenance Organization Databases. Pediatrics.
1438 Vesikari T. (2008). Rotavirus vaccines. Scandinavian Journal of Infectious Diseases.
1439 Vesikari T, Becker T, Gajdos V, et al. (2012). Immunogenicity and safety of a two-dose regimen of a combined measles, mumps, rubella and varicella live vaccine (ProQuad((registered trademark))) in infants from 9 months of age. Vaccine.
1440 Vesikari T, Block SL, Guerra F, et al. (2012). Immunogenicity, safety and reactogenicity of a mammalian cell-culture-derived influenza vaccine in healthy children and adolescents three to seventeen years of age. Pediatric Infectious Disease Journal.
1441 Vesikari T, Forsten A, Herbinger KH, et al. (2012). Safety and immunogenicity of an MF59([REGISTERED])-adjuvanted A/H5N1 pre-pandemic influenza vaccine in adults and the elderly. Vaccine.
1442 Vesikari T, Joensuu J, Baer M, et al. (1999). Concurrent administration of rhesus rotavirus tetravalent (RRV-TV) vaccine with pentavalent diphtheria-pertussis-tetanus-Haemophilus influenzae b-inactivated polio and hepatitis B vaccines. Acta Paediatrica, International Journal of Paediatrics.
1443 Vesikari T, Karvonen A, Bianco V, et al. (2011). Tetravalent meningococcal serogroups A, C, W-135 and Y conjugate vaccine is well tolerated and immunogenic when co-administered with measles-mumps-rubella-varicella vaccine during the second year of life: An open, randomized controlled trial. Vaccine.
1444 Vesikari T, Karvonen A, Borrow R, et al. (2011). Results from a randomized clinical trial of coadministration of RotaTeq, a pentavalent rotavirus vaccine, and NeisVac-C, a meningococcal serogroup C conjugate vaccine. Clinical & Vaccine Immunology: CVI.
1445 Vesikari T, Karvonen A, Korhonen T, et al. (2011). Immunogenicity of 10-Valent Pneumococcal Nontypeable Haemophilus Influenzae Protein D Conjugate Vaccine When Administered as Catch-up Vaccination to Children 7 Months to 5 Years of Age. Pediatric Infectious Disease Journal.
1446 Vesikari T, Karvonen A, Lindblad N, et al. (2010). Safety and immunogenicity of a booster dose of the 10-valent pneumococcal nontypeable Haemophilus influenzae protein D conjugate vaccine coadministered with measles-mumps-rubella-varicella vaccine in children aged 12 to 16 months. Pediatric Infectious Disease Journal.
1447 Vesikari T, Karvonen A, Prymula R, et al. (2010). Immunogenicity and safety of the human rotavirus vaccine Rotarix co-administered with routine infant vaccines following the vaccination schedules in Europe. Vaccine.
1448 Vesikari T, Knuf M, Wutzler P, et al. (2011). Oil-in-water emulsion adjuvant with influenza vaccine in young children. New England Journal of Medicine.
1449 Vesikari T, Martin JC, Liss CL, et al. (2011). Safety and Immunogenicity of a Modified Process Hepatitis B Vaccine in Healthy Infants. Pediatric Infectious Disease Journal.
1450 Vidal P, Reyna J, Saldana P, et al. (2011). Events temporarily associated with anti-influenza A (H1N1) vaccination in Mexico. Archives of Medical Research.
1451 Vigano A, Giacomet V, Pariani E, et al. (2011). Long-term immunogenicity after one and two doses of a monovalent MF59-adjuvanted A/H1N1 Influenza virus vaccine coadministered with the seasonal 2009-2010 nonadjuvanted Influenza virus vaccine in HIV-infected children, adolescents, and young adults in a randomized controlled trial. Clinical & Vaccine Immunology: CVI.
1452 Vilella A, Dal-Re R, Simo D, et al. (2005). Reactogenicity profile of a combined hepatitis A and B vaccine in clinical practice: A naturalistic study in adult travellers. Vaccine.
1453 Voelker R. (2012). Study finds Tdap vaccine is safe for older adults. JAMA.
1454 von Kries R. (2006). Comment on B. Zinka et al., Unexplained cases of sudden infant death shortly after hexavalent vaccination. Vaccine.
1455 Von Spiczak S, Helbig I, Drechsel-Baeuerle U, et al. (2011). A retrospective population-based study on seizures related to childhood vaccination. Epilepsia.
1456 Waddington CS, Andrews N, Hoschler K, et al. (2010). Open-label, randomised, parallelgroup, multicentre study to evaluate the safety, tolerability and immunogenicity of an AS03(B)/oil-inwater emulsion-adjuvanted (AS03(B)) split-virion versus non-adjuvanted whole-virion H1N1 influenza vaccine in UK children 6 months to 12 years of age. Health Technology Assessment.
1457 Waddington CS, Walker WT, Oeser C, et al. (2010). Safety and immunogenicity of AS03B adjuvanted split virion versus non-adjuvanted whole virion H1N1 influenza vaccine in UK children aged 6 months-12 years: open label, randomised, parallel group, multicentre study. BMJ.
1458 Wade AG, Crawford GM, Pumford N, et al. (2011). Patient reported outcome data following influenza A (H1N1p) vaccination in the 2009-2010 season: web-based and telephone evaluation. Therapeutics & Clinical Risk Management.
1459 Waggie Z, Geldenhuys H, Sutter RW, et al. (2012). Randomized trial of type 1 and type 3 oral monovalent poliovirus vaccines in newborns in Africa. Journal of Infectious Diseases.
1460 Waggie Z, Geldenhuys H, Sutter RW, et al. (2012). Randomized trial of type 1 and type 3 oral monovalent poliovirus vaccines in newborns in Africa. Journal of Infectious Diseases.
1461 Waites KB, Canupp KC, Chen YY, et al. (2008). Revaccination of adults with spinal cord injury using the 23-valent pneumococcal polysaccharide vaccine. Journal of Spinal Cord Medicine.
1462 Walker FJ, Singleton RJ, Bulkow LR, et al. (2005). Reactions after 3 or more doses of pneumococcal polysaccharide vaccine in adults in Alaska. Clinical Infectious Diseases.
1463 Walker RI. (2005). New vaccines against enteric bacteria for children in less developed countries. Expert Review of Vaccines.
1464 Walker WT, de Whalley P, Andrews N, et al. (2012). H1N1 antibody persistence 1 year after immunization with an adjuvanted or whole-virion pandemic vaccine and immunogenicity and reactogenicity of subsequent seasonal influenza vaccine: a multicenter follow-on study. Clinical Infectious Diseases.
1465 Walter EB, Moggio MV, Drucker RP, et al. (1990). Immunogenicity of Haemophilus b conjugate vaccine (meningococcal protein conjugate) in children with prior invasive Haemophilus influenzae type b disease. Pediatric Infectious Disease Journal.
1466 Walters JAE, Smith S, Poole P, et al. (2010). Injectable vaccines for preventing pneumococcal infection in patients with chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews.
1467 Wang IJ, Huang LM, Guo YL, et al. (2012). Haemophilus influenzae type b combination vaccines and atopic disorders: A prospective cohort study. Journal of the Formosan Medical Association.
1468 Ward RL, Bernstein DI. (2009). Rotarix: a rotavirus vaccine for the world. Clinical Infectious Diseases.
1469 Watemberg N, Dagan R, Arbelli Y, et al. (1991). Safety and immunogenicity of Haemophilus type b-tetanus protein conjugate vaccine, mixed in the same syringe with diphtheria-tetanus-pertussis vaccine in young infants. Pediatric Infectious Disease Journal.
1470 Waters O, Ahmad T. (2011). Opportunistic infections and vaccinations in IBD patients. Journal of Crohn's and Colitis.
1471 Watson L, Wilson BJ, Waugh N. (2002). Pneumococcal polysaccharide vaccine: a systematic review of clinical effectiveness in adults. Vaccine.
1472 Weckx LY, Thompson A, Berezin EN, et al. (2012). A phase 3, randomized, double-blind trial comparing the safety and immunogenicity of the 7-valent and 13-valent pneumococcal conjugate vaccines, given with routine pediatric vaccinations, in healthy infants in Brazil. Vaccine.
1473 Wei SH, Chao YN, Huang SE, et al. (2011). Adverse effects of tetanus toxoid, reduced diphtheria toxoid, and acellular pertussis vaccine in 6- to 7-year-old children. Pediatrics & Neonatology.
1474 Weinberg A, Allshouse AA, MaWhinney S, et al. (2012). Responses to Hepatitis A Virus Vaccine in HIV-Infected Women: Effect of Hormonal Contraceptives and HIV Disease Characteristics. Jaids-Journal of Acquired Immune Deficiency Syndromes.
1475 Werther RL, Crawford NW, Boniface K, et al. (2009). Rotavirus vaccine induced diarrhea in a child with severe combined immune deficiency. Journal of Allergy and Clinical Immunology.
1476 West DJ, Hesley TM, Jonas LC, et al. (1997). Safety and immunogenicity of a bivalent Haemophilus influenzae type b/hepatitis B vaccine in healthy infants. Hib-HB Vaccine Study Group. Pediatric Infectious Disease Journal.
1477 West DJ, Hesley TM, Jonas LC, et al. (1997). Safety and immunogenicity of a bivalent haemophilus influenzae type b/hepatitis B vaccine in healthy infants. Pediatric Infectious Disease Journal.
1478 Weston WM, Friedland LR, Wu X, et al. (2011). Immunogenicity and reactogenicity of co-administered tetanus-diphtheria-acellular pertussis (Tdap) and tetravalent meningococcal conjugate (MCV4) vaccines compared to their separate administration. Vaccine.
1479 Weston WM, Friedland LR, Wu X, et al. (2012). Vaccination of adults 65 years of age and older with tetanus toxoid, reduced diphtheria toxoid and acellular pertussis vaccine (Boostrix()): results of two randomized trials. Vaccine.
1480 Weston WM, Friedland LR, Wu XF, et al. (2012). Vaccination of adults 65 years of age and older with tetanus toxoid, reduced diphtheria toxoid and acellular pertussis vaccine (Boostrix (R)): Results of two randomized trials. Vaccine.
1481 Weston WM, Klein NP. (2008). Kinrix: a new combination DTaP-IPV vaccine for children aged 4-6 years. Expert Review of Vaccines.
1482 Whelan J, Hahne S, Berbers G, et al. (2012). Immunogenicity of a hexavalent vaccine co-administered with 7-valent pneumococcal conjugate vaccine: Findings from the national immunization program in the Netherlands. Human Vaccines and Immunotherapeutics.
1483 White CJ, Stinson D, Stachle B, et al. (1997). Measles, mumps, rubella, and varicella combination vaccine: Safety and immunogenicity alone and in combination with other vaccines given to children. Clinical Infectious Diseases.
1484 White CJ, Stinson D, Staehle B, et al. (1997). Measles, mumps, rubella, and varicella combination vaccine: safety and immunogenicity alone and in combination with other vaccines given to children. Measles, Mumps, Rubella, Varicella Vaccine Study Group. Clinical Infectious Diseases.
1485 White SJ, Boldt KL, Holditch SJ, et al. (2012). Measles, mumps, and rubella. Clinical Obstetrics and Gynecology.
1486 Whitney CG. (2002). The potential of pneumococcal conjugate vaccines for children. Pediatric Infectious Disease Journal.
1487 Whitney CG. (2005). New safety information for an old vaccine. Clinical Infectious Diseases.
1488 Wilhelm DJ, Paegle RD. (1967). Thrombocytopenic purpura and pneumonia following measles vaccination. American Journal of Diseases of Children.
1489 Wilkin T, Lee JY, Lensing SY, et al. (2010). Safety and Immunogenicity of the Quadrivalent Human Papillomavirus Vaccine in HIV-1-Infected Men. Journal of Infectious Diseases.
1490 Williams DJ, Hall M, Brogan TV, et al. (2011). Influenza Coinfection and Outcomes in Children With Complicated Pneumonia. Archives of Pediatrics & Adolescent Medicine.
1491 Williams SE, Klein NP, Halsey N, et al. (2011). Overview of the Clinical Consult Case Review of adverse events following immunization: Clinical Immunization Safety Assessment (CISA) network 2004-2009. Vaccine.
1492 Williams SE, Pahud BA, Vellozzi C, et al. (2011). Causality assessment of serious neurologic adverse events following 2009 H1N1 vaccination. Vaccine.
1493 Williamson R. (2003). The balance between privacy, safety and community health. Journal of Paediatrics & Child Health.
1494 Wilson K, Hawken S. (2012). Incidence of adverse events in premature children following 2-mo vaccination. Human Vaccines and Immunotherapeutics.
1495 Wilson K, Hawken S, Potter BK, et al. (2011). Patterns of emergency room visits, admissions and death following recommended pediatric vaccinations-A population based study of 969,519 vaccination events. Vaccine.
1496 Win KM, Aye M, Htay-Htay H, et al. (1997). Comparison of separate and mixed administration of DTPw-HBV and Hib vaccines: Immunogenicity and reactogenicity profiles. International Journal of Infectious Diseases.
1497 Wise RP, Salive ME, Braun MM, et al. (2000). Postlicensure safety surveillance for varicella vaccine. JAMA.
1498 Wiwanitkit V. (2010). Adverse effect in diabetic patients who get swine flu vaccination: Implication for vaccine safety. Diabetologia Croatica.
1499 Wong SH, Lennon DR, Jackson CM, et al. (2009). Immunogenicity and tolerability in infants of a New Zealand epidemic strain meningococcal B outer membrane vesicle vaccine. Pediatric Infectious Disease Journal.
1500 Wong-Chew RM, Garcia-Leon ML, Espinosa-Torres Torrija B, et al. (2011). Increasing the time of exposure to aerosol measles vaccine elicits an immune response equivalent to that seen in 9-month-old Mexican children given the same dose subcutaneously. Journal of Infectious Diseases.
1501 Woo EJ, Ball R, Bostrom A, et al. (2004). Vaccine risk perception among reporters of autism after vaccination: Vaccine adverse event reporting system 1990-2001. American Journal of Public Health.
1502 Woo EJ, Miller NB, Ball R. (2006). Adverse events after hepatitis A B combination vaccine. Vaccine.
1503 Woo EJ, Wise RP, Menschik D, et al. (2011). Thrombocytopenia after vaccination: Case reports to the US Vaccine Adverse Event Reporting System, 1990-2008. Vaccine.
1504 Wood N, McIntyre P, Wong M. (2006). Vaccination for the paediatrician. Journal of Paediatrics & Child Health.
1505 Wood RA, Berger M, Dreskin SC, et al. (2008). An algorithm for treatment of patients with hypersensitivity reactions after vaccines. Pediatrics.
1506 Wu J, Xu F, Lu L, et al. (2010). Safety and effectiveness of a 2009 H1N1 vaccine in Beijing. New England Journal of Medicine.
1507 Wu J, Zhong X, Li CKF, et al. (2011). Optimal vaccination strategies for 2009 pandemic H1N1 and seasonal influenza vaccines in humans. Vaccine.
1508 Wuorimaa T, Dagan R, Eskola J, et al. (2001). Tolerability and immunogenicity of an eleven-valent pneumococcal conjugate vaccine in healthy toddlers. Pediatric Infectious Disease Journal.
1509 Wuorimaa T, Kayhty H, Leroy O, et al. (2001). Tolerability and immunogenicity of an 11-valent pneumococcal conjugate vaccine in adults. Vaccine.
1510 Wysocki J, Tansey S, Brachet E, et al. (2010). Randomised, controlled trial of concomitant pneumococcal and meningococcal conjugate vaccines. Vaccine.
1511 Xu S, Zhang L, Nelson JC, et al. (2011). Identifying optimal risk windows for self-controlled case series studies of vaccine safety. Statistics in Medicine.
1512 Yacoub H, Khan H, Islam S, et al. (2010). Guillain-Barre Syndrome after Influenza Vaccination in the United States. A Report from the CDC/FDA Vaccine Adverse Event Reporting System. (1990-2009). Neurology.
1513 Yanagisawa N, Maeda K, Ajisawa A, et al. (2011). Reduced immune response to influenza A (H1N1) 2009 monovalent vaccine in HIV-infected Japanese subjects. Vaccine.
1514 Yeager DP, Toy EC, Baker B. (1999). Influenza vaccination in pregnancy. Am J Perinatol.
1515 Yee SS, Dutta PR, Solin LJ, et al. (2010). RE: Efficacy and safety of influenza vaccination during chemotherapy treatment. Journal of Supportive Oncology.
1516 Yeh SH, Gurtman A, Hurley DC, et al. (2010). Immunogenicity and safety of 13-Valent pneumococcal conjugate vaccine in infants and toddlers. Pediatrics.
1517 Yeh SH, Ward JI, Partridge S, et al. (2001). Safety and immunogenicity of a pentavalent diphtheria, tetanus, pertussis, hepatitis B and polio combination vaccine in infants. Pediatric Infectious Disease Journal.
1518 Yeh SJ, Huang LM, Chen JM, et al. (1997). Safety and immunogenicity of a conjugated Haemophilus influenzae type B polysaccharide-Neisseria meningitidis outer membrane protein vaccine. Journal of the Formosan Medical Association.
1519 Yen C, Tate JE, Steiner CA, et al. (2012). Trends in intussusception hospitalizations among US infants before and after implementation of the rotavirus vaccination program, 2000-2009. Journal of Infectious Diseases.
1520 Yogev R, Arditi M, Chadwick EG, et al. (1990). Haemophilus influenzae type b conjugate vaccine (meningococcal protein conjugate): immunogenicity and safety at various doses. Pediatrics.
1521 Yong M, Schoonen WM, Li L, et al. (2010). Epidemiology of paediatric immune thrombocytopenia in the General Practice Research Database. British Journal of Haematology.
1522 Young HA, Geier DA, Geier MR. (2008). Thimerosal exposure in infants and neurodevelopmental disorders: an assessment of computerized medical records in the Vaccine Safety Datalink. Journal of the Neurological Sciences.
1523 Youngster I, Kozer E, Lazarovitch Z, et al. (2011). Probiotics and the immunological response to infant vaccinations: a prospective, placebo controlled pilot study. Archives of Disease in Childhood.
1524 Yousef E, Mannan S. (2008). Systemic reaction to pneumococcal vaccine: how common in pediatrics?. Allergy & Asthma Proceedings.
1525 Yuen SK, Wong ML, Chan YK, et al. (2010). SIADH After Influenza Vaccination. Hong Kong Journal of Nephrology.
1526 Yuksel N, Beyazova U, Balci IF, et al. (2012). Immunogenicity of a Haemophilus influenzae type b-tetanus conjugate vaccine when administered separately or in combined vaccines for primary immunization in two consecutive national schedules in Turkey. International Journal of Infectious Diseases.
1527 Zafrir Y, Agmon-Levin N, Paz Z, et al. (2012). Autoimmunity following Hepatitis B vaccine as part of the spectrum of ‘Autoimmune (Auto-inflammatory) Syndrome induced by Adjuvants’ (ASIA): Analysis of 93 cases. Lupus.
1528 Zaman K, Roy E, Arifeen SE, et al. (2008). Effectiveness of maternal influenza immunization in mothers and infants. New England Journal of Medicine.
1529 Zanardi LR, Haber P, Mootrey GT, et al. (2001). Intussusception among recipients of rotavirus vaccine: reports to the vaccine adverse event reporting system. Pediatrics.
1530 Zanetti A, Parlato A, Romano L, et al. (2012). Challenge with a hepatitis B vaccine in two cohorts of 4-7-year-old children primed with hexavalent vaccines: An open-label, randomised trial in Italy. Vaccine.
1531 Zangwill KM, Eriksen E, Lee M, et al. (2008). A population-based, postlicensure evaluation of the safety of a combination diphtheria, tetanus, acellular pertussis, hepatitis B, and inactivated poliovirus vaccine in a large managed care organization. Pediatrics.
1532 Zangwill KM, Greenberg DP, Chiu CY, et al. (2003). Safety and immunogenicity of a heptavalent pneumococcal conjugate vaccine in infants. Vaccine.
1533 Zangwill KM, Yeh SH, Wong EJ, et al. (2010). Paralytic Syndromes in Children: Epidemiology and Relationship to Vaccination. Pediatric Neurology.
1534 Zastrow A, Schnitzler P, Eckerle I, et al. (2012). Immunogenicity and Safety of H1N1 Vaccination in Anorexia Nervosa-Results from a Pilot Study. International Journal of Eating Disorders.
1535 Zent O, Arras-Reiter C, Broeker M, et al. (2002). Immediate allergic reactions after vaccinations - A post-marketing surveillance review. European Journal of Pediatrics.
1536 Zepp F, Behre U, Kindler K, et al. (2007). Immunogenicity and safety of a tetravalent measles-mumps-rubella-varicella vaccine co-administered with a booster dose of a combined diphtheria-tetanus-acellular pertussis-hepatitis B-inactivated poliovirus-Haemophilus influenzae type b conjugate vaccine in healthy children aged 12-23 months. European Journal of Pediatrics.
1537 Zepp F, Knuf M, Heininger U, et al. (2004). Safety, reactogenicity and immunogenicity of a combined hexavalent tetanus, diphtheria, acellular pertussis, hepatitis B, inactivated poliovirus vaccine and Haemophilus influenzae type b conjugate vaccine, for primary immunization of infants. Vaccine.
1538 Zepp F, Schuind A, Meyer C, et al. (2002). Safety and reactogenicity of a novel DTPa-HBV-IPV combined vaccine given along with commercial Hib vaccines in comparison with separate concomitant administration of DTPa, Hib, and OPV vaccines in infants. Pediatrics.
1539 Zhang ZL, Zhu XJ, Wang X, et al. (2012). Interchangeability and tolerability of two inactivated hepatitis A vaccines in Chinese children. Vaccine.
1540 Zheng H, Chen Y, Wang F, et al. (2011). Comparing live attenuated and inactivated hepatitis A vaccines: an immunogenicity study after one single dose. Vaccine.
1541 Zheteyeva Y, Moro PL, Yue X, et al. (2013). Safety of meningococcal polysaccharide-protein conjugate vaccine in pregnancy: a review of the Vaccine Adverse Event Reporting System. American Journal of Obstetrics & Gynecology.
1542 Zheteyeva YA, Moro PL, Tepper NK, et al. (2012). Adverse event reports after tetanus toxoid, reduced diphtheria toxoid, and acellular pertussis vaccines in pregnant women. American Journal of Obstetrics and Gynecology.
1543 Zhou W, Pool V, DeStefano F, et al. (2004). A potential signal of Bell's palsy after parenteral inactivated influenza vaccines: reports to the Vaccine Adverse Event Reporting System (VAERS)--United States, 1991-2001. Pharmacoepidemiol Drug Saf.
1544 Zickafoose JS, Benneyworth BD, Riebschleger MP, et al. (2012). Hospitalizations for intussusception before and after the reintroduction of rotavirus vaccine in the United States. Archives of Pediatrics & Adolescent Medicine.
1545 Zielen S, Buhring I, Strnad N, et al. (2000). Immunogenicity and tolerance of a 7-valent pneumococcal conjugate vaccine in nonresponders to the 23-valent pneumococcal vaccine. Infection & Immunity.
1546 Zimmerman RK, Middleton DB, Burns IT, et al. (2007). Routine vaccines across the life span, 2007. Journal of Family Practice.
1547 Zinka B, Rauch E, Buettner A, et al. (2006). Unexplained cases of sudden infant death shortly after hexavalent vaccination. Vaccine.
1548 Zollinger WD, Boslego JE, Frasch CE, et al. (1984). Safety of vaccines containing meningococcal group B polysaccharide. Lancet.
1549 Zuccotti GV, Pariani E, Scaramuzza A, et al. (2011). Long-lasting immunogenicity and safety of a 2009 pandemic influenza A(H1N1) MF59-adjuvanted vaccine when co-administered with a 2009-2010 seasonal influenza vaccine in young patients with type 1 diabetes mellitus. Diabetic Medicine.

## Rejected as Included in 2011 IOM Report – 64

1 (2000). Infections and vaccinations as risk factors for childhood type I (insulin-dependent) diabetes mellitus: a multicentre case-control investigation. EURODIAB Substudy 2 Study Group. Diabetologia.
2 (2001). The safety of inactivated influenza vaccine in adults and children with asthma. N Engl J Med.
3 Abu-Shakra M, Zalmanson S, Neumann L, et al. (2000). Influenza virus vaccination of patients with systemic lupus erythematosus: effects on disease activity. J Rheumatol.
4 Ahlgren C, Toren K, Oden A, et al. (2009). A population-based case-control study on viral infections and vaccinations and subsequent multiple sclerosis risk. Eur J Epidemiol.
5 Altobelli E, Petrocelli R, Verrotti A, et al. (2003). Infections and risk of type I diabetes in childhood: a population-based case-control study. Eur J Epidemiol.
6 Andrews N, Stowe J, Miller E, et al. (2007). Post-licensure safety of the meningococcal group C conjugate vaccine. Hum Vaccin.
7 Ashkenazi S, Vertruyen A, Aristegui J, et al. (2006). Superior relative efficacy of live attenuated influenza vaccine compared with inactivated influenza vaccine in young children with recurrent respiratory tract infections. Pediatr Infect Dis J.
8 Barlow WE, Davis RL, Glasser JW, et al. (2001). The risk of seizures after receipt of whole-cell pertussis or measles, mumps, and rubella vaccine. N Engl J Med.
9 Belshe RB, Edwards KM, Vesikari T, et al. (2007). Live attenuated versus inactivated influenza vaccine in infants and young children. N Engl J Med.
10 Belshe RB, Nichol KL, Black SB, et al. (2004). Safety, efficacy, and effectiveness of live, attenuated, cold-adapted influenza vaccine in an indicated population aged 5-49 years. Clin Infect Dis.
11 Bengtsson C, Kapetanovic MC, Kallberg H, et al. (2010). Common vaccinations among adults do not increase the risk of developing rheumatoid arthritis: results from the Swedish EIRA study. Ann Rheum Dis.
12 Benjamin CM, Chew GC, Silman AJ. (1992). Joint and limb symptoms in children after immunisation with measles, mumps, and rubella vaccine. BMJ.
13 Bergen R, Black S, Shinefield H, et al. (2004). Safety of cold-adapted live attenuated influenza vaccine in a large cohort of children and adolescents. Pediatr Infect Dis J.
14 Black S, Shinefield H, Ray P, et al. (1997). Risk of hospitalization because of aseptic meningitis after measles-mumps-rubella vaccination in one- to two-year-old children: an analysis of the Vaccine Safety Datalink (VSD) Project. Pediatr Infect Dis J.
15 Blom L, Nystrom L, Dahlquist G. (1991). The Swedish childhood diabetes study. Vaccinations and infections as risk determinants for diabetes in childhood. Diabetologia.
16 Bueving HJ, Bernsen RM, de Jongste JC, et al. (2004). Does influenza vaccination exacerbate asthma in children?. Vaccine.
17 Burwen DR, Ball R, Bryan WW, et al. (2010). Evaluation of Guillain-Barre Syndrome among recipients of influenza vaccine in 2000 and 2001. Am J Prev Med.
18 Chen RT, Moses JM, Markowitz LE, et al. (1991). Adverse events following measles-mumps-rubella and measles vaccinations in college students. Vaccine.
19 Confavreux C, Suissa S, Saddier P, et al. (2001). Vaccinations and the risk of relapse in multiple sclerosis. Vaccines in Multiple Sclerosis Study Group. N Engl J Med.
20 De Serres G, Skowronski DM, Guay M, et al. (2004). Recurrence risk of oculorespiratory syndrome after influenza vaccination: randomized controlled trial of previously affected persons. Arch Intern Med.
21 Del Porto F, Lagana B, Biselli R, et al. (2006). Influenza vaccine administration in patients with systemic lupus erythematosus and rheumatoid arthritis. Safety and immunogenicity. Vaccine.
22 DeStefano F, Mullooly JP, Okoro CA, et al. (2001). Childhood vaccinations, vaccination timing, and risk of type 1 diabetes mellitus. Pediatrics.
23 DeStefano F, Verstraeten T, Jackson LA, et al. (2003). Vaccinations and risk of central nervous system demyelinating diseases in adults. Arch Neurol.
24 Farrington P, Pugh S, Colville A, et al. (1995). A new method for active surveillance of adverse events from diphtheria/tetanus/pertussis and measles/mumps/rubella vaccines. Lancet.
25 Fleming DM, Crovari P, Wahn U, et al. (2006). Comparison of the efficacy and safety of live attenuated cold-adapted influenza vaccine, trivalent, with trivalent inactivated influenza virus vaccine in children and adolescents with asthma. Pediatr Infect Dis J.
26 France EK, Glanz JM, Xu S, et al. (2004). Safety of the trivalent inactivated influenza vaccine among children: a population-based study. Arch Pediatr Adolesc Med.
27 Goodman MJ, Nordin JD, Harper P, et al. (2006). The safety of trivalent influenza vaccine among healthy children 6 to 24 months of age. Pediatrics.
28 Greene SK, Kulldorff M, Lewis EM, et al. (2010). Near real-time surveillance for influenza vaccine safety: proof-of-concept in the Vaccine Safety Datalink Project. Am J Epidemiol.
29 Griffin MR, Ray WA, Mortimer EA, et al. (1991). Risk of seizures after measles-mumps-rubella immunization. Pediatrics.
30 Hambidge SJ, Glanz JM, France EK, et al. (2006). Safety of trivalent inactivated influenza vaccine in children 6 to 23 months old. JAMA.
31 Heijstek MW, Pileggi GC, Zonneveld-Huijssoon E, et al. (2007). Safety of measles, mumps and rubella vaccination in juvenile idiopathic arthritis. Ann Rheum Dis.
32 Hernan MA, Jick SS, Olek MJ, et al. (2004). Recombinant hepatitis B vaccine and the risk of multiple sclerosis: a prospective study. Neurology.
33 Hocine MN, Farrington CP, Touze E, et al. (2007). Hepatitis B vaccination and first central nervous system demyelinating events: reanalysis of a case-control study using the self-controlled case series method. Vaccine.
34 Holvast A, Stegeman CA, Benne CA, et al. (2009). Wegener's granulomatosis patients show an adequate antibody response to influenza vaccination. Ann Rheum Dis.
35 Huang WT, Gargiullo PM, Broder KR, et al. (2010). Lack of association between acellular pertussis vaccine and seizures in early childhood. Pediatrics.
36 Hughes RA, Charlton J, Latinovic R, et al. (2006). No association between immunization and Guillain-Barre syndrome in the United Kingdom, 1992 to 2000. Arch Intern Med.
37 Hurwitz ES, Schonberger LB, Nelson DB, et al. (1981). Guillain-Barre syndrome and the 1978-1979 influenza vaccine. N Engl J Med.
38 Hviid A, Stellfeld M, Wohlfahrt J, et al. (2004). Childhood vaccination and type 1 diabetes. N Engl J Med.
39 Juurlink DN, Stukel TA, Kwong J, et al. (2006). Guillain-Barre syndrome after influenza vaccination in adults: a population-based study. Arch Intern Med.
40 Klein NP, Hansen J, Lewis E, et al. (2010). Post-marketing safety evaluation of a tetanus toxoid, reduced diphtheria toxoid and 3-component acellular pertussis vaccine administered to a cohort of adolescents in a United States health maintenance organization. Pediatr Infect Dis J.
41 Kmiecik T, Arnoux S, Kobryn A, et al. (2007). Influenza vaccination in adults with asthma: safety of an inactivated trivalent influenza vaccine. J Asthma.
42 Madsen KM, Hviid A, Vestergaard M, et al. (2002). A population-based study of measles, mumps, and rubella vaccination and autism. N Engl J Med.
43 Makela A, Nuorti JP, Peltola H. (2002). Neurologic disorders after measles-mumps-rubella vaccination. Pediatrics.
44 Miller AE, Morgante LA, Buchwald LY, et al. (1997). A multicenter, randomized, double-blind, placebo-controlled trial of influenza immunization in multiple sclerosis. Neurology.
45 Miller E, Andrews N, Stowe J, et al. (2007). Risks of convulsion and aseptic meningitis following measles-mumps-rubella vaccination in the United Kingdom. Am J Epidemiol.
46 Nicholson KG, Nguyen-Van-Tam JS, Ahmed AH, et al. (1998). Randomised placebo-controlled crossover trial on effect of inactivated influenza vaccine on pulmonary function in asthma. Lancet.
47 Pattison E, Harrison BJ, Griffiths CE, et al. (2008). Environmental risk factors for the development of psoriatic arthritis: results from a case-control study. Ann Rheum Dis.
48 Payne DC, Rose CE, Kerrison J, et al. (2006). Anthrax vaccination and risk of optic neuritis in the United States military, 1998-2003. Arch Neurol.
49 Pedroza A, Huerta JG, Garcia Mde L, et al. (2009). The safety and immunogenicity of influenza vaccine in children with asthma in Mexico. Int J Infect Dis.
50 Peltola H, Heinonen OP. (1986). Frequency of true adverse reactions to measles-mumps-rubella vaccine. A double-blind placebo-controlled trial in twins. Lancet.
51 Piedra PA, Gaglani MJ, Riggs M, et al. (2005). Live attenuated influenza vaccine, trivalent, is safe in healthy children 18 months to 4 years, 5 to 9 years, and 10 to 18 years of age in a community-based, nonrandomized, open-label trial. Pediatrics.
52 Ray P, Hayward J, Michelson D, et al. (2006). Encephalopathy after whole-cell pertussis or measles vaccination: lack of evidence for a causal association in a retrospective case-control study. Pediatr Infect Dis J.
53 Scheifele DW, Duval B, Russell ML, et al. (2003). Ocular and respiratory symptoms attributable to inactivated split influenza vaccine: evidence from a controlled trial involving adults. Clin Infect Dis.
54 Skowronski DM, De Serres G, Scheifele D, et al. (2003). Randomized, double-blind, placebo-controlled trial to assess the rate of recurrence of oculorespiratory syndrome following influenza vaccination among persons previously affected. Clin Infect Dis.
55 Smeeth L, Cook C, Fombonne E, et al. (2004). MMR vaccination and pervasive developmental disorders: a case-control study. Lancet.
56 Stowe J, Andrews N, Wise L, et al. (2006). Bell's palsy and parenteral inactivated influenza vaccine. Hum Vaccin.
57 Stowe J, Andrews N, Wise L, et al. (2009). Investigation of the temporal association of Guillain-Barre syndrome with influenza vaccine and influenzalike illness using the United Kingdom General Practice Research Database. Am J Epidemiol.
58 Tam CC, O'Brien SJ, Petersen I, et al. (2007). Guillain-Barre syndrome and preceding infection with campylobacter, influenza and Epstein-Barr virus in the general practice research database. PLoS One.
59 Tata LJ, West J, Harrison T, et al. (2003). Does influenza vaccination increase consultations, corticosteroid prescriptions, or exacerbations in subjects with asthma or chronic obstructive pulmonary disease?. Thorax.
60 Taylor B, Miller E, Farrington CP, et al. (1999). Autism and measles, mumps, and rubella vaccine: no epidemiological evidence for a causal association. Lancet.
61 Vestergaard M, Hviid A, Madsen KM, et al. (2004). MMR vaccination and febrile seizures: evaluation of susceptible subgroups and long-term prognosis. JAMA.
62 Ward KN, Bryant NJ, Andrews NJ, et al. (2007). Risk of serious neurologic disease after immunization of young children in Britain and Ireland. Pediatrics.
63 Williams GW, Steinberg AD, Reinertsen JL, et al. (1978). Influenza immunization in systemic lupus eruthematosus. A double-blind trial. Ann Intern Med.
64 Yih WK, Nordin JD, Kulldorff M, et al. (2009). An assessment of the safety of adolescent and adult tetanus-diphtheria-acellular pertussis (Tdap) vaccine, using active surveillance for adverse events in the Vaccine Safety Datalink. Vaccine.

## Rejected for IOM Search Identified, Excluded – 85

1 Allsup S, Gosney M, Haycox A, et al. (2003). Cost-benefit evaluation of routine influenza immunisation in people 65-74 years of age. Health Technology Assessment (Winchester, England).
2 Allsup S, Haycox A, Regan M, et al. (2004). Is influenza vaccination cost effective for healthy people between ages 65 and 74 years? A randomised controlled trial. Vaccine.
3 Allsup SJ, Gosney M, Regan M, et al. (2001). Side effects of influenza vaccination in healthy older people: A randomised single-blind placebo-controlled trial. Gerontology.
4 Arnou R, Icardi G, De Decker M, et al. (2009). Intradermal influenza vaccine for older adults: a randomized controlled multicenter phase III study. Vaccine.
5 Ascherio A, Zhang SM, Hernan MA, et al. (2001). Hepatitis B vaccination and the risk of multiple sclerosis. N Engl J Med.
6 Asturias EJ, Dueger EL, Omer SB, et al. (2007). Randomized trial of inactivated and live polio vaccine schedules in Guatemalan infants. Journal of Infectious Diseases.
7 Avendano A, Ferreccio C, Lagos R, et al. (1993). Haemophilus influenzae type b polysaccharide-tetanus protein conjugate vaccine does not depress serologic responses to diphtheria, tetanus or pertussis antigens when coadministered in the same syringe with diphtheria-tetanus-pertussis vaccine at two, four and six months of age. Pediatric Infectious Disease Journal.
8 Belshe RB, Ambrose CS, Yi T. (2008). Safety and efficacy of live attenuated influenza vaccine in children 2-7 years of age. Vaccine.
9 Belshe RB, Gruber WC, Mendelman PM, et al. (2000). Efficacy of vaccination with live attenuated, cold-adapted, trivalent, intranasal influenza virus vaccine against a variant (A/Sydney) not contained in the vaccine. J Pediatr.
10 Belshe RB, Mendelman PM, Treanor J, et al. (1998). The efficacy of live attenuated, cold-adapted, trivalent, intranasal influenzavirus vaccine in children. N Engl J Med.
11 Belshe RB, Newman FK, Wilkins K, et al. (2007). Comparative immunogenicity of trivalent influenza vaccine administered by intradermal or intramuscular route in healthy adults. Vaccine.
12 Benke G, Abramson M, Raven J, et al. (2004). Asthma and vaccination history in a young adult cohort. Australian & New Zealand Journal of Public Health.
13 Bernsen RMD, van der Wouden JC. (2008). Measles, mumps and rubella infections and atopic disorders in MMR-unvaccinated and MMR-vaccinated children. Pediatric Allergy & Immunology.
14 Black C, Kaye JA, Jick H. (2003). MMR vaccine and idiopathic thrombocytopaenic purpura. Br J Clin Pharmacol.
15 Black SB, Shinefield HR, France EK, et al. (2004). Effectiveness of influenza vaccine during pregnancy in preventing hospitalizations and outpatient visits for respiratory illness in pregnant women and their infants. American Journal of Perinatology.
16 Block SL, Nolan T, Sattler C, et al. (2006). Comparison of the immunogenicity and reactogenicity of a prophylactic quadrivalent human papillomavirus (types 6, 11, 16, and 18) L1 virus-like particle vaccine in male and female adolescents and young adult women. Pediatrics.
17 Borcic B, Dobrovsak-Sourek V, Kaic B, et al. (1998). A comparative study of reactogenicity and immunogenicity of an oral and an inactivated polio vaccine. Acta Medica Croatica.
18 Carbone T, McEntire B, Kissin D, et al. (2008). Absence of an increase in cardiorespiratory events after diphtheria-tetanus-acellular pertussis immunization in preterm infants: a randomized, multicenter study. Pediatrics.
19 Chiu SS, Peiris JS, Chan KH, et al. (2007). Immunogenicity and safety of intradermal influenza immunization at a reduced dose in healthy children. Pediatrics.
20 Chuaychoo B, Wongsurakiat P, Nana A, et al. (2010). The immunogenicity of intradermal influenza vaccination in COPD patients. Vaccine.
21 Ciszewski A, Bilinska ZT, Brydak LB, et al. (2008). Influenza vaccination in secondary prevention from coronary ischaemic events in coronary artery disease: FLUCAD study. Eur Heart J.
22 Clements-Mann ML, Dudas R, Hoshino Y, et al. (2001). Safety and immunogenicity of live attenuated quadrivalent human-bovine (UK) reassortant rotavirus vaccine administered with childhood vaccines to infants. Vaccine.
23 De Villiers PJ, Steele AD, Hiemstra LA, et al. (2009). Efficacy and safety of a live attenuated influenza vaccine in adults 60 years of age and older. Vaccine.
24 Deinard AS, Ogburn P. (1981). A/NJ/8/76 influenza vaccination program: effects on maternal health and pregnancy outcome. Am J Obstet Gynecol.
25 DeStefano F, Bhasin TK, Thompson WW, et al. (2004). Age at first measles-mumps-rubella vaccination in children with autism and school-matched control subjects: a population-based study in metropolitan atlanta. Pediatrics.
26 Dockerty JD, Skegg DC, Elwood JM, et al. (1999). Infections, vaccinations, and the risk of childhood leukaemia. Br J Cancer.
27 Faden H, Duffy L. (1992). Effect of concurrent viral infection on systemic and local antibody responses to live attenuated and enhanced-potency inactivated poliovirus vaccines. American Journal of Diseases of Children.
28 Falsey AR, Treanor JJ, Tornieporth N, et al. (2009). Randomized, double-blind controlled phase 3 trial comparing the immunogenicity of high-dose and standard-dose influenza vaccine in adults 65 years of age and older. J Infect Dis.
29 Ferreccio C, Clemens J, Avendano A, et al. (1991). The clinical and immunologic response of Chilean infants to Haemophilus influenzae type b polysaccharide-tetanus protein conjugate vaccine coadministered in the same syringe with diphtheria-tetanus toxoids-pertussis vaccine at two, four and six months of age. Pediatric Infectious Disease Journal.
30 France EK, Glanz J, Xu S, et al. (2008). Risk of immune thrombocytopenic purpura after measles-mumps-rubella immunization in children. Pediatrics.
31 Garland SM, Hernandez-Avila M, Wheeler CM, et al. (2007). Quadrivalent vaccine against human papillomavirus to prevent anogenital diseases. N Engl J Med.
32 Gatchalian S, Palestroque E, De Vleeschauwer I, et al. (2008). The development of a new heptavalent diphtheria-tetanus-whole cell pertussis-hepatitis B-Haemophilus influenzae type b-Neisseria meningitidis serogroups A and C vaccine: a randomized dose-ranging trial of the conjugate vaccine components. International Journal of Infectious Diseases.
33 Giammanco G, Li Volti S, Mauro L, et al. (1991). Immune response to simultaneous administration of a recombinant DNA hepatitis B vaccine and multiple compulsory vaccines in infancy. Vaccine.
34 Gorse GJ, O'Connor TZ, Young SL, et al. (2003). Efficacy trial of live, cold-adapted and inactivated influenza virus vaccines in older adults with chronic obstructive pulmonary disease: A VA cooperative study. Vaccine.
35 Govaert TM, Dinant GJ, Aretz K, et al. (1993). Adverse reactions to influenza vaccine in elderly people: randomised double blind placebo controlled trial. BMJ.
36 Govaert TM, Dinant GJ, Aretz K, et al. (1993). Adverse reactions to influenza vaccine in elderly people: randomised double blind placebo controlled trial. BMJ.
37 Greco D, Salmaso S, Mastrantonio P, et al. (1996). A controlled trial of two acellular vaccines and one whole-cell vaccine against pertussis. Progetto Pertosse Working Group. N Engl J Med.
38 Grimprel E, Scott D, Laudat F, et al. (2008). Safety and Immunogenicity of a 13-valent Pneumococcal Conjugate Vaccine Given with Routine Pediatric Vaccination to Healthy Infants in France. Vaccine.
39 Group FIS. (2007). Quadrivalent vaccine against human papillomavirus to prevent high-grade cervical lesions. N Engl J Med.
40 Group FIS. (2007). Quadrivalent vaccine against human papillomavirus to prevent high-grade cervical lesions - Supplemental Table. N Engl J Med.
41 Haberg SE, Trogstad L, Gunnes N, et al. (2013). Risk of Fetal Death after Pandemic Influenza Virus Infection or Vaccination. N Engl J Med.
42 Harper DM, Franco EL, Wheeler C, et al. (2004). Efficacy of a bivalent L1 virus-like particle vaccine in prevention of infection with human papillomavirus types 16 and 18 in young women: a randomised controlled trial. Lancet.
43 Harper DM, Franco EL, Wheeler CM, et al. (2006). Sustained efficacy up to 4.5 years of a bivalent L1 virus-like particle vaccine against human papillomavirus types 16 and 18: follow-up from a randomised control trial. Lancet.
44 Holland D, Booy R, De Looze F, et al. (2008). Intradermal influenza vaccine administered using a new microinjection system produces superior immunogenicity in elderly adults: a randomized controlled trial. J Infect Dis.
45 Hurwitz EL, Morgenstern H. (2000). Effects of diphtheria-tetanus-pertussis or tetanus vaccination on allergies and allergy-related respiratory symptoms among children and adolescents in the United States. J Manipulative Physiol Ther.
46 Khanlou H, Sanchez S, Babaie M, et al. (2006). The safety and efficacy of dose-sparing intradermal administration of influenza vaccine in human immunodeficiency virus-positive patients. Arch Intern Med.
47 Lasky T, Terracciano GJ, Magder L, et al. (1998). The Guillain-Barre syndrome and the 1992-1993 and 1993-1994 influenza vaccines. N Engl J Med.
48 Leroux-Roels I, Vets E, Freese R, et al. (2008). Seasonal influenza vaccine delivered by intradermal microinjection: A randomised controlled safety and immunogenicity trial in adults. Vaccine.
49 Mallol-Mesnard N, Menegaux F, Auvrignon A, et al. (2007). Vaccination and the risk of childhood acute leukaemia: The ESCALE study (SFCE). International Journal of Epidemiology.
50 Margolis KL, Nichol KL, Poland GA, et al. (1990). Frequency of adverse reactions to influenza vaccine in the elderly. A randomized, placebo-controlled trial. JAMA.
51 McKeever TM, Lewis SA, Smith C, et al. (2004). Vaccination and allergic disease: a birth cohort study. Am J Public Health.
52 Miller C, Miller E, Rowe K, et al. (1989). Surveillance of symptoms following MMR vaccine in children. Practitioner.
53 Miller E, Andrews N, Grant A, et al. (2005). No evidence of an association between MMR vaccine and gait disturbance. Arch Dis Child.
54 Miller E, Waight P, Farrington CP, et al. (2001). Idiopathic thrombocytopenic purpura and MMR vaccine. Arch Dis Child.
55 Monto AS, Ohmit SE, Petrie JG, et al. (2009). Comparative efficacy of inactivated and live attenuated influenza vaccines. N Engl J Med.
56 Moriniere BJ, van Loon FP, Rhodes PH, et al. (1993). Immunogenicity of a supplemental dose of oral versus inactivated poliovirus vaccine. Lancet.
57 Munoz FM, Greisinger AJ, Wehmanen OA, et al. (2005). Safety of influenza vaccination during pregnancy. Am J Obstet Gynecol.
58 Munoz N, Manalastas R, Pitisuttithum P, et al. (2009). Safety, immunogenicity, and efficacy of quadrivalent human papillomavirus (types 6, 11, 16, 18) recombinant vaccine in women aged 24-45 years: a randomised, double-blind trial. Lancet.
59 Murray DL, Imagawa DT, Okada DM, et al. (1979). Antibody response to monovalent A/New Jersey/8/76 influenza vaccine in pregnant women. J Clin Microbiol.
60 Nichol KL, Margolis KL, Lind A, et al. (1996). Side effects associated with influenza vaccination in healthy working adults - A randomized, placebo-controlled trial. Archives of Internal Medicine.
61 Nichol KL, Mendelman PM, Mallon KP, et al. (1999). Effectiveness of live, attenuated intranasal influenza virus vaccine in healthy, working adults: a randomized controlled trial. JAMA.
62 Ohmit SE, Gross J, Victor JC, et al. (2009). Reduced reaction frequencies with repeated inactivated or live-attenuated influenza vaccination. Vaccine.
63 Ohmit SE, Victor JC, Rotthoff JR, et al. (2006). Prevention of antigenically drifted influenza by inactivated and live attenuated vaccines. N Engl J Med.
64 Ohmit SE, Victor JC, Teich ER, et al. (2008). Prevention of symptomatic seasonal influenza in 2005-2006 by inactivated and live attenuated vaccines. J Infect Dis.
65 Paavonen J, Jenkins D, Bosch FX, et al. (2007). Efficacy of a prophylactic adjuvanted bivalent L1 virus-like-particle vaccine against infection with human papillomavirus types 16 and 18 in young women: an interim analysis of a phase III double-blind, randomised controlled trial. Lancet.
66 Paavonen J, Naud P, Salmeron J, et al. (2009). Efficacy of human papillomavirus (HPV)-16/18 AS04-adjuvanted vaccine against cervical infection and precancer caused by oncogenic HPV types (PATRICIA): final analysis of a double-blind, randomised study in young women. Lancet.
67 Patja A, Paunio M, Kinnunen E, et al. (2001). Risk of Guillain-Barre syndrome after measles-mumps-rubella vaccination. J Pediatr.
68 Perez G, Lazcano-Ponce E, Hernandez-Avila M, et al. (2008). Safety, immunogenicity, and efficacy of quadrivalent human papillomavirus (types 6, 11, 16, 18) L1 virus-like-particle vaccine in Latin American women. Int J Cancer.
69 Pichichero M, Casey J, Blatter M, et al. (2005). Comparative trial of the safety and immunogenicity of quadrivalent (A, C, Y, W-135) meningococcal polysaccharide-diphtheria conjugate vaccine versus quadrivalent polysaccharide vaccine in two- to ten-year-old children. Pediatric Infectious Disease Journal.
70 Pichichero ME, Blatter MM, Kennedy WA, et al. (2006). Acellular pertussis vaccine booster combined with diphtheria and tetanus toxoids for adolescents. Pediatrics.
71 Pichichero ME, DeTora LM, Johnson DR. (2006). An adolescent and adult formulation combined tetanus, diphtheria and five-component pertussis vaccine. Expert Review of Vaccines.
72 Reisinger KS, Block SL, Lazcano-Ponce E, et al. (2007). Safety and persistent immunogenicity of a quadrivalent human papillomavirus types 6, 11, 16, 18 L1 virus-like particle vaccine in preadolescents and adolescents: a randomized controlled trial. Pediatr Infect Dis J.
73 Roost HP, Gassner M, Grize L, et al. (2004). Influence of MMR-vaccinations and diseases on atopic sensitization and allergic symptoms in Swiss schoolchildren. Pediatr Allergy Immunol.
74 Rue-Cover A, Iskander J, Lyn SN, et al. (2009). Death and serious illness following influenza vaccination: a multidisciplinary investigation. Pharmacoepidemiology and Drug Safety.
75 Shinefield HR, Black SB, Staehle BO, et al. (1998). Safety, tolerability and immunogenicity of concomitant injections in separate locations of M-M-R II, VARIVAX and TETRAMUNE in healthy children vs. concomitant injections of M-M-R II and TETRAMUNE followed six weeks later by VARIVAX. Pediatric Infectious Disease Journal.
76 Smeeth L, Thomas SL, Hall AJ, et al. (2004). Risk of myocardial infarction and stroke after acute infection or vaccination. New England Journal of Medicine.
77 Spitzer WO. (2003). Measles, mumps, and rubella vaccination and autism. N Engl J Med.
78 Takahashi H, Suzumura S, Shirakizawa F, et al. (2003). An epidemiological study on Japanese autism concerning routine childhood immunization history. Japanese Journal of Infectious Diseases.
79 Tam JS, Capeding MR, Lum LC, et al. (2007). Efficacy and safety of a live attenuated, cold-adapted influenza vaccine, trivalent against culture-confirmed influenza in young children in Asia. Pediatr Infect Dis J.
80 Taylor B, Miller E, Lingam R, et al. (2002). Measles, mumps, and rubella vaccination and bowel problems or developmental regression in children with autism: population study. BMJ.
81 Touze E, Fourrier A, Rue-Fenouche C, et al. (2002). Hepatitis B vaccination and first central nervous system demyelinating event: a case-control study. Neuroepidemiology.
82 Verstraeten T, Descamps D, David MP, et al. (2008). Analysis of adverse events of potential autoimmune aetiology in a large integrated safety database of AS04 adjuvanted vaccines. Vaccine.
83 Villa LL, Costa RL, Petta CA, et al. (2005). Prophylactic quadrivalent human papillomavirus (types 6, 11, 16, and 18) L1 virus-like particle vaccine in young women: a randomised double-blind placebo-controlled multicentre phase II efficacy trial. Lancet Oncol.
84 Wilde JA, McMillan JA, Serwint J, et al. (1999). Effectiveness of influenza vaccine in health care professionals - A randomized trial. Jama-Journal of the American Medical Association.
85 Zhu FC, Wang H, Fang HH, et al. (2009). A novel influenza A (H1N1) vaccine in various age groups. N Engl J Med.

## Rejected for No Relevant Groups (Vaccine and Population) – 33

1 Anderson EL, Belshe RB, Bartram J. (1986). Evaluation of rhesus rotavirus vaccine (MMU 18006) in infants and young children. Journal of Infectious Diseases.
2 Andrews N, Miller E, Grant A, et al. (2004). Thimerosal exposure in infants and developmental disorders: A retrospective cohort study in the United Kingdom does not support a causal association. Pediatrics.
3 Bernstein DI, Smith VE, Sherwood JR, et al. (1998). Safety and immnnogenicity of live, attenuated human rotavirus vaccine 89-12. Vaccine.
4 Black S, Klein NP, Shah J, et al. (2010). Immunogenicity and tolerability of a quadrivalent meningococcal glycoconjugate vaccine in children 2-10 years of age. Vaccine.
5 Chotpitayasunondh T, Panpitpat C, Thisyakorn U, et al. (1997). Safety and immunogenicity of a Haemophilus influenzae type B polysaccharide-tetanus toxoid conjugate vaccine combined with diphtheria, tetanus and pertussis vaccines in Thai infants. Southeast Asian Journal of Tropical Medicine & Public Health.
6 Christy C, Madore HP, Treanor JJ. (1986). Safety and immunogenicity of live attenuated rhesus monkey rotavirus vaccine. Journal of Infectious Diseases.
7 Dagan R, Kassis I, Sarov B, et al. (1992). Safety and immunogenicity of oral tetravalent human-rhesus reassortant rotavirus vaccine in neonates. Pediatric Infectious Disease Journal.
8 French N, Gordon SB, Mwalukomo T, et al. (2010). A trial of a 7-valent pneumococcal conjugate vaccine in HIV-infected adults. New England Journal of Medicine.
9 Goto N, Kawaguchi T, Watarai Y, et al. (2011). A vaccine to prevent herpes zoster in kidney transplantion. American Journal of Transplantation.
10 Hansen TS, Jess T, Vind I, et al. (2011). Environmental factors in inflammatory bowel disease: A case-control study based on a Danish inception cohort. Journal of Crohn's and Colitis.
11 Harjulehto-Mervaala T, Hovi T, Aro T, et al. (1995). Oral poliovirus vaccination and pregnancy complications. Acta Obstetricia et Gynecologica Scandinavica.
12 Joensuu J, Koskenniemi E, Pang XL, et al. (1997). Randomised placebo-controlled trial of rhesus-human reassortant rotavirus vaccine for prevention of severe rotavirus gastroenteritis. Lancet.
13 Joensuu J, Koskenniemi E, Vesikaei T. (1998). Symptoms associated with rhesus-human reassortant rotavirus vaccine in infants. Pediatric Infectious Disease Journal.
14 Khan AA, Zahidie A, Rabbani F. (2013). Interventions to reduce neonatal mortality from neonatal tetanus in low and middle income countries--a systematic review. BMC Public Health.
15 Lanata CF, Midthun K, Black RE, et al. (1996). Safety, immunogenicity, and protective efficacy of one and three doses of the tetravalent rhesus rotavirus vaccine in infants in Lima, Peru. Journal of Infectious Diseases.
16 Lehmann D, Pomat WS, Combs B, et al. (2002). Maternal immunization with pneumococcal polysaccharide vaccine in the highlands of Papua New Guinea. Vaccine.
17 Losonsky GA, Rennels MB, Kapikian AZ. (1986). Safety, infectivity, transmissibility and immunogenicity of rhesus rotavirus vaccine (MMU 18006) in infants. Pediatric Infectious Disease.
18 Mrukowicz JZ, Thompson J, Reed GW, et al. (1999). Epidemiology of rotavirus in infants and protection against symptomatic illness afforded by primary infection and vaccination. Vaccine.
19 Murphy TV, Gargiullo PM, Massoudi MS, et al. (2001). Intussusception among infants given an oral rotavirus vaccine. New England Journal of Medicine.
20 Palmu AA, Jokinen J, Borys D, et al. (2013). Effectiveness of the ten-valent pneumococcal Haemophilus influenzae protein D conjugate vaccine (PHiD-CV10) against invasive pneumococcal disease: a cluster randomised trial. Lancet.
21 Perez-Schael I, Blanco M, Garcia D, et al. (1994). Evaluation of the antigenicity and reactogenicity of varying formulations of the rhesus rotavirus-based quadrivalent and the M37 rotavirus vaccine candidates. Journal of Medical Virology.
22 Perez-Schael I, Guntinas MJ, Perez M, et al. (1997). Efficacy of the rhesus rotavirus-based quadrivalent vaccine in infants and young children in Venezuela. New England Journal of Medicine.
23 Pichichero ME, Losonsky GA. (1993). Asymptomatic Infections Due to Wild-Type Rotavirus May Prime for a Heterotypic Response to Vaccination with Rhesus Rotavirus. Clinical Infectious Diseases.
24 Pichichero ME, Losonsky GA, Rennels MB, et al. (1990). Effect of dose and a comparison of measures of vaccine take for oral rhesus rotavirus vaccine. Pediatric Infectious Disease Journal.
25 Quiambao BP, Nohynek HM, Kayhty H, et al. (2007). Immunogenicity and reactogenicity of 23-valent pneumococcal polysaccharide vaccine among pregnant Filipino women and placental transfer of antibodies. Vaccine.
26 Scott D, Ruckle J, Dar M, et al. (2008). Phase 1 trial of 13-valent pneumococcal conjugate vaccine in Japanese adults. Pediatrics International.
27 Stermole BM, Grandits GA, Roediger MP, et al. (2011). Long-term safety and serologic response to measles, mumps, and rubella vaccination in HIV-1 infected adults. Vaccine.
28 Tseng HF, Sy LS, Qian L, et al. (2013). Safety of a tetanus-diphtheria-acellular pertussis vaccine when used off-label in an elderly population. Clinical Infectious Diseases.
29 Verstraeten T, Baughman AL, Cadwell B, et al. (2001). Enhancing vaccine safety surveillance: a capture-recapture analysis of intussusception after rotavirus vaccination. American Journal of Epidemiology.
30 Vesikari T, Rautanen T, Varis T, et al. (1990). Rhesus Rotavirus candidate vaccine. Clinical trial in children vaccinated between 2 and 5 months of age. American Journal of Diseases of Children.
31 Vesikari T, Varis T, Green K, et al. (1991). Immunogenicity and safety of rhesus-human rotavirus reassortant vaccines with serotype 1 or 2 VP7 specificity. Vaccine.
32 Vodopija I, Baklaic Z, Vlatkovic R. (1986). Combined vaccination with live oral polio vaccine and the bovine rotavirus RIT 4237 strain. Vaccine.
33 Wacholder S, Chen BE, Wilcox A, et al. (2010). Risk of miscarriage with bivalent vaccine against human papillomavirus (HPV) types 16 and 18: Pooled analysis of two randomised controlled trials. Bmj.

## Rejected for Correction to Rejected Study – 8

1 (1996). Safety and efficacy of high-dose rhesus-human reassortant rotavirus vaccines - Report of the National Multicenter Trial. Pediatrics.
2 (2001). Intussusception among infants given an oral rotavirus vaccine. New England Journal of Medicine.
3 Chen J, Heyse JF, Heaton P. (2010). Age dependence of the risk of intussusception following tetravalent rhesus-human reassortant rotavirus tetravalent vaccine: Is it beyond doubt?. American Journal of Epidemiology.
4 Clark HF. (2004). Safety, efficacy, and immunogenicity of a live, quadrivalent human-bovine reassortant rotavirus vaccine in healthy infants (vol 144, pg 184, 2004). Journal of Pediatrics.
5 Liang XF. (2011). Safety of Influenza A (H1N1) Vaccine in Postmarketing Surveillance in China (vol 364, pg 638, 2011). New England Journal of Medicine.
6 Liang XF, Wang HQ, Wang JZ. (2010). Safety and immunogenicity of 2009 pandemic influenza A H1N1 vaccines in China: a multicentre, double-blind, randomised, placebo-controlled trial. (vol 375, pg 56, 2010). Lancet.
7 Livengood JR. (2001). Intussusception among infants given an oral rotavirus vaccine (vol 344, pg 564, 2001). New England Journal of Medicine.
8 Rennels, Fries S, Froehlich H. (1996). Safety and efficacy of high-dose rhesus-human reassortant rotavirus vaccines - Report of the National Multicenter Trial (vol 97, pg 7, 1996). Pediatrics.

## Rejected for Duplicate Publication – 22

1 Ambrose CS, Dubovsky F, Yi T, et al. (2012). The safety and efficacy of live attenuated influenza vaccine in young children with asthma or prior wheezing. European Journal of Clinical Microbiology and Infectious Diseases.
2 Bernsen RMD, Koes BW, de Jongste JC, et al. (2006). Haemophilus influenzae type b vaccination and reported atopic disorders in 8-12-year-old children. Pediatric Pulmonology.
3 Buttery J. (2006). A rotavirus vaccine for infants prevented rotavirus gastroenteritis with no increase in risk of intussusception. Evidence-Based Medicine.
4 Castellsague X, Munoz N, Pitisuttithum P, et al. (2011). End-of-study safety, immunogenicity, and efficacy of quadrivalent HPV (types 6, 11, 16, 18) recombinant vaccine in adult women 24-45 years of age. British Journal of Cancer.
5 Christie CD, Duncan ND. (2012). Rotavirus vaccine trial in Jamaica. West Indian Medical Journal.
6 Dennehy PH, Goveia MG, Dallas MJ, et al. (2007). The integrated phase III safety profile of the pentavalent human-bovine (WC3) reassortant rotavirus vaccine. International Journal of Infectious Diseases.
7 Ebell M. (2006). Oral rotavirus vaccines are safe and effective in children. American Family Physician.
8 Ehrlich HJ, Berezuk G, Fritsch S, et al. (2012). Clinical development of a Vero cell culture-derived seasonal influenza vaccine. Vaccine.
9 Farrington CP, Miller E, Taylor B. (2001). MMR and autism: further evidence against a causal association. Vaccine.
10 Fell DB, Sprague AE, Liu N, et al. (2012). H1N1 influenza vaccination during pregnancy and fetal and neonatal outcomes. American Journal of Public Health.
11 Lin TH, Lin SY, Lin CH, et al. (2012). AdimFlu-S() influenza A (H1N1) vaccine during pregnancy: the Taiwanese Pharmacovigilance Survey. Vaccine.
12 Linhares AC, Velazquez FR, Perez-Schael I, et al. (2008). Efficacy and safety of an oral live attenuated human rotavirus vaccine against rotavirus gastroenteritis during the first 2 years of life in Latin American infants: a randomised, double-blind, placebo-controlled phase III study. Lancet.
13 Miller EK, Dumitrescu L, Cupp C, et al. (2011). Atopy history and the genomics of wheezing after influenza vaccination in children 6-59 months of age. Vaccine.
14 Oxman MN, Levin MJ, Johnson GR, et al. (2005). A vaccine to prevent herpes zoster and postherpetic neuralgia in older adults. N Engl J Med.
15 Palefsky JM, Giuliano AR, Goldstone S, et al. (2011). HPV vaccine against anal HPV infection and anal intraepithelial neoplasia. New England Journal of Medicine.
16 Patel J. (2012). Study finds H1N1 vaccine safe for pregnant women. Expert Review of Vaccines.
17 Silfverdal SA, Nilsson L, Blennow M, et al. (2010). Vaccination of children-summary and conclusions from a systematic review. Acta Paediatrica, International Journal of Paediatrics.
18 Vermeulen JN, Lange JM, Tyring SK, et al. (2012). Safety, tolerability, and immunogenicity after 1 and 2 doses of zoster vaccine in healthy adults >=60 years of age. Vaccine.
19 Vermeulen JN, Lange JMA, Tyring SK, et al. (2012). Safety, tolerability, and immunogenicity after 1 and 2 doses of zoster vaccine in healthy adults (greater-than or equal to)60 years of age. Vaccine.
20 Vesikari T, Itzler R, Karvonen A, et al. (2009). RotaTeq, a pentavalent rotavirus vaccine: efficacy and safety among infants in Europe. Vaccine.
21 Vesikari T, Karvonen A, Puustinen L, et al. (2006). A short report on highlights of world-wide development of RIX4414: An European experience. Vaccine.
22 Virtanen M, Peltola H, Paunio M, et al. (2000). Day-to-day reactogenicity and the healthy vaccinee effect of measles-mumps-rubella vaccination. Pediatrics.

## Rejected, Not About Vaccine – 15

1 Almuneef M, Memish Z, Khan Y, et al. (1998). Childhood bacterial meningitis in Saudi Arabia. Journal of Infection.
2 Bahl R, Saxena M, Bhandari N, et al. (2009). Population-based incidence of intussusception and a case-control study to examine the association of intussusception with natural rotavirus infection among Indian children. Journal of Infectious Diseases.
3 Boulagnon C, Leveque N, Renois F, et al. (2012). Influenza A/H1N1 (2009) infection as a cause of unexpected out-of-hospital death in the young. Journal of Forensic Sciences.
4 Chen E, Grimwood K, Beasley S. (2004). Operative rates for acute intussusception in New Zealand [2]. New Zealand Medical Journal.
5 Dennehy PH. (2000). Transmission of rotavirus and other enteric pathogens in the home. Pediatric Infectious Disease Journal.
6 Gutierrez J, Issacson RS, Koppel BS. (2010). Subacute sclerosing panencephalitis: an update. Developmental Medicine & Child Neurology.
7 Janjua NZ, Skowronski DM, Hottes TS, et al. (2010). Seasonal influenza vaccine and increased risk of pandemic A/H1N1-related illness: First detection of the association in British Columbia, Canada. Clinical Infectious Diseases.
8 Kale PL, Andreozzi VL, Nobre FF. (2004). Time series analysis of deaths due to Diarrhoea in children in Rio de Janeiro, Brazil, 1980-1998. Journal of Health, Population and Nutrition.
9 Mori M, Kuwabara S, Miyake M, et al. (2000). Haemophilus influenzae infection and Guillain-Barre syndrome. Brain.
10 Neunert C, Lim W, Crowther M, et al. (2011). The American Society of Hematology 2011 evidence-based practice guideline for immune thrombocytopenia. Blood.
11 Nguyen AM, Noymer A. (2013). Influenza mortality in the United States, 2009 pandemic: burden, timing and age distribution. PLoS ONE.
12 Parashar UD, Kilgore PE, Holman RC, et al. (1998). Diarrheal mortality in US infants - Influence of birth weight on risk factors for death. Archives of Pediatrics & Adolescent Medicine.
13 Reyes MP, Fisher MW, Lerner AM. (1974). Pseudomonas endocarditis: hemagglutinating antibodies to Fisher-Devlin-Gnabasik immunotypes in sera. Journal of Laboratory & Clinical Medicine.
14 Takeuchi M, Osamura T, Yasunaga H, et al. (2012). Intussusception among Japanese children: an epidemiologic study using an administrative database. Bmc Pediatrics.
15 van der Werf N, Kroese FGM, Rozing J, et al. (2007). Viral infections as potential triggers of type 1 diabetes. Diabetes-Metabolism Research and Reviews.

## Rejected for Vaccine or Formulation Not Currently Recommended in US – 193

1 Aaby P, Ravn H, Roth A, et al. (2012). Early diphtheria-tetanus-pertussis vaccination associated with higher female mortality and no difference in male mortality in a cohort of low birthweight children: an observational study within a randomised trial. Archives of Disease in Childhood.
2 Aaby P, Roth A, Ravn H, et al. (2011). Randomized Trial of BCG Vaccination at Birth to Low-Birth-Weight Children: Beneficial Nonspecific Effects in the Neonatal Period?. Journal of Infectious Diseases.
3 Aavitsland P, Bjune G, Aasen S, et al. (1991). Adverse events following vaccine or placebo injection in an efficacy trial of an outer membrane vesicle vaccine against group B meningococcal disease in Norwegian secondary schools 1988-1991. NIPH Annals.
4 Alami Chentoufi A, Kritzer E, Yu DM, et al. (2012). Towards a rational design of an asymptomatic clinical herpes vaccine: The old, the new, and the unknown. Clinical and Developmental Immunology.
5 Ali SS, Chandrashekar SR, Singh M, et al. (2007). A multicenter, prospective, open-label, non-comparative study to evaluate the immunogenicity and tolerance of a new, fully liquid pentavalent vaccine (DTwP-HepB-Hib vaccine). Human Vaccines.
6 Aljadhey H, Alyabsi M, Alrwisan A, et al. (2012). The Safety of H1N1 Vaccine in Children in Saudi Arabia: A Cohort Study Using Modern Technology in a Developing Country. Drug Safety.
7 Anderson EL, Bowers T, Mink CM, et al. (1994). Safety and immunogenicity of meningococcal A and C polysaccharide conjugate vaccine in adults. Infection & Immunity.
8 Anderson P, Insel RA, Smith DH, et al. (1981). A polysaccharide-protein complex from Haemophilus influenzae type b. III. Vaccine trial in human adults. Journal of Infectious Diseases.
9 Andrews N, Stowe J, Al-Shahi Salman R, et al. (2011). Guillain-Barre syndrome and H1N1 (2009) pandemic influenza vaccination using an AS03 adjuvanted vaccine in the United Kingdom: self-controlled case series. Vaccine.
10 Araujo EC, Clemens SAC, Oliveira CS, et al. (2007). Safety, immunogenicity, and protective efficacy of two doses of RIX4414 live attenuated human rotavirus vaccine in healthy infants. Jornal de Pediatria.
11 Armstrong PK, Dowse GK, Effler PV, et al. (2011). Epidemiological study of severe febrile reactions in young children in Western Australia caused by a 2010 trivalent inactivated influenza vaccine. BMJ Open.
12 Atmar RL, Keitel WA, Quarles JM, et al. (2011). Evaluation of age-related differences in the immunogenicity of a G9 H9N2 influenza vaccine. Vaccine.
13 Atsmon J, Kate-Ilovitz E, Shaikevich D, et al. (2012). Safety and immunogenicity of multimeric-001--a novel universal influenza vaccine. Journal of Clinical Immunology.
14 Baker CJ, Paoletti LC, Rench MA, et al. (2004). Immune response of healthy women to 2 different group B streptococcal type V capsular polysaccharide-protein conjugate vaccines. Journal of Infectious Diseases.
15 Baker CJ, Paoletti LC, Wessels MR, et al. (1999). Safety and immunogenicity of capsular polysaccharide-tetanus toxoid conjugate vaccines for group B streptococcal types Ia and Ib. Journal of Infectious Diseases.
16 Bardage C, Persson I, Ortqvist A, et al. (2011). Neurological and autoimmune disorders after vaccination against pandemic influenza A (H1N1) with a monovalent adjuvanted vaccine: population based cohort study in Stockholm, Sweden. BMJ.
17 Barnes GL, Lund JS, Adams L, et al. (1997). Phase 1 trial of a candidate rotavirus vaccine (RV3) derived from a human neonate. Journal of Paediatrics & Child Health.
18 Beam TR, Crigler ED, Goldman JK, et al. (1980). Antibody response to polyvalent pneumococcal polysaccharide vaccine in diabetics. JAMA.
19 Behjati M, Ayatollahi J. (2008). Post BCG lymphadenitis in vaccinated infants in Yazd, Iran. Iranian Journal of Pediatrics.
20 Belshe RB, Leone PA, Bernstein DI, et al. (2012). Efficacy results of a trial of a herpes simplex vaccine. New England Journal of Medicine.
21 Beran J, Abdel-Messih IA, Raupachova J, et al. (2010). A phase III, randomized, open-label study to assess the tolerability and immunogenicity of an H5N1 influenza vaccine administered to healthy adults with a 1-, 2-, 3-, or 6-week interval between first and second doses. Clinical Therapeutics.
22 Beran J, Peeters M, Dewe W, et al. (2013). Immunogenicity and safety of quadrivalent versus trivalent inactivated influenza vaccine: a randomized, controlled trial in adults. BMC Infectious Diseases.
23 Berkowitz CD, Ward JI, Chiu CE, et al. (1990). Persistence of antibody and booster responses to reimmunization with Haemophilus influenzae type b polysaccharide and polysaccharide diphtheria toxoid conjugate vaccines in children initially immunized at 15 to 24 months of age. Pediatrics.
24 Bernsen RMD, Nagelkerke NJD, Thijs C, et al. (2008). Reported pertussis infection and risk of atopy in 8- to 12-yr-old vaccinated and non-vaccinated children. Pediatric Allergy & Immunology.
25 Bernstein DI, Sack DA, Rothstein E, et al. (1999). Efficacy of live, attenuated, human rotavirus vaccine 89-12 in infants: a randomised placebo-controlled trial. Lancet.
26 Bernstein DI, Smith VE, Sherwood JR, et al. (1998). Safety and immunogenicity of live, attenuated human rotavirus vaccine 89-12. Vaccine.
27 Beytout J, Launay O, Guiso N, et al. (2009). Safety of Tdap-IPV given one month after Td-IPV booster in healthy young adults: a placebo-controlled trial. Human Vaccines.
28 Bhandari N, Sharma P, Glass RI, et al. (2006). Safety and immunogenicity of two live attenuated human rotavirus vaccine candidates, 116E and I321, in infants: results of a randomised controlled trial. Vaccine.
29 Bischoff AL, Folsgaard NV, Carson CG, et al. (2013). Altered response to A(H1N1)pnd09 vaccination in pregnant women: a single blinded randomized controlled trial. PLoS ONE.
30 Black SB, Shinefield HR, Lampert D, et al. (1991). Safety and immunogenicity of oligosaccharide conjugate Haemophilus influenzae type b (HbOC) vaccine in infancy. The Northern California Kaiser Permanente Vaccine Study Center Pediatrics Group. Pediatric Infectious Disease Journal.
31 Bonvehi P, Boutriau D, Casellas J, et al. (2010). Three doses of an experimental detoxified L3-derived lipooligosaccharide meningococcal vaccine offer good safety but low immunogenicity in healthy young adults. Clinical & Vaccine Immunology: CVI.
32 Borja-Tabora C, Montalban C, Memish ZA, et al. (2013). Immune response, antibody persistence, and safety of a single dose of the quadrivalent meningococcal serogroups A, C, W-135, and Y tetanus toxoid conjugate vaccine in adolescents and adults: results of an open, randomised, controlled study. BMC Infectious Diseases.
33 Bresee JS, El Arifeen S, Azim T, et al. (2001). Safety and immunogenicity of tetravalent rhesus-based rotavirus vaccine in Bangladesh. Pediatric Infectious Disease Journal.
34 Cadranel S, Zeglache S, Jonckheer T, et al. (1987). Factors affecting antibody response of newborns to repeated administrations of the rotavirus vaccine RIT 4237. Journal of Pediatric Gastroenterology & Nutrition.
35 Candela S, Pergolizzi S, Ragni P, et al. (2013). An early (3-6 weeks) active surveillance study to assess the safety of pandemic influenza vaccine Focetria in a province of Emilia-Romagna region, Italy - part one. Vaccine.
36 Cassisi G, Sarzi-Puttini P, Cazzola M. (2011). Chronic widespread pain and fibromyalgia: Could there be some relationship with infections and vaccinations?. Clinical and Experimental Rheumatology.
37 Castellanos M, Cinza Z, Dorta Z, et al. (2010). Immunization with a DNA vaccine candidate in chronic hepatitis C patients is safe, well tolerated and does not impair immune response induction after anti-hepatitis B vaccination. Journal of Gene Medicine.
38 Castillo-Solorzano C, Reef SE, Morice A, et al. (2011). Rubella vaccination of unknowingly pregnant women during mass campaigns for rubella and congenital rubella syndrome elimination, the Americas 2001-2008. Journal of Infectious Diseases.
39 Chang EJ, Zangwill KM, Lee H, et al. (2002). Lack of association between rotavirus infection and intussusception: implications for use of attenuated rotavirus vaccines. Pediatric Infectious Disease Journal.
40 Cherif H, Hoglund M, Pauksens K. (2013). Adjuvanted influenza a (H1N1) 2009 vaccine in patients with hematological diseases: good safety and immunogenicity even in chemotherapy-treated patients. European Journal of Haematology.
41 Choo S, Seymour L, Morris R, et al. (2000). Immunogenicity and reactogenicity of a pneumococcal conjugate vaccine administered combined with a haemophilus influenzae type B conjugate vaccine in United Kingdom infants. Pediatric Infectious Disease Journal.
42 Claesson MH. (2011). Immunological Links to Nonspecific Effects of DTwP and BCG Vaccines on Infant Mortality. Journal of Tropical Medicine.
43 Clark HF, Bernstein DI, Dennehy PH, et al. (2004). Safety, efficacy, and immunogenicity of a live, quadrivalent human-bovine reassortant rotavirus vaccine in healthy infants. Journal of Pediatrics.
44 Clark HF, Borian FE, Plotkin SA. (1990). Immune protection of infants against rotavirus gastroenteritis by a serotype 1 reassortant of bovine rotavirus WC3. Journal of Infectious Diseases.
45 Clark HF, Burke CJ, Volkin DB, et al. (2003). Safety, immunogenicity and efficacy in healthy infants of G1 and G2 human reassortant rotavirus vaccine in a new stabilizer/buffer liquid formulation. Pediatric Infectious Disease Journal.
46 Classen JB, Classen DC. (2002). Clustering of cases of insulin dependent diabetes (IDDM) occurring three years after hemophilus influenza B (HiB) immunization support causal relationship between immunization and IDDM. Autoimmunity.
47 Cox RJ, Pedersen G, Madhun AS, et al. (2011). Evaluation of a virosomal H5N1 vaccine formulated with Matrix MTM adjuvant in a phase I clinical trial. Vaccine.
48 Cutts FT, Zaman SMA, Enwere G, et al. (2005). Efficacy of nine-valent pneumococcal conjugate vaccine against pneumonia and invasive pneumococcal disease in The Gambia: randomised, double-blind, placebo-controlled trial. Lancet.
49 Da Silva ESGR, Camacho LAB, Stavola MS, et al. (2011). Pregnancy outcomes following rubella vaccination: A prospective study in the State of Rio de Janeiro, Brazil, 2001-2002. Journal of Infectious Diseases.
50 Dagan R, Melamed R, Zamir O, et al. (1997). Safety and immunogenicity of tetravalent pneumococcal vaccines containing 6B, 14, 19F and 23F polysaccharides conjugated to either tetanus toxoid or diphtheria toxoid in young infants and their boosterability by native polysaccharide antigens. Pediatric Infectious Disease Journal.
51 Dang DA, Nguyen VT, Vu DT, et al. (2012). A dose-escalation safety and immunogenicity study of a new live attenuated human rotavirus vaccine (Rotavin-M1) in Vietnamese children. Vaccine.
52 Davis RL, Kolczak M, Lewis E, et al. (2005). Active surveillance of vaccine safety: a system to detect early signs of adverse events. Epidemiology.
53 de Oliveira LH, Struchiner CJ. (2000). Vaccine-associated paralytic poliomyelitis: a retrospective cohort study of acute flaccid paralyses in Brazil. International Journal of Epidemiology.
54 de Vos van Steenwijk PJ, Ramwadhdoebe TH, Lowik MJ, et al. (2012). A placebo-controlled randomized HPV16 synthetic long-peptide vaccination study in women with high-grade cervical squamous intraepithelial lesions. Cancer Immunology, Immunotherapy.
55 De Wals P, Deceuninck G, Toth E, et al. (2012). Risk of Guillain-Barre syndrome following H1N1 influenza vaccination in Quebec. JAMA.
56 Dennehy PH. (2006). A short report on the highlights of world-wide development of RIX4414: a North American experience. Comparative evaluation of safety and immunogenicity of two dosages of an oral live attenuated human rotavirus vaccine (RIX4414) in infants in the United States and Canada. Vaccine.
57 Dennehy PH, Rodgers GC, Ward RL, et al. (1996). Comparative evaluation of reactogenicity and immunogenicity of two dosages of oral tetravalent rhesus rotavirus vaccine. US Rhesus Rotavirus Vaccine Study Group. Pediatric Infectious Disease Journal.
58 Diaz-Ortega JL, Bennett JV, Castaneda D, et al. (2012). Aerosolized MMR vaccine: Evaluating potential transmission of components to vaccine administrators and contacts of vaccines. Biologicals.
59 Dieleman J, Romio S, Johansen K, et al. (2011). Guillain-Barre syndrome and adjuvanted pandemic influenza A (H1N1) 2009 vaccine: multinational case-control study in Europe. BMJ.
60 Diez-Domingo J, Garces-Sanchez M, Baldo JM, et al. (2010). Immunogenicity and Safety of H5N1 A/Vietnam/1194/2004 (Clade 1) AS03-adjuvanted prepandemic candidate influenza vaccines in children aged 3 to 9 years: a phase ii, randomized, open, controlled study. Pediatric Infectious Disease Journal.
61 Dikow R, Eckerle I, Ksoll-Rudek D, et al. (2011). Immunogenicity and efficacy in hemodialysis patients of an AS03(A)-adjuvanted vaccine for 2009 pandemic influenza A(H1N1): a nonrandomized trial. American Journal of Kidney Diseases.
62 Dos Santos BA, Ranieri TS, Bercini M, et al. (2002). An evaluation of the adverse reaction potential of three measles-mumps-rubella combination vaccines. Rev Panam Salud Publica.
63 Durrieu G, Palmaro A, Pourcel L, et al. (2012). First French experience of ADR reporting by patients after a mass immunization campaign with Influenza A (H1N1) pandemic vaccines: a comparison of reports submitted by patients and healthcare professionals. Drug Safety.
64 Eick A, Croll J, Weatherholtz R, et al. (2004). Safety and immunogenicity of two octavalent pneumococcal conjugate vaccines in American Indian infants. Vaccine.
65 el-Sayed N, el-Gamal Y, Abbassy AA, et al. (2008). Monovalent type 1 oral poliovirus vaccine in newborns. New England Journal of Medicine.
66 Eskola J, Kayhty H, Gordon LK, et al. (1988). Simultaneous administration of Haemophilus influenzae type b capsular polysaccharide-diphtheria toxoid conjugate vaccine with routine diphtheria-tetanus-pertussis and inactivated poliovirus vaccinations of childhood. Pediatric Infectious Disease Journal.
67 Eskola J, Kayhty H, Takala AK, et al. (1990). A randomized, prospective field trial of a conjugate vaccine in the protection of infants and young children against invasive Haemophilus influenzae type b disease. New England Journal of Medicine.
68 Espinoza F, Tregnaghi M, Gentile A, et al. (2010). Primary and booster vaccination in Latin American children with a DTPw-HBV/Hib combination: A randomized controlled trial. BMC Infectious Diseases.
69 Esposito S, Principi N. (2011). Influenza vaccination in young children. The Lancet Infectious Diseases.
70 Esteves K. (1988). Safety of oral poliomyelitis vaccine: results of a WHO enquiry. Bulletin of the World Health Organization.
71 Faridi MMA, Krishnamurthy S. (2008). Abortive reaction and time of scar formation after BCG vaccination. Vaccine.
72 Farooqi IS, Hopkin JM. (1998). Early childhood infection and atopic disorder. Thorax.
73 Fattom A, Fuller S, Propst M, et al. (2004). Safety and immunogenicity of a booster dose of Staphylococcus aureus types 5 and 8 capsular polysaccharide conjugate vaccine (StaphVAX) in hemodialysis patients. Vaccine.
74 Fragapane E, Gasparini R, Schioppa F, et al. (2010). A heterologous MF59-adjuvanted H5N1 prepandemic influenza booster vaccine induces a robust, cross-reactive immune response in adults and the elderly. Clinical & Vaccine Immunology: CVI.
75 Galbraith NS, Crosby G, Barnes JM, et al. (1971). Simultaneous immunization with B.C.G., diphtheria-tetanus, and oral poliomyelitis vaccines in children aged 13-14. British Medical Journal.
76 Gillard P, Caplanusi A, Knuf M, et al. (2012). An assessment of prime-boost vaccination schedules with AS03(A)-adjuvanted prepandemic H5N1 vaccines: A randomized study in European adults. Influenza and other Respiratory Viruses.
77 Gisselsson-Solen M, Melhus A, Hermansson A. (2011). Pneumococcal vaccination in children at risk of developing recurrent acute otitis media - A randomized study. Acta Paediatrica, International Journal of Paediatrics.
78 Haber P, Chen RT, Zanardi LR, et al. (2004). An analysis of rotavirus vaccine reports to the vaccine adverse event reporting system: more than intussusception alone?. Pediatrics.
79 Heijmans S, De Meulemeester M, Reynders P, et al. (2011). Immunogenicity profile of a 3.75-(mu)g hemagglutinin pandemic rH5N1 split virion AS03(A)-adjuvanted vaccine in elderly persons: A randomized trial. Journal of Infectious Diseases.
80 Heikkinen T, Young J, van Beek E, et al. (2012). Safety of MF59-adjuvanted A/H1N1 influenza vaccine in pregnancy: a comparative cohort study. American Journal of Obstetrics & Gynecology.
81 Henderson J, North K, Griffiths M, et al. (1999). Pertussis vaccination and wheezing illnesses in young children: prospective cohort study. The Longitudinal Study of Pregnancy and Childhood Team. BMJ.
82 Hien ND, Luan LT, Huong NT, et al. (2011). High immunogenicity of measles AIK-C vaccine produced in Vietnam. Eastern Journal of Medicine.
83 Hung IFN, Leung AYM, Chu DWS, et al. (2010). Prevention of acute myocardial infarction and stroke among elderly persons by dual pneumococcal and influenza vaccination: a prospective cohort study. Clinical Infectious Diseases.
84 Hwang SJ, Chang SC, Yu CJ, et al. (2011). Immunogenicity and safety of an AS03(A)-adjuvanted H5N1 influenza vaccine in a Taiwanese population. Journal of the Formosan Medical Association.
85 Ikeno D, Kimachi K, Kino Y, et al. (2010). Immunogenicity of an inactivated adjuvanted whole-virion influenza A (H5N1, NIBRG-14) vaccine administered by intramuscular or subcutaneous injection. Microbiology & Immunology.
86 Jick H, Vasilakis-Scaramozza C, Jick SS. (2001). Live attenuated polio vaccine and the risk of intussusception. British Journal of Clinical Pharmacology.
87 Johnson B, Gargiullo P, Murphy TV, et al. (2010). Sociodemographic and dietary risk factors for natural infant intussusception in the United States. Journal of Pediatric Gastroenterology & Nutrition.
88 Karsh J, Pavlidis N, Schiffman G, et al. (1980). Immunization of patients with Sjogren's syndrome with pneumococcal polysaccharide vaccine: a randomized trial. Arthritis & Rheumatism.
89 Katial RK, Brandt BL, Moran EE, et al. (2002). Immunogenicity and safety testing of a group B intranasal meningococcal native outer membrane vesicle vaccine. Infection & Immunity.
90 Kaur S, Faridi MMA, Agarwal KN. (2002). BCG vaccination reaction in low birth weight infants. Indian Journal of Medical Research.
91 Keitel W, Groth N, Lattanzi M, et al. (2010). Dose ranging of adjuvant and antigen in a cell culture H5N1 influenza vaccine: safety and immunogenicity of a phase 1/2 clinical trial. Vaccine.
92 Kerdpanich A, Warachit B, Kosuwon P, et al. (2008). Primary vaccination with a new heptavalent DTPw-HBV/Hib-Neisseria meningitidis serogroups A and C combined vaccine is well tolerated. International Journal of Infectious Diseases.
93 Khemiri M, Bagais A, Becher SB, et al. (2012). Tuberculous meningitis in Bacille Calmette-Guerin-vaccinated children: clinical spectrum and outcome. Journal of Child Neurology.
94 Ki M, Park T, Yi SG, et al. (2003). Risk analysis of aseptic meningitis after measles-mumps-rubella vaccination in Korean children by using a case-crossover design. Am J Epidemiol.
95 King JC, Vink PE, Farley JJ, et al. (1997). Safety and immunogenicity of three doses of a five-valent pneumococcal conjugate vaccine in children younger than two years with and without human immunodeficiency virus infection. Pediatrics.
96 Kotloff KL, Fattom A, Basham L, et al. (1996). Safety and immunogenicity of a tetravalent group B streptococcal polysaccharide vaccine in healthy adults. Vaccine.
97 Kramarz P, France EK, Destefano F, et al. (2001). Population-based study of rotavirus vaccination and intussusception. Pediatric Infectious Disease Journal.
98 Lanata CF, Black RE, Flores J, et al. (1996). Immunogenicity, safety and protective efficacy of one dose of the rhesus rotavirus vaccine and serotype 1 and 2 human-rhesus rotavirus reassortants in children from Lima, Peru. Vaccine.
99 Langley JM, Frenette L, Ferguson L, et al. (2010). Safety and cross-reactive immunogenicity of candidate AS03-adjuvanted prepandemic H5N1 influenza vaccines: a randomized controlled phase 1/2 trial in adults. Journal of Infectious Diseases.
100 Langley JM, Halperin SA, McNeil S, et al. (2006). Safety and immunogenicity of a Proteosome -trivalent inactivated influenza vaccine, given nasally to healthy adults. Vaccine.
101 Langley JM, Risi G, Caldwell M, et al. (2011). Dose-sparing H5N1 A/Indonesia/05/2005 pre-pandemic influenza vaccine in adults and elderly adults: a phase III, placebo-controlled, randomized study. Journal of Infectious Diseases.
102 Leach A, Ceesay SJ, Banya WA, et al. (1996). Pilot trial of a pentavalent pneumococcal polysaccharide/protein conjugate vaccine in Gambian infants. Pediatric Infectious Disease Journal.
103 Ledgerwood JE, Wei CJ, Hu Z, et al. (2011). DNA priming and influenza vaccine immunogenicity: two phase 1 open label randomised clinical trials. The Lancet Infectious Diseases.
104 Lee J, Robinson JL, Spady DW. (2006). Frequency of apnea, bradycardia, and desaturations following first diphtheria-tetanus-pertussis-inactivated polio-Haemophilus influenzae type B immunization in hospitalized preterm infants. Bmc Pediatrics.
105 Lepow ML, Barkin RM, Berkowitz CD, et al. (1987). Safety and immunogenicity of Haemophilus influenzae type b polysaccharide-diphtheria toxoid conjugate vaccine (PRP-D) in infants. Journal of Infectious Diseases.
106 Lewis SA, Britton JR. (1998). Measles infection, measles vaccination and the effect of birth order in the aetiology of hay fever. Clin Exp Allergy.
107 Li RC, Li Y, Yi N, et al. (2013). An open, prospective, randomized study comparing the immunogenicity and safety of two inactivated hepatitis a pediatric vaccines in toddlers, children and adolescents in china. Pediatric Infectious Disease Journal.
108 Li STT, Davis RL, Weiss NS. (2004). Intussusception and oral poliovirus vaccination: is there an association?. American Journal of Epidemiology.
109 Liang XF, Wang HQ, Wang JZ, et al. (2010). Safety and immunogenicity of 2009 pandemic influenza A H1N1 vaccines in China: a multicentre, double-blind, randomised, placebo-controlled trial. Lancet.
110 Loew-Baselli A, Pavlova BG, Fritsch S, et al. (2012). A non-adjuvanted whole-virus H1N1 pandemic vaccine is well tolerated and highly immunogenic in children and adolescents and induces substantial immunological memory. Vaccine.
111 Lopez P, Caicedo Y, Sierra A, et al. (2011). Combined, concurrent, and sequential administration of seasonal influenza and MF59-adjuvanted A/H5N1 vaccines: a phase II randomized, controlled trial of immunogenicity and safety in healthy adults. Journal of Infectious Diseases.
112 Lopez-Macias C, Ferat-Osorio E, Tenorio-Calvo A, et al. (2011). Safety and immunogenicity of a virus-like particle pandemic influenza A (H1N1) 2009 vaccine in a blinded, randomized, placebo-controlled trial of adults in Mexico. Vaccine.
113 Mackenzie IS, MacDonald TM, Shakir S, et al. (2012). Influenza H1N1 (swine flu) vaccination: a safety surveillance feasibility study using self-reporting of serious adverse events and pregnancy outcomes. British Journal of Clinical Pharmacology.
114 Maldonado Y, Hestvik L, Wilson M, et al. (1986). Safety and immunogenicity of bovine rotavirus vaccine RIT 4237 in 3-month-old infants. Journal of Pediatrics.
115 Markwick AJ, Rennels MB, Zito ET, et al. (1998). Oral tetravalent rotavirus vaccine can be successfully coadministered with oral poliovirus vaccine and a combined diphtheria, tetanus, pertussis and Haemophilus influenzae type b vaccine. US Rhesus Rotavirus Vaccine Study Group. Pediatric Infectious Disease Journal.
116 Marshall HS, Richmond PC, Nissen MD, et al. (2012). Safety and immunogenicity of a meningococcal B bivalent rLP2086 vaccine in healthy toddlers aged 18 to 36 months: A phase 1 randomized controlled clinical trial. Pediatric Infectious Disease Journal.
117 Matson DO. (2006). RotaShield: the ill-fated rhesus-human reassortant rotavirus vaccine. Pediatric Annals.
118 McElhaney JE, Simor AE, McNeil S, et al. (2011). Efficacy and safety of CVT-E002, a proprietary extract of Panax quinquefolius in the prevention of respiratory infections in influenza-vaccinated community-dwelling adults: A multicenter, randomized, double-blind, and placebo-controlled trial. Influenza Research and Treatment.
119 Medical Products Agency. (2011). A registry based comparative cohort study in four Swedish counties of the risk for narcolepsy after vaccination with Pandemrix—a first and preliminary report.
120 Menzel M, Muellinger B, Weber N, et al. (2005). Inhalative vaccination with pneumococcal polysaccharide in healthy volunteers. Vaccine.
121 Mitchell LA, Tingle AJ, MacWilliam L, et al. (1998). HLA-DR class II associations with rubella vaccine-induced joint manifestations. J Infect Dis.
122 Mohrenschlager M, Haberl VM, Kramer U, et al. (2007). Early BCG and pertussis vaccination and atopic diseases in 5- to 7-year-old preschool children from Augsburg, Germany: results from the MIRIAM study. Pediatr Allergy Immunol.
123 Moro ML, Nobilio L, Voci C, et al. (2013). A population based cohort study to assess the safety of pandemic influenza vaccine Focetria in Emilia-Romagna region, Italy - part two. Vaccine.
124 Mulholland EK, Byass P, Campbell H, et al. (1994). The immunogenicity and safety of Haemophilus influenzae type b-tetanus toxoid conjugate vaccine in Gambian infants. Annals of Tropical Paediatrics.
125 Nachman S, Kim S, King J, et al. (2003). Safety and immunogenicity of a heptavalent pneumococcal conjugate vaccine in infants with human immunodeficiency virus type 1 infection. Pediatrics.
126 Nagai H, Ikematsu H, Tenjinbaru K, et al. (2010). A phase II, open-label, multicentre study to evaluate the immunogenicity and safety of an adjuvanted prepandemic (H5N1) influenza vaccine in healthy Japanese adults. BMC Infectious Diseases.
127 Nelson JC, Yu O, Dominguez-Islas CP, et al. (2013). Adapting group sequential methods to observational postlicensure vaccine safety surveillance: results of a pentavalent combination DTaP-IPV-Hib vaccine safety study. American Journal of Epidemiology.
128 Nilsson L, Kjellman NI, Bjorksten B. (1998). A randomized controlled trial of the effect of pertussis vaccines on atopic disease. Arch Pediatr Adolesc Med.
129 Nohynek H, Jokinen J, Partinen M, et al. (2012). AS03 adjuvanted AH1N1 vaccine associated with an abrupt increase in the incidence of childhood narcolepsy in Finland. PLoS ONE.
130 Nokleby H, Feiring B. (1991). The Norwegian meningococcal group B outer membrane vesicle vaccine: side effects in phase II trials. NIPH Annals.
131 Obaro SK, Enwere GC, Deloria M, et al. (2002). Safety and immunogenicity of pneumococcal conjugate vaccine in combination with diphtheria, tetanus toxoid, pertussis and Haemophilus influenzae type b conjugate vaccine. Pediatric Infectious Disease Journal.
132 Oppermann M, Fritzsche J, Weber-Schoendorfer C, et al. (2012). A(H1N1)v2009: A controlled observational prospective cohort study on vaccine safety in pregnancy. Vaccine.
133 Ornoy A, Arnon J, Feingold M, et al. (1990). Spontaneous abortions following oral poliovirus vaccination in first trimester. Lancet.
134 Ortega-Barria E, Kanra G, Leroux G, et al. (2007). The immunogenicity and reactogenicity of DTPw-HBV/Hib 2.5 combination vaccine: results from four phase III multicenter trials across three continents. Vaccine.
135 Ouandaogo CR, Yameogo TM, Diomande FVK, et al. (2012). Adverse events following immunization during mass vaccination campaigns at first introduction of a meningococcal A conjugate vaccine in Burkina Faso, 2010. Vaccine.
136 Pardon F, Vilarino M, Barbero P, et al. (2011). Rubella vaccination of unknowingly pregnant women during 2006 mass campaign in Argentina. Journal of Infectious Diseases.
137 Pasternak B, Svanstrom H, Molgaard-Nielsen D, et al. (2012). Risk of adverse fetal outcomes following administration of a pandemic influenza A(H1N1) vaccine during pregnancy. JAMA.
138 Pasternak B, Svanstrom H, Molgaard-Nielsen D, et al. (2012). Vaccination against pandemic A/H1N1 2009 influenza in pregnancy and risk of fetal death: cohort study in Denmark. BMJ.
139 Paterson DL, Patel A. (1998). Bacillus Calmette-Guerin (BCG) immunotherapy for bladder cancer: review of complications and their treatment. Australian & New Zealand Journal of Surgery.
140 Peltola H, Kayhty H, Sivonen A, et al. (1977). Haemophilus influenzae type b capsular polysaccharide vaccine in children: a double-blind field study of 100,000 vaccinees 3 months to 5 years of age in Finland. Pediatrics.
141 Phonrat B, Pitisuttithum P, Chamnanchanunt S, et al. (2013). Safety and immune responses following administration of H1N1 live attenuated influenza vaccine in Thais. Vaccine.
142 Pichichero ME. (1990). Effect of breast-feeding on oral rhesus rotavirus vaccine seroconversion: a metaanalysis. Journal of Infectious Diseases.
143 Pichichero ME, Marsocci SM, Francis AB, et al. (1993). A comparative evaluation of the safety and immunogenicity of a single dose of unbuffered oral rhesus rotavirus serotype 3, rhesus/human reassortant serotypes 1, 2 and 4 and combined (tetravalent) vaccines in healthy infants. Vaccine.
144 Price CS, Thompson WW, Goodson B, et al. (2010). Prenatal and infant exposure to thimerosal from vaccines and immunoglobulins and risk of autism. Pediatrics.
145 Quiambao B, Van Der Meeren O, Kolhe D, et al. (2012). A randomized, dose-ranging assessment of the immunogenicity and safety of a booster dose of a combined diphtheria-tetanus-whole cell pertussishepatitis B-inactivated poliovirus-Hemophilus influenzae type b (DTPw-HBV-IPV/Hib) vaccine vs. co-administration of DTPw-HBV/Hib and IPV vaccines in 12 to 24 months old Filipino toddlers. Human Vaccines and Immunotherapeutics.
146 Raman T, Mukhopadhyaya A, Eapen CE, et al. (2003). Intussusception in southern Indian children: lack of association with diarrheal disease and oral polio vaccine immunization. Indian Journal of Gastroenterology.
147 Ray P, Black S, Shinefield H, et al. (1997). Risk of chronic arthropathy among women after rubella vaccination. Vaccine Safety Datalink Team. JAMA.
148 Rennels MB, Glass RI, Dennehy PH, et al. (1996). Safety and efficacy of high-dose rhesus-human reassortant rotavirus vaccines--report of the National Multicenter Trial. United States Rotavirus Vaccine Efficacy Group. Pediatrics.
149 Rhim JW, Lee KY, Kim SY, et al. (2013). Evaluation of immunogenicity and safety of the new tetanus-reduced diphtheria (Td) vaccines (GC1107) in healthy Korean adolescents: a phase II, double-blind, randomized, multicenter clinical trial. Journal of Korean Medical Science.
150 Richmond PC, Marshall HS, Nissen MD, et al. (2012). Safety, immunogenicity, and tolerability of meningococcal serogroup B bivalent recombinant lipoprotein 2086 vaccine in healthy adolescents: A randomised, single-blind, placebo-controlled, phase 2 trial. The Lancet Infectious Diseases.
151 Rigau-Perez JG, Overturf GD, Chan LS, et al. (1983). Reactions to booster pneumococcal vaccination in patients with sickle cell disease. Pediatric Infectious Disease.
152 Riley ID, Lehmann D, Alpers MP, et al. (1986). Pneumococcal vaccine prevents death from acute lower-respiratory-tract infections in Papua New Guinean children. Lancet.
153 Roth AE, Benn CS, Ravn H, et al. (2010). Effect of revaccination with BCG in early childhood on mortality: randomised trial in Guinea-Bissau. British Medical Journal.
154 Rubinstein F, Micone P, Bonotti A, et al. (2013). Influenza A/H1N1 MF59 adjuvanted vaccine in pregnant women and adverse perinatal outcomes: multicentre study. BMJ.
155 Ruiz-Palacios GM, Guerrero ML, Bautista-Marquez A, et al. (2007). Dose response and efficacy of a live, attenuated human rotavirus vaccine in Mexican infants. Pediatrics.
156 Saitoh A, Nagai A, Tenjinbaru K, et al. (2012). Safety and persistence of immunological response 6 months after intramuscular vaccination with an AS03-adjuvanted H1N1 2009 influenza vaccine: An open-label, randomized trial in Japanese children aged 6 months to 17 years. Human Vaccines and Immunotherapeutics.
157 Salinas B, Perez Schael I, Linhares AC, et al. (2005). Evaluation of safety, immunogenicity and efficacy of an attenuated rotavirus vaccine, RIX4414: A randomized, placebo-controlled trial in Latin American infants. Pediatric Infectious Disease Journal.
158 Salmon-Ceron D, Durier C, Desaint C, et al. (2010). Immunogenicity and safety of an HIV-1 lipopeptide vaccine in healthy adults: a phase 2 placebo-controlled ANRS trial. Aids.
159 Santolaya ME, O'Ryan ML, Valenzuela MT, et al. (2012). Immunogenicity and tolerability of a multicomponent meningococcal serogroup B (4CMenB) vaccine in healthy adolescents in Chile: a phase 2b/3 randomised, observer-blind, placebo-controlled study. Lancet.
160 Santosham M, Letson GW, Wolff M, et al. (1991). A field study of the safety and efficacy of two candidate rotavirus vaccines in a Native American population. Journal of Infectious Diseases.
161 Santosham M, Moulton LH, Reid R, et al. (1997). Efficacy and safety of high-dose rhesus-human reassortant rotavirus vaccine in Native American populations. Journal of Pediatrics.
162 Schmader KE, Levin MJ, Gnann JW, et al. (2012). Efficacy, safety, and tolerability of herpes zoster vaccine in persons aged 50-59 years. Clinical Infectious Diseases.
163 Schmitt HJ, Faber J, Lorenz I, et al. (2003). The safety, reactogenicity and immunogenicity of a 7-valent pneumococcal conjugate vaccine (7VPnC) concurrently administered with a combination DTaP-IPV-Hib vaccine. Vaccine.
164 Segaard OS, Lohse N, Harboe ZB, et al. (2010). Improving the immunogenicity of pneumococcal conjugate vaccine in HIV-infected adults with a toll-like receptor 9 agonist adjuvant: A randomized, controlled trial. Clinical Infectious Diseases.
165 Sharma H, Chowdhari S, Raina TR, et al. (2010). Sero-Surveillance to Assess Immunity to Rubella and Assessment of Immunogenicity and Safety of a Single dose of Rubella Vaccine in School Girls. Indian Journal of Community Medicine.
166 Sharma H, Patil V, Sharma D, et al. (2012). A phase III, randomized controlled study to assess the safety and immunogenicity of a semi-synthetic diphtheria, tetanus and whole-cell pertussis vaccine in Indian infants. Vaccine.
167 Sharma HJ, Oun SA, Bakr SSA, et al. (2010). No demonstrable association between the Leningrad-Zagreb mumps vaccine strain and aseptic meningitis in a large clinical trial in Egypt. Clinical Microbiology & Infection.
168 Simasathien S, Migasena S, Samakoses R, et al. (1994). Vaccination of Thai infants with rhesus-human reassortant tetravalent oral rotavirus vaccine. Pediatric Infectious Disease Journal.
169 Simonsen L, Viboud C, Elixhauser A, et al. (2005). More on RotaShield and intussusception: the role of age at the time of vaccination. Journal of Infectious Diseases.
170 Slater PE, Ben-Zvi T, Fogel A, et al. (1995). Absence of an association between rubella vaccination and arthritis in underimmune postpartum women. Vaccine.
171 Soares RC, Siqueira MM, Toscano CM, et al. (2011). Follow-up study of unknowingly pregnant women vaccinated against rubella in Brazil, 2001-2002. Journal of Infectious Diseases.
172 Strebel PM, Ion-Nedelcu N, Baughman AL, et al. (1995). Intramuscular injections within 30 days of immunization with oral poliovirus vaccine--a risk factor for vaccine-associated paralytic poliomyelitis. New England Journal of Medicine.
173 Sugawara T, Ohsuka Y, Taya K, et al. (2009). Diarrhea as a minor adverse effect due to oral polio vaccine. Japanese Journal of Infectious Diseases.
174 Sur D, Ochiai RL, Bhattacharya SK, et al. (2009). A cluster-randomized effectiveness trial of Vi typhoid vaccine in India. New England Journal of Medicine.
175 Tavares F, Nazareth I, Monegal JS, et al. (2011). Pregnancy and safety outcomes in women vaccinated with an AS03-adjuvanted split virion H1N1 (2009) pandemic influenza vaccine during pregnancy: a prospective cohort study. Vaccine.
176 Tingle AJ, Mitchell LA, Grace M, et al. (1997). Randomised double-blind placebo-controlled study on adverse effects of rubella immunisation in seronegative women. Lancet.
177 Tomljenovic L, Shaw CA. (2012). Mechanisms of aluminum adjuvant toxicity and autoimmunity in pediatric populations. Lupus.
178 Treanor JJ, Clark HF, Pichichero M, et al. (1995). Evaluation of the protective efficacy of a serotype 1 bovine-human rotavirus reassortant vaccine in infants. Pediatric Infectious Disease Journal.
179 Turley CB, Rupp RE, Johnson C, et al. (2011). Safety and immunogenicity of a recombinant M2e-flagellin influenza vaccine (STF2.4xM2e) in healthy adults. Vaccine.
180 Ugpo J, Lucero M, Williams G, et al. (2009). Reactogenicity and tolerability of a non-adjuvanted 11-valent diphtheria-tetanus toxoid pneumococcal conjugate vaccine in Filipino children. Vaccine.
181 Verge CF, Howard NJ, Irwig L, et al. (1994). Environmental factors in childhood IDDM. A population-based, case-control study. Diabetes Care.
182 Verity C, Stellitano L, Winstone AM, et al. (2011). Guillain-Barre syndrome and H1N1 influenza vaccine in UK children. Lancet.
183 Vesikari T, Isolauri E, D'Hondt E, et al. (1984). Protection of infants against rotavirus diarrhoea by RIT 4237 attenuated bovine rotavirus strain vaccine. Lancet.
184 Vesikari T, Joensuu J. (1996). Review of rotavirus vaccine trials in Finland. Journal of Infectious Diseases.
185 Vesikari T, Karvonen A, Forrest BD, et al. (2006). Neonatal administration of rhesus rotavirus tetravalent vaccine. Pediatric Infectious Disease Journal.
186 Vesikari T, Karvonen AV, Majuri J, et al. (2006). Safety, efficacy, and immunogenicity of 2 doses of bovine-human (UK) and rhesus-rhesus-human rotavirus reassortant tetravalent vaccines in Finnish children. Journal of Infectious Diseases.
187 Vesikari T, Pepin S, Kusters I, et al. (2012). Assessment of squalene adjuvanted and non-adjuvanted vaccines against pandemic H1N1 influenza in children 6 months to 17 years of age. Human vaccines & Immunotherapeutics.
188 Wiedermann G, Jovanovic D, Georges AM. (1982). Immunogenicity and reactogenicity of new multivalent pneumococcal vaccines. Zentralblatt fur Bakteriologie Mikrobiologie und Hygiene - Abt. 1 Orig A.
189 Wringe A, Fine PEM, Sutter RW, et al. (2008). Estimating the extent of vaccine-derived poliovirus infection. PLoS ONE.
190 Yang PC, Yu CJ, Chang SC, et al. (2012). Safety and immunogenicity of a split-virion AS03(A)-adjuvanted A/Indonesia/05/2005 (H5N1) vaccine in Taiwanese adults. Journal of the Formosan Medical Association.
191 Zhou WZ, Koo HW, Wang XY, et al. (2007). Revaccination with locally-produced vi typhoid polysaccharide vaccine among chinese school-aged children: safety and immunogenicity findings. Pediatric Infectious Disease Journal.
192 Zhu FC, Zhang J, Zhang XF, et al. (2010). Efficacy and safety of a recombinant hepatitis E vaccine in healthy adults: a large-scale, randomised, double-blind placebo-controlled, phase 3 trial. Lancet.
193 Zimmermann U, Gavazzi G, Richard P, et al. (2013). Immunogenicity and safety of a booster dose of diphtheria, tetanus, acellular pertussis and inactivated poliomyelitis vaccine (Tdap-IPV; Repevax) administered concomitantly versus non-concomitantly with an influenza vaccine (Vaxigrip) to adults aged >=60 years: an open-label, randomised trial. Vaccine.

## Rejected for Other – 3

1 de Vos van Steenwijk PJ, Ramwadhdoebe TH, Lowik MJG, et al. (2012). A placebo-controlled randomized HPV16 synthetic long-peptide vaccination study in women with high-grade cervical squamous intraepithelial lesions. Cancer Immunology, Immunotherapy.
2 Svanstrom H, Callreus T, Hviid A. (2010). Temporal data mining for adverse events following immunization in nationwide Danish healthcare databases. Drug Safety.
3 Swingler G, Fransman D, Hussey G. (2007). Conjugate vaccines for preventing Haemophilus influenzae type B infections. Cochrane Database of Systematic Reviews.

## Background - 353

1 (1981). From the NIH: Pneumococcal vaccination for patients with Sjogren's syndrome. JAMA.
2 (1993). Haemophilus influenzae B immunisation. Drug and Therapeutics Bulletin.
3 (1996). Update: vaccine side effects, adverse reactions, contraindications, and precautions. Recommendations of the Advisory Committee on Immunization Practices (ACIP). Morbidity & Mortality Weekly Report. Recommendations & Reports.
4 (1997). Poliomyelitis prevention: recommendations for use of inactivated poliovirus vaccine and live oral poliovirus vaccine. American Academy of Pediatrics Committee on Infectious Diseases. Pediatrics.
5 From the Centers for Disease Control and Prevention. (1999). Intussusception among recipients of rotavirus vaccine--United States, 1998-1999. JAMA.
6 (1999). Rotavirus vaccine for the prevention of rotavirus gastroenteritis among children. Recommendations of the Advisory Committee on Immunization Practices (ACIP). Morbidity & Mortality Weekly Report. Recommendations & Reports.
7 (1999). Intussusception among recipients of rotavirus vaccine - US, 1998-1999. Annals of Pharmacotherapy.
8 (2000). Acellular pertussis vaccines. Prescrire International.
9 (2000). Acellulat pertussis vaccines. New preparation. Better tolerated but less active?. Prescrire International.
10 (2002). Haemophilus influenzae type B vaccine safe and effective in early infancy. South African Medical Journal.
11 (2003). Pneumococcal 7-valent conjugate vaccine protects young children. Drugs and Therapy Perspectives.
12 (2003). Contraindications to vaccination in children. Mainly immunosuppression and a history of severe reactions. Prescrire International.
13 (2003). Immunization during pregnancy. International Journal of Gynecology and Obstetrics.
14 (2003). Immunization during pregnancy. Obstetrics and Gynecology.
15 (2003). MMR vaccine--how effective and how safe?. Drug Ther Bull.
16 (2004). Rotavirus vaccine - AVANT Immunotherapeutics/GlaxoSmithKline: 89-12, RIX4414. Drugs in R and D.
17 (2007). Hepatitis A vaccine recommendations committee on infectious diseases. Pediatrics.
18 (2009). Little evidence that supports a causal link between most vaccines and Guillain-Barre syndrome. Drugs and Therapy Perspectives.
19 (2010). PCV13: Proven efficacy and safety. International Journal of Infectious Diseases.
20 (2010). Committee opinion No. 467: Human papillomavirus vaccination. Obstetrics and Gynecology.
21 (2011). Meeting of the Global Advisory Committee on Vaccine Safety,June 2011. Weekly Epidemiological Record.
22 (2011). 13-valent pneumococcal conjugate vaccine. Prescrire International.
23 (2012). HPV vaccines and pregnancy: the situation in early 2012. Prescrire International.
24 Abramson JS, Baker CJ, Fisher MC, et al. (2000). Policy statement: Recommendations for the prevention of pneumococcal infections, including the use of pneumococcal conjugate vaccine (Prevnar), pneumococcal polysaccharide vaccine, and antibiotic prophylaxis. Pediatrics.
25 Adler UC. (2005). The influence of childhood infections and vaccination on the development of atopy: A systematic review of the direct epidemiological evidence. Homeopathy.
26 Al-Safi ZA, Shavell VI, Gonik B. (2011). Vaccination in pregnancy. Women's Health.
27 Ambrose CS. (2012). Use of intranasal live attenuated influenza vaccine in individuals with asthma or a history of wheezing. Human vaccines & Immunotherapeutics.
28 Ambrose CS, Wu XH, Knuf M, et al. (2012). The efficacy of intranasal live attenuated influenza vaccine in children 2 through 17 years of age: A meta-analysis of 8 randomized controlled studies. Vaccine.
29 Ambrose CS, Yi T, Falloon J. (2011). An integrated, multistudy analysis of the safety of Ann Arbor strain live attenuated influenza vaccine in children aged 2-17 years. Influenza & Other Respiratory Viruses.
30 Anderson EJ. (2011). Intussusception risk of rotavirus vaccination. New England Journal of Medicine.
31 Anderson EL. (1989). Prevention of pertussis. Seminars in Respiratory Infections.
32 (2012). Study: shingles vaccine safe for patients on immune-suppressing drugs. Human vaccines & Immunotherapeutics.
33 Avery RK. (1999). Vaccination of the immunosuppressed adult patient with rheumatologic disease. Rheumatic Disease Clinics of North America.
34 Babl FE, Lewena S, Brown L. (2006). Vaccination-related adverse events. Pediatric Emergency Care.
35 Baggs J, Gee J, Lewis E, et al. (2011). The vaccine safety datalink: A model for monitoring immunization safety. Pediatrics.
36 Balofsky A, Agmon-Levin N, Shoenfeld Y. (2010). The new H1N1 and HPV vaccines and old fears. Current Opinion in Rheumatology.
37 Bar-On ES, Goldberg E, Hellmann S, et al. (2012). Combined DTP-HBV-HIB vaccine versus separately administered DTP-HBV and HIB vaccines for primary prevention of diphtheria, tetanus, pertussis, hepatitis B and Haemophilus influenzae B (HIB). Cochrane Database of Systematic Reviews.
38 Barr E, Tamms G. (2007). Quadrivalent human papillomavirus vaccine. Clin Infect Dis.
39 Bart KJ, Orenstein WA, Hinman AR. (1987). The current status of immunization principles: Recommendations for use and adverse reactions. Journal of Allergy and Clinical Immunology.
40 Battista A, Ruggiero A, Coccia P, et al. (2012). Vaccination in children with cancer: A debate. Central European Journal of Medicine.
41 Baxter P. (2010). Pertussis vaccine encephalopathy: ‘Oh! Let us never, never doubt ’. Developmental Medicine & Child Neurology.
42 Bechini A, Tiscione E, Boccalini S, et al. (2012). Acellular pertussis vaccine use in risk groups (adolescents, pregnant women, newborns and health care workers): A review of evidences and recommendations. Vaccine.
43 Beck CR, McKenzie BC, Hashim AB, et al. (2011). Influenza vaccination for immunocompromised patients: systematic review and meta-analysis from a public health policy perspective. PLoS ONE.
44 Beeler J, Varricchio F, Wise R. (1996). Thrombocytopenia after immunization with measles vaccines: review of the vaccine adverse events reporting system (1990 to 1994). Pediatr Infect Dis J.
45 Bernstein DI. (2006). Live attenuated human rotavirus vaccine, Rotarix. Seminars in Pediatric Infectious Diseases.
46 Bernstein DI. (2007). A live attenuated human rotavirus vaccine. Drugs of Today.
47 Beyer WE, Palache AM, Kerstens R, et al. (1996). Gender differences in local and systemic reactions to inactivated influenza vaccine, established by a meta-analysis of fourteen independent studies. Eur J Clin Microbiol Infect Dis.
48 Beyer WEP, Nauta JJP, Palache AM, et al. (2011). Immunogenicity and safety of inactivated influenza vaccines in primed populations: a systematic literature review and meta-analysis. Vaccine.
49 Bigham M, Copes R. (2005). Thiomersal in vaccines: Balancing the risk of adverse effects with the risk of vaccine-preventable disease. Drug Safety.
50 Bines JE, Kohl KS, Forster J, et al. (2004). Acute intussusception in infants and children as an adverse event following immunization: Case definition and guidelines of data collection, analysis, and presentation. Vaccine.
51 Black S, Della Cioppa G, Malfroot A, et al. (2010). Safety of MF59-adjuvanted versus non-adjuvanted influenza vaccines in children and adolescents: an integrated analysis. Vaccine.
52 Blank M, Israeli E, Shoenfeld Y. (2012). When APS (Hughes syndrome) met the autoimmune/inflammatory syndrome induced by adjuvants (ASIA). Lupus.
53 Blencowe H, Lawn J, Vandelaer J, et al. (2010). Tetanus toxoid immunization to reduce mortality from neonatal tetanus. International Journal of Epidemiology.
54 Bliss SJ, O'Brien KL, Janoff EN, et al. (2008). The evidence for using conjugate vaccines to protect HIV-infected children against pneumococcal disease. The Lancet Infectious Diseases.
55 Bonanni P, Cohet C, Kjaer SK, et al. (2010). A summary of the post-licensure surveillance initiatives for GARDASIL/SILGARD. Vaccine.
56 Bonhoeffer J, Heininger U. (2007). Adverse events following immunization: Perception and evidence. Current Opinion in Infectious Diseases.
57 Bonhoeffer J, Siegrist CA, Heath PT. (2006). Immunisation of premature infants. Archives of Disease in Childhood.
58 Borchers AT, Keen CL, Shoenfeld Y, et al. (2002). Vaccines, viruses, and voodoo. Journal of Investigational Allergology and Clinical Immunology.
59 Bovier PA. (2008). Recent advances with a virosomal hepatitis A vaccine. Expert Opinion on Biological Therapy.
60 Brady MT, Bernstein HH, Byington CL, et al. (2011). Policy statement - Prevention of varicella: Update of recommendations for use of quadrivalent and monovalent varicella vaccines in children. Pediatrics.
61 Broder KR, Martin DB, Vellozzi C. (2012). Bridging the gap between data and public health needs. In the heat of a signal: Responding to a vaccine safety signal for febrile seizures after 2010-11 influenza vaccine in young children, United States. Vaccine.
62 Broder KR, Martin DB, Vellozzi C. (2012). In the heat of a signal: responding to a vaccine safety signal for febrile seizures after 2010-11 influenza vaccine in young children, United States. Vaccine.
63 Brunell PA, Bass JW, Daum RS. (1985). Hemophilus type b polysaccharide vaccine. Pediatrics.
64 Bryant KA, McVernon J, Marchant CD, et al. (2012). Immunogenicity and safety of measles-mumps-rubella and varicella vaccines coadministered with a fourth dose of Haemophilus influenzae type b and Neisseria meningitidis serogroups C and Y-tetanus toxoid conjugate vaccine in toddlers: A pooled analysis of randomized trials. Human Vaccines and Immunotherapeutics.
65 Campion JJ, Casto DT. (1988). Haemophilus influenzae type b conjugate vaccine. Journal of Pediatric Health Care.
66 Caple J. (2006). Pentavalent human-bovine reassortant rotavirus vaccine: a review of its efficacy and safety in preventing acute rotavirus gastroenteritis in healthy infants. Drugs of Today.
67 Carter NJ, Curran MP. (2011). Live attenuated influenza vaccine (FluMist(registered trademark); Fluenz(trademark)): A review of its use in the prevention of seasonal influenza in children and adults. Drugs.
68 Casey JR, Pichichero ME. (2005). Acellular pertussis vaccine safety and efficacy in children, adolescents and adults. Drugs.
69 Cates CJ, Rowe BH. (2013). Vaccines for preventing influenza in people with asthma. Cochrane Database of Systematic Reviews.
70 Cavassini ML, D'Acremont V, Furrer H, et al. (2005). Pharmacotherapy, vaccines and malaria advice for HIV-infected travellers. Expert Opinion on Pharmacotherapy.
71 Cendes F, Sankar R. (2011). Vaccinations and febrile seizures. Epilepsia.
72 Centers for Disease C, Prevention. (1999). Intussusception among recipients of rotavirus vaccine--United States, 1998-1999. MMWR - Morbidity & Mortality Weekly Report.
73 Centers for Disease C, Prevention. (1999). Withdrawal of rotavirus vaccine recommendation. MMWR - Morbidity & Mortality Weekly Report.
74 Centers for Disease C, Prevention. (2010). Licensure of a high-dose inactivated influenza vaccine for persons aged >or=65 years (Fluzone High-Dose) and guidance for use - United States, 2010. MMWR - Morbidity & Mortality Weekly Report.
75 Centers for Disease C, Prevention. (2010). Preliminary results: surveillance for Guillain-Barre syndrome after receipt of influenza A (H1N1) 2009 monovalent vaccine - United States, 2009-2010. MMWR - Morbidity & Mortality Weekly Report.
76 Centers for Disease C, Prevention. (2010). Update: Recommendations of the Advisory Committee on Immunization Practices (ACIP) regarding use of CSL seasonal influenza vaccine (Afluria) in the United States during 2010-11. MMWR - Morbidity & Mortality Weekly Report.
77 Centers for Disease C, Prevention. (2010). Licensure of a 13-valent pneumococcal conjugate vaccine (PCV13) and recommendations for use among children - Advisory Committee on Immunization Practices (ACIP), 2010. MMWR - Morbidity & Mortality Weekly Report.
78 Centers for Disease C, Prevention. (2011). Prevention and control of influenza with vaccines: recommendations of the Advisory Committee on Immunization Practices (ACIP), 2011. MMWR - Morbidity & Mortality Weekly Report.
79 Centers for Disease C, Prevention. (2011). Use of hepatitis B vaccination for adults with diabetes mellitus: recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR - Morbidity & Mortality Weekly Report.
80 Centers for Disease C, Prevention. (2011). Updated recommendations for use of tetanus toxoid, reduced diphtheria toxoid and acellular pertussis (Tdap) vaccine from the Advisory Committee on Immunization Practices, 2010. MMWR - Morbidity & Mortality Weekly Report.
81 Centers for Disease C, Prevention. (2012). Prevention and Control of Influenza with Vaccines: Recommendations of the Advisory Committee on Immunization Practices (ACIP) - United States, 2012-13 Influenza Season. MMWR - Morbidity & Mortality Weekly Report.
82 Centers for Disease C, Prevention, American Academy of Pediatrics Committee on Infectious D. (2011). Additional recommendations for use of tetanus toxoid, reduced-content diphtheria toxoid, and acellular pertussis vaccine (Tdap). Pediatrics.
83 Chaithongwongwatthana S, Yamasmit W, Limpongsanurak S, et al. (2012). Pneumococcal vaccination during pregnancy for preventing infant infection. Cochrane Database of Systematic Reviews.
84 Chambers S. (2006). Drug review - Prevenar(registered trademark). Drugs in Context.
85 Chan R. (2010). Cochrane review summary for cancer nursing: Influenza vaccination in children having chemotherapy for cancer. Cancer Nursing.
86 Chen N, Li Q, Zhang Y, et al. (2011). Vaccination for preventing postherpetic neuralgia. Cochrane Database of Systematic Reviews.
87 Chen RT. (1999). Vaccine risks: Real, perceived and unknown. Vaccine.
88 Chen RT, Mootrey G, DeStefano F. (2000). Safety of routine childhood vaccinations: An epidemiological review. Paediatric Drugs.
89 Cheuk DK, Chiang AK, Lee TL, et al. (2011). Vaccines for prophylaxis of viral infections in patients with hematological malignancies. Cochrane Database of Systematic Reviews.
90 Cheuvart B, Friedland LR, Abu-Elyazeed R, et al. (2009). The human rotavirus vaccine RIX4414 in infants: a review of safety and tolerability. Pediatric Infectious Disease Journal.
91 Choudhuri D, Huda T, Theodoratou E, et al. (2011). An evaluation of emerging vaccines for childhood meningococcal disease. Bmc Public Health.
92 Clark HF, Offit PA, Plotkin SA, et al. (2006). The new pentavalent rotavirus vaccine composed of bovine (strain WC3) -human rotavirus reassortants. Pediatric Infectious Disease Journal.
93 Classen DC, Classen JB. (1997). The timing of pediatric immunization and the risk of insulin-dependent diabetes mellitus. Infect Dis Clin Pract.
94 Clements C, Ball LK, Ball R, et al. (2001). Thiomersal in vaccines: Is removal warranted?. Drug Safety.
95 Clements CJ. (2004). The evidence for the safety of thiomersal in newborn and infant vaccines. Vaccine.
96 Clements CJ, Griffiths E. (2002). The global impact of vaccines containing aluminium adjuvants. Vaccine.
97 Clements CJ, McIntyre PB. (2006). When science is not enough - A risk/benefit profile of thiomersal-containing vaccines. Expert Opinion on Drug Safety.
98 Cohen J. (2006). Adverse events following immunisation. Medicine Today.
99 Collinson A. (2012). Safety in numbers: Anaphylaxis risk in childhood immunisation. Archives of Disease in Childhood.
100 Committee on Infectious D. (2011). Policy statement-Prevention of varicella: update of recommendations for use of quadrivalent and monovalent varicella vaccines in children. Pediatrics.
101 Conti F, Rezai S, Valesini G. (2008). Vaccination and autoimmune rheumatic diseases. Autoimmunity Reviews.
102 Cook IF. (2009). Sex differences in injection site reactions with human vaccines. Human Vaccines.
103 Cooper B, Detora L, Stoddard J. (2011). Menveo(registered trademark): A novel quadrivalent meningococcal CRM(197) conjugate vaccine against serogroups A, C, W-135 and y. Expert Review of Vaccines.
104 Cunliffe NA, Nakagomi O. (2005). A critical time for rotavirus vaccines: a review. Expert Review of Vaccines.
105 Curlin G, Landry S, Bernstein J, et al. (2011). Integrating safety and efficacy evaluation throughout vaccine research and development. Pediatrics.
106 Dales L, Hammer SJ, Smith NJ. (2001). Time trends in autism and in MMR immunization coverage in California. JAMA.
107 D'Andrilli G, Bovicelli A, Giordano A. (2010). HPV vaccines: State of the art. Journal of Cellular Physiology.
108 D'Angio CT. (2007). Active immunization of premature and low birth-weight infants: a review of immunogenicity, efficacy, and tolerability. Paediatric Drugs.
109 Darkes MJM, Plosker GL. (2002). Pneumococcal conjugate vaccine (Prevnar; PNCRM7): a review of its use in the prevention of Streptococcus pneumoniae infection. Paediatric Drugs.
110 De Vos B, Vesikari T, Linhares AC, et al. (2004). A rotavirus vaccine for prophylaxis of infants against rotavirus gastroenteritis. Pediatric Infectious Disease Journal.
111 Dell'Era L, Esposito S, Corona F, et al. (2011). Vaccination of children and adolescents with rheumatic diseases. Rheumatology.
112 Delore V, Salamand C, Marsh G, et al. (2006). Long-term clinical trial safety experience with the inactivated split influenza vaccine, Vaxigrip. Vaccine.
113 Demicheli V, Barale A, Rivetti A. (2013). Vaccines for women to prevent neonatal tetanus. Cochrane Database of Systematic Reviews.
114 Demicheli V, Rivetti A, Debalini MG, et al. (2012). Vaccines for measles, mumps and rubella in children. Cochrane Database of Systematic Reviews.
115 Demirjian A, Levy O. (2009). Safety and efficacy of neonatal vaccination. European Journal of Immunology.
116 DeStefano F. (2007). Vaccines and autism: Evidence does not support a causal association. Clinical Pharmacology and Therapeutics.
117 Destefano F, Pfeifer D, Nohynek H. (2008). Safety profile of pneumococcal conjugate vaccines: systematic review of pre- and post-licensure data. Bulletin of the World Health Organization.
118 DeStefano F, Thompson WW. (2004). MMR vaccine and autism: an update of the scientific evidence. Expert Rev Vaccines.
119 Dhillon S. (2010). Spotlight on DTPa-HBV-IPVHib vaccine (Infanrix hexa((trademark))). BioDrugs.
120 Dhillon S. (2010). DTPa-HBV-IPVHib vaccine (infanrix hexa(trademark)): A review of its use as primary and booster vaccination. Drugs.
121 Dhillon S, Curran MP. (2008). Live attenuated measles, mumps, rubella, and varicella zoster virus vaccine (Priorix-Tetra). Paediatric Drugs.
122 Dhillon S, Keam SJ. (2008). DTaP-IPV/Hib vaccine (Pentacel(registered trademark)). Pediatric Drugs.
123 Dinleyici EC, Yargic ZA. (2009). Current knowledge regarding the investigational 13-valent pneumococcal conjugate vaccine. Expert Review of Vaccines.
124 Duggan ST. (2010). Pneumococcal polysaccharide conjugate vaccine (13-Valent, Adsorbed) Prevenar 13((registered trademark)). Drugs.
125 Dull PM, McIntosh ED. (2012). Meningococcal vaccine development - from glycoconjugates against MenACWY to proteins against MenB - potential for broad protection against meningococcal disease. Vaccine.
126 Eichelberger MC, Sperber E, Wagner M, et al. (2002). Clinical evaluation of a single oral dose of human-bovine (UK) reassortant rotavirus vaccines Wa x UK (P1A[8],G6) and Wa x (DS-1 x UK) (P1A[8],G2). Journal of Medical Virology.
127 Eldred BE, Dean AJ, McGuire TM, et al. (2006). Vaccine components and constituents: Responding to consumer concerns. Medical Journal of Australia.
128 Etter DJ, Zimet GD, Rickert VI. (2012). Human papillomavirus vaccine in adolescent women: A 2012 update. Current Opinion in Obstetrics and Gynecology.
129 Evans G. (1996). Vaccine liability and safety: A progress report. Pediatric Infectious Disease Journal.
130 Faix RG. (1991). Maternal immunization to prevent fetal and neonatal infection. Clinical Obstetrics and Gynecology.
131 Farez MF, Correale J. (2011). Immunizations and risk of multiple sclerosis: systematic review and meta-analysis. Journal of Neurology.
132 Fernandes GC, Camacho LAB, Sa Carvalho M. (2005). Surveillance system of vaccine adverse events and local data analysis - The experience in a middle-sized city in Brazil, 1999-2001. Vaccine.
133 Ferreccio C, Clemens J, Avendano A, et al. (1991). The Clinical and Immunological Response of Chilean Infants to Haemophilus-Influenzae Type B-Polysaccharide-Tetanus Protein Conjugate Vaccine Coadministered in the Same Syringe with Diphtheria-Tetanus Toxoids-Pertussis Vaccine at 2, 4 and 6 Months of Age. Pediatric Infectious Disease Journal.
134 Fine MJ, Smith MA, Carson CA, et al. (1994). Efficacy of pneumococcal vaccination in adults: A meta-analysis of randomized controlled trials. Archives of Internal Medicine.
135 Fiore AE, Uyeki TM, Broder K, et al. (2010). Prevention and control of influenza with vaccines: recommendations of the Advisory Committee on Immunization Practices (ACIP), 2010. Morbidity & Mortality Weekly Report. Recommendations & Reports.
136 Flohr C, Yeo L. (2011). Atopic dermatitis and the hygiene hypothesis revisited. Current Problems in Dermatology.
137 Fombonne E, Zakarian R, Bennett A, et al. (2006). Pervasive developmental disorders in Montreal, Quebec, Canada: Prevalence and links with immunizations. Pediatrics.
138 Forinash AB, Yancey AM, Pitlick JM, et al. (2011). Safety of the HPV bivalent and quadrivalent vaccines during pregnancy. Annals of Pharmacotherapy.
139 Fox KA, Theiler R. (2011). Vaccination in pregnancy. Current Pharmaceutical Biotechnology.
140 Frampton JE, Keating GM. (2006). Reduced-antigen, combined diphtheria, tetanus, and acellular pertussis vaccine (boostrix(trademark)): A review of its use as a single-dose booster immunization. BioDrugs.
141 Frenck RW, Seward JF. (2010). Varicella vaccine safety and immunogenicity in patients with juvenile rheumatic diseases receiving methotrexate and corticosteroids. Arthritis care & research.
142 Fritsche PJ, Helbling A, Ballmer-Weber BK. (2010). Vaccine hypersensitivity - Update and overview. Swiss Medical Weekly.
143 Gagliardi AM, Gomes Silva BN, Torloni MR, et al. (2012). Vaccines for preventing herpes zoster in older adults. Cochrane Database of Systematic Reviews.
144 Galiza EP, Heath PT. (2008). Adverse events following immunisation - fact and fiction. Paediatrics and Child Health.
145 Geier DA, Geier MR. (2004). A comparative evaluation of the effects of MMR immmunization and mercury doses from thimerosal-containing childhood vaccines on the population prevalence of autism. Medical Science Monitor.
146 Ghaffar F. (2005). The safety of 7-valent pneumococcal conjugate vaccine. Expert Opinion on Drug Safety.
147 Girard M. (2005). Autoimmune hazards of hepatitis B vaccine. Autoimmunity Reviews.
148 Gladstone RA, Jefferies JM, Faust SN, et al. (2012). Pneumococcal 13-valent conjugate vaccine for the prevention of invasive pneumococcal disease in children and adults. Expert Review of Vaccines.
149 Glass RI, Patel M, Parashar U. (2011). Lessons from the US rotavirus vaccination program. JAMA.
150 Gleeson TD, Wallace MR, Tasker SA. (2006). Vaccination in patients with HIV infection. Current Infectious Disease Reports.
151 Glezen WP. (2001). Maternal vaccines. Primary Care - Clinics in Office Practice.
152 Gluck T, Muller-Ladner U. (2008). Vaccination in patients with chronic rheumatic or autoimmune diseases. Clinical Infectious Diseases.
153 Gold M, Goodwin H, Botham S, et al. (2000). Re-vaccination of 421 children with a past history of an adverse vaccine reaction in a special immunisation service. Archives of Disease in Childhood.
154 Goldschmidt I, Pfister ED, Becker M, et al. (2011). Acceptance and adverse events of the 2009 H1N1 vaccination in immunosuppressed pediatric liver transplant recipients. Journal of Pediatrics.
155 Goldstone SE, Vuocolo S. (2012). A prophylactic quadrivalent vaccine for the prevention of infection and disease related to HPV-6, -11, -16 and -18. Expert Review of Vaccines.
156 Goveia MG, Ciarlet M, Owen KE, et al. (2011). Development, clinical evaluation, and post-licensure impact of RotaTeq, a pentavalent rotavirus vaccine. Annals of the New York Academy of Sciences.
157 Goveia MG, Suprun L, Itzler RF, et al. (2010). Efficacy and safety of pentavalent human-bovine reassortant rotavirus vaccine when administered with greater than 10 weeks between doses. Pediatric Infectious Disease Journal.
158 Graves PM. (2000). Hemophilus vaccine and diabetes. Diabetes Care.
159 Gray J. (2011). Rotavirus vaccines: safety, efficacy and public health impact. Journal of Internal Medicine.
160 Greenberg DP. (2001). Considerations for hepatitis B as part of a combination vaccine. Pediatric Infectious Disease Journal.
161 Greenberg HB. (2011). Rotavirus vaccination and intussusception--act two. New England Journal of Medicine.
162 Griffiths UK, Clark A, Gessner B, et al. (2012). Dose-specific efficacy of Haemophilus influenzae type b conjugate vaccines: A systematic review and meta- Analysis of controlled clinical trials. Epidemiology and Infection.
163 Gruber C, Nilsson L, Bjorksten B. (2001). Do early childhood immunizations influence the development of atopy and do they cause allergic reactions?. Pediatric Allergy and Immunology.
164 Gruber WC, Scott DA, Emini EA. (2012). Development and clinical evaluation of Prevnar 13, a 13-valent pneumocococcal CRM(197) conjugate vaccine. Annals of the New York Academy of Sciences.
165 Guidozzi F. (2008). The HPV vaccine - What the family practitioner needs to know. South African Family Practice.
166 Haber P, DeStefano F, Angulo FJ, et al. (2004). Guillain-Barre syndrome following influenza vaccination. JAMA.
167 Halsey NA, Chesney PJ, Gerber MA, et al. (1997). Poliomyelitis prevention: Recommendations for use of inactivated poliovirus vaccine and live oral poliovirus vaccine. Pediatrics.
168 Heaton PM, Ciarlet M. (2007). Vaccines: the pentavalent rotavirus vaccine: discovery to licensure and beyond. Clinical Infectious Diseases.
169 Heijstek MW, Ott De Bruin LM, Bijl M, et al. (2011). EULAR recommendations for vaccination in paediatric patients with rheumatic diseases. Annals of the Rheumatic Diseases.
170 Heijstek MW, Ott de Bruin LM, Borrow R, et al. (2011). Vaccination in paediatric patients with auto-immune rheumatic diseases: a systemic literature review for the European League against Rheumatism evidence-based recommendations. Autoimmunity Reviews.
171 Heininger U. (2008). Pertussis immunisation in adolescents and adults. Advances in Experimental Medicine and Biology.
172 Heyse JF, Kuter BJ, Dallas MJ, et al. (2008). Evaluating the safety of a rotavirus vaccine: the REST of the story. Clinical Trials.
173 Huang DB, Wu JJ, Tyring SK. (2004). A review of licensed viral vaccines, some of their safety concerns, and the advances in the development of investigational viral vaccines. Journal of Infection.
174 Huang WT, Chang S, Miller ER, et al. (2010). Safety assessment of recalled Haemophilus influenzae type b (Hib) conjugate vaccines--United States, 2007-2008. Pharmacoepidemiology & Drug Safety.
175 Hussain H, Omer SB, Manganello JA, et al. (2011). Immunization safety in US print media, 1995-2005. Pediatrics.
176 IOM. (2001). Immunization safety review: influenza vaccines and neurological complications.
177 Iskander J, Broder K. (2008). Monitoring the safety of annual and pandemic influenza vaccines: lessons from the US experience. Expert Review of Vaccines.
178 Iskander JK, Gidudu J, Arboleda N, et al. (2008). Selected major issues in vaccine safety. Annales Nestle.
179 Izurieta HS, Haber P, Wise RP, et al. (2005). Adverse events reported following live, cold-adapted, intranasal influenza vaccine. JAMA.
180 Jacobson RM. (2003). Vaccine safety. Immunology and Allergy Clinics of North America.
181 Jamieson DJ, Rasmussen SA. (2012). The safety of adjuvants in influenza vaccines during pregnancy: what do we know and why do we need them?. American Journal of Obstetrics & Gynecology.
182 Jefferies JMC, Macdonald E, Faust SN, et al. (2011). 13-valent pneumococcal conjugate vaccine (PCV13). Human Vaccines.
183 Jefferson T, Di Pietrantonj C, Al-Ansary LA, et al. (2010). Vaccines for preventing influenza in the elderly. Cochrane Database of Systematic Reviews.
184 Jefferson T, Di Pietrantonj C, Rivetti A, et al. (2010). Vaccines for preventing influenza in healthy adults. Cochrane Database of Systematic Reviews.
185 Jefferson T, Price D, Demicheli V, et al. (2003). Unintended events following immunization with MMR: a systematic review. Vaccine.
186 Jefferson T, Rivetti A, Di Pietrantonj C, et al. (2012). Vaccines for preventing influenza in healthy children. Cochrane Database of Systematic Reviews.
187 Jeffery DR. (2002). The use of vaccinations in patients with multiple sclerosis. Infections in Medicine.
188 Jick H, Kaye JA. (2003). Epidemiology and Possible Causes of Autism. Pharmacotherapy.
189 Joura EA, Garland SM, Paavonen J, et al. (2012). Effect of the human papillomavirus (HPV) quadrivalent vaccine in a subgroup of women with cervical and vulvar disease: Retrospective pooled analysis of trial data. BMJ.
190 Kaczorowski J. (2010). Pneumococcal vaccination and cardiovascular events in men. JAMA.
191 Kanesa-thasan N, Shaw A, Stoddard JJ, et al. (2011). Ensuring the optimal safety of licensed vaccines: A perspective of the vaccine research, development, and manufacturing companies. Pediatrics.
192 Kaplan SL. (1990). Haemophilus influenzae type B conjugate vaccines. Pediatr Ann.
193 Karande S, Gogtay NJ, Kshirsagar NA. (2003). Efficacy and safety of vaccines in Indian children: A review. Paediatric and Perinatal Drug Therapy.
194 Kaye JA, del Mar Melero-Montes M, Jick H. (2001). Mumps, measles, and rubella vaccine and the incidence of autism recorded by general practitioners: a time trend analysis. BMJ.
195 Keating GM, Noble S, Averhoff FM, et al. (2003). Recombinant hepatitis B vaccine (Engerix-B(registered trademark)): A review of its immunogenicity and protective efficacy against hepatitis B. Drugs.
196 Kennedy RC, Byers VS, Marchalonis JJ. (2004). Measles virus infection and vaccination: Potential role in chronic illness and associated adverse events. Critical Reviews in Immunology.
197 Khromava A, Cohen CJ, Mazur M, et al. (2012). Manufacturers' postmarketing safety surveillance of influenza vaccine exposure in pregnancy. American Journal of Obstetrics and Gynecology.
198 Kohl KS, Marcy SM, Blum M, et al. (2004). Fever after immunization: Current concepts and improved future scientific understanding. Clinical Infectious Diseases.
199 Koppen S, de Groot R, Neijens HJ, et al. (2004). No epidemiological evidence for infant vaccinations to cause allergic disease. Vaccine.
200 Kuo AM, Brown JN, Clinard V. (2012). Effect of influenza vaccination on international normalized ratio during chronic warfarin therapy. Journal of Clinical Pharmacy and Therapeutics.
201 Kwok R. (2011). Vaccines: The real issues in vaccine safety. Nature.
202 Labrie JE, Keiser PB. (2010). Whole cell vaccination for meningococcus: Lessons from an idea for which time has gone. Human Vaccines.
203 Lacroix I, Damase-Michel C, Kreft-Jais C, et al. (2011). 2009 H1N1 influenza vaccines in pregnant women: the French Pharmacovigilance survey. Vaccine.
204 Lapphra K, Scheifele DW. (2011). Can children with minor illnesses be safely immunized?. Paediatrics and Child Health.
205 LaRussa PS, Edwards KM, Dekker CL, et al. (2011). Understanding the role of human variation in vaccine adverse events: The clinical immunization safety assessment network. Pediatrics.
206 Lavelle EC, O'Hagan DT. (2006). Delivery systems and adjuvants for oral vaccines. Expert Opinion on Drug Delivery.
207 Lepage P, Vergison A. (2007). Prevention of childhood rotavirus disease through the use of Rotarix and RotaTeq vaccines. Expert Opinion on Biological Therapy.
208 Lepage P, Vergison A. (2012). Impact of rotavirus vaccines on rotavirus disease. Expert Review of Anti-Infective Therapy.
209 Lepow ML. (1991). Pediatric immunizations and adverse events. Current Opinion in Infectious Diseases.
210 Levavi H. (2010). Human papillomavirus vaccination - To adolescents. Pediatric Endocrinology Reviews.
211 Lieu TA, Nguyen MD, Ball R, et al. (2012). Health outcomes of interest for evaluation in the Post-Licensure Rapid Immunization Safety Monitoring Program. Vaccine.
212 Lindblad EB. (2004). Aluminium adjuvants - In retrospect and prospect. Vaccine.
213 Linhares AC, Villa LL. (2006). Vaccines against rotavirus and human papillomavirus (HPV). Jornal de Pediatria.
214 Livengood JR, Mullen JR, White JW, et al. (1989). Family history of convulsions and use of pertussis vaccine. Journal of Pediatrics.
215 Lloyd JC, Haber P, Mootrey GT, et al. (2003). Adverse event reporting rates following tetanus-diphtheria and tetanus toxoid vaccinations: data from the Vaccine Adverse Event Reporting System (VAERS), 1991-1997. Vaccine.
216 Loebermann M, Winkelmann A, Hartung HP, et al. (2012). Vaccination against infection in patients with multiple sclerosis. Nature Reviews Neurology.
217 Lu B, Kumar A, Castellsague X, et al. (2011). Efficacy and safety of prophylactic vaccines against cervical HPV infection and diseases among women: a systematic review & meta-analysis. BMC Infectious Diseases.
218 Lucero MG, Dulalia VE, Nillos LT, et al. (2009). Pneumococcal conjugate vaccines for preventing vaccine-type invasive pneumococcal disease and X-ray defined pneumonia in children less than two years of age. Cochrane Database of Systematic Reviews.
219 MacDonald NE, Riley LE, Steinhoff MC. (2009). Influenza immunization in pregnancy. Obstet Gynecol.
220 Madaan A, Maddox DE. (2003). Vaccine allergy: Diagnosis and management. Immunology and Allergy Clinics of North America.
221 Mak TK, Mangtani P, Leese J, et al. (2008). Influenza vaccination in pregnancy: current evidence and selected national policies. Lancet Infect Dis.
222 Makris MC, Polyzos KA, Mavros MN, et al. (2012). Safety of Hepatitis B, Pneumococcal Polysaccharide and Meningococcal Polysaccharide Vaccines in Pregnancy A Systematic Review. Drug Safety.
223 Manzoli L, De Vito C, Salanti G, et al. (2011). Meta-analysis of the immunogenicity and tolerability of pandemic influenza A 2009 (H1N1) vaccines. PLoS ONE.
224 Manzoli L, Ioannidis JPA, Flacco ME, et al. (2012). Effectiveness and harms of seasonal and pandemic influenza vaccines in children, adults and elderly: A critical review and re-analysis of 15 meta-analyses. Human Vaccines and Immunotherapeutics.
225 Marin M, Broder KR, Temte JL, et al. (2010). Use of combination measles, mumps, rubella, and varicella vaccine: recommendations of the Advisory Committee on Immunization Practices (ACIP). Morbidity & Mortality Weekly Report Recommendations & Reports.
226 Marshall GS. (2009). Rotavirus disease and prevention through vaccination. Pediatric Infectious Disease Journal.
227 Marshall GS, Gellin BG. (2001). Challenges to vaccine safety. Primary Care - Clinics in Office Practice.
228 Marshall V, Gruber M. (2012). Influenza immunization during pregnancy: US regulatory perspective. American Journal of Obstetrics & Gynecology.
229 Martin BL, Nelson MR, Hershey JN, et al. (2003). Adverse reactions to vaccines. Clinical Reviews in Allergy and Immunology.
230 Mary Healy C. (2012). Vaccines in pregnant women and research initiatives. Clinical Obstetrics and Gynecology.
231 Mathew JL, El Dib R, Mathew PJ, et al. (2008). Hepatitis B immunisation in persons not previously exposed to hepatitis B or with unknown exposure status. Cochrane Database of Systematic Reviews.
232 Matson DO. (2006). The pentavalent rotavirus vaccine, RotaTeq. Seminars in Pediatric Infectious Diseases.
233 McCormack PL, Keam SJ. (2009). Rotavirus vaccine RIX4414 (Rotarix): a review of its use in the prevention of rotavirus gastroenteritis. Paediatric Drugs.
234 McIntyre P. (1994). Vaccines against invasive Haemophilus influenzae type b disease. Journal of Paediatrics and Child Health.
235 McKeage K, Romanowski B. (2011). AS04-adjuvanted human papillomavirus (HPV) types 16 and 18 vaccine (Cervarix((registered trademark))): A review of its use in the prevention of premalignant cervical lesions and cervical cancer causally related to certain oncogenic HPV types. Drugs.
236 McMahon AW, Iskander JK, Haber P, et al. (2008). Inactivated influenza vaccine (IIV) in children <2 years of age: examination of selected adverse events reported to the Vaccine Adverse Event Reporting System (VAERS) after thimerosal-free or thimerosal-containing vaccine. Vaccine.
237 McPhillips H, Marcuse EK. (2001). Vaccine safety. Current Problems in Pediatrics.
238 McVernon J, Nolan T. (2011). Panvax(registered trademark): A monovalent inactivated unadjuvanted vaccine against pandemic influenza A (H1N1) 2009. Expert Review of Vaccines.
239 Merchant N, Waldrop J. (2012). The safety advantages of pentavalent vaccines. Nurse Practitioner.
240 Michiels B, Govaerts F, Remmen R, et al. (2011). A systematic review of the evidence on the effectiveness and risks of inactivated influenza vaccines in different target groups. Vaccine.
241 Miravalle A, Biller J, Schnitzler E, et al. (2010). Neurological complications following vaccinations. Neurological Research.
242 Mirzayeva R, Steele AD, Parashar UD, et al. (2009). Evaluation of rotavirus vaccines in Asia-Are there lessons to be learnt?. Vaccine.
243 Molinaro GA, Lee DA. (2006). Rotavirus vaccines [1]. New England Journal of Medicine.
244 Monsonego J, Cortes J, Greppe C, et al. (2010). Benefits of vaccinating young adult women with a prophylactic quadrivalent human papillomavirus (types 6, 11, 16 and 18) vaccine. Vaccine.
245 Mooi FR, de Greeff SC. (2007). The case for maternal vaccination against pertussis. Lancet Infectious Diseases.
246 Moore MR, O'Brien K, Nuorti JP, et al. (2007). Pitfalls in case-control studies of vaccine effectiveness. Clinical Infectious Diseases.
247 Moore RA, Wiffen PJ, Lipsky BA. (2000). Are the pneumococcal polysaccharide vaccines effective? Meta-analysis of the prospective trials. BMC Family Practice.
248 Moro PL, Tepper NK, Grohskopf LA, et al. (2012). Safety of seasonal influenza and influenza A (H1N1) 2009 monovalent vaccines in pregnancy. Expert Review of Vaccines.
249 Mu XD. (2011). Safety and effectiveness of a 2009 H1N1 vaccine in Beijing [2]. New England Journal of Medicine.
250 Muehlhans S, Richard G, Ali M, et al. (2012). Safety reporting in developing country vaccine clinical trials-A systematic review. Vaccine.
251 Muhammad RD, Haber P, Broder KR, et al. (2011). Adverse events following trivalent inactivated influenza vaccination in children: Analysis of the vaccine adverse event reporting system. Pediatric Infectious Disease Journal.
252 Munoz FM. (2007). Vaccination during pregnancy. Women's Health.
253 Munoz FM. (2012). Safety of influenza vaccines in pregnant women. American Journal of Obstetrics and Gynecology.
254 Munoz FM, Englund JA. (2001). Vaccines in pregnancy. Infectious Disease Clinics of North America.
255 Murphy TV, Smith PJ, Gargiullo PM, et al. (2003). The first rotavirus vaccine and intussusception: epidemiological studies and policy decisions. Journal of Infectious Diseases.
256 Murray D, Jackson C. (2002). A conjugate vaccine for the prevention of pediatric pneumococcal disease. Military Medicine.
257 Nokleby H. (2007). Neurological adverse events of immunization: Experience with an aluminum adjuvanted meningococcal B outer membrane vesicle vaccine. Expert Review of Vaccines.
258 Noorbakhsh F, Johnson RT, Emery D, et al. (2008). Acute Disseminated Encephalomyelitis: Clinical and Pathogenesis Features. Neurologic Clinics.
259 Nor Aripin KNB, Choonara I, Sammons HM. (2012). Systematic review of safety in paediatric drug trials published in 2007. European Journal of Clinical Pharmacology.
260 Nunes MC, Madhi SA. (2011). Review on the immunogenicity and safety of PCV-13 in infants and toddlers. Expert Review of Vaccines.
261 Nunes MC, Madhi SA. (2012). Safety, immunogenicity and efficacy of pneumococcal conjugate vaccine in HIV-infected individuals. Human Vaccines & Immunotherapeutics.
262 Obaro SK. (2002). The new pneumococcal vaccine. Clinical Microbiology and Infection.
263 Obaro SK, Pugatch D, Luzuriaga K. (2004). Immunogenicity and efficacy of childhood vaccines in HIV-1-infected children. Lancet Infectious Diseases.
264 Obonyo CO, Lau J. (2006). Efficacy of Haemophilus influenzae type b vaccination of children: a meta-analysis. European Journal of Clinical Microbiology & Infectious Diseases.
265 Offit PA, Jew RK. (2003). Addressing Parents' Concerns: Do Vaccines Contain Harmful Preservatives, Adjuvants, Additives, or Residuals?. Pediatrics.
266 O'Hagan DT, Rappuoli R. (2004). The safety of vaccines. Drug Discovery Today.
267 Omer SB. (2012). Safety of quadrivalent human papillomavirus vaccine. Journal of Internal Medicine.
268 Oosterhuis-Kafeja F, Beutels P, Van Damme P. (2007). Immunogenicity, efficacy, safety and effectiveness of pneumococcal conjugate vaccines (1998-2006). Vaccine.
269 Orbach H, Agmon-Levin N, Zandman-Goddard G. (2010). Vaccines and autoimmune diseases of the adult. Discovery Medicine.
270 Orbach H, Tanay A. (2009). Vaccines as a trigger for myopathies. Lupus.
271 Ornoy A, Tenenbaum A. (2006). Pregnancy outcome following infections by coxsackie, echo, measles, mumps, hepatitis, polio and encephalitis viruses. Reproductive Toxicology.
272 Ortqvist A, Blennow M, Carlsson RM, et al. (2010). Vaccination of children - A systematic review. Acta Paediatrica, International Journal of Paediatrics.
273 O'Ryan M. (2007). Rotarix (RIX4414): an oral human rotavirus vaccine. Expert Review of Vaccines.
274 Pai VB, Heyneman CA, Erramouspe J. (2002). Conjugated heptavalent pneumococcal vaccine. Annals of Pharmacotherapy.
275 Pancharoen C, Ananworanich J, Thisyakorn U. (2004). Immunization for persons infected with human immunodeficiency virus. Current HIV Research.
276 Papaevangelou V, Spyridis N. (2012). MenACWY-TT vaccine for active immunization against invasive meningococcal disease. Expert Review of Vaccines.
277 Patel MM, Haber P, Baggs J, et al. (2009). Intussusception and rotavirus vaccination: a review of the available evidence. Expert Review of Vaccines.
278 Pavia M, Bianco A, Nobile CGA, et al. (2009). Efficacy of Pneumococcal Vaccination in Children Younger Than 24 Months: A Meta-Analysis. Pediatrics.
279 Peter G, Myers MG, National Vaccine Advisory C, et al. (2002). Intussusception, rotavirus, and oral vaccines: summary of a workshop. Pediatrics.
280 Phua KB, Quak SH, Emmanuel S, et al. (2006). A short report on highlights of worldwide development of RIX4414: A Singaporean experience. Vaccine.
281 Pichichero ME, Casey JR. (2005). Acellular pertussis vaccines for adolescents. Pediatric Infectious Disease Journal.
282 Plosker GL. (2011). Rotavirus vaccine RIX4414 (Rotarix(trademark)): A pharmacoeconomic review of its use in the prevention of rotavirus gastroenteritis in developing countries. PharmacoEconomics.
283 Plosker GL. (2011). Rotavirus vaccine RIX4414 (Rotarix(trademark)): A pharmacoeconomic review of its use in the prevention of rotavirus gastroenteritis in developed countries. PharmacoEconomics.
284 Plotkin SA. (2001). Lessons learned concerning vaccine safety. Vaccine.
285 Pomfret TC, Gagnon Jr JM, Gilchrist AT. (2011). Quadrivalent human papillomavirus (HPV) vaccine: A review of safety, efficacy, and pharmacoeconomics. Journal of Clinical Pharmacy and Therapeutics.
286 Poorolajal J, Mahmoodi M, Haghdoost A, et al. (2010). Booster dose vaccination for preventing hepatitis B. Cochrane Database of Systematic Reviews.
287 Principi N, Esposito S. (2012). Use of the 13-valent pneumococcal conjugate vaccine in infants and young children. Expert Opinion on Biological Therapy.
288 Rasmussen SA. (2012). Human teratogens update 2011: Can we ensure safety during pregnancy?. Birth Defects Research Part a-Clinical and Molecular Teratology.
289 Rath B, Linder T, Cornblath D, et al. (2007). “All that palsies is not Bell's [1]”-The need to define Bell's palsy as an adverse event following immunization. Vaccine.
290 Ridgway D, Wolff LJ. (1993). Active immunization of children with leukemia and other malignancies. Leukemia & Lymphoma.
291 Rightmier E, Stevens V, Brown J. (2011). Streptococcus pneumoniae vaccination in older adults. American Journal of Geriatric Pharmacotherapy.
292 Rimland B, McGinnis W. (2002). Vaccines and autism. Laboratory Medicine.
293 Rivas P, Herrero MD, Puente S, et al. (2007). Immunizations in HIV-infected adults. AIDS Reviews.
294 Rivetti D, Jefferson T, Thomas R, et al. (2006). Vaccines for preventing influenza in the elderly. Cochrane Database of Systematic Reviews.
295 Rose M, Zielen S. (2009). Impact of infant immunization programs with pneumococcal conjugate vaccine in Europe. Expert Review of Vaccines.
296 Rosenberg M, Sparks R, McMahon A, et al. (2009). Serious adverse events rarely reported after trivalent inactivated influenza vaccine (TIV) in children 6-23 months of age. Vaccine.
297 Royle J. (2003). Meningococcal vaccines. Medicine Today.
298 Rubinstein E. (2004). Vaccination and autoimmune diseases: The argument against. Israel Medical Association Journal.
299 Ruiz LP. (2006). Rotavirus vaccines. New England Journal of Medicine.
300 Rutschmann OT, McCrory DC, Matchar DB, et al. (2002). Immunization and MS: A summary of published evidence and recommendations. Neurology.
301 Salemi S, D'Amelio R. (2010). Are anti-infectious vaccinations safe and effective in patients with autoimmunity. International Reviews of Immunology.
302 Salemi S, D'Amelio R. (2010). Vaccinations and autoimmune diseases. International Reviews of Immunology.
303 Sangkomkamhang US, Lumbiganon P, Laopaiboon M. (2011). Hepatitis B vaccination during pregnancy for preventing infant infection. Cochrane Database of Systematic Reviews.
304 Satterwhite TK. (1981). Use of the pneumococcal vaccine. American Family Physician.
305 Scott LJ. (2010). Tdap(5) vaccine (Covaxis(registered trademark)): A review of its use as a single-booster immunization for the prevention of tetanus, diphtheria, and pertussis in children (Aged (greater-than or equal to)4 Years), adolescents, and adults. Biodrugs.
306 Scott P, Moss WJ, Gilani Z, et al. (2011). Measles vaccination in HIV-infected children: systematic review and meta-analysis of safety and immunogenicity. Journal of Infectious Diseases.
307 Shobha V. (2012). Common anti-infective prophylaxis and vaccinations in autoimmune inflammatory rheumatic diseases. Indian Journal of Rheumatology.
308 Shreffler WG. (2005). A synthetic conjugate polysaccharide vaccine against Haemophilus influenzae type b. Pediatrics.
309 Simonsen L, Viboud C, Taylor RJ, et al. (2009). Influenza vaccination and mortality benefits: new insights, new opportunities. Vaccine.
310 Skowronski DM, De Serres G. (2009). Is routine influenza immunization warranted in early pregnancy?. Vaccine.
311 Small TN, Cowan MJ. (2011). Immunization of hematopoietic stem cell transplant recipients against vaccine-preventable diseases. Expert Review of Clinical Immunology.
312 Smith DH, Madore DV, Eby RJ, et al. (1989). Haemophilus b oligosaccharide-CRM197 and other Haemophilus b conjugate vaccines: a status report. Advances in Experimental Medicine & Biology.
313 Smith-McCune K. (2010). Quadrivalent HPV vaccine administered to women who became pregnant during trials did not appear to adversely affect pregnancy outcome; however, use during pregnancy is not recommended. Evidence-Based Medicine.
314 Soares-Weiser K, Maclehose H, Bergman H, et al. (2012). Vaccines for preventing rotavirus diarrhoea: vaccines in use. Cochrane Database of Systematic Reviews.
315 Sonneville R, Klein I, de Broucker T, et al. (2009). Post-infectious encephalitis in adults: Diagnosis and management. Journal of Infection.
316 Souayah N, Nasar A, Suri MFK, et al. (2007). Guillain-Barre syndrome after vaccination in United States. A report from the CDC/FDA Vaccine Adverse Event Reporting System. Vaccine.
317 Srivastava VK, Laisram N, Srivastava RK. (1989). Immunization status in paralytic poliomyelitis--a hospital based study. Indian Pediatrics.
318 Stephenson J. (2000). Vaccines pose no diabetes, bowel disease risk. Journal of the American Medical Association.
319 Sucher AJ, Chahine EB, Nelson M, et al. (2011). Prevnar 13, the new 13-valent pneumococcal conjugate vaccine. Annals of Pharmacotherapy.
320 Tai JH, Curns AT, Parashar UD, et al. (2006). Rotavirus vaccination and intussusception: can we decrease temporally associated background cases of intussusception by restricting the vaccination schedule?. Pediatrics.
321 Tamma PD, Ault KA, del Rio C, et al. (2009). Safety of influenza vaccination during pregnancy. Am J Obstet Gynecol.
322 Tapiainen T, Heininger U. (2005). Fever following immunization. Expert Review of Vaccines.
323 Thjodleifsson B, Davidsdottir K, Agnarsson U, et al. (2002). Effect of Pentavac and measles-mumps-rubella (MMR) vaccination on the intestine. Gut.
324 Toback SL, Beigi R, Tennis P, et al. (2012). Maternal outcomes among pregnant women receiving live attenuated influenza vaccine. Influenza & Other Respiratory Viruses.
325 Tom-Revzon C. (2007). Rotavirus live, oral, pentavalent vaccine. Clinical Therapeutics.
326 Tozzi AE. (2004). Field evaluation of vaccine safety. Vaccine.
327 Tsai TF. (2011). MF59((registered trademark)) adjuvanted seasonal and pandemic influenza vaccines. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan.
328 Van Assen S, Agmon-Levin N, Elkayam O, et al. (2011). EULAR recommendations for vaccination in adult patients with autoimmune inflammatory rheumatic diseases. Annals of the Rheumatic Diseases.
329 Van Assen S, Elkayam O, Agmon-Levin N, et al. (2011). Vaccination in adult patients with auto-immune inflammatory rheumatic diseases: A systematic literature review for the European League Against Rheumatism evidence-based recommendations for vaccination in adult patients with auto-immune inflammatory rheumatic diseases. Autoimmunity Reviews.
330 Van Der Meeren O, Kuriyakose S, Kolhe D, et al. (2012). Immunogenicity of Infanrix(trademark) hexa administered at 3, 5 and 11 months of age. Vaccine.
331 Vesikari T. (2012). Rotavirus vaccination: A concise review. Clinical Microbiology and Infection.
332 Vesikari T, Giaquinto C, Huppertz HI. (2006). Clinical trials of rotavirus vaccines in Europe. Pediatric Infectious Disease Journal.
333 Wandstrat TL, Kaplan-Machlis B, Temple ME, et al. (1999). Tetravalent rotavirus vaccine. Annals of Pharmacotherapy.
334 Watson W. (2000). Pneumococcal conjugate vaccines. Pediatric Infectious Disease Journal.
335 Weaver BA. (2006). Epidemiology and natural history of genital human papillomavirus infection. J Am Osteopath Assoc.
336 Weber DJ, Rutala WA. (2003). Immunization of immunocompromised persons. Immunology and Allergy Clinics of North America.
337 Weinberg GA, Granoff DM. (1988). Polysaccharide-protein conjugate vaccines for the prevention of Haemophilus influenzae type b disease. Journal of Pediatrics.
338 Weldeselassie YG, Whitaker HJ, Farrington CP. (2011). Use of the self-controlled case-series method in vaccine safety studies: Review and recommendations for best practice. Epidemiology and Infection.
339 Wharton M. (2010). Vaccine safety: Current systems and recent findings. Current Opinion in Pediatrics.
340 Wiedermann U, Kollaritsch H. (2006). Vaccines against traveler's diarrhoea and rotavirus disease - a review. Wiener Klinische Wochenschrift.
341 Wilson K, Mills E, Ross C, et al. (2003). Association of autistic spectrum disorder and the measles, mumps, and rubella vaccine: a systematic review of current epidemiological evidence. Arch Pediatr Adolesc Med.
342 Wilson ME. (2001). Travel-related vaccines. Infectious Disease Clinics of North America.
343 Woo EJ, Burwen DR, Gatumu SNM, et al. (2003). Extensive limb swelling after immunization: Reports to the Vaccine Adverse Event Reporting System. Clinical Infectious Diseases.
344 Yancey AM, Pitlick JM, Forinash AB. (2010). The prophylactic role for the human papillomavirus quadrivalent vaccine in males. Annals of Pharmacotherapy.
345 Yates L, Pierce M, Stephens S, et al. (2010). Influenza A/HINIv in pregnancy: An investigation of the characteristics and management of affected women and the relationship to pregnancy outcomes for mother and infant. Health Technology Assessment.
346 Yeh SH. (2005). PEDIARIX: clinical trials. Expert Review of Vaccines.
347 Yih WK, Kulldorff M, Fireman BH, et al. (2011). Active surveillance for adverse events: The experience of the vaccine safety datalink project. Pediatrics.
348 Yin JK, Khandaker G, Rashid H, et al. (2011). Immunogenicity and safety of pandemic influenza A (H1N1) 2009 vaccine: systematic review and meta-analysis. Influenza & Other Respiratory Viruses.
349 Young F, Marra F. (2011). A systematic review of intradermal influenza vaccines. Vaccine.
350 Zareba G. (2006). A new combination vaccine for measles, mumps, rubella and varicella. Drugs of Today.
351 Zhang L, Prietsch SOM, Axelsson I, et al. (2012). Acellular vaccines for preventing whooping cough in children. Cochrane Database of Systematic Reviews.
352 Zimmerman RK, Middleton DB, Burns IT, et al. (2003). Routine vaccines across the life span, 2003. Journal of Family Practice.
353 Zuccotti GV. (2010). Safety of a virosomal adjuvanted influenza vaccine in children suffering from chronic disease. Open Vaccine Journal.

## Mechanistic Studies – 39

1 (1999). Childhood immunizations and type 1 diabetes: summary of an Institute for Vaccine Safety Workshop The Institute for Vaccine Safety Diabetes Workshop Panel. Pediatr Infect Dis J.
2 Agmon-Levin N, Paz Z, Israeli E, et al. (2009). Vaccines and autoimmunity. Nature Reviews Rheumatology.
3 Aguilar JC, Rodriguez EG. (2007). Vaccine adjuvants revisited. Vaccine.
4 Ahmed SS, Plotkin SA, Black S, et al. (2011). Assessing the safety of adjuvanted vaccines. Science Translational Medicine.
5 Anhoury ML, Arickx M, Boon B, et al. (1979). Analysis of a bivalent meningococcal vaccine (A + C). Part I. Analytical and safety data. Annales de la Societe Belge de Medecine Tropicale.
6 Annunziata P. (2012). Reply to: “Miller Fisher syndrome following vaccination”. Infection.
7 Aron-Maor A, Shoenfeld Y. (2001). Vaccination and systemic lupus erythematosus: the bidirectional dilemmas. Lupus.
8 Bines JE, Patel M, Parashar U. (2009). Assessment of postlicensure safety of rotavirus vaccines, with emphasis on intussusception. Journal of Infectious Diseases.
9 Blyth CC, Currie AJ, Wiertsema SP, et al. (2011). Trivalent influenza vaccine and febrile adverse events in Australia, 2010: clinical features and potential mechanisms. Vaccine.
10 Chen RT, Pless R, Destefano F. (2001). Epidemiology of autoimmune reactions induced by vaccination. Journal of Autoimmunity.
11 Christian LM, Iams JD, Porter K, et al. (2011). Inflammatory responses to trivalent influenza virus vaccine among pregnant women. Vaccine.
12 Clarke JB. (2010). Mechanisms of adverse drug reactions to biologics. Handbook of Experimental Pharmacology.
13 Cojocaru M, Cojocaru IM, Radu-Popescu MA, et al. (2010). The relationship between vaccination and the development of autoimmune diseases. Farmacia.
14 Flanagan KL, Klein SL, Skakkebaek NE, et al. (2011). Sex differences in the vaccine-specific and non-targeted effects of vaccines. Vaccine.
15 Higashi HG, Luna E, Precioso AR, et al. (2009). Acellular and “low” pertussis vaccines: Adverse events and the role of mutations. Revista Do Instituto De Medicina Tropical De Sao Paulo.
16 Hilleman MR. (2003). Critical overview and outlook: Pathogenesis, prevention, and treatment of hepatitis and hepatocarcinoma caused by hepatitis B virus. Vaccine.
17 Huynh W, Cordato DJ, Kehdi E, et al. (2008). Post-vaccination encephalomyelitis: literature review and illustrative case. Journal of Clinical Neuroscience.
18 Israeli E, Agmon-Levin N, Blank M, et al. (2012). Guillain-Barre Syndrome-A Classical Autoimmune Disease Triggered by Infection or Vaccination. Clinical Reviews in Allergy & Immunology.
19 Kapetanovic MC, Roseman C, Jonsson G, et al. (2011). Antibody response is reduced following vaccination with 7-valent conjugate pneumococcal vaccine in adult methotrexate-treated patients with established arthritis, but not those treated with tumor necrosis factor inhibitors. Arthritis and Rheumatism.
20 Klein SL, Jedlicka A, Pekosz A. (2010). The Xs and Y of immune responses to viral vaccines. The Lancet Infectious Diseases.
21 Koenig HC, Sutherland A, Izurieta HS, et al. (2011). Application of the immunological disease continuum to study autoimmune and other inflammatory events after vaccination. Vaccine.
22 Lynch M, Shieh WJ, Bresee JS, et al. (2006). Intussusception after administration of the rhesus tetravalent rotavirus vaccine (Rotashield): the search for a pathogenic mechanism. Pediatrics.
23 Midthun K, Halsey NA, Jett-Goheen M, et al. (1991). Safety and immunogenicity of human rotavirus vaccine strain M37 in adults, children, and infants. Journal of Infectious Diseases.
24 Mrozek-Budzyn D, Kieltyka A, Majewska R. (2010). Lack of association between measles-mumps-rubella vaccination and autism in children: a case-control study. Pediatr Infect Dis J.
25 Murphy BR, Morens DM, Simonsen L, et al. (2003). Reappraisal of the association of intussusception with the licensed live rotavirus vaccine challenges initial conclusions. Journal of Infectious Diseases.
26 Neville B. (2010). Dravet syndrome and ‘immunization encephalopathy’. Developmental Medicine & Child Neurology.
27 Perdan-Pirkmajer K, Thallinger GG, Snoj N, et al. (2012). Autoimmune response following influenza vaccination in patients with autoimmune inflammatory rheumatic disease. Lupus.
28 Richmand BJ. (2011). Hypothesis: Conjugate vaccines may predispose children to autism spectrum disorders. Medical Hypotheses.
29 Ronaghy A, de Jager W, Zonneveld-Huijssoon E, et al. (2011). Vaccination leads to an aberrant FOXP3 T-cell response in non-remitting juvenile idiopathic arthritis. Annals of the Rheumatic Diseases.
30 Rothman KJ, Young-Xu Y, Arellano F. (2006). Age dependence of the relation between reassortant rotavirus vaccine (RotaShield) and intussusception. Journal of Infectious Diseases.
31 Salemi S, D'Amelio R. (2010). Could autoimmunity be induced by vaccination?. International Reviews of Immunology.
32 Sejvar JJ. (2011). Vaccines and neurologic disease. Seminars in Neurology.
33 Shoenfeld Y, Agmon-Levin N. (2011). ‘ASIA’ - Autoimmune/inflammatory syndrome induced by adjuvants. Journal of Autoimmunity.
34 Siegrist CA. (2007). Mechanisms Underlying Adverse Reactions to Vaccines. Journal of Comparative Pathology.
35 Skowronski DM, Lu H, Warrington R, et al. (2003). Does antigen-specific cytokine response correlate with the experience of oculorespiratory syndrome after influenza vaccine?. J Infect Dis.
36 Stubgen JP. (2010). Neuromuscular disorders associated with Hepatitis B vaccination. Journal of the Neurological Sciences.
37 Tang YW, Li H, Wu H, et al. (2007). Host single-nucleotide polymorphisms and altered responses to inactivated influenza vaccine. J Infect Dis.
38 Toubi E. (2012). ASIA - autoimmune syndromes induced by adjuvants: Rare, but worth considering. Israel Medical Association Journal.
39 Vessal S, Kravis LP. (1976). Immunologic mechanisms responsible for adverse reactions to routine immunizations in children. Clinical Pediatrics.