# Appendix C Evidence Tables

Evidence Table 1 Postmarketing studies: Adults

Evidence Table 2 Vaccinated versus unvaccinated: Adults

Evidence Table 3 Postmarketing studies: Children-adolsecents

Evidence Table 4 Vaccinated versus unvaccinated: Children-adolescents

Evidence Table 5 Postmarketing studies: Mixed population

Evidence Table 6 Vaccinated versus unvaccinated: Mixed population

Evidence Table 7 Postmarketing studies: Pregnant women