# Appendix B Data Abstraction Tools

Title and Abstract Screening Form

Vaccine Safety Full-Text Inclusion Screening

Case Control, Self-Controlled Case Series, or Multivariate Risk Factor Analyses

Data Abstraction Form-Controlled Trials and Head-to-Head Cohort Comparisons