# Appendix A Literature Search Strategy

## Summary of Search Strategy – Vaccine Safety

Databases: MEDLINE (OVID), EMBASE, Web of Science, Cochrane SR, DARE, and CENTRAL to cover the existing clinical literature.

General approach: We combine search terms for the vaccine with general adverse event terms and specific adverse events.

We use generic vaccine terms as well as specific available vaccines. The list of specific adverse events for Influenza, Hib, Tetanus, Diphtheria, Pertussis, Varicella, Human Papillomavirus, Measles-Mumps-Rubella, Meningococcal, Hepatitis A, and Hepatitis B was based on the Institute of Medicine (IOM) 2011 report, Vaccine Adverse Event Reporting System (VAERS) data, and Food and Drug Administration (FDA) Mini-Sentinel data. The list of specific adverse events for Polio, Rotavirus, Zoster, and Pneumococcal (vaccines not covered by the IOM report) was based on VAERS, Mini-Sentinel, and HRSA information. General adverse event terms were used as a safeguard against missing new harms that have not yet been identified in existing summary reports.

We chose the search date of January, 2010 for the vaccines covered by the IOM report based on the IOM search date (August, 2010). For the remaining vaccines we searched without date restriction. Our search went through August 2013. Animal studies and editorials were excluded where possible. We combined Medical Subject Headings (MeSH) with free text terms in order to capture new publications not yet assigned controlled language in the electronic databases. The vaccine specific searches will de-duplicate within vaccines and across vaccines and combined in one master library. In addition, references of included studies, studies included in pertinent reviews and suggestions from clinical experts will be screened.

## Vaccine Safety – Search Methodologies

### LANGUAGE

English

### SEARCH STRATEGY

NOTE:

“/” =MESH heading

“exp”=exploded MESH heading

“mp”=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier

“$”= truncation/wild card

### MMR

measles mumps rubella vaccine/ or measles vaccine/ or (vaccination/ and measles/) or mumps vaccine/ or (vaccination/ and mumps/) or rubella vaccine/ or (vaccination/ and rubella/) or ((measles or mumps or rubella or mmr) adj5 (vaccin$ or immuniz$ or immunis$)).mp. or (“triviaten berna” or priorix or trimovax or virivac or pluserix or proquad or “mmr 1” or “mmr 2” or “mmr I” or “mmr II” or mmr1 or mmr2 or attenuvax or mumpsvax or meruvax).mp.

AND

safe$.mp. or safety/ or (harm$ or adverse or toxic or toxicity or toxicities).mp. or “side effect$”.mp. or death.mp. or mortality/ or anaphylaxis/ or anaphylactic shock/ or anaphyla$.mp. or exp arthralgia/ or exp arthritis/ or arthropathy, neurogenic.mp. or exp arthropathy/ or arthritis.mp. or arthralgia.mp. or arthropath$.mp. or autistic disorder/ or autism/ or infantile autism/ or asperger syndrome/ or rett syndrome/ or schizophrenia, childhood/ or child development disorders, pervasive/ or (childhood disintegrative disorder/ or pervasive development disorder.mp.) not otherwise specified/ or (autism or autistic or “pervasive development disorder$”).mp. or (rett syndrome or retts syndrome).mp. or (asperger syndrome or kanner syndrome or (child$ adj5 schizophrenia)).mp. or (pervasive child$ development$ disorder$ or disintegrative disorder$).mp. or exp ataxia/ or ataxi$.mp. or brachial plexus neuritis/ or brachial plexus neuritis.mp. or brachial neuritis.mp. or exp optic neuritis/ or optic neuritis.mp. or neuromyelitis optica.mp. or brachial neuralgia.mp. or amyotroph$ neuralgi$.mp. or (cervicobrachial neuralgi$ or cervico-brachial neuralgi$ or parsonage-turner syndrome or parsonage-aldren-turner syndrome or brachial neuritides or shoulder-girdle neuropath$).mp. or brachial plexus neuritides.mp. or chronic fatigue syndrome/ or fatigue syndrome, chronic/ or fatigue syndrome$.mp. or chronic fatigue.mp. or myalgic encephalomyelitis.mp. or fatigue disorder.mp. or (royal free disease or chronic remitting demyelinating disease$ or disseminated neuropathy).mp. or Chronic inflammatory demyelinating polyneuropathy/ or polyradiculoneuropathy, chronic inflammatory demyelinating/ or exp multiple sclerosis/ or (polyneuropath$ or polyradiculoneuropath$ or multiple sclerosis).mp. or exp complex regional pain syndromes/ or exp complex regional pain syndrome/ or (complex regional pain or causalgia or reflex sympathetic dystrophy).mp. or seizures/ or Seizures, febrile/ or convulsion/ or exp epilepsies, myoclonic/ or spasms, infantile/ or Myoclonus epilepsy/ or myoclonus seizure/ or myoclonus/ or convulsion$.ti,ab. or epileps$.mp. or (myoclon$ or spasm$ or convuls$ or seizure$).mp. or exp encephalitis/ or exp encephalitis, viral/ or exp brain disease/ or encephal$.ti,ab. or Encephalomyelitis.mp. or fibromylagia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. encephalopath$.mp. or brain inflammation. or Myofascial pain syndrome.mp. or frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. or (Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides).mp. or (shoulder impingement or subacromial impingement).mp. or exp hearing loss/ or (hearing adj2 loss).mp. or (deafness or hypoacusis or hypoacuses or hearing impairment).mp. or hepatitis/ or hepatitis.mp. or (Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes).mp. or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes).mp. or (iddm or brittle diabetes or autoimmune diabetes or ketosis-prone diabetes).mp. or (Meningitis or meningo$ or meningeal or arachnoiditis or meningitides or pachymeningitis).mp. or pachymeningitides.mp. or myelitis, transverse.mp. or transverse myelitis.mp. or encephalomyelitis, acute disseminated/ or demyelinating.mp. or exp guillain-barre syndrome/ or “fisher$ adj3 syndrome” or guillain barre.mp. or guillain-barre.mp. or myelitis.mp. or opsoclonus myoclonus syndrome/ or opsoclonus myoclonus syndrome.mp. or (dancing eyes dancing feet or opsoclonus myoclonus ataxia or kinsbourne syndrome).mp. or exp inflammatory bowel diseases/ or inflammatory bowel disease$.mp. or exp syncope/ or syncop$.mp. or (fainting or (vasovagal adj5 (collapse or attack or shock or reaction$)) or thrombocytopen$).mp. or ((viral or virus) and infection$ and (immunodeficien$ or immunocompromis$ or immunosuppress$)).mp. or (spontaneous abort$ or congenital abnormal$).mp. or abnormalities, congenital/ OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (tic OR tics).mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR arthritis, rheumatoid/ OR rheumatoid arthritis.mp. OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR crohn$ OR ulcerative colitis.mp. OR reiter$,mp. OR fibromyalgia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. or “myofascial pain syndrome”.mp. OR (uveitis or narcoleps$ or stillbirth or stillborn or still-born or “systemic allergic reaction” or “polyarteritis nodosa” or stroke or strokes or “cerebrovascular accident” or “cerebrovascular accidents” or vasculitis).mp. OR (“ankylosing spondylitis” or “polymyalgia rheumatica” or “sudden infant death”).mp. or sudden infant death/ or sids.mp. or “cot death”.mp. or “unexpected infant death”.mp. or “serum sickness”.mp.

NOT

editorials

### VARICELLA/ZOSTER

exp chickenpox vaccine/ or ((vaccines/ or vaccination/) and chickenpox/) or chickenpox vaccin$.mp. or varicella vaccin$.mp. or ((vaccin$ or immuniz$ or immunis$).mp. and ((chicken pox or chickenpox or varicella).mp. or exp herpes zoster/ or zoster.mp. or shingles.mp.)) or varivax.mp. or varcel.mp. or varzos.mp. or varilrix.mp. or zostavax.mp.

AND

Safe$.mp. or safety/ or (harm$ or adverse or toxic or toxicity or toxicities).mp. or “side effect$”.mp. or death.mp. or mortality/ OR (viral adj3 reactiv$).mp. or anaphylaxis/ or anaphylactic shock/ or anaphyla$.mp. or exp arthralgia/ or exp arthritis/ or arthropathy, neurogenic.mp. or exp arthropathy/ or arthritis.mp. or arthralgia.mp. or arthropath$.mp. or allergic OR allergy OR allergies {Including Related Terms} OR exp cerebellar ataxia/ or spinocerebellar ataxias/ or ataxia telangiectasia/ or machado-joseph disease/ or cerebellar ataxia$.mp. or cerebellar incoordination$.mp. or cerebellar dysmetria$.mp. or hypermetria$.mp. or adiadochokines$.mp. or cerebellar hemiataxia$.mp. or spinocerebellar ataxia$.mp. or spinocerebellar atrophy.mp. or ataxia telangiectasi$.mp. or machado-joseph.mp. or louis-bar syndrome.mp. or azorean disease.mp. OR exp myocardial infarction/ or exp stroke/ or exp death, sudden/ or cerebrovascular accident$.mp. or myocardial infarction$.mp. or heart attack$.mp. or stroke.mp. or sudden death.mp. or Seizures, febrile/ or convulsion/ or exp epilepsies, myoclonic/ or spasms, infantile/ or Myoclonus epilepsy/ or myoclonus seizure/ or myoclonus/ or convulsion$.ti,ab. or epileps$.mp. or spasm$.mp. or myoclon$.mp. or seizure$.mp. OR (((small fiber neuropath$ or oka vzv or oka varicella).mp. or ((varicella zoster virus.mp. or herpesvirus 3, human/) and (immunosuppres$ or immunocompromise$ or immunodeficien$).mp.) or disseminat$.mp.) adj3 oka.mp.) or exp brain disease/ or encephal$.mp. or encephalopath$.mp. or brain inflammation.mp. or brain disease$.mp. or brain disorder$.mp. or exp encephalitis/ or exp encephalitis, viral/ OR (small fiber neuropath$ or oka vzv or oka varicella).mp. OR (varicella zoster virus.mp. or herpesvirus 3, human/) and (immunosuppres$ or immunocompromise$ or immunodeficien$).mp. OR (disseminat$ adj3 oka).mp. or exp brain disease/ or encephal$.mp. or encephalopath$.mp. or brain inflammation.mp. or brain disease$.mp. or brain disorder$.mp. or exp encephalitis/ or exp encephalitis, viral/ OR (frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome/ or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. or (Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides).mp. or (shoulder impingement or subacromial impingement).mp. or varicella.mp.) adj3 hepatitis.mp. OR frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome/ or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. 16-(Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides or (shoulder impingement or subacromial impingement)).mp. OR (varicella adj3 hepatitis).mp. OR (Meningitis or meningo$ or meningeal or arachnoiditis or meningitides or pachymeningitis or pachymeningitides).mp. or exp guillain-barre syndrome/ or myelitis, transverse.mp. or transverse myelitis.mp. or encephalomyelitis, acute disseminated/ or acute disseminated encephalomyelitis OR demyelinating.mp. or guillain barre.mp. or guillain-barre.mp. or fisher syndrome.mp. or fishers syndrome.mp. OR herpesvirus 3.mp. OR (vz adj2 virus).mp. OR ((varicella zoster virus or hhv-3 or ocular herpes zoster virus or chickenpox virus or herpesvirus varicellae) and (immunocompromis$ or immunosuppre$ or immunodeficien$)).mp. OR exp pneumonia/ or pneumonia.mp. or lung inflammation.mp. or pulmonary inflammation.mp. OR exp syncope/ or syncop$.mp. or fainting OR (vasovagal adj5 (collapse or attack or shock or reaction$)).mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR exp thrombocytopenia/ or hemolytic-uremic syndrome/ or jacobsen distal 11q deletion syndrome/ or jacobsen distal 11q deletion.mp. or purpura, thrombocytopenic/ or thrombocytopenia, neonatal alloimmune/ or thrombocytopen$.mp. or thrombopen$.mp. OR (ramsey-hunt or ramsey hunt or (hunt adj3 syndrome)).mp. OR ((bell$ adj2 palsy) or hemolytic-uremic syndrome or (spontaneous abort$ or congenital abnormal$)).mp. or abnormalities, congenital/ OR (Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes).mp. or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes).mp. or (iddm or brittle diabetes or autoimmune diabetes or ketosis-prone diabetes).mp. OR (tic OR tics).mp. OR uveitis OR narcolep$.mp. OR rheumatoid arthritis.mp. OR live adj3 varicella.mp. OR (herpes zoster).mp. OR ataxia OR polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. or smallfiber neuropath$.mp. or small fiber neuropath$.mp. OR vasculitis.mp. OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR fibromyalgia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. or “myofascial pain syndrome”.mp. OR sudden infant death/ or sudden infant death$.mp. or sids.mp. or cot death.mp. or unexpected infant death.mp. OR serum sickness.mp.

NOT

Editorials

### INFLUENZA

influenza vaccines/ or (vaccination/ and influenza, human/) or flu vaccine.mp. or influenza vaccine$.mp. OR (((vaccin$ or immuniz$ or immunis$) and (influenza or flu or haemophilus b or haemophilus type b or haemophilus influenza$ type b or hib)) or afluria or agriflu or fluarix or flu-imune or flulaval or flumist or flushield or fluvirin or fluzone).mp.

AND

Safe$.mp. or safety/ or (harm$ or adverse or toxic or toxicity or toxicities).mp. or “side effect$”.mp. or death.mp. or mortality/ OR anaphylaxis/ or anaphylactic shock/ or anaphyla$.mp. or exp arthralgia/ or exp arthritis/ or arthropathy, neurogenic.mp. or exp arthropathy/ or arthritis.mp. or arthralgia.mp. or arthropath$.mp. OR (allergy or allergies or allergic).mp. OR asthma/ or status asthmaticus/ OR asthma$.mp. or (bell$ adj3 palsy).mp. or (facial adj3 paraly$).mp. or (facial adj3 neuropath$).mp. OR brachial plexus neuritis/ or brachial neuritis.mp. or brachial plexus neuritis.mp. or neuralgia.mp. or brachial plexus neuropath$.mp. or small fiber neuropath$.mp. OR exp myocardial infarction/ or exp stroke/ or exp death, sudden/ or cerebrovascular accident$.mp. or myocardial infarction$.mp. or heart attack$.mp. or stroke.mp. or sudden death.mp. OR Chronic inflammatory demyelinating polyneuropathy/ or polyradiculoneuropathy, chronic inflammatory demyelinating/ or exp multiple sclerosis/ or (polyneuropath$ or polyradiculoneuropath$ or multiple sclerosis).mp. OR neuromyelitis optica/ or chronic remitting demyelinating disease.mp. or disseminated neuropathy.mp. OR neuromyelitis optica or optic neuritis).mp. or exp complex regional pain syndromes/ or exp complex regional pain syndrome/ or (complex regional pain or causalgia or reflex sympathetic dystrophy).mp. or seizures/ OR Seizures, febrile/ or convulsion/ or exp epilepsies, myoclonic/ or spasms, infantile/ or Myoclonus epilepsy/ or myoclonus seizure/ or myoclonus/ or convulsion$.ti,ab. or epileps$.mp. OR (myoclon$ or spasm$ or convuls$ or seizure$).mp. or exp encephalitis/ or exp encephalitis, viral/ OR exp brain disease/ or encephal$.ti,ab. or encephalopath$.mp. or brain inflammation.mp. OR encephalomyelitis.mp. or fibromylagia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. OR Myofascial pain syndrome.mp. or frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome/ or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. or (Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides).mp. OR (shoulder impingement or subacromial impingement).mp. or exp guillain-barre syndrome/ or myelitis, transverse.mp. or transverse myelitis.mp. or encephalomyelitis, acute disseminated/ or demyelinating.mp. or guillain barre.mp. or guillain-barre.mp. or myelitis.mp. or fisher syndrome.mp. or fishers syndrome.mp. OR oculorespiratory syndrome$ or polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. or small fiberneuropath$.mp. or small fiber neuropath$.mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR exp syncope/ or syncop$.mp. or fainting.mp. or (vasovagal adj5 (collapse or attack or shock or reaction$)).mp. 23-vasculitis/ or vasculitis.mp. or vasculitides.mp. or angiitis.mp. or angiitides.mp. or aortitis.mp. or arteritis.mp. or phlebitis.mp. or behcet syndrome.mp. or wegener granulomatosis.mp. or thrombophlebitis.mp. or papulosis.mp. or sickle cell.mp. OR (spontaneous abort$ or congenital abnormal$).mp. or abnormalities, congenital/ or congenital defect$.mp. or stillbirth$.mp. or stillborn.mp. or sudden infant death/ or sudden infant death$.mp. or sids.mp. or cot death.mp. or unexpected infant death.mp. OR (Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes).mp. or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes).mp. or (iddm or brittle diabetes or autoimmune diabetes or ketosis-prone diabetes).mp. OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (Tic OR tics).mp. OR uveitis OR narcolep$.mp. OR rheumatoid arthritis.mp. OR birth adj3 defect$.mp. OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR eclampsia OR pre-eclampsia OR preeclampsia OR (preterm labor OR preterm labour).mp. OR “severe combined immune deficiency” OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR “serum sickness”.mp.

NOT

Editorials

### HEPATITIS A

hepatitis a/ or hepatitis a vaccines/ or ((vaccination/ or vaccines/) and (hepatitis a/ or hepatitis a virus, human/)) or “hepatitis a vaccin$”.mp. or ((vaccin$ or immuniz$ or immunis$ or immunolog$) and “hepatitis a”).mp. OR (havrix or vaqta or twinrix).mp.

AND

Safe$.mp. or safety/ or (harm$ or adverse or toxic or toxicity or toxicities).mp. or “side effect$”.mp. or death.mp. or mortality/ OR anaphylaxis/ or anaphylactic shock/ or anaphyla$.mp. or allergy.mp. or allergies.mp. or allergic.mp. OR ((bell$ adj2 palsy) or (facial adj2 paraly$) or (facial adj2 neuropath$)).mp. or Chronic inflammatory demyelinating polyneuropathy/ or “Chronic inflammatory demyelinating polyneuropathy”.mp. or polyradiculoneuropathy, chronic inflammatory demyelinating/ or polyradiculoneuropathy.mp. or exp multiple sclerosis/ or “multiple sclerosis”.mp. or “chronic remitting demyelinating disease$”.mp. or “disseminated neuropath$”.mp. OR frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome/ or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. or (Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides).mp. or (shoulder impingement or subacromial impingement).mp. OR hepatitis, autoimmune/ or autoimmune hepatitis/ or “autoimmune hepatitis”.mp. OR myelitis, transverse.mp. or transverse myelitis.mp. or encephalomyelitis, acute disseminated/ OR acute disseminated encephalomyelitis or demyelinating.mp. or exp guillain-barre syndrome/ OR guillain barre.mp. or guillain-barre.mp. or “fisher syndrome”.mp. or “fishers syndrome”.mp. OR myelitis.mp. or exp syncope/ or syncop$.mp. or fainting.mp. or (vasovagal adj5 (collapse or attack or shock or reaction$)).mp. OR (seizure$ or convuls$ or spasm$ or “birth defect$” or spontaneous abort$ or congenital abnormal$).mp. or abnormalities, congenital/ or stillbirth$.mp. or stillborn.mp. or “still-born”.mp. or “sudden infant death”.mp. or sids.mp. or “cot death$”.mp. or “unexpected infant death$”.mp. OR exp Purpura, Thrombocytopenic, Idiopathic/ or “idiopathic thrombocytopenic purpura”.mp. OR tics/ or tic.mp. or tics.mp. or (uveitis or narcolep$).mp. or exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. or (rheumatoid arthritis or “polyarteritis nodosa”).mp. OR (Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes)).mp. OR (stroke or strokes or “cerebrovascular accident” or “cerebrovascular accidents” or vasculitis).mp. OR (thromboembolis$ or exp myocardial ischemia/ OR ischemic heart disease or myocardial infarction or “heart attack” or angina or “ankylosing spondylitis” or “polymyalgia rheumatica” or fibromyalgia or “serum sickness”).mp. OR narcolep$.mp. OR vasculitis OR fibromylagia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. OR Myofascial pain syndrome.mp.

NOT

Editorials

### HEPATITIS B

hepatitis b vaccines/ or ((vaccination/ or vaccines/) and (hepatitis b/ or hepatitis b virus/)) or “hepatitis b vaccin$”.mp. or ((vaccin$ or immuniz$ or immunis$ or immunolog$) and “hepatitis b”).mp. or “engerix-b”.mp. or “engerix b”.mp. or “recombivax hb”.mp. or “recombivax-hb”.mp. or twinrix.mp. or hexavax.mp. or .mp.

AND

safe$.mp. or safety/ or (harm$ or adverse or toxic or toxicity or toxicities).mp. or “side effect$”.mp. or death.mp. or mortality/ OR anaphylaxis/ or anaphylactic shock/ or anaphyla$.mp. or allergy.mp. or allergies.mp. or allergic.mp. OR exp arthralgia/ or exp arthritis/ or arthropathy, neurogenic.mp. or exp arthropathy/ or arthritis.mp. or arthralgia.mp. or arthropath$.mp. OR rheumatoid arthritis/ or rheumatoid arthritis.mp. or brachial plexus neuritis/ or brachial neuritis.mp. or brachial plexus neuritis.mp. or neuralgia.mp. or brachial plexus neuropath$.mp. or small fiber neuropath$.mp. OR

Chronic inflammatory demyelinating polyneuropathy/ or polyradiculoneuropathy, chronic inflammatory demyelinating/ or exp multiple sclerosis/ or (polyneuropath$ or polyradiculoneuropath$ or multiple sclerosis).mp. OR demyelinat$.mp. OR neuromyelitis optica/ or chronic remitting demyelinating disease.mp. or disseminated neuropathy.mp. OR exp complex regional pain syndrome/ or exp complex regional pain syndromes/ or “complex regional pain”.mp. or causalgia.mp. or “reflex sympathetic dystrophy”.mp. OR Seizures, febrile/ or convulsion/ or exp epilepsies, myoclonic/ or spasms, infantile/ or Myoclonus epilepsy/ or myoclonus seizure/ or myoclonus/ or convulsion$.ti,ab. or epileps$.mp. or (myoclon$ or spasm$ or convuls$ or seizure$).mp. or exp epilepsy/ OR exp encephalitis/ or exp encephalitis, viral/ or exp brain disease/ or encephal$.ti,ab. or encephalopath$.mp. or brain inflammation.mp. or encephalomyelitis.mp. OR Brain Diseases/ OR erythema nodosum/ or “erythema nodosum”.mp. or erythemat$.mp. OR fibromyalgia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. or “myofascial pain syndrome”.mp. OR frozen shoulder/ or exp bursitis/ or shoulder impingement syndrome/ or exp synovitis/ or frozen shoulder.mp. or bursitis.mp. or synovitis.mp. or synovitides.mp. or bursitides.mp. or (Adhesive capsulitis or adhesive capsulitides or periarthritis or periarthritides).mp. or (shoulder impingement or subacromial impingement).mp. OR transverse myelitis.mp. or encephalomyelitis, acute disseminated/ or guillain barre.mp. OR guillian-barre.mp. OR myelitis.mp. or fisher syndrome.mp. or fishers syndrome.mp. OR myelitis.mp. or polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR exp syncope/ or syncop$.mp. or fainting.mp. or (vasovagal adj5 (collapse or attack or shock or reaction$)).mp. OR vasculitis/ or vasculitis.mp. or vasculitides.mp. or angiitis.mp. or angiitides.mp. or aortitis.mp. or arteritis.mp. or phlebitis.mp. or behcet syndrome.mp. or wegener granulomatosis.mp. or thrombophlebitis.mp. OR Endarteritis/ OR (Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes)).mp. OR exp thyroiditis, autoimmune/ or “autoimmune thyroid”.mp. or “autoimmune thyroiditis”.mp. or “auto-immune thyroid”.mp. or “auto-immune thyroiditis”.mp. OR (spontaneous abort$ or congenital abnormal$).mp. or abnormalities, congenital/ or congenital defect$.mp. or stillbirth$.mp. or stillborn.mp. or sudden infant death/ or sudden infant death$.mp. or sids.mp. or cot death.mp. or unexpected infant death.mp. OR (tic or tics).mp. OR uveitis or narcolep$ or birth defects or stroke or cerebrovascular accident$ or thromboembolism$ or exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina or eclampsia or pre-eclampsia or preeclampsia or preterm or “pre-term” or “premature labor” or “premature labour” or reiter$ or ankylosing spondylitis or polymyalgia rheumatica or “serum sickness”).mp. OR exp Purpura, Thrombocytopenic, Idiopathic/ or “idiopathic thrombocytopenic purpura”.mp. OR (Meningitis or meningo$ or meningeal or arachnoiditis or meningitides or pachymeningitis).mp. or pachymeningitides.mp. OR “severe combined immune deficiency”

NOT

Editorials

### HUMAN PAPILLOMAVIRUS

papillomavirus vaccines/ OR (vaccination/ AND (papillomaviridae/ OR papillomavirus infections/)) OR “papillomavirus vaccin$” OR ((vaccin$ OR immuniz$) AND (papillomaviridae OR papillomavirus)) OR cervarix OR gardasil

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR amyotrophic lateral sclerosis/ OR “amyotrophic lateral sclerosis” OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR allergic OR allergy OR allergies OR exp arthralgia/ OR exp arthritis/ OR arthropathy, neurogenic/ OR exp arthropathy/ OR arthritis OR arthralgia OR arthropath$ OR brachial plexus neuritis/ OR “brachial neuritis” OR “brachial plexus neuritis” OR neuralgia OR brachial plexus neuropath$ OR chronic inflammatory demyelinating polyneuropathy/ OR polyradiculoneuropathy, chronic inflammatory demyelinating/ OR exp multiple sclerosis/ OR neuromyelitis optica/ OR polyneuropath$ OR polyradiculoneuropath$ OR multiple sclerosis OR “neuromyelitis optica” OR OR seizures/ OR seizures, febrile/ or convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR exp encephalitis/ OR exp encephalitis, viral/ OR encephalitis OR “brain inflammation” OR encephalomyelitis OR exp brain disease/ OR encephalopath$.ti,ab. OR encephal$ or “brain disease” OR “frozen shoulder” OR bursitis OR synovitis OR synovitides OR bursitides OR adhesive capsulitis OR adhesive capsulitides OR periarthritis OR periarthritides OR “shoulder impingement” OR “subacromial impingement” OR hypercoagulab$ OR exp guillain barre syndrome/ OR “guillain barre” OR exp guillain-barre syndrome/ OR guillain-barre” OR myelitis, transverse/ OR “transverse myelitis” OR encephalomyelitis, acute disseminated/ OR “acute disseminated encephalomyelitis” OR “cerebrovascular accident” OR stroke OR myelitis OR encephalomyelitis OR demyelinating OR exp pancreatitis/ OR pancreatitis OR exp lupus erythematosus, systemic/ OR systemic lupus OR libman-sacks disease OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR thromboembolism/ or thromboembol$ OR hypercoagula$ OR appendicitis OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR Diabetes mellitus, type 1 or insulin dependent diabetes or insulin-dependent diabetes or (type 1 diabetes or type1 diabetes or juvenile onset diabetes or juvenile-onset diabetes)).mp. OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR uveitis OR narcolep$.mp. OR rheumatoid arthritis.mp. OR Fisher$ adj syndrome.mp. OR oculorespiratory syndrome$.mp. or polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. or smallfiber neuropath$.mp. or small fiber neuropath$.mp. OR vasculitis OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR Pancreatitis.mp. OR ankylosing spondylitis.mp. OR fibromyalgia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. or “myofascial pain syndrome”.mp. OR serum sickness.mp. OR Steril$.mp. OR infertile$.mp.

NOT

Editorials

### DIPHTHERIA TOXOID-, TETANUS TOXOID-, AND ACELLULAR PERTUSSIS-CONTAINING VACCINES

diphtheria-tetanus-acellular pertussis vaccines/ OR diphtheria pertussis tetanus vaccine/ OR tetanus toxoid/ OR “diphtheria-tetanus vaccine”/ OR (“diphtheria tetanus” OR “tetanus diphtheria” OR “tetanus and diphtheria” OR “diphtheria and tetanus”).ti,ab. OR “tetanus toxoid”.mp. OR DTaP.mp. OR TDaP.mp. OR (vaccin$ adj5 (DT OR TD OR TT)).mp. OR “tetanus diphtheria acellular pertussis”.mp. OR “tetanus diphtheria and acellular pertussis”.mp. OR ((“Diphtheria tetanus acellular pertussis” OR “tetanus diphtheria acellular pertussis” OR “diphtheria tetanus” OR “tetanus diphtheria” OR “tetanus toxoid” OR “tetanus and diphtheria” OR “diphtheria and tetanus” OR DTaP OR TDAP OR DT OR TD OR TT) adj5 (vaccin$ OR immuniz$) OR Tripedia OR Acelimune OR Infanrix OR hexavax OR “quatro virelon” OR decavac OR “acel-imune” OR “acel imune” OR certiva OR daptacel OR trihibit OR pediarix OR kinrix OR pentacel OR “tri-immunol” OR “tri immunol” OR adacel OR boostrix OR ditanrix

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR allergic OR allergy OR allergies OR exp arthralgia/ OR exp arthritis/ OR arthropathy, neurogenic/ OR exp arthropathy/ OR arthritis OR arthralgia OR arthropath$ OR exp arthritis, rheumatoid/ OR “rheumatoid arthritis” OR exp ataxia/ OR ataxia$ OR “coordination impairment$” OR dyssynergia OR “rubral tremor” OR autistic disorder/ OR autism/ OR infantile autism/ OR Asperger syndrome/ OR Rett syndrome/ OR schizophrenia, childhood/ OR child development disorders, pervasive/ OR childhood disintegrative disorder/ OR pervasive development disorder not otherwise specified/ OR autism OR autistic OR “kanner$ syndrome” OR “autism spectrum” OR “rett$ syndrome” OR “asperger$ syndrome” OR “child$ schizophrenia” OR “pervasive child$ development$ disorder$” OR “pervasive development disorder$” OR “disintegrative disorder?” OR bell palsy/ OR “bell$ palsy” OR “facial paralys$” OR “facial neuropath$” OR chronic inflammatory demyelinating polyneuropathy/ OR polyradiculoneuropathy, chronic inflammatory demyelinating/ OR exp multiple sclerosis/ OR “chronic remitting demyelinating disease$” OR “disseminated neuropathy” OR polyneuropath$ OR polyradiculoneuropath$ OR multiple sclerosis OR exp urticaria/ OR urticaria$ OR hives OR angioedema OR exp complex regional pain syndrome/ OR exp complex regional pain syndromes/ OR “complex regional pain” OR causalgia OR “reflex sympathetic dystrophy” OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR exp encephalitis/ OR exp encephalitis, viral/ OR encephalitis OR “brain inflammation” OR encephalomyelitis OR exp brain disease/ OR encephalopath$.ti,ab. OR encephal$ OR “brain disease” OR fibromyalgia/ OR fibromyalgia$ OR fibrositis OR fibrositides OR “myofascial pain syndrome” OR frozen shoulder/ OR exp bursitis/ OR shoulder impingement syndrome/ OR exp synovitis/ OR “frozen shoulder” OR bursitis OR synovitis OR synovitides OR bursitides OR adhesive capsulitis OR adhesive capsulitides OR periarthritis OR periarthritides OR “shoulder impingement” OR “subacromial impingement” OR exp purpura, thrombocytopenic, idiopathic/ OR idiopathic thrombocytopenic purpura/ OR “idiopathic thrombocytopenic purpura$” OR “werlhof$ disease” OR “autoimmune thrombocytopenic purpura$” OR “autoimmune thrombocytopenia$” OR “thrombocytopen$ purpura” OR diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin- dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR exp guillain barre syndrome/ OR “guillain barre” OR exp guillain- barre syndrome/ OR “guillain-barre” OR myelitis, transverse/ OR “transverse myelitis” OR encephalomyelitis, acute disseminated/ OR myelitis OR encephalomyelitis OR demyelinating OR Myocarditis/ OR myocarditis OR carditis or myocarditides OR pericarditis OR Opsoclonus-myoclonus syndrome/ OR (“Opsoclonus myoclonus syndrome” OR“dancing eyes dancing feet syndrome” OR “opsoclonus myoclonus ataxia” OR “kinsbourne syndrome” OR exp optic neuritis/ OR “optic neuritis” OR “optic neuritides” OR neuropapillitis OR neuropapillitides OR “retrobulbar neuritis” OR serum sickness/ OR “serum sickness$” OR “serum disease” OR “plasma sensitivity” OR sudden infant death/ OR “sudden infant death” OR SIDS OR “cot death” OR“unexpected infant death” OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR “congenital defect$” OR stillbirth$ OR stillborn OR exp meningitis/ OR meningitis OR “cranial nerve$” OR paraly$ OR (tic OR tics).mp. OR uveitis OR narcolep$.mp. OR birth adj3 defect$.mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR thrombocytopen$.mp. OR Fisher$ adj syndrome.mp. OR polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. or smallfiber neuropath$.mp. or small fiber neuropath$.mp. OR exp stroke/ or exp death, sudden/ or cerebrovascular accident$.mp. OR vasculitis OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR eclampsia OR pre-eclampsia OR preeclampsia OR (preterm labor OR preterm labour).mp. OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR myoclonus OR “severe combined immune deficiency”

NOT

Editorials

### MENINGOCOCCAL

meningococcal vaccines/ OR MPSV4.mp. OR menomune.mp. OR MCV4.mp. or menactra.mp. OR ((vaccination/ or vaccines/) AND exp meningitis/)) OR mening$ vaccin$ OR ((vaccin$ OR immuniz$) AND meningitis))

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR allergic OR allergy OR allergies OR bell palsy/ OR “bell$ palsy” OR “facial paralys$” OR “facial neuropath$” OR exp headache disorders/ OR (chronic adj2 headache$) OR headache disorder$ or headache syndrome$ OR cephalgia syndrome$ OR intractable headache$ OR chronic inflammatory demyelinating polyneuropathy/ or polyradiculoneuropathy, chronic inflammatory demyelinating/ OR exp multiple sclerosis/ OR “chronic remitting demyelinating disease$” OR “disseminated neuropathy” OR polyneuropath$ OR polyradiculoneuropath$ OR multiple sclerosis OR exp encephalitis/ OR exp encephalitis, viral/ OR encephalitis or brain inflammation or encephalomyelitis OR exp brain disease/ OR encephal$.ti,ab. OR brain disease$or encephal$ OR encephalomyelitis, acute disseminated OR “acute disseminated encephalomyelitis” OR myelitis, transverse/ OR “transverse myelitis” OR demyelinating OR encephalomyelitis OR frozen shoulder/ OR exp bursitis/ OR shoulder impingement syndrome/ OR exp synovitis/ OR “frozen shoulder” OR bursitis OR synovitis OR synovitides OR bursitides OR adhesive capsulitis OR adhesive capsulitides OR periarthritis OR periarthritides OR “shoulder impingement” OR “subacromial impingement” OR exp guillain barre syndrome/ OR “guillain barre” OR exp guillain- barre syndrome/ OR “guillain-barre” OR myelitis OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR thrombocytopenia$ OR thrombopenia$ OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR purpura, schonlein-henoch/ OR “henoch-schonlein purpura$” OR diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin- dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR uveitis OR narcolep$.mp. OR rheumatoid arthritis.mp. OR Fisher$ adj syndrome.mp. OR (tic OR tics).mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR exp stroke/ or exp death, sudden/ or cerebrovascular accident$.mp. OR vasculitis OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina OR vasculitis OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR

fibromyalgia/ or fibromyalg$.mp. or fibrositis.mp. or fibrositides.mp. or “myofascial pain syndrome”.mp. OR “serum sickness”.mp.

NOT

Editorials

### POLIOVIRUS

poliovirus Vaccine, Inactivated/ OR (polio$AND (vaccine$ OR vaccinate$ OR vaccination$ OR immuniz$ OR immunis$)) OR ipol OR poliovax OR hexavax OR “quatro virelon” OR pediarix OR kinrix OR pentacel OR orimune

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR exp ataxia/ OR ataxia$ OR “coordination impairment$” OR dyssynergia OR “rubral tremor” OR “gait adj3 disturb$” OR allergic OR allergy OR allergies OR ((edema OR oedema) adj3 peripheral) OR exp urticaria/ OR urticaria$ OR hives OR angioedema OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR dyskinesia$ OR “gaze palsy” OR hematochezia OR haematochezia OR hypotonia OR intussuscept$ OR sudden infant death/ OR “sudden infant death” OR SIDS OR “cot death” OR“unexpected infant death” OR tremor OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR wheez$ OR asthma/ OR status asthmaticus/ OR asthma$ OR “paralytic polio$” OR “vaccine strain polio viral infection” OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR encephalomyelitis, acute disseminated OR “acute disseminated encephalomyelitis” OR exp guillain barre syndrome/ OR “guillain barre” OR exp guillain- barre syndrome/ OR “guillain-barre” OR myelitis, transverse/ OR “transverse myelitis” OR fibromyalgia/ OR fibromyalgia$ OR fibrositis OR fibrositides OR thrombocytopenia$ OR thrombopenia$ OR diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin- dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (tic OR tics).mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR uveitis OR narcolep$.mp. OR Fisher$ adj syndrome.mp. OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR “serum sickness”.mp.

NOT

editorials

### PNEUMOCOCCAL

pneumococcal vaccines/ OR (pneumonia/ OR pneumonia.ti,ab. OR pneumococ$) AND (vaccine$ OR vaccinate$ OR vaccination$ OR immuniz$ OR immunis$)) OR prevnar OR pneumovax OR “pnu-imune” OR “pnu imune” OR “pneumococcal polysaccharide$”

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR exp ataxia/ OR ataxia$ OR “coordination impairment$” OR dyssynergia OR “gait adj3 disturb$” OR allergic OR allergy OR allergies OR ((edema OR oedema) adj3 peripheral) OR exp urticaria/ OR urticaria$ OR hives OR angioedema OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR dyskinesia$ OR “gaze palsy” OR hematochezia OR haematochezia OR hypotonia OR intussuscept$ OR sudden infant death/ OR “sudden infant death” OR SIDS OR “cot death” OR“unexpected infant death” OR tremor OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR wheez$ OR asthma/ OR status asthmaticus/ OR asthma$ OR exp arthritis/ OR arthropathy, neurogenic/ OR exp arthropathy/ OR arthritis OR arthropath$ OR chronic fatigue syndrome/ OR fatigue syndrome, chronic/ OR “fatigue syndrome$” OR “chronic fatigue” OR “fatigue disorder” OR asthenia OR hyperhidrosis OR hypoaesthesia$ OR hypoesthesia$ OR paraesthesia$ OR paresthesia$ OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR exp guillainbarre syndrome/ OR “guillain barre” OR myelitis, transverse/ OR “transverse myelitis” OR fibromyalgia/ OR fibromyalgia$ OR fibrositis OR fibrositides OR thrombocytopenia$ OR thrombopenia$ OR serum sickness/ OR “serum sickness$” OR “serum disease” OR “plasma sensitivity” OR encephalomyelitis, acute disseminated/ OR “acute disseminated encephalomyelitis” OR exp diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin-dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (tic OR tics).mp. OR uveitis OR narcolep$.mp. OR Fisher$ adj syndrome.mp. OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR exp polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR rheumatoid arthritis.mp. OR thrombocytopen$.mp. OR exp brain disease/ or encephal$.ti,ab. or encephalopath$.mp. or brain inflammation.mp. OR exp multiple sclerosis/ OR multiple sclerosis.mp. OR vasculitis OR exp stroke/ or exp death, sudden/ or cerebrovascular accident$.mp. OR thromboembolism$.mp. OR exp myocardial ischemia/ OR ischemic heart disease or “heart attack” or myocardial infarction or angina

NOT

editorials

### ROTAVIRUS

rotavirus vaccines/ OR rotavirus$ C OR rotarix OR rotateq OR rotashield

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR urticaria/ OR urticaria$ OR hives OR angioedema OR allergic OR allergy OR allergies OR intussuscept$ OR sudden infant death/ OR “sudden infant death” OR SIDS OR “cot death” OR“unexpected infant death” OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR dyskinesia$ OR tremor$ OR exp syncope/ OR syncope OR syncopes OR syncopal OR fainting OR (vasovagal adj (collapse OR attack OR shock OR reaction)) OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR encephalomyelitis, acute disseminated/ OR “acute disseminated encephalomyelitis” OR exp guillainbarre syndrome/ OR “guillain barre” OR myelitis, transverse/ OR “transverse myelitis” OR fibromyalgia/ OR fibromyalgia$ OR fibrositis OR fibrositides OR “kawasaki disease$” OR “kawasaki syndrome$” OR exp meningitis/ OR meningitis OR exp encephalitis, viral/ OR encephalitis or brain inflammation or encephalomyelitis OR exp brain disease/ OR encephal$.ti,ab. OR brain disease$or encephal$ OR myocarditis OR “gram-negative sepsis” OR exp gastrointestinal hemorrhage/ OR “gastrointestinal bleeding” OR exp diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin-dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (tic OR tics).mp. OR intussuscept$.mp OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR rheumatoid arthritis.mp. OR Fisher$ adj syndrome.mp. OR exp polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR vasculitis OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR “serum sickness”.mp.

NOT

editorials

### HAEMOPHILUS INFLUENZA TYPE B

haemophilus vaccines/ OR haemophilus influenza type b polysaccharide vaccine-tetanus toxin conjugate [Supplementary Concept] OR (“haemophilus b” OR “haemophilus type b” OR “haemophilus influenzae type b” OR hib) AND (vaccine$ OR vaccinate$ OR vaccination$ OR immuniz$ OR immunis$) OR acthib OR hiberix OR hibtiter OR omnihib OR pedvaxhib OR prohibit OR tetracoq

AND

safe$ OR harm$ OR adverse OR toxic OR toxicity OR toxicities OR “side effect” OR “side effects” OR death OR mortality/ OR anaphylaxis/ OR anaphylactic shock/ OR anaphyla$ OR seizures/ OR seizures, febrile/ OR convulsion/ OR exp epilepsies, myoclonic/ OR spasms, infantile/ OR myoclonus epilepsy/ OR myoclonus seizure/ OR myoclonus/ OR convulsion$.ti,ab. OR epileps$ OR myoclon$ OR spasm$ OR convulsion$ OR seizure$ OR urticaria/ OR urticaria$ OR hives OR angioedema OR allergic OR allergy OR allergies OR intussuscept$ OR tremor$ OR hypotoni$ OR sudden infant death/ OR “sudden infant death” OR SIDS OR “cot death” OR“unexpected infant death” OR “spontaneous abort$” OR “congenital abnormal$” OR abnormalities, congenital/ OR encephalomyelitis, acute disseminated/ OR “acute disseminated encephalomyelitis” OR exp guillainbarre syndrome/ OR “guillain barre” OR myelitis, transverse/ OR “transverse myelitis” OR fibromyalgia/ OR fibromyalgia$ OR fibrositis OR fibrositides OR (susceptib$ adj3 hib) OR (susceptib$ adj3 haemophilus) OR thrombocytopenia$ OR thrombopenia$ OR exp diabetes mellitus, type 1/ OR “insulin dependent diabetes” OR “insulin-dependent diabetes” OR “type 1 diabetes” OR “juvenile onset diabetes” OR “sudden-onset diabetes” OR IDDM OR “brittle diabetes” OR “autoimmune diabetes” OR “ketosis-prone diabetes” OR Idiopathic thrombocytopenic purpura OR thrombocytopenic purpura, idiopathic/ OR Purpura, Thrombocytopenic, Idiopathic/ OR (tic OR tics).mp. OR uveitis OR narcolep$.mp. OR exp lupus erythematosus, systemic/ or systemic lupus erythematosus.mp. or libman-sacks.mp. or systemic lupus.mp. OR rheumatoid arthritis.mp. OR Fisher$ adj syndrome.mp. OR exp polyarteritis nodosa/ or polyarteritis nodosa.mp. or periarteritis nodosa.mp. or essential polyarteritis.mp. or necrotizing arteritis.mp. OR ankylosing spondylitis.mp. OR polymyalgia rheumatica.mp. OR “serum sickness”.mp.

NOT

editorials