# Abbreviations/Acronyms

ACIP: Advisory Committee on Immunization Practices
ADEM: Acute disseminated encephalomyelitis
AEs: Adverse Events
AHRQ: Agency for Healthcare Research and Quality
ALL: Acute lymphoblastic leukemia
CAP: Community-acquired pneumonia
CCTs: Controlled Clinical Trials
CDC: Centers for Disease Control and Prevention
CER: Comparative Effectiveness Review
CI: Confidence Interval
CIDP: Chronic inflammatory demyelinating polyneuropathy
COPD: Chronic obstructive pulmonary disease
CTCAE: Common Terminology Criteria for Adverse Events
CVD: Cardiovascular Disease
DPT: Diphtheria–Pertussis–Tetanus vaccine
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
GBS: Guillain–Barré Syndrome
GERD: Gastroesophageal reflux disease
GI: Gastrointestinal
GPRD: General Practice Research Database (UK)
Hib: Haemophilus influenzae type b
HMO: Health Maintenance Organization
HPV: Human papillomavirus
HR: Hazard ratio
HZ: Herpes Zoster
ICD: International Classification of Diseases
IHD: Ischemic heart disease
ILI: Influenza-Like Illness
IOM: Institute of Medicine
IPD: Invasive pneumococcal disease
IPV: Inactivated polio vaccine
IRR: Incidence rate ratio
ITP: Idiopathic thrombocytic purpura
KQs: Key Questions
LAIV: Live attenuated influenza vaccine
MaxSPRT: Maximized sequential probability ratio test
MCO: Managed Care Organization
MCV: Meningococcal conjugate vaccine
MI: Myocardial infarction
MIV: Monovalent inactivated pandemic H1N1 vaccine
MMR: Measles, mumps, and rubella
MPSV: Meningococcal polysaccharide vaccine
MS: Multiple Sclerosis
NIH: National Institute of Health
OASH: Office of the Assistant Secretary for Health
OHSU: Oregon Health Sciences University
OR: Odds ratio
PAEDS: Pediatric Active Enhanced Disease Surveillance
PCV: Pneumococcal conjugate vaccine
PPV: Pneumococcal polysaccharide vaccination
PRAMS: Pregnancy Risk Assessment Monitoring System
PV: Pneumococcal vaccine
RAD: Reactive airway disease
RCTs: Randomized Controlled Trials
RR: Relative risk
SAE: Serious adverse events
SAS: Statistical Analysis System
SCCS: Self-controlled case series
SD: Standard deviation
SIDS: Sudden Infant Death Syndrome
SIPs: Scientific Information Packets
SLE: Systemic lupus erythematosus
SRC: Scientific Resource Center
Td: Tetanus, diphtheria
Tdap: Tetanus, diphtheria, and acellular pertussis vaccine
TEP: Technical Expert Panel
TIV: Trivalent influenza vaccine
TOO: Task Order Officer
TP: Thrombocytopenic purpura
USD: Urea cycle disorders
VAERS: Vaccine Adverse Event Reporting System
VICP: Vaccine Injury Compensation Program
VSD: Vaccine Safety Datalink
VZV: Varicella-Zoster Virus