# Results

## Introduction

This chapter presents the results of the systematic review of the literature on smoking cessation interventions for pregnant and postpartum women. We begin with the results of our literature searches and an overview of the included studies as a whole. This is followed by results and detailed analysis for each Key Question.

Within Key Question 1 (KQ1) we have attempted to group together studies according to the primary component of the intervention. Virtually no studies were truly unimodal; however, we placed studies into one of six broad categories based on the description by the authors for the primary intervention of interest. Results are presented by primary intervention in the following order: counseling; educational materials; NRT; peer support; other interventions; and multicomponent interventions. For each category, we include a description of the included studies, a table summarizing the characteristics of the good and fair quality studies, a detailed synthesis, and a table of key outcomes for all included studies. When there were a sufficient number of studies with outcome data for postpartum interventions or relapse prevention, we included these under a separate subheading.

Key Question 2 (KQ2) is organized by infant outcomes. These analyses are followed by a review of the studies addressing Key Question 3 (KQ3), which pertains to harms associated with the interventions identified for KQ1. Key Question 4 (KQ4) focuses on the components of the interventions, which are organized by smoking cessation and relapse prevention, and include the meta-analysis results. These are the primary effectiveness results used for strength-of-evidence assessments in Chapter 4. For Key Question 5 (KQ5), we organize patient characteristics by factors that modify success of the intervention and those related to the probability of cessation.

We also describe studies in summary tables, generally organized to present validated smoking cessation outcomes in a single summary in the relevant section of text. Details on quality assessment for individual studies can be found in Appendix I. Information about the overall strength of evidence supporting the effectiveness of specific interventions is summarized in the Discussion chapter.

## Results of Literature Searches

We identified 2,454 titles and abstracts for screening. Of these, 417 publications were promoted for full-text review. At full-text review, we excluded 345 publications. We found 72 publications from 59 unique studies that met criteria for inclusion. Of these, three were prospective cohort studies retained for KQ3, KQ4, and/or KQ5. We extracted data from the remaining 56 randomized controlled trials (RCTs) to address the Key Questions. The literature search and screening results are summarized in Figure 2. The complete list of references excluded at full-text review and exclusion reasons is provided in Appendix G. We received no published or unpublished data from the requests to manufacturers of the pharmacologic smoking cessation aids.

Figure 2 Flow diagram of literature search and screening

Abbreviations: KQ = Key Question; RCT = randomized controlled trial.

The literature flow diagram illustrates the number of citations retrieved from electronic database searches (n=2380) and other searches (n=74). A total of 2454 citations were retrieved for screening. At the level of abstract screening, 2037 citations were excluded. Of 417 citations that were promoted for full-text review the diagram lists the individual reasons for exclusion: not an eligible study design (n=226); did not report outcomes/results for smoking cessation intervention (n=185); did not include 20 or more participants per group (n=139); not an eligible study population (n=120); not original research (n=83); did not report biochemical validation of cessation (n=58); unable to obtain (n=3); duplicate (n=3); and related to included study but did not address a Key Question (n=8). The diagram notes that the exclusion reason counts do not tally as publications could be excluded for multiple reasons. The figure indicates that the total number of included papers is 72 representing 59 unique studies, consisting of RCTs (n=56) and prospective cohort studies (n=3). Included studies were distributed among the Key Questions (KQs). RCTs: KQ1 (n=56); KQ2 (n=13); KQ3 (n=4); KQ4 (n=28); KQ5 (n=15). Prospective cohorts studies: KQ1 (NA); KQ2: (NA); KQ3 (n=0); KQ4 (n=0); KQ5 (n=3). Meta-analysis: KQ4 (n=23).

## Description of Included Studies

We included 59 unique studies that address our Key Questions: 56 RCTs and three prospective controlled cohort studies. Included studies evaluated interventions based on behavioral, educational, medical, and other approaches to promote smoking cessation or relapse prevention among pregnant or postpartum women using at least one comparator or usual care. The majority of studies (55 studies) included in this review recruited pregnant women; four studies were conducted in the postpartum period. Studies enrolled women who were current smokers (42 studies), recent quitters (8 studies) or both (9 studies). The duration of followup in the studies included in this review was generally short. Most studies that delivered an intervention during pregnancy limited followup to the prenatal period. Only 15 studies reported biochemically validated cessation after birth. For studies evaluating an intervention delivered in the postpartum period, one study reported cessation at 6 weeks postpartum,79 one at 8 weeks postpartum,80 one at 3 months postpartum,81 and one at 6 months postpartum.82 For RCTs, we assessed individual study quality as good for 13 studies, fair for 15 studies, and poor for 28 studies. The cohort studies were assessed as fair (2 studies) and poor (1 study) quality. A summary of all component items and overall risk of bias/quality score for each included study is provided in Appendix I.

For KQ2, we did not identify any publications that explicitly focused on infant outcomes in the context of treating maternal smoking behavior. The publications included for KQ2 are focused on smoking cessation patterns in mothers, with infant outcomes as a secondary outcome. Included studies evaluated the effect of these interventions on birth weight, gestational age, preterm birth, neonatal death, and neonatal intensive care unit (NICU) admission. For KQ3, we identified four studies reporting on harms of the included interventions. For KQ4 we extracted relevant data from 24 good and fair quality RCTs. Patient characteristics reported in 14 RCTs,39, 82-94 and three cohort studies38, 95, 96 are described in KQ5.

## Key Question 1 Intervention Outcomes for Pregnant and Postpartum Women

Of the 59 included studies, 56 RCTs (13 good quality, 15 fair quality, 28 poor quality) evaluated one or more interventions designed to reduce smoking or to prevent relapse in pregnant or postpartum women. The majority of the studies were conducted in the United States (39 studies);11, 39, 79, 80, 83-87, 89-94, 97-121 six in the United Kingdom;88, 122-126 four were conducted in Australia;127-130 two in Canada;82, 131 and one each in Spain,81 Scotland,132 Denmark,133 and Sweden.134 Fifty-two studies enrolled women who were pregnant.11, 39, 83-94, 97-134 Four of the RCTs enrolled women in the postpartum period.79-82

Eight studies79, 80, 82, 94, 99, 111, 112, 114 restricted enrollment to women who had recently quit smoking. Forty-one studies39, 83-87, 89-93, 97, 98, 100-104, 107-110, 113, 115-125, 128-134 included current smokers only, and seven studies11, 81, 88, 105, 106, 126, 127 included both current smokers and women who had quit smoking immediately prior to or during pregnancy. Biochemical validation methods for smoking cessation included: expired carbon monoxide (9 studies);82, 86, 88, 92, 102, 113, 116, 118, 119 cotinine measured in saliva, urine, or blood (31 studies);11, 39, 79, 81, 83, 85, 87, 89, 91, 94, 97, 98, 101, 103-106, 108, 109, 111, 117, 120, 123-127, 129, 130, 132, 133 cotinine-creatinine ratio (3 studies);114, 115, 131 and thiocyanate (4 studies).93, 110, 112, 134 Multiple validation methods were used in nine studies.80, 84, 90, 99, 100, 107, 121, 122, 128

Smoking cessation and relapse prevention interventions, both prenatal and postpartum, were overwhelmingly multifaceted. Studies deployed multiple components in the intervention being compared with usual care or an alternative level of standard cessation services, both of which were also typically multicomponent. We have grouped studies by the predominant component of the intervention, which included counseling (14 studies);81, 82, 86, 87, 89, 90, 99, 105, 108, 111, 114, 115, 129, 132 educational materials (10 studies);94, 97, 113, 116, 117, 119, 123, 125, 126, 134 NRT (5 studies);102, 104, 120, 122, 128 peer support (4 studies);85, 101, 107, 109 other (9 studies),80, 83, 84, 100, 106, 118, ^#3597^, 124, 131 which consisted of various unique studies; and multicomponent interventions (14 studies).11, 39, 79, 88, 91-93, 98, 103, 110, 112, 127, 130, 133 Descriptions of smoking cessation intervention components can be found in Table 4.

Table 4 Descriptions of smoking cessation intervention components

Component | Description
Clinic Reinforcement | Identifying participants at followup visits (usually by flagging patient charts) to remind staff to address smoking (e.g., assessment of smoking status, encouragement to achieve or maintain cessation).
Counseling | Any form of individual counseling (e.g., in person, by telephone), however brief, delivered by a range of practitioners (e.g., obstetrician, peers).
Feedback About Biologic Measures | Pregnant woman's ultrasound images, stress tests, biochemical tests for smoking (e.g., carbon monoxide, cotinine), or other biologic data presented to her to promote and/or sustain smoking cessation.
Groups | Support groups or group counseling to promote and/or sustain smoking cessation.
Incentives | Both financial and symbolic rewards (baby gifts, t-shirts, mugs, awards) contingent upon smoking reduction or cessation. This does not include gifts given at study enrollment or incentives for study visits.
Information | Education about pregnancy and smoking in the form of pamphlet, video, or other educational material. This includes factual or educational material only as distinguished from a Quit Guide which contains practical information and/or directions that the patient can use.
NRT | Pharmacological nicotine replacement therapy (e.g., patches, gum).
Partner/Household/Social Context | Identification of the smoking patterns of the partner, friends, and family as key aspects of the assessment process because these patterns potentially influence the woman's smoking behaviors. This may include household members.
Peer Support | Encouraging the identification and involvement of a peer or “buddy” for the pregnant woman as ongoing social support during the cessation process. This includes buddy contracts and lay health advisors.
Personal Followup | Followup with the purpose of sustaining the impact of the other components and offering encouragement (e.g., calls, postcards, congratulations letters).
Prescription To Quit | A written “prescription” from care provider typically including a target quit date.
Quit Guide | A take-home, patient-focused guide to quitting, usually incorporating some skill building, tips on reduction and cessation, and practical advice. This includes practical information and/or directions that the patient can use or do as distinguished from Information which provides factual or educational material only.
Stop Smoking Contract | Contract or formalized commitment to a specific quit date.
Usual Care | Described as such by study authors without specific details about what this entails.
Other | Unique component that cannot be grouped.

Overall, effects of individual studies were mixed, with nine of the good and fair quality studies reporting statistically significant positive results. In all cases where types of interventions were suggested to have positive results in some studies, other studies appear to contradict those results, even among higher quality studies. Among positive studies, most were multicomponent and form a heterogeneous set of interventions. The meta-analysis presented in KQ4 provides a detailed exploration of the individual components that may promote the apparent success of interventions. Table 5 presents individual difference in smoking cessation at the end of pregnancy for the good and fair quality studies and is followed by Table 6, which presents the difference in smoking relapse at last followup. Relapse prevention indicates the woman has not resumed smoking and is synonymous with continued cessation

Table 5 Difference in smoking cessation at end of pregnancy

Author, Year Country (Number Randomized) | Quality | Intervention (number analyzed) | Cessation, % | Cessation, %Δ | Significance (association)
Heil et al., 2008^84^ U.S. (82) | Fair | Contingent vouchers (37) Control (40) | 41.0 10.0 | 31.0 | *(p=0.003)
Ondersma et al., 2012^97^ U.S. (110) | Good | Educational materials (CD-5A's) (23) Usual care (23) | 43.5 17.4 | 26.1 | *(p<0.05) (OR=10.1,^a^ 95% CI: 1.4 to 75.0)
Donatelle et al., 2000^110^ U.S. (220) | Fair | Multicomponent (105) Usual care (102) | 32.0 9.0 | 23.0 | *(p<0.0001)
Dornelas et al., 2006^86^ U.S. (105) | Fair | Counseling (53) Usual care (52) | 28.3 9.6 | 18.7 | *(p=0.02)
Windsor et al., 1985^93^ U.S. (309) | Fair | Multicomponent (102) Usual care (104) | 14.0 2.0 | 12.0 | *(RR=0.12, 95% CI: 0.05 to 0.19)
Walsh et al., 1997^130^ U.S. (293) | Good | Multicomponent (127) Control (125) | 13.0 6.0 | 7.0 | *(p=0.0353)
Windsor et al., 1993^39^ U.S. (994) | Fair | Multicomponent (400) Usual care (414) | 14.3 8.5 | 5.8 | *(p=0.01)
Albrecht et al., 2006^85^ U.S. (142) | Good | Peer Support (TFS-B) (45) Usual care (50) | NR | NR | *(p=0.01) (OR=3.73, 99% CI: 1.00 to 13.89)
Hartmann et al., 1996^92^ U.S. (250) | Good | Multicomponent (107) Usual care (100) | 20.0 10.0 | 10.0 | NS (p=0.052) (OR=2.20, 95% CI: 0.98 to 4.94)
Hennrikus et al., 2010^101^ U.S. (82) | Fair | Peer Support (54) Usual care (28) | 13.0 3.6 | 9.4 | NS
Ershoff et al., 1989^117^ U.S. (323) | Fair | Educational materials (126) Usual care (116) | 26.2 17.2 | 9.0 | NS (p=0.09)^b^
Windsor et al., 1985^93^ U.S. (309) | Fair | Multicomponent (Windsor Guide) (102) Multicomponent (ALA Guide) (103) | 14.0 6.0 | 8.0 | NS (RR=0.08, 95% CI: −0.00 to 0.16)
Stotts et al., 2009^83^ U.S. (360) | Fair | Biologic feedback (MI + US) (120) Usual care (BP) (120) | 18.3 10.8 | 7.5 | NS (p=0.30)^c^
Burling et al., 1991^119^ U.S. (139) | Fair | Educational materials (70) Usual care (69) | 13.0 5.7 | 7.3 | NS
Naughton et al., 2012^123^ U.K. (207) | Good | Educational materials (96) Usual care (102) | 12.5 7.8 | 4.7 | NS (OR=1.68, 95% CI: 0.66 to 4.31)
Secker-Walker et al., 1998^90^ U.S. (399) | Fair | Counseling (135) Usual care (141) | 14.1 9.9 | 4.2 | NS (OR=1.49, 95% CI: 0.71 to 3.10)
Ershoff et al., 1999^89^ U.S. (390) | Fair | Counseling (MI) (101) Counseling (IVR) (120) | 20.8 16.7 | 4.1 | NS
Windsor et al., 1985^93^ U.S. (309) | Fair | Multicomponent (103) Usual care (104) | 6.0 2.0 | 4.0 | NS (RR=0.04, 95% CI: −0.01 to 0.09)
Stotts et al., 2009^83^ U.S. (360) | Fair | Biologic feedback (BP + US) (120) Usual care (BP) (120) | 14.2 10.8 | 3.4 | NS (p=0.30)^d^
Oncken et al., 2008^102^ U.S. (194) | Fair | NRT (100) Placebo (94) | 18.0 14.9 | 3.1 | NS (p=0.56)
Malchodi et al., 2003^107^ U.S. (142) | Good | Peer Support (67) Usual care (75) | 24.0 21.0 | 3.0 | NS (p=0.84)
Rigotti et al., 2006^87^ U.S. (442) | Good | Counseling (209) Usual care (212) | 10.0 7.5 | 2.5 | NS (p=0.39) (OR=1.37, 95% CI: 0.69 to 2.70)
Coleman et al., 2012^122^ U.K. (1050) | Good | NRT (521) Placebo (529) | 9.4 7.6 | 1.8 | NS (OR=1.26, 95% CI: 0.82 to 1.96)
Cinciripini et al., 2010^100^ U.S. (266) | Good | Other (CBT) (128) Usual care (129) | 18.0 16.3 | 1.7 | NS (OR=1.1, 95% CI: 0.6 to 2.2)
Gielen et al., 1997^91^ U.S. (467) | Fair | Multicomponent (193) Usual care (198) | 6.2 5.6 | 0.6 | NS
Hajek et al., 2001^88^ U.K. (1120)^e^ | Good | Multicomponent (431) Usual care (440) | 6.0 7.0 | (1.0) | NS
Ershoff et al., 1999^89^ U.S. (390) | Fair | Counseling (MI) (101) Booklet (111) | 20.8 22.5 | (1.7) | NS
Moore et al., 2002^126^ U.K. (1527) | Good | Educational materials (600) Usual care (695) | 18.8 20.7 | (1.9) | NS (95% CI: −3.5% to 7.3%)
Ondersma et al., 2012^97^ U.S. (110) | Good | Educational materials (CD-5A's + CM-Lite) (26) Usual care (23) | 15.4 17.4 | (2.0) | NS
Ondersma et al., 2012^97^ U.S. (110) | Good | Educational materials (CM-Lite) (22) Usual care (23) | 13.6 17.4 | (3.8) | NS
Ershoff et al., 1999^89^ U.S. (390) | Fair | Counseling (IVR) (120) Booklet (111) | 16.7 22.5 | (5.8) | NS
Albrecht et al., 2006^85^ U.S. (142) | Good | Peer Support (TFS) (47) Usual care (50) | NR | NR | NS (p=0.16) (OR=2.11, 99% CI: 0.54 to 8.19)
Albrecht et al., 2006^85^ U.S. (142) | Good | Peer Support (TFS) (47) Peer Support (TFS-B) (45) | NR | NR | NS (p=0.21) (OR=1.77, 99% CI: 0.55 to 5.71)

Abbreviations: BP = best practice; CBT = cognitive behavioral therapy; CI = confidence interval; CD-5A's = computer delivered 5A's; CM-Lite = low intensity contingency management; NS = not significant; NR = not reported; NRT = nicotine replacement therapy; OR = odds ratio; RR = relative risk; TFS = Teen FreshStart; TFS-B = Teen FreshStart plus buddy; IVR = interactive voice response; MI = motivational interviewing; US = ultrasound; U.S. = United States.

Notes: Includes good and fair quality studies only; includes a separate row for each comparison of multiple intervention studies; does not include studies that reported cessation at postpartum only; does not include studies that enrolled recent quitters only; rows ordered by significance and then by difference in cessation; asterisk (*) indicates statistical significance.

a Odds ratio adjusted for minority status and baseline smoking status; unadjusted OR=3.7 (95% CI: 0.94 to 14.2) p=NS.

b When combining early, middle, and late quitters to calculate overall quit rates, 26.2 percent of women in the intervention arm and 17.2 percent of control women were considered quit over the study period. The difference is not significant as calculated by the review team. Study reports differences as adjusted for “Early Quitting” (OR=2.80, 95% CI: 1.17 to 6.69); outcome selected post hoc upon seeing the difference in proportions among the subgroup, and assigns a smoking status to individuals who were later quitters, more of whom were in the control group, thus inflating the observed effect in terms of overall quit rates.

c P-value for 3-way comparison

d P-value for 3-way comparison

e Enrolled smokers (n=871) and quitters (n=249); relapse prevention for quitters reported in table 6.

Table 6 Difference in smoking relapse at last followup

Author, Year Country (Number randomized) | Quality | Intervention (number analyzed) | Relapse prevention,^a^ % | Relapse prevention, %Δ | Significance (association)
Phillips et al., 2012^80^ U.S. (54) | Good | Mother-infant bonding (21) Usual care (28) | 81.0^b^ 46.0 | 35.0 | *(p<0.001)
Suplee, 2005^79^ U.S. (62) | Fair | Multicomponent (30) Usual care (32) | 37.0^c^ 25.0 | 12.0 | NS (p=0.319)
Johnson et al., 2000^82^ Canada (254) | Good | Counseling (125) Usual care (126) | 37.6^d^ 27.0 | 10.6 | NS (p=0.1) (OR=1.63, 95% CI: 0.96 to 2.78)
Ershoff et al., 1995^94^ U.S. (218) | Fair | Educational materials (87) Usual care (84) | 83.9 79.8 | 4.1 | NS
Hajek et al., 2001^88^ U.K. (1120)^e^ | Good | Multicomponent (114) Usual care (135) | 23.0^f^ 25.0 | (2.0) | NS

Abbreviations: CI=confidence interval; NS=not significant; OR=odds ratio; U.K.=United Kingdom; U.S.=United States.

Notes: Includes good and fair quality studies only; does not include studies that enrolled current smokers only; rows ordered by significance and then by difference in relapse prevention; asterisk (*) indicates statistical significance.

a Relapse prevention indicates the woman has not resumed smoking and is synonymous with continued cessation.

b 8 weeks postpartum

c 4 to 8 weeks postpartum

d 6 months postpartum

e Enrolled smokers (n=871) and quitters (n=249); cessation for current smokers reported in table 5

f 6 months postpartum

### Counseling

#### Key Points

- Fourteen studies attempted to assess counseling interventions as the primary intervention, although counseling was ubiquitous in the overall literature: two of these were good quality, three of fair quality, and nine of poor quality.
- Counseling interventions included motivational interviewing, cognitive behavioral therapy (CBT), and psychotherapy.
- Nine studies enrolled pregnant women who were current smokers. One fair-quality study found a significant effect of the intervention at the end of pregnancy; however, the difference in the intervention and control groups did not persist at six months postpartum.
- Four studies enrolled pregnant women who had quit smoking prior to study entry, and none of these studies found statistically significant differences in maintaining cessation between the intervention and control groups.
- Two studies evaluated counseling for postpartum women who were not smoking at the time of birth, and neither had an effective intervention.
- Postpartum relapse rates were high and increased over time.

#### Description of Included Studies

We identified 14 RCTs81, 82, 86, 87, 89, 90, 99, 105, 108, 111, 114, 115, 129, 132 that examined effectiveness of counseling interventions in getting smokers to quit or helping quitters avoid relapse. Ten of the studies were conducted in the United States,86, 87, 89, 90, 99, 105, 108, 111, 114, 115 and one each in Canada,82 Scotland,132 Spain,81 and Australia.129 The majority (12) of the studies included pregnant women,86, 87, 89, 90, 99, 105, 108, 111, 114, 115, 129, 132 and two studies enrolled women during their postpartum hospitalization.81, 82 Eight studies were conducted in pregnant women who were currently smoking,86, 87, 89, 90, 108, 115, 129, 132 four studies enrolled women who had quit smoking prior to the study (recent quitters),82, 99, 111, 114 and two studies enrolled both current and former smokers.81, 105 These 14 studies included a total of 5,499 participants at randomization (range 105 to 1,065) and 4,371 participants at analysis (range 92 to 762). Eleven studies reported outcomes at the end of pregnancy, and six studies reported postpartum outcomes with the latest followup at 12 months postpartum. Two studies were good quality,82, 87 three fair quality,86, 89, 90 and the remaining nine were scored poor quality.81, 99, 105, 108, 111, 114, 115, 129, 132 Table 7 provides an overview of the good and fair quality studies.

Table 7 Overview of good and fair quality studies for counseling interventions

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time Point for Final Validated Cessation Measure | Population | Effect
Rigotti et al., 2006^87^ 442 Good | Telephone counseling vs. “best practice” brief counseling | Counseling, clinic reinforcement, information, and personal followup | Pregnancy: 28 weeks to term Postpartum: 3 months | Pregnant smokers, mean gestation 12.6 weeks, mean age 28.5, 87.5% White, 73% private insurance | No difference at either time point
Johnson et al., 2000^82^ 254 Good | In-hospital counseling sessions and telephone followup vs. usual care | Counseling, personal followup, and quit guide | Pregnancy: NA Postpartum: 6 months | Women enrolled after birth, recent quitters, mean age 27.6 years, 75% Canadian born | No difference
Dornelas et al., 2006^86^ 105 Fair | In-person counseling and telephone followup vs. usual care | Counseling, clinic reinforcement, information, and personal followup | Pregnancy: 36 weeks Postpartum: 6 months | Pregnant smokers,≤ 30 weeks' gestation, low-income, 66% Hispanic | Cessation significantly (p=0.02) higher for intervention vs. control at end of pregnancy; no difference at 6 months postpartum
Ershoff et al., 1999^89^ 390 Fair | Motivational interviewing telephone counseling and booklet vs. computerized cessation program and booklet vs. booklet only | Counseling, personal followup, and quit guide vs. quit guide and other | Pregnancy: 32 to 36 weeks Postpartum: NR | Pregnant smokers, age ≥ 18 years, 60% White, 50% at least some college, 100% HMO | No difference
Secker-Walker et al., 1998^90^ 399 Fair | Structured physician advice and referral to individualized behavior change counseling vs. usual care | Counseling, clinic reinforcement, and feedback about biologic measures | Pregnancy: 36 weeks Postpartum: NR | Pregnant smokers, mean age 22.5 years, 72% Medicaid | No difference

Abbreviations: NA = not applicable; NR = not reported.

The type of counseling and provider varied among the studies. Motivational interviewing, defined as “a collaborative, person-centered form of guiding to elicit and strengthen motivation for change,”135 was used in seven studies, either alone or in combination with cognitive behavioral methods.81, 87, 89, 99, 105, 108, 132 Two studies82, 129 evaluated CBT, a therapy that focuses on changing an individual's thoughts in order to promote behavior change. Psychotherapy, which assumes behavioral change is more likely when the patient experiences affective arousal during the counseling with a high degree of interpersonal engagement with the therapist, was used in one study.86 Four studies evaluated individualized smoking behavior change counseling for cessation90, 115 or relapse prevention.111, 114

Seven studies evaluated individual in-person counseling,90, 111, 114, 115, 129 including two studies that provided home visits,105, 132 and five studies that used telephone counseling.81, 87, 89, 99, 108 In two studies, the intervention was a combination of an in-person counseling session with followup telephone sessions.82, 86 Treatment providers included therapists, bachelor or masters level counselors, trained midwives, public health nurses, and nurse educators.

#### Detailed Synthesis

##### Pregnant Women

###### Smoking Cessation

Nine counseling studies, one good quality,87 three fair quality,86, 89, 90 and five poor quality,105, 108, 115, 129, 132 enrolled pregnant women who were currently smoking. Four of the counseling interventions were based on motivational interviewing techniques,89, 105, 108, 132 one study used CBT,129 one study used CBT and motivational interviewing,87 and one study evaluated a 90-minute psychotherapy session.86 Two studies provided individualized smoking behavior change counseling.90, 115 Counseling was conducted in-person in five studies, either at the clinic90, 115, 129 or at the patient's home,105, 132 and delivered by telephone in three studies.87, 89, 108 One study combined a clinic in-person session with telephone followup.86 The number of scheduled counseling sessions ranged from one to six, though treatment fidelity varied widely within studies.

The proportions of reported cessation at the end of pregnancy ranged from less than 5 percent up to 34 percent. There were no statistically significant differences in cessation between groups in six studies that only reported a validated cessation measure at the end of pregnancy.89, 90, 108, 115, 129, 132 Three studies reported validated cessation measured at 3 months87 and 6 months86, 105 postpartum, ranging from 4 to 10 percent, in addition to the end of pregnancy. Although one of these studies reported higher cessation in the women randomized to the counseling intervention at the end of pregnancy, the difference between groups was not sustained by 6 months postpartum.86 Cessation declined in the postpartum period in both studies that reported validated outcomes from the end of pregnancy and postpartum.86, 87 Outcomes of these studies are summarized in Table 8.

Table 8 Smoking cessation outcomes of counseling interventions for pregnant women

Author, Year Country Population Quality | Comparison Groups (number randomized/ analyzed) | Key Cessation Outcomes
Rigotti et al., 2006^87^ U.S. Pregnant smokers Good | G1: Telephone counseling intervention (220/209) G2: Brief counseling (“best practice”) call (222/212) | - No significant difference in cessation between groups at the end of pregnancy (10% in G1 vs. 7.5% in G2) or at 3 months postpartum (6.7% in G1 vs. 7.1% in G2).; - Very few women had sustained abstinence at both time points (4.8% in G1 and 3.3% in G2).; - Smoking fewer than 10 cigarettes per day and younger (< 25 years) age were predictors of cessation.
Dornelas et al., 2006^86^ U.S. Pregnant smokers Fair | G1: One in-person counseling session and telephone followup (53/53) G2: Usual care (52/52) | - Biochemically confirmed cessation in G1 was significantly higher than in G2 (28.3% vs. 9.6%, p=0.015) at the end of pregnancy.; - Cessation declined in both groups (9.4% in G1 vs. 3.8% in G2, p=0.251) at 6 months postpartum.
Ershoff et al., 1999^89^ U.S. Pregnant smokers Fair | G1: Motivational interviewing telephone counseling and booklet (126/101) G2: Computerized telephone cessation program plus booklet (133/120) G3: Booklet only (131/111) | - Urinary cotinine confirmed cessation was comparable in the three groups at the end of pregnancy: 20.8% (G1) vs. 16.7% (G2) vs. 22.5% (G3).
Secker-Walker et al., 1998^90^ U.S. Pregnant smokers Fair | G1: Structured physician advice and referral to individual smoking behavior change counseling (197/135) G2: Usual care (202) | - Cessation at the 36-week prenatal visit confirmed by carbon monoxide exhalation was similar in both groups (14.1% in G1 vs. 9.9% in G2).
Reitzel et al., 2010^99^ U.S. Pregnant quitters Poor | G1: Motivation and Problem solving (MAPS) counseling- 6 telephone sessions (68/68) G2: MAPS plus two additional in-person counseling sessions (68/68) G3: Usual care (115/115) | - The authors combined the findings from women in G1 and G2 for analyses.; - Smoking cessation was not significantly higher in the combined intervention groups (41.9% in G1 + G2 vs. 27.8% in G3) at 8 weeks postpartum.; - Smoking cessation had declined in both groups (22.8% in G1 + G2 vs. 16.5% in G3, p=0.08) at 6 months postpartum.
Ruger et al., 2008^105^ U.S. Pregnant smokers and quitters Poor | G1: Motivational interviewing home visits and self-help materials (156, 132 smokers and 24 quitters/131, 110 smokers and 21 quitters) G2: Usual care including self-help materials (146, 113 smokers and 33 quitters/128, 100 smokers and 28 quitters) | - No difference in the number of nonsmokers at 6 months postpartum in G1 vs. G2 for current smokers (6% vs. 8%) and recent quitters (43% vs. 18%).
Tappin et al., 2005^132^ Scotland Pregnant smokers Poor | G1: Home based motivational interviewing (351/351) G2: Usual care (411/411) | - Cotinine validated quit proportion at the end of pregnancy was 4.8% in G1 and 4.6% in G2 (RR=1.05; 95% CI: 0.55 to 1.98).
Stotts et al., 2002^108^ U.S. Pregnant smokers Poor | G1: Two motivational interviewing based telephone counseling calls and personalized letter (134/86) G2: Usual care (135/89) | - The proportion of women with urinary cotinine confirmed cotinine cessation at the 34-week prenatal visit was comparable between groups (32% in G1 vs. 34% in G2, p<0.65).
Panjari et al., 1999^129^ AUS Pregnant smokers Poor | G1: Counseling sessions provided by midwife (476/339) G2: Usual care (537/393) | - No significant difference in the proportion of women who quit in late pregnancy between groups (11.9% in G1 vs. 9.8% in G2, p=0.41).
Secker-Walker et al., 1998^111^ U.S. Pregnant quitters Poor | G1: Structured physician advice and referral to relapse prevention counselor (62/44) G2: Usual care (63/48) | - Carbon monoxide exhalation confirmed cessation was 77% in both groups at the 36-week prenatal visit.
Secker-Walker et al., 1995^114^ U.S. Pregnant quitters Poor | G1: Individualized smoking relapse prevention counseling (89/68) G2: Usual care (86/65) | - In the subset of women with cotinine verified smoking outcomes, 29.5% in G1 and 27.9% in G2 relapsed to smoking by the end of pregnancy.
Secker-Walker et al., 1994^115^ U.S. Pregnant smokers Poor | G1: Individualized smoking cessation counseling (300/188) G2: Usual care (300/226) | - The proportion of women who had urinary cotinine-creatinine ratios ≤80 ng/mg at the 36-week visit was similar in both groups (11.8% in G1 vs. 12.5% in G2).

Abbreviations: AUS = Australia; CI = confidence interval; G = group; MAPS = motivation and problem solving; NS = not significant; OR = odds ratio; RR = risk ratio; U.S. = United States.

A good-quality study in 442 U.S. women recruited from a health maintenance organization (HMO) and community clinics evaluated a motivational interviewing and cognitive-behavioral counseling intervention delivered by trained counselors via telephone.87 The mean number of calls was five (range 0 to 20), and 96 percent of the women received at least one call. The control group received a brief smoking counseling call at enrollment consistent with best practices. The cotinine validated quit proportions at the end of pregnancy were 10 percent for the intervention group and 7.5 percent for the control group (OR=1.37; 95% CI: 0.69 to 2.70). These declined to 6.7 percent and 7.1 percent respectively at the 3-month postpartum visit (OR=0.93; 95% CI: 0.44 to 1.99).

The three studies of fair quality were conducted in the United States.86, 89, 90 Ershoff et al randomized 390 HMO members into one of three groups: motivational interviewing telephone counseling plus a quit guide booklet, a computerized cessation program plus booklet, and a control group who only received the booklet.89 The cotinine validated quit rates in late pregnancy were similar in all three groups (20.8%, 16.7%, and 22.5% respectively). A fair-quality study in 105 low-income predominantly Hispanic women compared a 90-minute in-person psychotherapy session administered by a trained counselor with telephone followup to usual care which included standard cessation advice from a health care provider.86 Cessation was significantly higher among women who were randomized to the intervention compared with the usual care group at the end of pregnancy verified by carbon monoxide levels, (28.3% vs. 9.6%, p=0.015) but these proportions fell by 6 months postpartum to 9.4 percent and 3.8 percent respectively (p=0.251). Only 68 percent of the women who were randomized to the intervention group received the counseling session, and telephone followup averaged 2.6 calls for this subset.

A fair-quality study that recruited women from a State maternal infant care clinic for underserved women and an adolescent clinic in Vermont randomized 197 women to receive structured physician advice and referral to individual relapse prevention counseling at their first, second, third, and fifth prenatal visits and 202 women to usual care.90 At the 36-week prenatal visit, 14.1 percent of women in the intervention group and 9.9 percent in the control group were not smoking (OR=1.49; 95% CI: 0.71 to 3.10).

The five studies of poorer quality did not report statistically significant benefits of counseling interventions.105, 108, 115, 129, 132

###### Relapse Prevention

Four U.S. studies, all of poor quality, enrolled pregnant women who had quit smoking at the start of the study.99, 105, 111, 114 One of these studies also enrolled current smokers.105 The counseling intervention was individualized smoking relapse prevention in two studies,111, 114 a combination of problem-solving skills and motivational interviewing in one study,99 and an individually tailored motivational intervention in one study.105 Counseling was conducted in person in three studies, either at the clinic111, 114 or in the patient's home,105 and via telephone in one study.99Some of the participants in the study with telephone counseling also received in-person counseling sessions.99 Two studies used in-person clinic individualized smoking relapse prevention counseling.111, 114

None of the studies found statistically significant differences in cessation between the intervention and control groups. The proportions of cessation ranged from 70 percent to 77 percent in the two studies that reported validated measures at the end of pregnancy111, 114 and 17 percent to 43 percent in the two studies that reported validated measure at 8 weeks99 and 6 months99, 105 postpartum. Outcomes of these studies are summarized in Table 8.

##### Postpartum Women

###### Relapse Prevention

Two studies, one good and one poor quality, enrolled women during postpartum hospitalization who had quit smoking while they were pregnant.81, 82

A good-quality study conducted in five Canadian hospitals randomized 254 women who had quit at least 6 weeks prior to birth to intervention or usual care.82 Mothers in the intervention arm received an in-person counseling session from a nurse and up to eight telephone followup phone calls during the first 3 postpartum months, which was compared with usual care. Smoking status was assessed at a home visit six months postpartum and verified by a carbon monoxide exhalation level of less than 10 parts per million (ppm). The majority of women in this study had resumed smoking, but a higher proportion of women who received counseling maintained cessation compared with those who had usual care (37.6% vs. 27.0%; OR=1.63; 95% CI: 0.96 to 2.78). At 12-month followup, cessation had declined to 21.0 percent in the intervention group and to 18.5 percent in the control group.136 The authors noted that among women who maintained cessation at 6 months, 21 percent had relapsed at one year. However, 16 percent who were smoking at 6 months had stopped smoking at 12 months. The poor-quality study81 of motivational interviewing telephone counseling sessions enrolled both current smokers and recent quitters (defined as women who had stopped smoking at the beginning of or during pregnancy) but only reported outcomes on the latter, which can be found in Table 9.

Table 9 Smoking cessation outcomes of counseling interventions for postpartum women

Author, Year Country Population Quality | Comparison Groups (number randomized/ analyzed) | Key Cessation Outcomes
Johnson et al., 2000^82^ Canada Postpartum quitters Good | G1: In-hospital counseling session after birth and telephone followup up to 8 sessions (125/121) G2: Usual care (126/120) | - Smoking cessation at the 6-month postpartum visit fell to 38% in G1 and 27% in G2 (OR=1.63; 95% CI: 0.96 to 2.78).
Jimenez-Muro et al., 2012^81^ Spain Postpartum smokers and quitters Poor | G1: Four telephone calls based on Motivational Interviewing (205, 117 smokers and 88 quitters/88 quitters) G2: Control group received two status check calls (207, 117 smokers and 90 quitters/90 quitters) | - No difference in smoking cessation at 3 months postpartum (31% in G1 vs. 23% in G2, p=0.13).; - Only half of the women attended the 3-month visit.

Abbreviations: CI = confidence interval; G = group; NS = not significant; OR = odds ratio.

### Educational Materials

#### Key Points

- Ten studies assessed educational materials interventions: three of good quality, three of fair quality, and four of poor quality.
- Five studies primarily focused primarily on print-based interventions, two on video-based interventions, and three on technology-based interventions.
- One study reported that a computer-based 5A's intervention was associated with higher quit rates than usual care. Two additional studies found greater cessation in intervention participants compared with control participants earlier in pregnancy, but the differences had attenuated by the end of pregnancy.
- No specific educational materials were associated with higher cessation than other materials.
- Loss to followup for reasons other than pregnancy loss or changing practitioners was high across studies.

#### Description of Included Studies

Ten studies reported in 13 publications addressed educational materials interventions for smoking cessation.94, 97, 113, 116, 117, 119, 123, 125, 126, 134, 137-139 Six studies were conducted in the United States,94, 97, 113, 116, 117, 119, 139 three in the United Kingdom,123, 125, 126, 137, 138 and one in Sweden.134 All of the studies were conducted during the prenatal period. Most studies (8) enrolled women who were current smokers. One included both current smokers and recent quitters,126 and one included only recent quitters.94 These 10 studies included a total of 4,418 participants at randomization (range 60 to 1527) and 2,562 participants at analysis (range 46 to 653). All ten studies report outcomes at the end of pregnancy, and two studies report postpartum outcomes with the latest followup at 8 weeks postpartum. We rated three studies as good quality,97, 123, 126 three as fair,94, 117, 119 and four as poor.113, 116, 125, 134

Studies assessed print-based, video-based, or technology-based educational materials and often combined modalities. We have organized studies in this section by the modality of the key active component. The materials included quit guides, which provide practical advice for quitting smoking or preventing relapse, and information, which is factual or educational material only. An overview of the good and fair studies is presented in Table 10; outcomes for all of the studies are presented in Table 11.

Table 10 Overview of good and fair quality studies for educational materials

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time Point for Final Validated Cessation Measure | Population | Effect
Naughton et al., 2012^123^ 207 Good | Tailored self-help materials via mail and text message vs. non-tailored self-help materials via mail | Quit guide and personal followup | Pregnancy: 12 weeks post-enrollment Postpartum: NR | Adult smokers <21 weeks pregnant at baseline, median age 26,100% White, 100% National Health Service | No difference
Ondersma et al., 2012^97^ 110 Good | Computer-delivered 5A's vs. contingency management vs. computer-delivered 5A's plus contingency management vs. usual care | Information and other vs. feedback and incentives vs. incentives, information, feedback, and other | Pregnancy: 10 weeks post-enrollment Postpartum: NR | Lower income, adult smokers, ≤27 weeks pregnant at baseline, 90% Black | Significantly (p<0.05) greater cotinine-validated cessation in computer-based 5A's arm vs. usual care (OR=10.1,^a^ 95% CI: 1.4 to 75.0)
Moore et al., 2002^126^ 1,527 Good | Quit guides vs. usual care | Quit guide and counseling | Pregnancy: End of second trimester Postpartum: NR | Adult smokers and recent quitters, < 17 weeks pregnant at baseline, 100% National Health Service | No difference
Burling et al., 1991^119^ 139 Fair | Counseling with and without a personalized letter from the Chief of Service and American Cancer Society pamphlet vs. usual care | Information, counseling, and personal followup | Pregnancy: Last study contact^a^ Postpartum: NR | Adult smokers average gestation less than 24 weeks | No difference in the overall cessation, but greater cessation for the intervention group at the second contact, so intervention may be associated with earlier quitting
Ershoff et al., 1989^117^ 323 Fair | Quit guides vs. usual care | Quit guide, counseling, and information | Pregnancy: 34 weeks Postpartum: NR | Adult smokers, majority 9 to 13 weeks pregnant at baseline, majority White, 100% HMO | No difference in overall cessation, although investigators suggest that intervention participants quit earlier in pregnancy

Abbreviations: HMO = health maintenance organization; NR = not reported.

a Varied, (approximately 34 weeks' gestation)

Table 11 Smoking cessation outcomes of educational materials

Author, Year Country Population Quality | Comparison Groups (number randomized/analyzed) | Key Cessation Outcomes
Naughton et al., 2012^123^ U.K. Pregnant smokers Good | G1: Tailored quit guide plus tailored text messages (102/96) G2: Non-tailored quit guide (105/102) | - Differences in cotinine-validated cessation 12 weeks after enrollment were not significant (12.5% in G1 vs. 7.8% in G2, OR=1.68, 95% CI: 0.66 to 4.31).
Ondersma et al., 2012^97^ U.S. Pregnant smokers Good | G1: Computer-delivered 5A's (CD-5A's) brief intervention (26/23) G2: Computer-assisted low-intensity contingency management (CM-Lite) (28/22) G3: CD-5A's plus CM-Lite (30/26) G4: Usual care (26/23) | - At the 10-week followup visit, cotinine validated smoking cessation was 43.5% in G1, 13.6% in G2, and 15.4% in G3 compared with 17.4% in the usual care group (G4).; - The difference in outcomes was significant when comparing the CD-5A's group (G1) to the usual care group (G4) only.
Lawrence et al., 2003^125^ U.K. Pregnant smokers Poor | G1: Stage-quit guides (305/219) G2: Stage-based quit guides plus interactive computer program to assess state of change (324/249) G3: Controls (standard advice) (289/185) | - No significant differences between groups at 30 weeks pregnancy or at 10 days after birth.
Moore et al., 2002^126^ U.K. Pregnant smokers and quitters Good | G1: Quit Guides (724/113) G2: Usual care (803/144) | - No difference in the urine cotinine validated smoking cessation (18.8% in G1 vs. 20.7% in G2) at the end of the second trimester of pregnancy.
Secker-Walker et al., 1997^113^ U.S. Pregnant smokers Poor | G1: Video, advice, and tip sheet (30/19) G2: Advice and tip sheet (30/27) | - Five of the 19 video group participants reported not smoking at 36 weeks and had exhaled carbon monoxide levels in the non-smoking range compared with zero women in the comparison group (p=0.02).
Price et al., 1991^116^ U.S. Pregnant smokers Poor | G1: Educational video (71/46) G2: American Lung Association quit guide (52/39) G3: Usual care (70/24) | - No significant differences in carbon monoxide exhalation validated smoking cessation between the groups (8.7% in G1, 5.1% in G2, and 4.2% in G3) at birth.
Hjalmarson et al., 1991^134^ Sweden Pregnant smokers Poor | G1: Quit Guide (Windsor) (492/444) G2: Information sheet from physician (231/209) | - No significant differences in cessation at the end of pregnancy (30.4% in G1 vs. 8.6% in G2; OR=0.7; 95% CI: 0.4 to 1.1).; - Smoking cessation at 8 weeks postpartum was 15.8% in G1 and 9.1% in G2, a statistically significant difference (OR=0.5; 95% CI: 0.3 to 0.9).
Ershoff et al., 1989^117^ U.S. Pregnant smokers Fair | G1: Quit Guide (165/126) G2: Usual care (158/116) | - No difference in overall cessation, although investigators suggest that intervention participants quit earlier in pregnancy.; - Early quit was predicted by intervention status with 22.2% of early quitters in G1 vs. 8.6% in G2.
Burling et al., 1991^119^ U.S. Pregnant smokers Fair | G1: Counseling plus a personalized letter and American Cancer Society pamphlet (70/70) G2: Counseling only (69/69) | - No difference in cessation at the final study visit, but higher cessation at visit 2 (11.6% in G1 vs. 1.4% in G2; p<0.01).
Ershoff et al., 1995^94^ U.S. Pregnant quitters Fair | G1: Quit Guide to prevent relapse (110/87) G2: Usual Care (108/84) | - At the 26-week interview, 78.9% of the 87 women in the intervention group available for followup and 84.7% of 84 women in the usual care arm had confirmed smoking cessation (proportions adjusted for gravida, length of abstinence, smoking belief, and quitting self-efficacy); p=NS.

Abbreviations: CI = confidence interval; G = group; NS = not significant; OR = odds ratio; RR = risk ratio; UK = United Kingdom; U.S. = United States.

#### Detailed Synthesis

Of the 10 studies evaluating educational materials, five focused primarily on print-based interventions,94, 117, 119, 126, 134two on video-based interventions,113, 116 and three on technology-based interventions.97, 123, 125 The proportion of women with validated smoking cessation ranged from zero to 85 percent at the end of pregnancy and from 4 to 16 percent at 10 days125 to 8 weeks134 postpartum. Three studies demonstrated some effectiveness of an educational materials intervention. In one good-quality but small study (n=110), 43.5 percent of women that completed a tailored, single-session, interactive computer program had validated cessation at the end of pregnancy compared with 17.4 percent of women that received usual care (OR=10.2; 95% CI: 1.4 to 75.0).97 Two studies found a higher proportion of cessation in intervention participants compared with control participants at one time point but no difference at another time point.119, 134

##### Print-Based Interventions

Five studies examined the effects of print-based educational materials.94, 117, 119, 126, 134 Of these, one was good quality,126 three fair,94, 117, 119 and one poor.134

The one good-quality cluster RCT was conducted in the United Kingdom and allocated midwives to usual care or usual care plus distribution of five self-help booklets (quit guides) with pregnant women who were currently smoking or who had stopped after learning they were pregnant.126 No description was provided of what smoking cessation elements may have been a part of usual care. Midwives were instructed to spend about 5 minutes reviewing the first booklet with participants allocated to the self-help intervention; subsequent booklets were mailed. Booklets included motivational and behavioral strategies for cessation and relapse prevention. Women completed a mailed questionnaire at 26 weeks' gestation, and investigators collected a urine sample for cotinine analysis from those indicating smoking cessation for 7 or more days (n=363/1317 completing the followup questionnaire). Results for current smokers and recent quitters were not reported separately. One hundred thirteen (18.8%) women in the intervention group and 144 (20.7%) women in the usual care group had validated non-smoking status, and there was no significant difference in cessation between the two groups (difference=1.9%; 95% CI: −3.5% to 7.3%; p=NS).

Three fair-quality studies considered the potential for written educational materials to lead to increases in cessation during pregnancy.94, 117, 119 Two of the studies used the same intervention in different study populations (current smokers and recent quitters).

In one fair-quality study, investigators randomized pregnant smokers, defined by either self-report or exhaled carbon monoxide analysis, to receive either nurse-provided education (counseling) about health behaviors including smoking or the same education plus a personal letter from the chief of the prenatal clinic and an American Cancer Society pamphlet about smoking during pregnancy.119 The counseling component was a standard part of prenatal care. The letter identified participants as probable smokers based on interviews and carbon monoxide exhalation samples, advised them about the health risks of smoking, and encouraged them to quit.119 Investigators assessed smoking status via self-report and exhaled carbon monoxide at each clinic visit. The number of study contacts ranged from 2 to 12, and investigators analyzed data from the first, second, and last contacts, which they say roughly corresponded to the 24^th^, 28^th^, and 34^th^ weeks of gestation. Cessation was significantly higher in the intervention group compared with the usual care group at the second study contact (11.6% vs. 1.4%, p<0.01) but not at the third contact (13.0% in the intervention group vs. 5.7% in usual care, p<0.10), suggesting that although women in the intervention group may have quit earlier, rates of quitting evened out through pregnancy.119

One HMO-based RCT reported in two publications117, 139 and conducted in the United States included 323 current smokers from varied socioeconomic and ethnic backgrounds. The study assessed the effects of a quit guide that comprised a series of eight self-help booklets focused on cessation motivation and relapse prevention and targeted to pregnant women compared with usual care. All participants received a two-page pamphlet on smoking cessation delivered by a health educator, and the participants randomized to the intervention group also received the first of eight self-help booklets along with a brief overview from a health educator. Investigators mailed the remaining booklets to participants at weekly intervals. Participants completed a telephone interview at 26 weeks followed by analysis of stored urine samples to validate self-reported quitting (quit defined as no cotinine value greater than 29 ng/ml and at least one value less than 10 ng/ml). Investigators also performed a final urinalysis at 34 weeks.

Investigators classified the participants as follows:

- early quitters (quit when less than 20 weeks pregnant)
- middle quitters (quit between 20 and 26 weeks pregnancy)
- late quitters (smoking at 26-week interview but cotinine-demonstrated quit at 34 weeks)
- early relapsers (quit prior to the 26-week interview but had relapsed by 26 weeks)
- late relapsers (quit prior to 26 weeks and were not smoking at the 26-week interview, but cotinine demonstrated smoking at 34 weeks)
- nonquitters (had made no quit attempts and were continuing to smoke at 26 weeks, with cotinine-demonstrated smoking at 34 weeks)

When combining early, middle, and late quitters to calculate overall cessation, 26.2 percent of women in the intervention arm and 17.2 percent of control women quit over the study period. The difference in overall cessation is not significant as calculated by the review team (p=0.09). The authors report that 22.2 percent of the intervention group were early quitters, while 8.6 percent of the comparison group were early quitters, suggesting that if timing of quitting is the key outcome, there may be an effect of the intervention, despite no overall advantage. The selection of early quitting as an outcome appears to have been a post hoc decision, however, and doing so assigns a smoking status to individuals who were later quitters, more of whom were in the control group, thus inflating the observed effect in terms of overall quit rates. However, this study may demonstrate a benefit in terms of timing of quitting, under the assumption that earlier quitting may be beneficial.

In a separate study, but using the same intervention, study investigators randomized 218 women who reported having stopped smoking since learning of their pregnancy to receive the self-help booklets or usual care in order to assess the program's utility in preventing relapse.94 More women in the intervention arm were primigravida (32.6% vs. 13.1% of usual care women, p<0.01), and more reported they were very confident in their ability to maintain smoking cessation during pregnancy (95.4% vs. 86.9% of usual care women, p<0.05). At the 26-week interview, 78.9 percent of women in the intervention group and 84.7 percent of women in the usual care arm had confirmed smoking cessation (proportions adjusted for gravida, length of abstinence, smoking belief, and quitting self-efficacy); the difference between the arms was not significant.94

One poor quality RCT134 compared a basic information sheet to a quit guide and reported no effect at 30 to 34 weeks' gestation but a significant difference at 8 weeks after birth when 15.8% of intervention and 9.1% of control participants had stopped smoking (OR=0.5; 95% CI: 0.3 to 0.9).

##### Video-Based Interventions

Two studies of video-based interventions were both of poor quality. One reported no difference in cessation when a video focused on potential effects of smoking on the fetus was compared with a quit guide or usual care.116 The second reports significantly (p=0.02) greater cessation with a video, created using principles of social learning, about the personal experiences of four lower-income women as they attempted to quit smoking.113 Five of the 19 video group participants reported not smoking at 36 weeks and had exhaled carbon monoxide levels in the non-smoking range compared with zero women in the comparison group (p=0.02).

##### Technology-Based Interventions

Three studies, two of good quality and one poor, used technology-based interventions, including text messaging and computer-delivered interventions.

A good-quality trial conducted in the United Kingdom was designed primarily as a feasibility study, but powered to detect a difference in cessation.123 The study included 207 women randomized to either the MiQuit program, which included a tailored quit guide with advice specific to a participant's smoking history and attitude toward quitting as reported in a baseline questionnaire plus tailored text messages (approximately 80 over 11 weeks, with greater frequency in the first 4 weeks), or a non-tailored self-help pamphlet. Differences in cotinine-validated cessation at a 3-month followup were not significant between groups (12.5% in the MiQuit group vs. 7.8% in the pamphlet-only group, OR=1.68, 95% CI: 0.66 to 4.31).

A second good-quality study conducted at an urban clinic in the United States also primarily evaluated the acceptability of interventions aimed at lower-income smokers,97 assessing the following four interventions in pregnant smokers:

- Computer-delivered 5A's (Ask, Advise, Assess, Assist, Arrange). Women allocated to this arm completed a single-session interactive computer program tailored to their smoking history and attitudes toward quitting. The program used a video-based “advise” component focused on the benefits of quitting. Women unwilling to set a change goal received a motivational intervention consistent with the 5Rs (Relevance, Risks, Rewards, Roadblocks, Repetition).
- Usual care. Women allocated to this arm received standard cessation advice from their clinic providers. They also completed a computer-based exercise that did not address smoking cessation as a sham technique to maintain blinding of research assistants.
- Lower intensity contingency management. Women in this arm could request urinary cotinine testing at any prenatal visit and were eligible to receive up to five retail gift card reinforcers provided that cotinine levels revealed abstinence from smoking.
- Combined arm. Women allocated to this condition completed the 5A's computer program and could request cotinine testing and be eligible for up to five gift cards if cotinine tests revealed smoking cessation.

At approximately 10 weeks after randomization, four women (17.4%) in the usual care arm, 10 women (43.5%) in the 5A's arm, three women (13.6%) in the contingency management arm, and four women (15.4%) in the combined arm had quit per cotinine validation. Women in the CD-5A's group had 10 times the odds of a cotinine confirmed quit (OR=10.2; 95% CI: 1.4 to 75.0) relative to usual care, but the very small n and thus lack of precision decrease confidence in this result.

A poor-quality cluster-randomized trial125 reported in three publications125, 137, 138 and conducted in the United Kingdom allocated prenatal clinics to one of three arms: usual care, stage of change-based quit guides (“Pro-Change Programme for a Healthy Pregnancy”), or a tailored, interactive computer program focused on cessation plus the Pro-Change quit guides. There were no significant differences between arms at 30 weeks' gestation or at 10 days after birth.

### NRT

#### Key Points

- Five studies assessed NRT interventions in pregnant women who were current smokers: two of good quality, one of fair quality, and two of poor quality.
- Three studies used nicotine patches; one used gum; and one allowed participants to choose nicotine patches, gum, or lozenges.
- One good-quality study had inconsistent effectiveness findings with significantly higher cessation in the nicotine patch group than placebo group at some visits and no difference at other visits
- In a poor-quality RCT, a higher proportion of women who chose nicotine patch, gum, or lozenge in addition to CBT quit smoking compared with women who had only CBT.

#### Description of Included Studies

Five RCTs had NRT interventions as their primary focus. Three of the studies were conducted in the United States,102, 104, 120 one in England,122 and one in Australia.128

All five studies enrolled pregnant women who were current smokers. These five studies included a total of 1,517 participants at randomization (range 40 to 1050) and 1,438 participants at analysis (range 40 to 1050). All five studies report outcomes at the end of pregnancy, and one study reports postpartum outcomes with the latest followup at 12 weeks postpartum. One study was assessed as good quality,99, 122 one as fair,102 and three as poor.104, 120, 128 Table 12 provides an overview of the good and fair quality studies, and Table 13 reports outcomes for all studies in this section.

Table 12 Overview of good and fair quality studies for NRT intervention

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time point for Final Validated Cessation Measure | Population | Effect
Coleman et al., 2012^122^ 1050 Good | NRT (patch) vs. placebo | NRT, counseling, personal followup, quit contract, and quit guide | Pregnancy: Birth Postpartum: NR | Smokers, aged 16 and older, between 12 to 24 weeks' gestation at baseline, 97% White | Higher proportion of women in NRT group quit smoking at one month after quit date, but no difference at birth
Oncken et al., 2008^102^ 194 Fair | NRT (gum) + counseling vs. placebo + counseling | NRT, clinic reinforcement, counseling, information, and personal followup | Pregnancy: 32 to 34 weeks Postpartum: 6 to 12 weeks | Smokers, aged 16 and older, ≤ 26 weeks pregnant, 54% Hispanic | No difference at either time point

Abbreviations: CBT = cognitive behavioral therapy; NRT = nicotine replacement therapy: NR = not reported.

Table 13 Smoking cessation outcomes of NRT

Author, Year Country Population Quality | Comparison Groups (number randomized/ analyzed) | Key Cessation Outcomes
Coleman et al., 2012^122^ U.K. Pregnant smokers Good | G1: NRT (patch) (521/521) G2: Placebo (529/529) | - No difference in cessation at birth between groups (9.4% in G1 vs. 7.6% in G2, OR=1.26; 95% CI: 0.82 to 1.96).
Oncken et al., 2008^102^ U.S. Pregnant smokers Fair | G1: NRT (gum) (100/100) G2: Placebo (94/94) | - No significant differences in cessation between groups at 32 to 34 weeks' gestation (18.0% in G1 vs. 14.9% in G2) or at 6 to 12 weeks postpartum (11.0% in G1 vs. 9.6% in G2).
El-Mohandes et al., 2012^120^ U.S. Pregnant smokers Poor | G1: NRT (patch) + CBT (26/26) G2: CBT (26/26) | - Cessation was higher in G1 compared with G2 at visit 3 (23% vs. 0%, p=0.02) and visit 6 (19% vs. 0%, p=0.05), but not at visits 4 and 5.
Pollak et al., 2007^104^ U.S. Pregnant smokers Poor | G1: NRT (patch, gum, or lozenge) + CBT (122/73) G2: CBT (59/29) | - Cessation was significantly higher in G1 than G2 at 38 weeks' gestation (18% vs. 7%, p=0.01) but not at 3 months postpartum (20% vs. 14%, p=0.55).
Hotham et al., 2006^128^ AUS Pregnant smokers Poor | G1: NRT (patch) + counseling (20/20) G2: Counseling (20/20) | - At the end of pregnancy 3 women (15%) in G1 and none (0%) in G2 were abstinent (p=NR).; - Fourteen women (35%) withdrew from the study.

Abbreviations: AUS = Australia; CBT = cognitive behavioral therapy; NRT = nicotine replacement therapy: NR = not reported; U.K. = United Kingdom; U.S. = United States.

Nicotine replacement therapy products provide low doses of nicotine without the toxins found in cigarette smoke. These products can help reduce cravings and symptoms that are experienced with smoking cessation. Five forms of NRT are approved by the U.S. Food and Drug Administration: patch, gum, nasal spray, inhalers, and lozenges.

#### Detailed Synthesis

Three studies provided NRT as a patch;120, 122, 128 one study used nicotine gum;102 and one study allowed participants to choose nicotine patches, gum, or lozenges.104 Biologically confirmed cessation at the end of pregnancy ranged from zero to 23 percent. Only one study reported postpartum cessation, and it was decreased from end of pregnancy. One poor-quality study had inconsistent effectiveness findings with significantly higher cessation in the nicotine patch group than placebo group at some visits and no difference at other visits.120 In a poor-quality RCT, a higher proportion of women who chose nicotine patch, gum, or lozenge in addition to CBT quit smoking compared with women who only had CBT.104

In a good-quality study of 1050 pregnant smokers in England, investigators assigned the intervention group to 8 weeks of treatment with nicotine patches (15 mg per 16 hours) and behavioral support while the control group received a placebo patch and behavioral support.122 At one month after the quit date, cessation with carbon monoxide confirmation was higher in the nicotine patch group than the placebo group (21.3% vs. 11.7%; OR=2.05; 95% CI: 1.46 to 2.88). Cessation at birth was confirmed by exhaled carbon monoxide and salivary cotinine level measurement. Cessation in the nicotine patch group and the placebo group was comparable (9.4% vs. 7.6%; OR=1.26; 95% CI: 0.82 to 1.96).

A fair-quality study in the United States enrolled 194 pregnant smokers.102 Women in the intervention group received 6 weeks of 2 mg nicotine gum and behavioral counseling while women in the control group received a placebo gum and behavioral counseling. There were no significant differences in cessation between the nicotine gum group and placebo group at 32 to 34 weeks' gestation (18.0% vs. 14.9%) or 6 to 12 weeks postpartum (11.0% vs. 9.6%). The Data and Safety and Monitoring Board recommended that enrollment be stopped early due to lack of efficacy.

A poor-quality study in the United States randomized 52 pregnant smokers to either nicotine patches and CBT or to CBT alone.120 The study used a 10-week NRT regimen, and one of two dosing options (21 mg-14 mg-7 mg or 14 mg-7 mg) was chosen based on baseline salivary cotinine levels. Participants had six visits, four of which (visits 3 to 6) occurred after the intervention was initiated. The proportion of women with cotinine confirmed cessation was significantly higher in the nicotine patch group compared with the placebo group at visit three (23% vs. zero, p=0.02) and visit six (19% vs. zero, p=0.05), but not at visit four (12% in both groups, p=1.00) or visit five (12% vs. 8%, p=1.00).

In a poor-quality study with 181 pregnant smokers, women in the intervention group received CBT and patient-preference open-label selection of nicotine patch, gum, or lozenge with the dosage adjusted by prior smoking level.104 Women in the control group received CBT. Another poor-quality study randomized 40 pregnant smokers to counseling to stop smoking and nicotine patches (15 mg over 16 hours) for a maximum of 12 weeks or counseling to stop smoking. Outcomes for these studies can be found in Table 13.^128^

### Peer Support

#### Key Points

- Four studies assessed peer support interventions in pregnant women who were current smokers: two of good quality, one of fair quality, and one of poor quality.
- Two studies used specially-trained, non-smoking peer counselors from the community, and two studies had female friends or family members as peer supporters.
- Compared with family members, friends were more effective supporters, and trends suggested that ex-smokers were the more effective supporters than never or current smokers.
- Adding peer support to office-based counseling programs did not increase cessation.

#### Description of Included Studies

In this section we describe those studies that were predominantly focused on examining whether improvements in cessation rates could be achieved by proactively involving a peer. We sought studies that included lay women, friends, family members, partners, or other individuals as the peer support person, or that provided group meetings explicitly designed with a peer support and encouragement model, as opposed to a smoking cessation education model.

The approach to peer support varied in each study and is summarized in Table 14. Two of the four studies used specially-trained, non-smoking peer counselors from the community to provide cessation advice and support, in person during visits in one instance,107 and by telephone referral in the other.109 In the other studies women identified a candidate peer support person who then either participated with them in smoking cessation sessions85 or who received special training for those who were peer supporters.101 In both of these studies the supporters were female friends or family members. We did not identify studies that focused on the partner/spouse or other adult members of the household as the support person.

Table 14 Peer supporters and training strategies used in prenatal smoking cessation interventions

Author, Year, Country, Quality | Characteristics of Peer Supporters | Training for Supporters
Trained Lay Health Advisors
Solomon et al., 2000^109^ U.S. Poor | A female, ex-smoker, peer-support counselor made calls around quit dates, then weekly, and more rarely when “smoking changes stabilized.” | Eight hours of training, format not specified. Providers in the study were using Agency for Health Care Policy & Research smoking cessation counseling guidelines.
Malchodi et al., 2003^107^ U.S. Good | Smoking cessation counseling from lay community health outreach workers with the same “social-environmental and cultural qualities” as participants. Sessions as convenient for participant by phone, in her home, or at clinic. | Two standardized training sessions: 3-hr Agency for Health Care Policy & Research smoking cessation counseling guidelines and 2-hour strategies for motivational counseling.
Friend or Family Member
Albrecht et al., 2006^85^ U.S. Good | A female peer “buddy” was selected by the teenage smoker receiving prenatal care and the buddy was invited to attend an 8-week cessation program with the teen smoker. The group session were also co-led by a teen. | Other than attendance at the group, no additional training was provided to the supporters.
Hennrikus et al., 2010^101^ U.S. Fair | Smokers in prenatal care identified “a woman in her social network” to serve as a supporter: 60% were relatives and 40% were friends. | Supporters had one in-person visit with a cessation counselor and monthly telephone calls. Sessions were used to review efforts and to identify specific activities to support cessation.

Abbreviations: U.S. = United States.

Four RCTs, all conducted in U.S. urban clinics, focused on peer support.85, 101, 107, 109 Three studies were underpowered for their primary outcomes.85, 101, 109 All four studies enrolled pregnant women who were current smokers. These four studies included a total of 517 participants (range 82 to 151) at randomization and analysis. All four studies report outcomes at the end of pregnancy, and two studies report postpartum outcomes with the latest followup at one year postpartum. Two studies were good quality,85, 107 one was fair quality,101 and one was poor.109 Table 15 provides an overview of the good and fair quality studies.

Table 15 Overview of good and fair quality studies for peer support interventions

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time Point for Final Validated Cessation Measure | Population | Effect
Albrecht et al., 2006^85^ 142 Good | Teen peer counseling vs. teen peer counseling plus buddy vs. usual care | Group vs. group and peer support | Pregnancy: 8 weeks after intervention Postpartum: 1 year | Teenage smokers, aged 14 to 19, most in second trimester at baseline, 53% White, 42% African-American | No difference in cessation among the groups after 1 year
Malchodi et al., 2003^107^ 142 Good | Peer counseling vs. usual care | Clinic reinforcement, counseling, peer support, and quit guide | Pregnancy: 36 weeks Postpartum: NR | Smokers, aged 18 to 41, 63% Hispanic | No difference
Hennrikus et al., 2010^101^ 82 Fair | Peer supporters who received monthly counseling vs. no contact with control group supporters | Counseling and peer support | Pregnancy: Just prior to expected due date Postpartum: 3 months | Smokers, median age 24, 67% racial minorities or Hispanic, 71% had other children | No difference at either time point

Abbreviations: NR = not reported.

#### Detailed Synthesis

The proportion of women with biologically confirmed abstinence at the end of pregnancy ranged from 4 to 24 percent. Only one study reported numerical data for validated postpartum cessation data, ranging from zero to 9 percent. Outcomes of these studies are summarized in Table 16.

Table 16 Smoking cessation outcomes of peer support interventions

Author, Year Country Population Quality | Comparison Groups (number randomized/analyzed) | Key Cessation Outcomes
Albrecht et al., 2006^85^ U.S. Pregnant smokers Good | G1: Teen peer counseling with peer co-leader, group setting, individual support (47/47) G2: Teen peer counseling plus non-smoking buddy (45/45) G3: Usual care (50/50) | - After 8 weeks, cotinine confirmed cessation rates were comparable between G1 and G2 (p=0.21) and G1 and G3 (p=0.16).; - More teens in G2 quit compared with G3 (p=0.01; OR=3.7; 95% CI: 1.0 to 13.9).; - At 1-year followup there were no significant differences in cessation between the groups.
Malchodi et al., 2003^107^ U.S. Pregnant smokers Good | G1: Peer counseling (67/67) G2: Usual care (75/75) | - Cessation was similar in groups G1 and G2 at 36 weeks' gestation (24% vs. 21%, p=0.84).
Hennrikus et al., 2010^101^ U.S. Pregnant smokers Fair | G1: Support person received monthly contact from counselor (54/54) G2: Control- no further contact (28/28) | - No difference in cessation between groups at end of pregnancy (13% in G1 vs. 3.6% in G2, p=NS) or at 3 months postpartum (9.3% in G1 vs. 0% at G2, p=NR).
Solomon et al., 2000^109^ U.S. Pregnant smokers Poor | G1: Telephone peer support plus cessation advice and printed materials (77/77) G2: Brief smoking cessation advice and materials (74/74) | - No significant difference in cessation at 28 to 34 weeks' gestation (18.2% in G1 vs. 14.9% in G2, p=NS).

Abbreviations: NR = not reported; NS = nonsignificant; U.S. = United States.

##### Trained Lay Health Advisors

Two RCTs, one of good quality107 and one of poor quality,109 engaged lay women as peers in supporting cessation. The good-quality study, which was conducted at a community hospital tertiary care clinic, added peer cessation counselors to a clinic-based brief intervention program designed specifically for pregnant women.107 In the poor-quality study, participants from a large obstetrics practice were randomized assignment to a clinic-based brief smoking cessation program delivered by obstetricians and midwives compared with the same clinic-based program along with calls from a trained ex-smoker who called participants soon after referral, around quit dates, and thereafter to plan and reinforce steps.109 Neither study achieved significantly higher cessation among those in the intervention group with additional peer counseling support. Each study noted the difficulty of achieving the target level of exposure, with a median of six contacts (out of goal of eight) in the study with peer counselors and only 53 percent participating in phone counseling in the telephone-based program.

##### Friends or Family Members as Peer Cessation Supporters

Two studies engaged participants in identifying a specific individual to support them in smoking cessation.85, 101 A fair-quality study (n=82) was described as a pilot study and noted to be under-powered to detect the anticipated reduction in smoking.101 The study reported biologically confirmed cessation, using an intention-to-treat approach, of 13.0 percent and 3.6 percent in the peer supported versus usual care group (p>0.05). Early in participation both groups of pregnant smokers had one in-person smoking cessation session. In the intervention groups, the identified peer supporters were also invited to an in-person session and had monthly calls with a cessation counselor on the study staff. In the calls, the trained counselor assisted the peer supporter in developing strategies to help the participant quit smoking. Those with a peer supporter reported greater perceived support for cessation, and trends suggested support was most effective from those who were ex-smokers and for those who selected a friend rather than a family member as their supporter. By 3 months postpartum all but 9.3 percent of the intervention group and the entire usual care group had returned to smoking.

The teen-specific program, Teen FreshStart (TFS), enrolled and randomly assigned 142 pregnant smokers to one of three groups: usual care, TFS—an 8-week group cognitive behavioral program, and TFS plus a peer supporter, called a “buddy.”85 The teens in the peer support arm were encouraged to bring a nonsmoking friend of similar age with them to participate in TFS. Cotinine confirmed cessation rates were comparable between TFS and TFS plus a buddy (p=0.21) and between TFS and usual care (p=0.16). The additional comparison between TFS with a buddy to usual care found that more than three times as many teens in the TFS with buddy group (OR= 3.7; 95% CI: 1.00 to 13.89) were quit after the 8-week program. However, given the lack of significant advantage of TFS with buddy to TFS alone, it would be spurious to conclude that the addition of the buddy is evidence of superiority to TFS alone. By one-year followup cessation among all three arms was comparable.

### Other Interventions

#### Key Points

- Nine studies assessed other interventions: two of good quality, two of fair quality, and five of poor quality.
- Three studies assessed various forms of biologic feedback intended to motivate pregnant smokers to quit. Other studies evaluated facilitation of mother-infant bonding, modified delivery of self-help materials, financial incentives, counseling for depression, and clinic reinforcement.
- In one good-quality study of postpartum women who quit smoking during or prior to pregnancy, a higher proportion of participants who received an intervention to promote maternal-infant bonding remained abstinent at 8 weeks postpartum compared with participants who received usual care.
- A fair-quality study found cessation was higher at the end of pregnancy and 12 weeks postpartum in women who received financial vouchers for retail items contingent on their smoking status compared with women who received vouchers regardless of their smoking status. The different between groups was not sustained at 6 months postpartum. A poor-quality study found higher incidence of smoking abstinence at 12 weeks post-intervention in women who received contingent financial incentives compared with women who received non-contingent incentives or usual care.
- One poor-quality study reported higher cessation in women receiving brief, immediate guidance on self-help materials compared with women offered a 2-hour evening class.

#### Description of Included Studies

We identified nine studies evaluating various unique strategies to promote smoking cessation or continued abstinence among pregnant or postpartum women.80, 83, 84, 100, 106, 118, 121, 124, 131 Seven of these studies were conducted in the United States,80, 83, 84, 100, 106, 118, 121 one in Canada,131 and one in the United Kingdom.124 Seven studies focused on pregnant women who were current smokers,83, 84, 100, 118, 121, 124, 131 while one study also included pregnant women who were recent quitters.106 One study focused on relapse prevention among postpartum women who had quit smoking during pregnancy.80 These studies, including eight traditional RCTs80, 83, 84, 100, 118, 121, 124, 131 and one cluster-randomized trial,106 had a total of 2056 participants at randomization (range 54 to 609) and participants at analysis (range 49 to 468). For overall quality, we assessed two studies as good,80, 100 two as fair,83, 84 and four as poor.106, 118, 124, 131 Table 17 provides an overview of the good and fair quality studies, and Table 18 reports outcomes for all studies in this section.

Table 17 Overview of good and fair quality studies for other interventions

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time Point for Final Validated Cessation Measure | Population | Effect
Phillips et al., 2012^80^ 54 Good | Enhanced support for maternal infant bonding vs. usual care | Counseling, information, partner/household/social context, personal followup, and other | Pregnancy: NA Postpartum: 8 weeks | Mothers with infants in NICU, not currently smoking; mean age 24, 68% White; majority Medicaid | More women in the intervention group (81%) remained abstinent compared with the women in the control group (46%)
Cinciripini et al., 2010^100^ 266 Good | Cognitive behavioral analysis psychotherapy vs. health and wellness education | Counseling and other | Pregnancy: 3 and 6 months post treatment Postpartum: 3 and 6 months | Smokers, 37% DSM-IV criteria major depression, mean age 25,≤ 32 weeks' gestation, 54% African-American | No differences between groups at any time point
Stotts et al., 2009^83^ 360 Fair | Ultrasound feedback plus motivational interviewing counseling vs. ultrasound feedback and best practice counseling (AHRQ guidelines) vs. best practice counseling | Counseling, feedback about biologic measures, and information | Pregnancy: 8^th^ month Postpartum: NR | Smokers, age ≥ 16 years, 5^th^ month pregnancy, 55% White, 37% African-American | No differences between groups
Heil et al., 2008^84^ 82 Fair | Contingent vouchers vs. non-contingent vouchers | Counseling, incentives, information, and quit contract | Pregnancy: Postpartum: 12 weeks and 6 months | Smokers, mean gestation 9 weeks, > 90% White; 16% private insurance | Cessation higher for contingent vouchers at end of pregnancy and 12 weeks postpartum. (p=0.003) No difference at 6 months postpartum

Abbreviations: AHRQ = Agency for Healthcare Research and Quality; NA = not applicable; NR = not reported.

Table 18 Smoking cessation outcomes of other interventions

Author, Year Country Population Quality | Comparison Groups (number randomized/analyzed) | Key Cessation Outcomes
Phillips et al., 2012^80^ U.S. Postpartum women who had quit smoking Good | G1: Enhanced support for maternal-infant bonding plus weekly encouragement to remain smoke free and breast feeding support (24/21) G2: Weekly encouragement to remain smoke free and routine breast feeding support (30/28) | - At 8 weeks postpartum, 81% of women in G1 remained abstinent compared with 46% in G2 (p<0.001).
Cinciripini et al., 2010^100^ U.S. Pregnant smokers Good | G1: Cognitive behavioral analysis system of psychotherapy (133/128) G2: Health and wellness education (133/129) | - No significant differences in cessation between groups at end of treatment, 3 and 6 months post treatment, and 3 and 6 months postpartum.; - Cessation declined over time in both groups and at 6 months postpartum was 7.0% in G1 and 9.3% in G2.
Stotts et al., 2009^83^ U.S. Pregnant smokers Fair | G1: Ultrasound feedback and motivational interviewing counseling (120/115) G2: Ultrasound feedback and best practice counseling per AHRQ guidelines (120/115) G3: Best practice counseling (120/114) | - No significant differences in cessation at the end of pregnancy between groups (18.3% in G1 vs. 14.2% in G2 vs. 10.8% in G3, p=0.30).
Heil et al., 2008^84^ U.S. Pregnant smokers Fair | G1: Contingent vouchers (40/37) G2: Non-contingent vouchers (42/40) | - Cessation was higher for women receiving contingent vouchers (41% in G1 vs. 10% in G2, p=0.003) at end of pregnancy and at 12 weeks postpartum (24% in G1 vs. 3% in G2, p=0.006).; - The difference was not sustained at 6 months postpartum (G1 8% vs. G2 3%, p=NS).
Pbert et al., 2004^106^ U.S. Pregnant smokers and quitters Poor | G1: Provider training, office practice management system, coordination of document sharing among clinics (272/214) G2: Usual care (278/254) | - No significant effect on smoking status by group assignment.
Cope et al., 2003^124^ U.K. Pregnant smokers Poor | G1: Feedback from point of care urine test, quit date and leaflet (164/109) G2: Usual care including anti-smoking counseling (116/83) | - At 36 weeks' gestation 22% in G1 had quit smoking compared with 6.8% in G2 (p=NR).
O'Connor et al., 1992^131^ CAN Pregnant smokers Poor | G1: Counseling, quit guide, evening cessation class, individualized counseling session (115/94) G2: Usual care (109/96) | - Cessation higher in G1 than in G2 at 1 month post-intervention (14.9% vs. 5.0%, p=0.02) and 6 weeks postpartum (13.8% vs. 5.2%, p=0.04).
Bauman et al., 1983^118^ U.S. Pregnant smokers Poor | G1: Scripted feedback on exhaled carbon monoxide level (NR/NR) G2: Script without exhaled carbon monoxide level provided (NR/NR) G1+G2: (226/170) | - No difference in smoking cessation at 6-week followup for subset of participants who were smokers at baseline (24% in G1 vs. 23% in G2).
Tuten et al., 2012^121^ U.S. Pregnant smokers Poor | G1: Contingent behavioral incentive (42/42) G2: Non-contingent behavioral incentive (28/28) G3: Treatment as usual (32/32) | - At week 12, 31% in G1 had met the abstinence objective compared to 0% in G2 and G3.

Abbreviations: CAN = Canada; NR = not reported; NS = nonsignificant; U.K. = United Kingdom; U.S. = United States.

Three RCTs explored various forms of biologic feedback intended to motivate pregnant smokers to quit.83, 118, 124 Two studies examined financial incentives to promote smoking cessation.84, 121Four studies evaluated unique interventions for smoking cessation: facilitation of mother-infant bonding,80 modified delivery of self-help materials,131 counseling for depression,100 and clinic reinforcement.106

#### Detailed Synthesis

##### Feedback About Biologic Measures

Three RCTs evaluated approaches involving targeted biologic feedback to aid smoking cessation among pregnant smokers. One fair-quality RCT with 360 participants included three arms: a “best practices” standard cessation counseling arm, an arm adding ultrasound imaging with embedded risk counseling during imaging to the standard counseling, and a third arm pairing the ultrasound imaging with embedded risk messages with motivational interviewing.83 Smoking cessation was comparable in the three groups (10.8% vs. 14.2% vs. 18.3%, respectively) during the eighth month of gestation (p=0.30). Followup analysis did not show any significant effects of group assignment at any time point in the study.

Providing point-of-care urine cotinine testing with visual and quantitative representation of results to pregnant participants was the focus of one poor-quality RCT.124 Among 192 women followed to birth, 22 percent of women in the intervention group had quit smoking at birth as compared with 6.8 percent in the usual care group (test of statistical significance not reported).

Another poor-quality RCT comprising 170 participants assessed whether providing carbon monoxide testing results and counseling to pregnant smokers led to greater smoking cessation than counseling alone. Carbon monoxide results 6 weeks later among those who had been current smokers at time of intervention indicated that similar proportions of women remained current smokers in each group (76% in intervention arm, 77% in control arm).118

##### Facilitation of Mother-Infant Bonding

A good-quality RCT enrolled 54 postpartum nonsmoking women, with a history of tobacco use during or prior to pregnancy, from a neonatal intensive care unit to evaluate a strategy for prevention of smoking relapse.80 The study compared continued smoking cessation rates among women randomized to receive educational materials (i.e., DVDs, books, and handouts) about newborn behavior and encouragement of frequent and prolonged skin-to-skin contact with their infants intended to facilitate mother-infant bonding as compared with women receiving usual care. This trial found a significant benefit for the enhanced bonding approach, observing an 81 percent continued cessation rate in the intervention group as compared with 46 percent in the comparison group (p<0.001) at 8 weeks postpartum.80

##### Delivery Method for Self-Help Material

A second delivery-focused RCT, assessed as poor quality, compared usual care to an intervention including personalized counseling and use of a quit guide (“Windsor's 7-Day Self-Help Quit Plan”93) among 224 pregnant smokers.131 Women randomized to usual care were offered an evening class providing guidance on the self-help program, which authors described as the routine practice within the clinic. The experimental arm offered women the option of an in-clinic visit, including individual review of the self-help program and a followup call instead of the evening class. While none of the women in the usual care group attended an evening class, 93 percent of the women in the experimental group received the in-clinic intervention by the time of the second followup visit. Followup analysis revealed a significantly increased incidence of cessation in the intervention group as compared with usual care at one month post-intervention (14.9% vs. 5%, p=0.02) and at 6 weeks postpartum (13.8% vs. 5.2%, p=0.04).

##### Incentives

One fair-quality RCT explored the utility of financial incentives in improving smoking cessation rates among 82 pregnant smokers.84 One group received vouchers redeemable for retail items ($15/visit antepartum, $20/visit postpartum) independent of current smoking status, and the other group received vouchers contingent on their current smoking status (starting point $6.25, increasing by $1.25 per consecutive negative test up to a maximum of $45). Biologically confirmed smoking cessation was significantly greater in women receiving the status-contingent vouchers as compared with those receiving noncontingent vouchers at the end of pregnancy (41% vs. 10%, p=0.003) and at 12 weeks postpartum (24% vs. 3%, p=0.006). However, cessation was similar in the two groups by 24 weeks postpartum.

A second RCT of poor quality compared the efficacy of a contingent incentive intervention with non-contingency management or treatment as usual among pregnant smokers attending a university-based drug and alcohol treatment clinic for pregnant women.121 The study included three groups: contingent incentives ($7.50 for meeting first reduction/abstinence target increased by $1.00/day for each consecutive target, up to maximum $41.50); non-contingent incentives (incentives based on previously determined schedule, independent of smoking status): and treatment as usual. At 12 weeks after starting the intervention, 31% of the contingent incentive group achieved the abstinence target (exhaled carbon monoxide <4 ppm) as compared with none of the women in the non-contingent and usual care groups. No test of statistical significance was reported.

Of note, although only two studies focused exclusively on incentives, the use of incentives was explored in other studies and is isolated as an effect in the meta-analysis of components in KQ4.

##### Treatment of Depression

A good-quality RCT including 266 pregnant smokers explored the utility of a depression-focused cognitive behavioral intervention. Women randomized to the intervention group received ten individualized sessions at a rate of one to two per week until birth, while the control group had a time- and attention-matched health education session.100 Approximately three-quarters of enrolled women had a lifetime history of major depressive disorder, with about half in full or partial remission at time of study enrollment. Analysis of outcome data revealed no significant main effect of treatment group at any time point (3 and 6 months post treatment, 3 and 6 months postpartum) for any of the study's definitions for abstinence.

##### Clinic Reinforcement

A cluster-randomized trial assessed as poor quality, including six clinics and 609 patients, evaluated the use of a health-center based intervention as compared with usual care for smoking cessation among pregnant active smokers and pregnant women who had recently quit.106 The intervention included provider training in delivery of a cessation intervention, an office practice management system which included reminders about screening and education with followup documentation, and a process for sharing documents among prenatal clinics. Analysis of outcome data indicated no significant effect on smoking status by group assignment.

### Multicomponent

#### Key Points

- Fourteen studies included multicomponent interventions: three of good quality, five of fair quality, and six of poor quality.
- Thirteen components of interventions (not including usual care) were used in various combinations in these studies. The most common components were counseling, quit guides, clinic reinforcement, peer support, and personal followup.
- Five of 12 studies focused on pregnant smokers reported statistically significant improvements in smoking cessation with a range of 5 to 23 percent difference between the intervention and control groups at the end of pregnancy. Two of these studies also had a significant difference at six to 12 weeks postpartum.
- One of four studies focused on pregnant women who had quit smoking was effective at the end of pregnancy with 65 percent cessation in the intervention participants and 53 percent in the control participants. There was no longer a significant difference at six months postpartum.
- One study focused on postpartum women was not effective for relapse prevention.
- The most common interventions in successful studies were also common in studies that failed to demonstrate effectiveness thus it is not possible to say which interventions are superior.

#### Description of Included Studies

We classified 14 studies in which a combination of components was implemented as an intervention without a clear primary component as multicomponent studies.11, 39, 79, 88, 91-93, 98, 103, 110, 112, 127, 130, 133 Ten of these studies were conducted in the United States,11, 39, 79, 91-93, 98, 103, 110, 112 two in Europe,88, 133 and two in Australia.127, 130 Thirteen studies evaluated interventions conducted during pregnancy, and one of these also included an intervention during postpartum hospitalization.91 One study focused solely on a postpartum intervention.79 Nine studies only enrolled current smokers,39, 91-93, 98, 103, 110, 130, 133 two studies only enrolled recent quitters,79, 112 and three studies enrolled both current smokers and recent quitters.11, 88, 127 In these 14 studies, a total of 12,139 women were randomized (range 62 to 5572) and 11,868 were analyzed (range 62 to 5572). Smoking cessation outcomes are reported by twelve studies at the end of pregnancy,11, 39, 88, 91-93, 103, 110, 112, 127, 130, 133 five studies at four to 12 weeks postpartum,79, 98, 103, 110, 130 and two studies at six months postpartum.88, 91 Of the 14 multicomponent intervention studies, three were of good quality,88, 92, 130 five of fair quality,39, 79, 91, 93, 110 and six of poor quality.11, 98, 103, 112, 127, 133

We used the descriptions in Table 4 to classify the components of the interventions in these studies, which are shown in Table 19. This was challenging at times because the level of detail in descriptions of interventions was not consistent across studies. In addition, specific components in individual studies varied. Therefore, the components are defined somewhat broadly to allow a variety of similar studies to be classified together. The most common intervention was counseling, which was included in all 14 studies. Ten studies included information,11, 39, 79, 91, 93, 98, 112, 127, 130, 133 nine studies included quit guides,39, 88, 91-93, 98, 103, 110, 130 seven studies included clinic reinforcement,39, 88, 91, 92, 98, 112, 130 six studies included peer support,39, 88, 110, 112, 127, 130 and five studies included personal followup.39, 91, 92, 112, 130 Interventions found in two studies included NRT,127, 133 incentives,110, 130 feedback about biologic changes,88, 92 prescription to quit,91, 92 and stop smoking contract.88, 127 One study addressed the smoking status of participants' significant others,127 and one study included a group smoking cessation program.133 The number of interventions per study in the intervention arms ranged from two to seven with a mean of 4.0 interventions.

Table 19 Types of smoking cessation interventions in multicomponent studies

Author, Year Country Quality | Study Arm | Clinic Reinforcement | Counseling | Feedback | Groups | Incentives | Information | NRT | Partner/Household | Peer Support | Personal Followup | Prescription To Quit | Quit Contract | Quit Guide | Usual Care | Total Components
Hajek et al., 2001^88^ U.K. Good | Intervention | ● | ● | ● | | | | | | ● | | | ● | ● | | 6
Hajek et al., 2001^88^ U.K. Good | Control | | | | | | | | | | | | | | ● | 1
Hartmann et al., 1996^92^ U.S. Good | Intervention | ● | ● | ● | | | | | | | ● | ● | | ● | | 6
Hartmann et al., 1996^92^ U.S. Good | Control | | | | | | | | | | | | | | ● | 1
Walsh et al., 1997^130^ AUS Good | Intervention | ● | ▲ | | | ● | ▲ | | | ● | ● | | | ● | | 7
Walsh et al., 1997^130^ AUS Good | Control | | ▲ | | | | ▲ | | | | | | | | | 2
Donatelle et al., 2000^110^ U.S. Fair | Intervention | | ● | | | ● | ● | | | ● | | | | ● | | 5
Donatelle et al., 2000^110^ U.S. Fair | Control | | ● | | | | ● | | | | | | | ● | | 3
Gielen et al., 1997^91^ U.S. Fair | Intervention | ● | ▲ | | | | ● | | | | ● | ● | | ● | | 6
Gielen et al., 1997^91^ U.S. Fair | Control | | ▲ | | | | ● | | | | | | | | | 2
Suplee, 2005^79^ U.S. Fair | Intervention | | ● | | | | ● | | | | | | | | | 2
Suplee, 2005^79^ U.S. Fair | Control | | | | | | | | | | | | | | ● | 1
Windsor et al., 1993^39^ U.S. Fair | Intervention | ● | ▲ | | | | ● | | | ● | ● | | | ● | | 6
Windsor et al., 1993^39^ U.S. Fair | Control | | ▲ | | | | ● | | | | | | | | | 2
Windsor et al., 1985^93^ U.S. Fair | Intervention 1 | | ● | | | | ● | | | | | | | ▲ | | 3
Windsor et al., 1985^93^ U.S. Fair | Intervention 2 | | ● | | | | ● | | | | | | | ▲ | | 3
Windsor et al., 1985^93^ U.S. Fair | Control | | ▲ | | | | | | | | | | | | | 1
Bullock et al., 2009^103^ U.S. Poor | Intervention 1 | | ● | | | | | | | | | | | ● | | 2
Bullock et al., 2009^103^ U.S. Poor | Intervention 2 | | ● | | | | | | | | | | | | | 1
Bullock et al., 2009^103^ U.S. Poor | Intervention 3 | | | | | | | | | | | | | ● | | 1
Bullock et al., 2009^103^ U.S. Poor | Control | | | | | | ● | | | | | | | | | 1
Eades et al., 2012^127^ AUS Poor | Intervention | | ▲ | | | | ● | ● | ● | ● | | | ● | | | 6
Eades et al., 2012^127^ AUS Poor | Control | | ▲ | | | | | | | | | | | | | 1
Hegaard et al., 2003^133^ Denmark Poor | Intervention | | ▲ | | ● | | ● | ● | | | | | | | | 4
Hegaard et al., 2003^133^ Denmark Poor | Control | | ▲ | | | | | | | | | | | | | 1
Kendrick et al., 1995^11^ U.S. Poor | Intervention | | ● | | | | ● | | | | | | | | | 2
Kendrick et al., 1995^11^ U.S. Poor | Control | | | | | | | | | | | | | | ● | 1
Lowe et al., 1997^112^ U.S. Poor | Intervention | ● | ▲ | | | | ● | | | ● | ● | | | | | 5
Lowe et al., 1997^112^ U.S. Poor | Control | | ▲ | | | | | | | | | | | | | 1
Windsor et al., 2011^98^ U.S. Poor | Intervention | ● | ▲ | | | | ● | | | | | | | ● | | 4
Windsor et al., 2011^98^ U.S. Poor | Control | ● | ▲ | | | | | | | | | | | | | 2

Abbreviations: AUS = Australia; U.K. = United Kingdom; U.S. = United States.

Note: Studies organized by quality (good, fair, poor) then alphabetical order.

a For interventions, ● indicates the intervention was the same for the different arms, and ▲ indicates the intervention varied for the different arms (e.g., control arm got brief counseling while intervention arm got longer counseling).

#### Detailed Synthesis

Table 20 provides an overview of the good and fair quality studies, and Table 21 reports outcomes for all studies in this section. The proportion of women with validated smoking cessation ranged from one to 65 percent at the end of pregnancy and from 3 to 37 percent postpartum.

Table 20 Overview of good and fair quality studies for multicomponent interventions

Study, Year Number Randomized Quality | Intervention | Components of Intervention Arm(s) | Time Point for Final Validated Cessation Measure | Population | Effect
Hajek et al., 2001^88,c^ 1120 Good | Midwife advice with carbon monoxide reading, written material, quit contract, support from another pregnant smoker, reinforcement at visits vs. usual care | Clinic reinforcement, counseling, feedback about biologic measures, peer support, quit contract, and quit guide | Pregnancy: Birth Postpartum: 6 months | Pregnant smokers and recent quitters, mean age 26.9-28.2 | No difference for smokers Cessation significantly higher for recent quitters at end of pregnancy but no difference at 6 months postpartum
Walsh et al., 1997^130^ 293 Good | Physician advice, videotape, midwife counseling, self-help manual, lottery, social support, and chart reminder vs. prestudy smoking advice | Clinic reinforcement, counseling, incentives, information, peer support, personal followup, and quit guide | Pregnancy: Visit closest to 34^th^ week of gestation Postpartum: 6 to 12 weeks | Pregnant smokers at first prenatal visit | Cessation higher in the intervention group at end of pregnancy and 6 to 12 weeks postpartum (p=0.0353)
Hartmann et al., 1996^92^ 207 Good | Counseling, smoking cessation manual, prescription to quit, and followup via mail and telephone vs. usual care | Clinic reinforcement, counseling, feedback about biologic measures, personal followup, prescription to quit, and quit guide | Pregnancy: Last prenatal visit | Pregnant smokers, mean age 24.8, mean of 14.6-14.7 weeks pregnant at first visit, 51% white and 46% black | No effect
Suplee, 2005^79^ 62 Fair | Brief counseling session with educational materials vs. usual care | Counseling and information | Postpartum: 4 to 8 weeks | Postpartum women who had quit smoking during pregnancy, mean age 22.6, 81% African American | No effect
Donatelle et al., 2000^110^ 220 Fair | Financial incentive vouchers for participant and support person, counseling, information, and quit guide vs. counseling, information, and quit guide | Counseling, incentives, information, peer support, and quit guide | Pregnancy: 8 months Postpartum: 2 months | Pregnant smokers, mean age 23.5 to 24.0, mean gestational age 16.4 to 16.6 weeks, 88% to 90% white, WIC eligible | Cessation higher in the intervention group at the end of pregnancy and 2 months postpartum (p<0.0001)
Gielen et al., 1997^91^ 467 Fair | Quit guide, counseling session, education materials, clinic reinforcement including prescription to quit and written letters or encouragement, and routine clinic advice vs. routine clinic advice | Clinic reinforcement, counseling, information, personal followup, prescription to quit, and quit guide | Pregnancy: Third trimester | Pregnant smokers, mean age 23.3 to 24.1, mean gestational age at enrollment 4.1 to 4.2 months, 85% African American | No effect
Windsor et al., 1993^39^ 814 Fair | Counseling, quite guide, clinic reinforcement, social support vs. advice and pamphlets | Clinic reinforcement, counseling, information, peer support, personal followup, and quit guide | Pregnancy: After 32^nd^ week of gestation | Pregnant smokers, mean age 24.6, mean gestational age at entry 4.0 months, 52% black | Cessation higher in the intervention group at the end of pregnancy (p=0.01)
Windsor et al., 1985^93^ 309 Fair | American Lung Association quit manual, counseling, and education booklet vs. Windsor quit manual, counseling, and education booklet vs. standard cessation advice | Counseling, information, and quit guide | Pregnancy: Last month of gestation or within 48 hours of birth | Pregnant smokers, mean age 23.6, mean gestational age at entry 3.7 months, 57% black | Cessation higher in the intervention (Windsor guide) group at the end of pregnancy compared with the usual care group (RR=0.12, 95% CI: 0.05 to 0.19)

Abbreviations: AUS = Australia; CI = confidence interval; NS = not significant; OR = odds ratio; RR = risk ratio; UK = United Kingdom; U.S. = United States.

Table 21 Smoking cessation outcomes of multicomponent interventions

Author, Year Country Population Quality | Comparison Groups (number randomized/analyzed) | Key Cessation Outcomes
Hajek et al., 2001^88^ U.K. Good | G1: Clinic reinforcement, counseling, feedback about biologic measures, peer support, quit contract, quit guide (431 smokers and 114 quitters/431 and 114) G2: Usual care (440 smokers and 135 quitters/440 and 135) | - For current smokers, no significant differences at birth (11% in G1 vs. 10% in G2) or 6 months postpartum (3% in G1 and G2).; - For recent quitters, abstinence was 65% in G1 and 53% in G2 at birth (p<0.05) and 23% in G1 and 25% in G2 at 6 months postpartum (p=NS).
Walsh et al., 1997^130^ AUS Pregnant smokers Good | G1: Clinic reinforcement, counseling, incentives, information, peer support, personal followup, quit guide (148/127) G2: Counseling and information that were different than G1 (145/125) | - Cessation higher in G1 than G2 at 34 weeks' gestation (13% vs. 6%, p=0.0353) and 6 to 12 weeks postpartum (10% vs. 1%, p=0.0011).
Hartmann et al., 1996^92^ U.S. Pregnant smokers Good | G1: Clinic reinforcement, counseling, feedback about biologic measures, personal followup, prescription to quit, quit guide (107/107) G2: Usual care (100/100) | - No significant difference in cessation at last prenatal visit (20% in G1 vs. 10% in G2, p=0.052, OR=2.20, 95% CI: 0.98 to 4.94).
Suplee, 2005^79^ U.S. Fair | G1: Counseling, information (30/30) G2: Usual care (32/32) | - No significant difference in cessation at 4 to 8 weeks postpartum (37% in G1 vs. 25% in G2, p=0.319).
Donatelle et al., 2000^110^ U.S. Fair | G1: Counseling, incentives, information, peer support, quit guide (112/105 end of pregnancy/103 postpartum) G2: Counseling, information, quit guide (108/102) | - Cessation higher in G1 than G2 at 8 months gestation (32% vs. 9%, p<0.0001) and 2 months postpartum (21% vs. 6%, p<0.0009).
Gielen et al., 1997^91^ U.S. Fair | G1: Clinic reinforcement, counseling, information, personal followup, prescription to quit, quit guide (232/193) G2: Counseling that was different than G1, information (235/198) | - No significant difference in cessation in third trimester (6.2% G1 vs. 5.6% G2).
Windsor et al., 1993^39^ U.S. Fair | G1: Clinic reinforcement, counseling, information, peer support, personal followup, quit guide (400/400) G2: Counseling that was different than G1, information (414/414) | - At end of pregnancy, cessation was higher in G1 than G2 (14.3% vs. 8.5%, p=0.01).
Windsor et al., 1985^93^ U.S. Fair | G1: Counseling, information, ALA quit guide (103/103) G2: Counseling, information, Windsor quit guide (102/102) G3: Counseling different than G1 and G2 (104/104) | - At the end of pregnancy, cessation was 6% in G1, 14% in G2, and 2% in G3 (12% difference between G1 and G3, 95% CI: 0.05 to 0.19).
Eades et al., 2012^127^ AUS Poor | G1: Counseling, information, NRT, partner/household/social context, peer support, quit contract (124 smokers and 24 quitters/124 and 24) G2: Counseling that was different than G1 (107 smokers and 8 quitters/107 and 8) | - For current smokers, no significant difference in cessation at end of pregnancy (1% in G1 vs. 2% in G2; p=0.965; RR 1.01; 95% CI: 0.98 to 1.04).; - For recent quitters, no significant difference in cessation at end of pregnancy (42% intervention, 25% control (p=0.39^a^).
Windsor et al., 2011^98^ U.S. Poor | G1: Clinic reinforcement, counseling, information, quit guide (547/547) G2: Clinic reinforcement, counseling that was different than G1 (546/546) | - No significant difference in cessation at ≤ 90 days postpartum (12% in G1 vs. 10% in G2, p=0.31).
Bullock et al., 2009^103^ U.S. Poor | G1: Counseling, quit guide (170/129) G2: Counseling (175/132) G3: Quit guide (179/141) G4: Information (171/128) | - No significant differences in cessation at end of pregnancy (17.0% G1 vs. 22.0% G2 vs. 19.2% G3 vs.17.2% G4, p=0.72) or 6 weeks postpartum (12.4% G1, 11.4% G2, 13.5% G3, 13.3% G4, p=0.71).
Hegaard et al., 2003^133^ Denmark Poor | G1: Counseling, groups, information, NRT (327/327) G2: Counseling that was different than G1 (320/320) | - Cessation in 37th week of gestation was higher in G1 than G2 (7.0% vs. 2.2%, p=0.004).
Kendrick et al., 1995^11,a^ U.S. Poor | G1: Counseling, information (3064/888) G2: Usual care (2508/1177) | - Results for current smokers and recent quitters reported together.; - No significant difference in cessation at end of pregnancy (6.1% in G1, 5.9% in G2, OR=1.0, 95% CI: 0.69 to 1.6).
Lowe et al., 1997^112^ U.S. Poor | G1: Clinic reinforcement, counseling, information, peer support, personal followup (52/52) G2: Counseling that was different than G1 (45/45) | - No significant difference in cessation at end of pregnancy (29% in G1 vs. 44% in G2, p=0.1).

Abbreviations: AUS = Australia; mos. = months; NR = not reported; NS = nonsignificant; U.S. = United States; wks. = weeks.

a Calculated by the systematic review team using a 2-sided test of proportions.

##### Pregnant Women

###### Smoking Cessation

Twelve multicomponent intervention studies focused on pregnant women who were current smokers: nine only enrolled current smokers,39, 91-93, 98, 103, 110, 130, 133 and three enrolled both current smokers and recent quitters.11, 88, 127 All of these studies assessed interventions implemented during pregnancy. One study also included a postpartum intervention in which participants received additional counseling along with a quit or relapse prevention guide (depending on smoking status) during their postpartum hospitalization.91 Table 19 identifies the specific components of interventions performed in each study. Eleven studies report outcomes at the end of pregnancy (more than 28 weeks' gestation through birth),11, 39, 88, 91-93, 103, 110, 127, 130, 133 and six studies report postpartum outcomes.88, 91, 98, 103, 110, 130

One good-quality RCT enrolled 293 women receiving care at an urban teaching hospital's antenatal clinic in Australia.130 Women in the experimental group received advice from a physician and counseling from a midwife, watched a smoking cessation videotape, were given a quit guide, were offered entry into a lottery with a monetary award if they stopped smoking, had the opportunity to identify a support person who was given educational materials to assist with smoking cessation, had a sticker placed in their medical record, and were sent a letter from the midwife they saw at the first visit.130 Women in the control group received standard stop smoking advice from a physician and midwife and were give a package of anti-smoking materials. Smoking cessation validated by urine cotinine was significantly higher in the experimental group than the control group at the end of pregnancy (13% vs. 7%, p=0.0353) and at 6 to 12 weeks postpartum (10% vs. 1%, p=0.0011). The other two good-quality RCTs did not demonstrate benefit. One was a study of 250 patients at a resident obstetric clinic in North Carolina,92 and the other included 1120 women receiving care at hospital and community trusts in the United Kingdom where the midwives had been randomized to provide intervention or usual care.88 There was significant overlap in the interventions across the good-quality studies: all three included clinic reinforcement, counseling, and a quit guide, and two out of three included feedback about biologic measures, peer support, and personal followup.

Three of the four fair-quality RCTs demonstrated effectiveness. Two of these studies were conducted in the same public health clinics in Birmingham, Alabama.39, 93 The intervention in both studies included similar counseling with a quit guide. In addition, intervention participants in the second study had a reminder form placed in their medical record, received a followup letter and quarterly newsletter, and were given buddy materials (letter, contract, and tip sheet).39 All of the study participants received informational pamphlets and brief advice about smoking cessation during a group prenatal education class. The first study had 309 participants with two intervention groups that received different quit guides, and one intervention group had 14 percent cessation confirmed with saliva thiocyanate compared with 2 percent in the control group at the end of pregnancy (12% difference, 95% CI: 0.05 to 0.19).93 Findings for the other intervention group (with a different quit guide) were not significant. The quit guide that was successful in the first study was used in the second study of 994 participants, which had 14.3 percent saliva cotinine confirmed cessation in the intervention group and 8.5 percent in the control group at the end of pregnancy (p=0.01).39 Interestingly, the addition of clinic reinforcement, personal followup, and peer support interventions in the second study did not lead to higher cessation than was found in the first study which did not include these interventions. Also notable is the fact that two later studies with similar designs, a fair-quality trial with 467 participants conducted in Baltimore, Maryland91 and a poor-quality trial with 1093 participants across several Alabama counties,98 did not demonstrate effectiveness. The authors of the Baltimore study91 propose the lack of effectiveness compared with earlier studies39, 93 may be due to differences in the populations in Birmingham and Baltimore or the fact that they used a peer counselor while the Birmingham studies used a professional counselor. The authors of the Alabama study98 believe their results may be explained by exposure of a significant proportion of the control group to the intervention methods.

The third fair-quality study that was effective enrolled 220 women attending WIC clinics in Oregon.110 All participants received verbal and written information about smoking cessation along with a quit guide. In addition, the intervention group participants identified a social supporter who was preferably a female non-smoker with whom they had regular contact. Both the participant and her social supporter were eligible for financial vouchers for each month of smoking cessation. Cessation confirmed with saliva thiocyanate was higher in the intervention group than the control group at both the end of pregnancy (32% vs. 9%, p<0.0001) and two months postpartum (21% vs. 6%, p<0.0009).

Among the five poor-quality studies focused on current smokers,11, 98, 103, 127, 133 one trial found a significant difference in cessation between the intervention and control groups (7.0% vs. 2.2% respectively, p=0.004).133 Interventions in this study of 695 women receiving midwifery care in Denmark included individual and group counseling, written information about the risks of smoking, and NRT.133

###### Relapse Prevention

Four multicomponent intervention studies focused on pregnant women who were recent quitters: one enrolled only pregnant women who had recently quit smoking,112 and three enrolled both current smokers and recent quitters.11, 88, 127 (Table 21) identifies the specific categories of interventions performed in each study. Four studies report outcomes at the end of pregnancy (more than 28 weeks' gestation through birth),11, 88, 112, 127 and two studies report postpartum outcomes.88, 112

In the good-quality study, midwives at nine hospital and community trusts in the United Kingdom were randomized to provide intervention or routine care to 1120 women.88 Participants in the intervention group received midwife counseling that included information about their carbon monoxide reading, a quit guide, a quit contract, pairing with another pregnant smoker for peer support, and clinic reinforcement via notes in their medical charts to encourage cessation at followup visits. At the end of pregnancy, cessation was 65 percent in the intervention group and 53 percent in the control group (p<0.05). There was no longer a significant difference between the groups at six months postpartum. This study also enrolled current smokers, and the findings for those participants were not significant. None of the three poor-quality studies of recent quitters demonstrated effectiveness.

##### Postpartum Women

###### Relapse Prevention

One fair-quality, U. S., multicomponent intervention study evaluated a counseling intervention with educational materials conducted during postpartum hospitalization of 62 women.79 At 4 to 8 weeks postpartum, 37 percent of women in the intervention had biochemically validated cessation compared with 25 percent of the control group (p=0.319).

## Key Question 2 Intervention Effects on Infant Outcomes

### Key Points

- Only 13 out of the 56 RCTs in our review included infant outcomes, and no studies included child outcomes.
- Thirteen studies reported mean birth weight and had inconsistent findings; three of these studies had results that were statistically significant but not clinically meaningful.
- Seven studies reported gestational age and had inconsistent findings. Only one of these studies had results that were statistically significant with women who received NRT in addition to CBT giving birth an average of one week later than women who received CBT only.
- Seven studies that reported preterm birth found a lower incidence in the intervention group compared to the control group; however, this was not statistically significant in any of these studies. One study did not find any difference in incidence of preterm birth.
- Neonatal deaths were only reported in two studies with no significant difference between intervention and control groups.
- All six studies that reported NICU admissions found a lower incidence in the intervention group compared to the control group; however, this was not statistically significant in any of these studies.

### Description of Included Studies

In our pool of included studies, we identified 13 that reported infant outcomes associated with smoking cessation and/or relapse prevention interventions among pregnant women.84, 102, 104, 105, 117, 120-122, 124, 129, 132-134 Infant outcomes from one of these studies117 were presented in a separate publication.139 Eight of these studies were conducted in the United States,84, 102, 104, 105, 117, 120, 121, 133, 139 three in the United Kingdom,122, 124, 132 and one study each in Sweden134 and Australia.129 The interventions represented include three counseling studies,105, 129, 132 two assessments of educational materials,117, 134, 139 four studies of NRT,102, 104, 120, 122 two studies of incentives,84, 121 and one study each of a multicomponent intervention,133 and point-of-care nicotine testing.124 One study was good quality,122 three were of fair quality,84, 102, 139 and nine of poor quality.104, 105, 120, 121, 124, 129, 132-134 All studies focused on infant outcomes during the immediate postpartum period; none of the studies included infant outcomes after hospital discharge or further followup of any child-related outcomes.

### Detailed Synthesis

#### Birth Weight

All 13 studies reported mean birth weight outcomes. In a poor-quality Australian study that compared midwife-provided counseling to usual care in pregnant smokers and had outcomes for 728 infants, mean birth weight was higher among infants born to women in the intervention group compared to the control group, (3250 grams vs. 3166 grams, p=0.04) but the difference was reduced to 29 grams (p=0.41) when preterm births were excluded.129 In a fair-quality multicenter U.S. study that randomized 194 pregnant smokers to receive behavioral counseling plus either nicotine gum or placebo gum, the newborns from the intervention group had a statistically significant higher birth weight than the newborns from the control group (3287 grams vs. 2950 grams, p<0.001).102 In a poor-quality UK study that assessed the effect of feedback to women about a point-of-care nicotine test, investigators reported a significant difference in birth weight between the intervention and control groups after adjusting for nicotine metabolites (3.26 kg vs. 3.08 kg, p<0.03).124 While these three studies had statistically significant findings, these differences in birth weight between intervention and control groups are not clinically meaningful. Among the ten studies that did not show a statistically significant between-group difference in birth weight, six reported higher mean birth weight in the intervention group84, 120, 121, 132, 134, 139 and four reported higher mean birth weight in the control group.104, 105, 122, 133

Seven studies reported the proportion of births that were low birth weight (less than 2500 grams).84, 105, 120, 121, 133, 134, 139 Two were of fair quality,84, 139 and five of poor quality.105, 120, 121, 133, 134 None of these studies found statistically significant differences in the incidence of low birth weight between the intervention and control groups.

#### Gestational Age

Seven studies reported outcomes related to gestational age including one good quality,122 two of fair quality,84, 102 and three of poor quality.104, 120, 121, 132 The primary component of the intervention was counseling in one study,132 NRT in four studies,102, 104, 120, 122 and a unique incentive strategy in one study.84 In a good-quality RCT conducted in the United States that randomized 52 pregnant smokers to either nicotine patches and CBT or to CBT alone, women in the intervention group gave birth at a higher gestational age as compared with their control counterparts (39.4 vs. 38.4 weeks, p=0.02).120 The other five studies did not show a statistically significant between-group difference in gestational age, which was higher in the intervention group in two studies,84, 102 higher in the control group in two studies,104, 132 and equivalent in the intervention and control groups in two studies.121, 122

#### Preterm Birth

Seven studies reported preterm birth outcomes including one of good quality,122 two of fair quality,84, 139 and four of poor quality.120, 129, 132, 134 The primary component of the intervention was counseling in two studies,129, 132 educational materials in two studies,134, 139 NRT in two studies,120, 122 and a unique incentive strategy in one study.84 None of the studies had statistically significant findings, but all of the studies found a lower incidence of preterm birth in the intervention group compared to the control group.

#### Neonatal Death

Two studies122, 132 reported neonatal death outcomes that were not statistically significant. In a poor-quality RCT that evaluated a counseling intervention, there was one preterm neonatal death in each group (intervention n=351, control n=411).132 A multicenter UK study of good quality comparing the effectiveness of nicotine patch therapy to placebo for smoking cessation had no neonatal deaths in the intervention group (n=507) and two neonatal deaths in the control group (n=517).122

#### NICU Admission

Six studies reported NICU admission outcomes including one of good quality,122 two of fair quality,84, 139 and three of poor quality.105, 121, 132 The primary component of the intervention was counseling in two studies,105, 132 educational materials in one study,139 NRT in one study,122 and an incentive strategy in two studies.84, 121 None of the studies had statistically significant findings, but all of the studies found a lower incidence of NICU admissions in the intervention group compared to the control group.

## Key Question 3 Intervention Harms for Pregnant and Postpartum Women

### Key Points

- Four out of the 56 RCTs in our review reported harms or adverse events associated with smoking cessation interventions. None of the included prospective cohort studies assessed harms of cessation interventions.
- One educational materials study assessed the effect of the cessation intervention on women's stress levels and did not find a difference in mean stress scores between groups.
- Three RCTs did not find adverse events or harms increased with NRT interventions in pregnant smokers. Caution is warranted in interpreting these results, given the low numbers of participants and the low adherence rates.

### Description of Included Studies

In our pool of included studies, we identified four RCTs that reported harms or adverse events associated with smoking cessation interventions.102, 104, 122, 125 Two of these studies were conducted in the United States,102, 104and two in the United Kingdom.122, 125 The interventions included three studies of NRT102, 104, 122 and one of educational materials.125 None of the prospective cohort studies included in our review assessed harms of smoking cessation interventions.

### Detailed Synthesis

#### Educational Materials

A poor-quality cluster RCT conducted in the United Kingdom and described in the educational materials interventions addressed KQ3. This study evaluated stage of change-based quit guides and a tailored, interactive computer program focused on cessation.125 In addition to assessing smoking cessation at 30 weeks' gestation and at 10 days postpartum, investigators assessed the effect of the cessation intervention on women's stress levels using the Perceived Stress Scale.137 Women completed the questionnaire between 12 and 20 weeks' gestation, between 23 and 25 weeks' gestation, between 28 and 30 weeks' gestation, and at 10 days postpartum. Mean stress scores did not differ between groups at baseline or at 30 weeks' gestation (mean 1.6 ± 0.8 at both time points), but they increased slightly within each group. Mean scores fell slightly in all arms after birth.

#### NRT

Three RCTs of NRT interventions in pregnant smokers included reporting of adverse events or harms. A good-quality study enrolled 1050 pregnant smokers, between 12 and 24 weeks' gestation, at hospital settings in England.122 The intervention group was assigned to 8 weeks of treatment with nicotine patches (15 mg per 16 hours) and behavioral support. The control group received a placebo patch and behavioral support. The incidence of adverse pregnancy and birth outcomes was similar in the two groups; raw data were provided without statistics.

A fair-quality U.S. study enrolled 194 pregnant smokers (less than 26 weeks' gestation).102 Women in the intervention group received 6 weeks of 2 milligram nicotine gum and behavioral counseling, while women in the control group received a placebo gum and behavioral counseling. There was no significant difference between the groups in specific adverse events, nor composite adverse effects (maternal hospitalization, low birth weight, preterm birth, spontaneous abortion, intrauterine fetal death, newborn death, NICU admission).

A poor-quality U.S. study enrolled 181 pregnant smokers (13 to 25 weeks' gestation).104 Women in the control group received CBT. Women in the intervention group received CBT and patient-preference open-label selection of nicotine patch, nicotine gum, or nicotine lozenge with the dosage adjusted by prior smoking level. This trial was halted for a two-fold difference in serious adverse events between arms, but the Data Safety and Monitoring Board stated they did not believe the difference was related to NRT use. Adverse events, from most to least frequent, included preterm birth (less than 37 weeks), NICU admissions, small-for-gestational age, placental abruption, and fetal demise. Adverse events occurred in 30 percent (34/113) of the women in the intervention arm compared with 17 percent (10/58) of women in the control arm (p=0.07). After adjusting for previous preterm birth, the proportion of women with adverse events decreased to 27 percent in the intervention arm and 18 percent in the control arm (p=0.26).

## Key Question 4 Effectiveness of Intervention Components

### Key Points

- In 24 good and fair quality RCTs of smoking cessation interventions, the most common components of the interventions were counseling, information, quit guides, personal followup, and clinic reinforcement.
- A meta-analysis of the study components in 23 smoking cessation RCTs found that the use of incentives was most strongly associated with substantially increased smoking cessation.
- The other components likely to have a positive effect were feedback about biologic measures, NRT, information, personal followup, and quit guides.
- In the six good and fair quality RCTs of relapse prevention interventions, the most common components of the interventions were counseling, quit guides, information, and personal followup. These studies were too heterogeneous to conduct an analysis to assess the effect of the components.
- Data were not available to specifically assess the impact of provider or care site for this Key Question.

### Description of Included Studies

Twenty-eight good and fair quality RCTs were available for this Key Question. Three studies targeted postpartum women,79, 80, 82 and the rest enrolled pregnant women. Twenty-two focused on current smokers,39, 83-87, 89-93, 97, 100-102, 107, 110, 117, 119, 122, 123, 130 four focused on recent quitters,79, 80, 82, 94 and two included both smokers and quitters.88, 126 We did not find any cohort studies that had appropriate information for inclusion in the meta-analysis, which is the basis for this Key Question.

### Detailed Synthesis

The included RCTs had multiple components of the intervention itself, and some studies used the same component in both the intervention and control arms. We classified the components of the intervention and control arms for each study in this section according to the descriptions in Table 4. These studies are grouped below by those that focused on smoking cessation versus relapse prevention. Data were not available to specifically assess the impact of provider or care site for this Key Question

#### Smoking Cessation

Twenty-four studies assessed smoking cessation interventions: 11 of good quality85, 87, 88, 92, 97, 100, 107, 122, 123, 126, 130 and 13 of fair quality.39, 83, 84, 86, 89-91, 93, 101, 102, 110, 117, 119 Two of these studies also included recent quitters.88, 126 All 24 studies evaluated prenatal interventions, and one study also included an intervention during postpartum hospitalization.91

Table 22 presents an overview of the components used in these studies. The components were counseling in 21 studies;39, 83, 84, 86-93, 100-102, 107, 110, 117, 119, 122, 126, 130 quit guides in 14 studies;39, 84, 88-93, 107, 110, 117, 122, ^#18^, 126, 130 information in 13 studies;39, 83, 84, 86, 87, 91, 93, 97, 102, 110, 117, 119, 130 personal followup in 12 studies;39, 83, 86, 87, 89, 91, 92, 102, 119, 122, 123, 130 clinic reinforcement in 10 studies;39, 83, 86-88, 90-92, 102, 107, 130 peer support in seven studies;39, 85, 88, 101, 107, 110, 130 feedback about biologic measures in five studies;83, 88, 90, 92, 97 incentives in four studies;84, 97, 110, 130 NRT in two studies;84, 102, 122 quit contracts in three studies;84, 88, 122 other unique interventions, including counseling for depression,100 a computerized interactive telephone support system,89 and an interactive computer delivered intervention,97 in three studies; prescriptions to quit in two studies;91, 92 and groups in one study.85 No studies included a partner/household/social context component.

Table 22 Smoking cessation intervention components from studies of current smokers^a^

Author, Year Quality | Study Arm | Clinic Reinforcement | Counseling | Feedback | Groups | Incentives | Information | NRT | Partner/Household | Peer Support | Personal Followup | Prescription To Quit | Quit Contract | Quit Guide | Usual Care | Other | Total Components | Description of Other
Coleman et al., 2012^122^ Good | Intervention | | ● | | | | | ● | | | ● | | ● | ● | | | 5
Coleman et al., 2012^122^ Good | Control | | ● | | | | | | | | ● | | ● | ● | | | 4
Naughton et al., 2012^123^ Good | Intervention | | | | | | | | | | ● | | | ▲ | | | 2
Naughton et al., 2012^123^ Good | Control | | | | | | | | | | | | | ▲ | | | 1
Ondersma et al., 2012^97^ Good | Intervention 1 | | | | | | ● | | | | | | | | | ● | 2 | Interactive computer-delivered smoking cessation intervention
Ondersma et al., 2012^97^ Good | Intervention 2 | | | ● | | ● | | | | | | | | | | | 2
Ondersma et al., 2012^97^ Good | Intervention 3 | | | ● | | ● | ● | | | | | | | | | ● | 4 | Interactive computer-delivered smoking cessation intervention
Ondersma et al., 2012^97^ Good | Control | | | | | | | | | | | | | | ● | ▲ | 1 | Interactive computer program (not smoking related)
Cinciripini et al., 2010^100^ Good | Intervention | | ● | | | | | | | | | | | | | ▲ | 2 | Cognitive behavioral analysis system of psychotherapy
Cinciripini et al., 2010^100^ Good | Control | | ● | | | | | | | | | | | | | ▲ | 2 | Health and wellness education
Albrecht et al., 2006^85^ Good | Intervention 1 | | | | ● | | | | | | | | | | | | 1
Albrecht et al., 2006^85^ Good | Intervention 2 | | | | ● | | | | | ● | | | | | | | 2
Albrecht et al., 2006^85^ Good | Control | | ● | | | | ● | | | | | | | | | | 2
Rigotti et al., 2006^87^ Good | Intervention | ● | ▲ | | | | ▲ | | | | ● | | | | | | 4
Rigotti et al., 2006^87^ Good | Control | ● | ▲ | | | | ▲ | | | | | | | | | | 3
Malchodi et al., 2003^107^ Good | Intervention | ● | ● | | | | | | | ● | | | | ● | | | 4
Malchodi et al., 2003^107^ Good | Control | ● | ● | | | | | | | | | | | ● | | | 3
Moore et al., 2002^126,b^ Good | Intervention | | ● | | | | | | | | | | | ● | | | 2
Moore et al., 2002^126,b^ Good | Control | | | | | | | | | | | | | | ● | | 1
Hajek et al., 2001^88,b^ Good | Intervention | ● | ● | ● | | | | | | ● | | | ● | ● | | | 6
Hajek et al., 2001^88,b^ Good | Control | | | | | | | | | | | | | | ● | | 1
Walsh et al., 1997^130^ Good | Intervention | ● | ▲ | | | ● | ▲ | | | ● | ● | | | ● | | | 7
Walsh et al., 1997^130^ Good | Control | | ▲ | | | | ▲ | | | | | | | | | | 2
Hartmann et al., 1996^92^ Good | Intervention | ● | ● | ● | | | | | | | ● | ● | | ● | | | 6
Hartmann et al., 1996^92^ Good | Control | | | | | | | | | | | | | | ● | | 1
Hennrikus et al., 2010^101^ Fair | Intervention | | ● | | | | | | | ● | | | | | | | 2
Hennrikus et al., 2010^101^ Fair | Control | | ● | | | | | | | | | | | | | | 1
Stotts et al., 2009^83^ Fair | Intervention 1 | | ● | ● | | | ● | | | | | | | | | | 3
Stotts et al., 2009^83^ Fair | Intervention 2 | | ▲ | ● | | | | | | | ● | | | | | | 3
Stotts et al., 2009^83^ Fair | Control | | ● | | | | ● | | | | | | | | | | 2
Heil et al., 2008^84^ Fair | Intervention | | ● | | | ● | ● | | | | | | ● | | | | 4
Heil et al., 2008^84^ Fair | Control | | ● | | | | ● | | | | | | ● | | | | 3
Oncken et al., 2008^102^ Fair | Intervention | ● | ● | | | | ● | ● | | | ● | | | | | | 5
Oncken et al., 2008^102^ Fair | Control | ● | ● | | | | ● | | | | ● | | | | | | 4
Dornelas et al., 2006^86^ Fair | Intervention | ● | ▲ | | | | ● | | | | ● | | | | | | 4
Dornelas et al., 2006^86^ Fair | Control | ● | ▲ | | | | ● | | | | | | | | | | 3
Donatelle et al., 2000^110^ Fair | Intervention | | ● | | | ● | ● | | | ● | | | | ● | | | 5
Donatelle et al., 2000^110^ Fair | Control | | ● | | | | ● | | | | | | | ● | | | 3
Ershoff et al., 1999^89^ Fair | Intervention 1 | | | | | | | | | | | | | ● | | ● | 2 | Computerized interactive telephone support system
Ershoff et al., 1999^89^ Fair | Intervention 2 | | ● | | | | | | | | ● | | | ● | | | 3
Ershoff et al., 1999^89^ Fair | Control | | | | | | | | | | | | | ● | | | 1
Secker-Walker et al., 1998^90^ Fair | Intervention | ● | ▲ | ● | | | | | | | | | | | | | 3
Secker-Walker et al., 1998^90^ Fair | Control | | ▲ | | | | ● | | | | | | | ● | | | 3
Gielen et al., 1997^91^ Fair | Intervention | ● | ▲ | | | | ● | | | | ● | ● | | ● | | | 6
Gielen et al., 1997^91^ Fair | Control | | ▲ | | | | ● | | | | | | | | | | 2
Windsor et al., 1993^39^ Fair | Intervention | ● | ▲ | | | | ● | | | ● | ● | | | ● | | | 6
Windsor et al., 1993^39^ Fair | Control | | ▲ | | | | ● | | | | | | | | | | 2
Burling et al., 1991^119^ Fair | Intervention | | ● | | | | ● | | | | ● | | | | | | 3
Burling et al., 1991^119^ Fair | Control | | ● | | | | | | | | | | | | | | 1
Ershoff et al., 1989^117^ Fair | Intervention | | ● | | | | ● | | | | | | | ● | | | 3
Ershoff et al., 1989^117^ Fair | Control | | ● | | | | ● | | | | | | | | | | 1
Windsor et al., 1985^93^ Fair | Intervention 1 | | ● | | | | ● | | | | | | | ▲ | | | 3
Windsor et al., 1985^93^ Fair | Intervention 2 | | ● | | | | ● | | | | | | | ▲ | | | 3
Windsor et al., 1985^93^ Fair | Control | | ▲ | | | | | | | | | | | | | | 1

a Includes good and fair quality studies only; ● indicates the intervention was the same for the different arms; ▲ indicates the intervention varied for the different arms (e.g., control arm got brief counseling while intervention arm got longer counseling); studies organized by quality then chronologically, then alphabetically by first author.

b Study also enrolled recent quitters.

We were able to combine 23 of these studies into a robust random effects meta-analysis to quantify the relative impact of components of the interventions on smoking cessation. One study126was excluded because outcomes for smoking cessation and relapse prevention were reported together and could not be calculated separately. Nine components were evaluated individually: clinic reinforcement, feedback, incentives, information, NRT, peer support, personal followup, prescription to quit, quit guides and other, which combined relatively rarer components, such as groups and quit contracts. Counseling was ubiquitous in both intervention and control arms of the studies; thus it could not be assessed as a driver of effect. Rather, counseling studies are described qualitatively in the report. The model used was a logistic mixed effects model that estimated quit rates across studies. Table 23 presents the findings of the model.

Table 23 Relative impact of intervention components on smoking cessation

Component | OR | SD | Lower Bound | Upper Bound | Posterior Probability OR >Null
Incentives | 3.23 | 0.69 | 1.98 | 4.59 | 100%
Feedback | 1.43 | 0.30 | 0.88 | 2.03 | 95%
Information | 1.32 | 0.24 | 0.88 | 1.79 | 93%
Personal Followup | 1.25 | 0.16 | 0.94 | 1.57 | 95%
NRT | 1.24 | 0.22 | 0.84 | 1.68 | 87%
Quit Guide | 1.18 | 0.19 | 0.82 | 1.56 | 83%
Prescription to Quit | 1.13 | 0.42 | 0.46 | 1.95 | 57%
Peer Support | 1.07 | 0.20 | 0.70 | 1.46 | 60%
Clinic Reinforcement | 1.05 | 0.22 | 0.65 | 1.49 | 55%

Abbreviations: OR = odds ratio; NRT = nicotine replacement therapy; SD = standard deviation.

#### Relapse Prevention

Six studies assessed interventions to prevent relapse in women who had recently quit smoking: four of good quality80, 82, 88, 126 and two of fair quality.79, 94 Two of these studies also included current smokers.88, 126 Three studies evaluated prenatal interventions,88, 94, 126 and three studies evaluated postpartum interventions.79, 80, 82

Table 24 presents an overview of the components in these studies. The components were counseling in all six studies, quit guides in four studies,82, 88, 94, 126 information in three studies,79, 80, 94 and personal followup in two studies.80, 82 Clinic reinforcement,88 feedback about biologic measures,88 information,79 partner/household/social context,80 peer support,88 a quit contract,88 and a unique mother-infant bonding intervention80 were each used in one study. No studies included group, incentive, NRT, or prescription to quit components. These studies were too heterogeneous to conduct an analysis to assess the effect of the components; there was not a sufficient number of studies with the same components.

Table 24 Relapse prevention intervention components from studies of recent quitters^a^

Author, Year Quality | Study Arm | Clinic Reinforcement | Counseling | Feedback | Groups | Incentives | Information | NRT | Partner/Household | Peer Support | Personal Followup | Prescription to Quit | Quit Contract | Quit Guide | Usual Care | Other | Total Interventions | Other Description
Phillips et al., 2012^80^ Good | Intervention | | ● | | | | ● | | ● | | ● | | | | | ● | 5 | Enhanced support in bonding with newborn
Phillips et al., 2012^80^ Good | Control | | ● | | | | ● | | ● | | ● | | | | | | 4
Moore et al., 2002^126,b^ Good | Intervention | | ● | | | | | | | | | | | ● | | | 2
Moore et al., 2002^126,b^ Good | Control | | | | | | | | | | | | | | ● | | 1
Hajek et al., 2001^88,b^ Good | Intervention | ● | ● | ● | | | | | | ● | | | ● | ● | | | 6
Hajek et al., 2001^88,b^ Good | Control | | | | | | | | | | | | | | ● | | 1
Johnson et al., 2000^82^ Good | Intervention | | ● | | | | | | | | ● | | | ● | | | 2
Johnson et al., 2000^82^ Good | Control | | | | | | | | | | | | | | ● | | 1
Suplee, 2005^79^ Fair | Intervention | | ● | | | | ● | | | | | | | | | | 2
Suplee, 2005^79^ Fair | Control | | | | | | | | | | | | | | ● | | 1
Ershoff et al., 1995^94^ Fair | Intervention | | ▲ | | | | ● | | | | | | | ● | | | 3
Ershoff et al., 1995^94^ Fair | Control | | ▲ | | | | ● | | | | | | | | | | 2

a Includes good and fair quality studies only; ● indicates the intervention was the same for the different arms; ▲ indicates the intervention varied for the different arms (e.g., control arm got brief counseling while intervention arm got longer counseling); studies organized by quality then chronologically and then by alphabetical order of first author.

b Study also enrolled current smokers.

## Key Question 5 Effect of Patient Characteristics on Effectiveness

### Key Points

- In this literature with biochemical validation of non-smoking status, few studies explicitly examined the influence of participant characteristics on probability of response to intervention or probability of successful cessation.
- No RCTs that demonstrated that the intervention being studied was superior to the comparison group outcomes provided analyses of effect modification by participant characteristics.
- Across good and fair quality trials, consistent and inter-related baseline predictors of achieving and maintaining cessation included lower levels of tobacco dependence as measured by biomarkers, questions gauging dependence, and cigarettes per day.
- Data were sparse to document the influence of maternal age, parity, other smokers in the home, a non-smoking partner, and smoke free policies in the home.
- Data were less consistent for the effects of education, prior experience with cessation, readiness to change, and self-reported motivation to quit.

### Description of Included Studies

We sought to obtain two types of evidence to inform this Key Question. The strongest, and therefore optimal form of information, is formal analysis of effect modification, also called interaction. The interaction of interest is that of the intervention received with characteristics of the participants. Ideally intention to take this approach is described in the statistical methods section of the publication as an a priori part of the data analysis plan. An example would be a study that specifically hypothesizes that women in their first pregnancy participating in the intervention arm of the trial will achieve higher cessation rates than women who smoke and already have children, and that then tests this hypothesis with an interaction term in a multivariate model that incorporates trial arm and parity. This approach investigates whether the characteristic of the participant in the smoking intervention program modifies the level of success of an intervention that is shown to be effective.

A second type of information comes from analyses of predictors of cessation within both the included clinical trials and large pre-post type cohort studies of smoking cessation and abstinence support programs. These analyses may at times be specified in advance but were most often post hoc and most common within studies that did not demonstrate efficacy of the intervention being studied. The approach may be used to explain the challenges of the population recruited to the study and to dissect why an intervention did not deliver the expected results. In other cases, the analysis of predictors was conducted as secondary activity for a subsequent publication. In other cases included in this grouping of the papers, investigators did formally examine effect modification but within the entire study population irrespective of intervention group. Data from analyses of these types help describe what factors may influence likelihood of cessation but do not provide information about which women will benefit from which types of intervention.

The information summarized here extends similar components of prior reviews because our entire review was restricted to publications that used biochemical validation of smoking status and thus overcomes the bias introduced by misclassification of outcomes as a result of deception.

### Detailed Synthesis

#### Factors That Modify Success of Intervention

Among the eight randomized trials that demonstrated efficacy or effectiveness of an intervention,39, 84, 86, 93, 97, 110, 117, 130 none had hypotheses or methods sections that indicated an a priori intention to assess effect modification. Likewise, none of the identified cohorts could address whether individual characteristics modified response to an effective intervention.38, 95, 96 A single study of counseling and phone followup among 105, predominantly low income Hispanic women, provided data stratified by initial smoking status, indicating that the intervention was significantly effective both among those who smoked fewer than 10 cigarettes per day at baseline and heavier smokers, suggesting no effect modification by level of nicotine dependence (baseline smoking intensity) but not providing data for the statistical test of interaction.86

An intervention designed specifically to test for an interaction between depression scores and effectiveness of an intervention based on cognitive behavioral analysis system of psychotherapy (CBAP), did not find evidence of benefit of the intervention in their biomarker validated outcome.100 This report with 257 participants notes significant interaction of higher depression scores and participation in the CBAP arm leading to improved cessation probability at 6 months after the end of treatment. They also report this effect was not present 3 months after end of treatment with CBAP, nor at 3 or 6 months postpartum.

#### Factors Related to Probability of Cessation

The analyses described here did not test for effect modification and thus did not directly address the type of intervention and the participant characteristic simultaneously to determine what intervention approaches might be projected to be most successful among specific groups of smokers. Therefore we have grouped studies in nested groups to organize the presentation of data about participant characteristics that were associated with likelihood of cessation (Table 25). First we restricted to the 28 fair or good quality trials identified in the overall literature review39, 79, 80, 82-94, 97, 100-102, 107, 110, 117, 119, 122, 123, 126, 130 and three cohort studies that also included biomarkers of cessation.38, 95, 96

Table 25 Individual characteristics in relation to achieving or maintaining cessation

Author, Year Timing of Intervention | Younger Maternal Age | Higher Education Level | First Baby | No Smokers in Home | Partner Does Not Smoke | Smoke Free Home | Less Tobacco Dependent | Prior Cessation Success | Motivation for Cessation | Other (See text)
Achieving Cessation^a,b^
Cinciripini PM et al., 2010^100^ | | | | | | | | | | NS
Stotts AL et al., 2009^83^ | | | | | | | ↑ | | NS
Heil SH et al., 2008^84, 141, 143^ | | | | | | | | | | ↑
Albrecht SA et al., 2006^85, 142, 144, 145^ | | | | | | | | | | ↑
Dornelas EA et al., 2006^86^ | ↑ | | | | | | | | NS | ↑
Rigotti NA et al., 2006^87, 146, 147^ | ↑ | | | | | NR | ↑ | | | NR
Hajek P et al., 2001^88,c^ | | NS | | | | | ↑ | | ↑
Ershoff DH et al., 1999^89^ | | NR | | | | NR | ↑ | | NR | NR
Secker-Walker RH et al., 1998^90^ | | | | | | | ↑ | | ↑
Gielen AC et al., 1997^91^ | | | | | | | | | | ↑
Hartmann KE et al., 1996^92^ | | | ↑ | | | | ↑ | | ↑ | ↑
Windsor, RA et al., 1993^39, 140^ | | | | | | | ↑ | | | ↑
Maintaining Cessation^d,e^
Hajek P et al., 2001^88,f^ | | ↑ | | | | | ↑ | | | ↑
Ershoff, DH et al., 1995^94^ | | | ↑ | | | | | ↑ | ↑ | ↑
Johnson JL et al., 2000^82, 136^Postpartum | | | | | ↑ | | ↑ | | | ↑

Abbreviations: NS = not significant; NR = p-value not reported but they reported the data in the context of other data with statistical backup.

Notes: Table limited to good and fair quality studies that evaluated a participant characteristic, biochemically validated cessation outcome, and presented statistical significance testing with the data.

a Reported in a total of 20 papers (12 unique studies plus eight related papers)

b Interventions targeted current smokers during pregnancy (25 studies); no studies of good or fair quality targeted interventions for current smokers in the postpartum period

c Study enrolled smokers and quitters; characteristics of quitters reported in “Maintaining Cessation” section

d Reported in a total of four papers (3 unique studies plus one related paper)

e Interventions targeted recent quitters during pregnancy in two studies88, 94 and in postpartum in one study82

f Study enrolled smokers and quitters; characteristics of smokers reported in “Achieving Cessation” section

We evaluated only those analyses using cessation endpoints for which there were biologically validated measures of cessation available, for instance if cessation was assessed at 3, 6, 9, and 12 months but cotinine was only measured at 6 and 12, we include only 6 and 12 month data. We present information by timing of the intervention (during pregnancy and postpartum), and within those time periods, we begin with data from trials that demonstrated efficacy of the intervention and conclude each subsection with data from studies that did not document a significant impact of intervention. We further group the type of characteristic associated with cessation in the same manner as Table 25:

- Maternal age
- Education
- Parity (first baby or not)
- Presence of other smokers in home
- Partner smoking status
- Smoke free home
- Level of tobacco dependence
- Prior success with cessation
- Baseline desire or motivation for cessation
- Other predictors of cessation

In total, studies from 18 populations provide information about how participant characteristics related to success in quitting smoking. This includes 14 randomized trials39, 82-94 of which four are from studies with interventions proven effective84, 86, 93, 140 and three cohort studies.38, 95, 96

##### Cessation During Pregnancy

Across intervention types, there were commonalities. Younger maternal age, which is correlated with fewer years of smoking, was reported to be associated with improved chance of cessation. A successful trial of in-person counseling and telephone followup reported that women ages 18 to 24 were most likely to quit and that this effect was retained in models that adjusted for number of children and number of prior pregnancies.86 A trial of telephone counseling also reported that women younger than 25 had higher odds of cessation (OR=2.41; 95% CI: 1.20 to 4.82).87 In contrast, in a large quasi-experimental analysis of 777 women in the Baby & Me Tobacco Free program implemented among postpartum women, authors report increasing maternal age was associated with improved odds of cessation (OR=1.07; 95% CI: 1.02 to 1.12).95

No studies of interventions found to be effective addressed the influence of maternal education. One trial of brief midwifery intervention in the United Kingdom found education did not predict cessation but was strongly associated with relapse among those who entered the intervention in a maintenance phase and needed to sustain cessation.88 Another study conducted in the United States reported that maternal education entered their multivariate model of predictors but did not report the effect size or statistical significance.89 The Baby & Me Tobacco Free cohort did not find years of school completed was associated with cessation in multivariable adjusted models.95

No studies of interventions found to be effective addressed the influence of parity. A single study reported from adjusted logistic models that women with fewer children were more likely to quit (p<0.01).92 Another trial, also using multivariate logistic models, found women having their first child may be much more likely to achieve cessation; however, the estimate was imprecise (OR=8.50; 95% CI: 1.03 to 70.21).94 A Danish cohort (n=3,156) of intervention during pregnancy as part of midwifery care reports women having their first child were more likely to quit but did not include the effect size estimate.96

How smoking is handled in the home can be captured in a number of ways that include whether others who live in the home are smokers, whether the partner smokes, and whether or not anyone is allowed to smoke inside the home as opposed to going outside to smoke. Though these characteristics are often considered predictors in the health behavior literature and in cohort analyses, only three trials comment on the influence with two addressing cessation during pregnancy. Neither study showed the intervention in the trial was effective. Both were conducted in the United States, and both reported an influence on cessation but did not provide direct statistical support. One group reported that a non-smoking policy in the home was a predictor in multivariate models but no odds ratios or confidence intervals were provided;87 the other noted exposure to passive smoke [in the home] was included in models but also did not provide data.89 A single intervention initiated in the postpartum period, for which the intervention itself was not superior to usual care, reported that those who had partners who smoked had higher odds of smoking (OR=1.81; 95% CI: 1.02 to 3.20),82 while the Baby & Me Smoke Free program found partner/spouse smoking status was not an independent predictor in multivariate models.95

Smoking habits at the time of enrollment were evaluated in several studies. Biomarkers and quantity of smoking were found to play a role in predicting cessation in a successful trial of a multicomponent intervention that centered around a pregnancy-specific quit guide.39, 93 There was a significant association of baseline cotinine levels with cessation such that those with higher cigarette use were less likely to quit.39 This research team also reported similar findings without providing statistical significance testing or estimates of the effect size, noting that “most quitters were light smokers” in a subsequent trial.93

Five other trials for which the intervention was not demonstrated to be more effective than the comparison group, reported similar findings: lower cigarette use at baseline improved chances of cessation,83 smoking fewer than 10 cigarettes per day was associated with nearly three-fold higher odds of cessation (OR=2.94; 95% CI: 1.37 to 6.29) as were women who smoked less than five compared to more in another study,87, 89 greater nicotine dependence as assessed by smoking first cigarette of the day within 30 minutes of awakening reduced chance of quitting88 as did higher breath carbon monoxide levels as a measure of intensity of smoking.90 A single study that initiated intervention postpartum evaluated baseline smoking and found a continuous decrease in chance of quitting for each cigarette smoked per day at baseline.82 Results in the Baby & Me cohort also support the role of baseline carbon monoxide and cigarettes per day in predicting cessation, including risk of dropping out of intervention.95

Self-reported readiness or motivation to quit as well as confidence in one's own ability to do so, were evaluated in multiple studies as markers of being able to successfully quit. The only trial with an effective intervention reported that baseline self-efficacy did not predict who would be able to quit. Other trials that pooled trial participants across arms found higher intention to quit predicted more than two-fold higher odds of cessation,90 self-reported desire to quit was associated with cessation,92 high levels of confidence in ability to remain abstinent multiple cessation by more than five-fold,94 and in a postpartum intervention, poor self-efficacy for cessation was associated with less ability to remain quit.82

Candidate predictors of cessation explored in single studies, indicated as “Other” in Table 25, included three results from trials for which the intervention was superior to the comparison:

- Smoking status in the first two weeks of treatment was a predictor of cessation status at the end of pregnancy.141
- The intervention was most effective when initiated early in gestation (<17 weeks).86
- Black women in one Alabama trial (n=814) were more likely to quit, but were also lighter smokers.39
- While in a cohort of 265 low-income women in Alabama, race was not found to be an independent predictor in models.38

Other characteristics reported to be modest predictors in studies without proven effectiveness of the intervention included these factors that were statistically meaningfully associated with cessation:

- Adolescents who quit had greater knowledge of harmful effects of smoking.142
- Helpful family and friends were more commonly reported among quitters.91, 92
- Perceived greater risks to the baby.92

##### Maintaining Cessation Achieved Before Study Participation

Some studies enrolled women who had already achieved cessation in order to assist them in remaining smoke free during and after their pregnancies. None of these achieved effectiveness for supporting maintenance using the intervention being studied compared to a usual care group. Only two studies,82, 88 with three publications,82, 88, 136 report on any predictors of continued abstinence among women who had quit.

A single study of midwife-delivered brief intervention in the United Kingdom88 found minimal educational attainment was associated with poor maintenance of cessation which was reduced by more than half compared to those with greater education at the time of birth. This association was no longer observed at last followup (i.e., 6 months after birth) when overall relapse rates were higher.88 They also reported that employment outside the home in a non-manual occupation and being married were linked with an 80 to 90 percent higher odds of remaining smoke-free.88 Other factors reported to be linked to maintaining cessation included: continuing to breastfeed for 12 months and having good mental health scores; whereas, having a partner who smoked was linked to relapse.82, 136