# References

1 Centers for Disease Control and Prevention. Smoking prevalence among women of reproductive age--United States, 2006. MMWR. Aug. 8. 2008;57(31):849-52. [pmid: 18685552].
2 Centers for Disease Control and Prevention. Tobacco Use: Targeting the Nation's Leading Killer at a Glance. 2011. Available at www.cdc.gov/chronicdisease/resources/publications/AAG/osh.htm.
3 Smoking-attributable mortality, years of potential life lost, and productivity losses--United States, 2000-2004. MMWR Morb Mortal Wkly Rep. Nov. 14. 2008;57(45):1226-8. [pmid: 19008791].
4 World Health Organization. Global health risks: mortality and burden of disease attributable to selected major risks. Geneval, Switzerland. World Health Organization. 2009. Available at www.who.int/healthinfo/global_burden_disease/GlobalHealthRisks_report_full.pdf.
5 Mucha L, Stephenson J, Morandi N, et al. Meta-analysis of disease risk associated with smoking, by gender and intensity of smoking. Gend Med. Dec. 2006;3(4):279-91. [pmid: 17582369].
6 Tan YY, Gast GC, van der Schouw YT. Gender differences in risk factors for coronary heart disease. Maturitas. Feb. 2010;65(2):149-60. [pmid: 19897327].
7 Mendelsohn C. Women who smoke - A review of the evidence. Aust Fam Physician. Jun. 2011;40(6):403-7. [pmid: 21655488].
8 American Lung Association. Women and tobacco use. Available at http://www.lung.org/stop-smoking/about-smoking/facts-figures/women-and-tobacco-use.html. November 29, 2012.
9 Boyd NR, Windsor RA, Perkins LL, et al. Quality of measurement of smoking status by self-report and saliva cotinine among pregnant women. Matern Child Health J. Jun. 1998;2(2):77-83. [pmid: 10728263].
10 Dietz PM, Homa D, England LJ, et al. Estimates of nondisclosure of cigarette smoking among pregnant and nonpregnant women of reproductive age in the United States. Am J Epidemiol. Feb. 1. 2011;173(3):355-9. [pmid: 21178103].
11 Kendrick JS, Zahniser SC, Miller N, et al. Integrating smoking cessation into routine public prenatal care: the Smoking Cessation in Pregnancy project. Am J Public Health. Feb. 1995;85(2):217-22. [pmid: 7856781].
12 Centers for Disease Control and Prevention. Preventing Smoking and Exposure to Secondhand Smoke Before, During, and After Pregnancy. July. 2007. Available at www.cdc.gov/nccdphp/publications/factsheets/prevention/pdf/smoking.pdf.
13 Aliyu MH, Lynch O, Wilson RE, et al. Association between tobacco use in pregnancy and placenta-associated syndromes: a population-based study. Arch Gynecol Obstet. Apr. 2011;283(4):729-34. [pmid: 20354707].
14 Ananth CV, Savitz DA, Luther ER. Maternal cigarette smoking as a risk factor for placental abruption, placenta previa, and uterine bleeding in pregnancy. Am J Epidemiol. Nov. 1. 1996;144(9):881-9. [pmid: 8890666].
15 Andres RL, Day MC. Perinatal complications associated with maternal tobacco use. Semin Neonatol. Aug. 2000;5(3):231-41. [pmid: 10956448].
16 Vardavas CI, Chatzi L, Patelarou E, et al. Smoking and smoking cessation during early pregnancy and its effect on adverse pregnancy outcomes and fetal growth. Eur J Pediatr. Jun. 2010;169(6):741-8. [pmid: 19953266].
17 Centers for Disease Control and Prevention. Women and smoking: a report of the Surgeon General. Executive summary. MMWR Recomm Rep. Aug. 30. 2002;51(RR-12):1-13. [pmid: 12222832].
18 Aliyu MH, Salihu HM, Wilson RE, et al. Prenatal smoking and risk of intrapartum stillbirth. Arch Environ Occup Health. Summer. 2007;62(2):87-92. [pmid: 18316266].
19 Cogswell ME, Weisberg P, Spong C. Cigarette smoking, alcohol use and adverse pregnancy outcomes: implications for micronutrient supplementation. J Nutr. May. 2003;133(5 Suppl 2):1722S-31S. [pmid: 12730490].
20 Lambers DS, Clark KE. The maternal and fetal physiologic effects of nicotine. Semin Perinatol. Apr. 1996;20(2):115-26. [pmid: 8857697].
21 Polakowski LL, Akinbami LJ, Mendola P. Prenatal smoking cessation and the risk of delivering preterm and small-for-gestational-age newborns. Obstet Gynecol. Aug. 2009;114(2 Pt 1):318-25. [pmid: 19622993].
22 Salihu HM, Aliyu MH, Kirby RS. In utero nicotine exposure and fetal growth inhibition among twins. Am J Perinatol. Nov. 2005;22(8):421-7. [pmid: 16283601].
23 Salihu HM, Aliyu MH, Pierre-Louis BJ, et al. Levels of excess infant deaths attributable to maternal smoking during pregnancy in the United States. Matern Child Health J. Dec. 2003;7(4):219-27. [pmid: 14682499].
24 Coleman-Cowger VH. Smoking cessation intervention for pregnant women: a call for extension to the postpartum period. Matern Child Health J. Jul. 2012;16(5):937-40. [pmid: 21710186].
25 McDonnell-Naughton M, McGarvey C, O'Regan M, et al. Maternal smoking and alcohol consumption during pregnancy as risk factors for sudden infant death. Ir Med J. Apr. 2012;105(4):105-8. [pmid: 22708221].
26 Schoendorf KC, Kiely JL. Relationship of sudden infant death syndrome to maternal smoking during and after pregnancy. Pediatrics. Dec. 1992;90(6):905-8. [pmid: 1437432].
27 Metzger MJ, Halperin AC, Manhart LE, et al. Association of maternal smoking during pregnancy with infant hospitalization and mortality due to infectious diseases. Pediatr Infect Dis J. Jan. 2013;32(1):e1-7. [pmid: 22929173].
28 DiFranza JR, Aligne CA, Weitzman M. Prenatal and postnatal environmental tobacco smoke exposure and children's health. Pediatrics. Apr. 2004;113(4 Suppl):1007-15. [pmid: 15060193].
29 Duijts L, Jaddoe VW, Hofman A, et al. Maternal smoking in prenatal and early postnatal life and the risk of respiratory tract infections in infancy. The Generation R study. Eur J Epidemiol. 2008;23(8):547-55. [pmid: 18553141].
30 Jaakkola JJ, Kosheleva AA, Katsnelson BA, et al. Prenatal and postnatal tobacco smoke exposure and respiratory health in Russian children. Respir Res. Mar. 28. 2006;7:48. [pmid: 16569224].
31 Taylor B, Wadsworth J. Maternal smoking during pregnancy and lower respiratory tract illness in early life. Arch Dis Child. Aug. 1987;62(8):786-91. [pmid: 3662581].
32 The Health Consequences of Involuntary Exposure to Tobacco Smoke: A Report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services. 2006. Available at www.surgeongeneral.gov/library/reports/secondhandsmoke/index.html.
33 Jones LL, Hashim A, McKeever T, et al. Parental and household smoking and the increased risk of bronchitis, bronchiolitis and other lower respiratory infections in infancy: systematic review and meta-analysis. Respir Res. Jan. 10. 2011;12:5. [pmid: 21219618].
34 Oberg M, Jaakkola MS, Woodward A, et al. Worldwide burden of disease from exposure to second-hand smoke: a retrospective analysis of data from 192 countries. Lancet. Jan. 8. 2011;377(9760):139-46. [pmid: 21112082].
35 Gergen PJ, Fowler JA, Maurer KR, et al. The burden of environmental tobacco smoke exposure on the respiratory health of children 2 months through 5 years of age in the United States: Third National Health and Nutrition Examination Survey, 1988 to 1994. Pediatrics. Feb. 1998;101(2):E8. [pmid: 9445518].
36 Stevens KR, Munoz LR. Cigarette smoking: Evidence to guide measurement. Res Nurs Health. Aug. 2004;27(4):281-92. [pmid: 15264266].
37 Gilligan C, Sanson-Fisher R, Eades S, et al. Assessing the accuracy of self-reported smoking status and impact of passive smoke exposure among pregnant Aboriginal and Torres Strait Islander women using cotinine biochemical validation. Drug Alcohol Rev. Jan. 2010;29(1):35-40. [pmid: 20078680].
38 Windsor RA, Woodby LL, Miller TM, et al. Effectiveness of Agency for Health Care Policy and Research clinical practice guideline and patient education methods for pregnant smokers in medicaid maternity care. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):68-75. [pmid: 10649158].
39 Windsor RA, Lowe JB, Perkins LL, et al. Health education for pregnant smokers: its behavioral impact and cost benefit. Am J Public Health. Feb. 1993;83(2):201-6. [pmid: 8427323].
40 Cope GF, Nayyar P, Holder R. Measurement of nicotine intake in pregnant women--associations to changes in blood cell count. Nicotine Tob Res. May. 2001;3(2):119-22. [pmid: 11403725].
41 Curry LE, Richardson A, Xiao H, et al. Nondisclosure of smoking status to health care providers among current and former smokers in the United States. Health Educ Behav. Jun. 2013;40(3):266-73. [pmid: 22984217].
42 Society for Research on Nicotine and Tobacco (SRNT) Subcommittee. Biochemical verification of tobacco use and cessation. Nicotine Tob Res. May. 2002;4(2):149-59. [pmid: 12028847].
43 Chantix (varencicline). [package insert]. New York, NY. Pfizer Labs. 2006.
44 Zyban (bupropion hydrochloride). [package insert]. Greenville, NC. GlaxoSmithKline. 2012.
45 NicoDerm CQ (nicotine patch). [package insert]. Bridgewater NJ. Sanofi Aventis US. 2012.
46 Nicorette (nicotine gum). [package insert]. GlaxoSmithKline. Moon Township, PA. 2012. Available at.
47 Nicotine polacrilex lozenge. [package insert]. Moon Township, PA. GlaxoSmithKline. 2013.
48 American College of Obstetricians and Gynecologists. Smoking Cessation During Pregnancy: A Clinicians Guide to Helping Pregnant Women Quit Smoking. 2011. Available at http://www.acog.org/About_ACOG/News_Room/∼/media/Departments/Tobacco%20Alcohol%20and%20Substance%20Abuse/SCDP.pdf.
49 Committee opinion no. 471: Smoking cessation during pregnancy. Obstet Gynecol. Nov. 2010;116(5):1241-4. [pmid: 20966731].
50 Levitt C, Shaw E, Wong S, et al. Systematic review of the literature on postpartum care: effectiveness of interventions for smoking relapse prevention, cessation, and reduction in postpartum women. Birth. Dec. 2007;34(4):341-7. [pmid: 18021150].
51 Coleman T, Chamberlain C, Davey MA, et al. Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. Sep. 2012;12:9-CD010078. [pmid: 22972148].
52 Myung SK, Ju W, Jung HS, et al. Efficacy and safety of pharmacotherapy for smoking cessation among pregnant smokers: a meta-analysis. BJOG. Aug. 2012;119(9):1029-39. [pmid: 22780818].
53 Lumley J, Chamberlain C, Dowswell T, et al. Interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. Jul. 8. 2009;(3):CD001055. [pmid: 19588322].
54 Greaves L, Poole N, Hemsing N, et al. Expecting to quit: a best practices review of smoking cessation interventions for pregnant and postpartum girls and women. 2nd ed. Vancouver, BC. British Columbia Centre of Excellence for Women's Health. 2011. Available at http://www.hc-sc.gc.ca/hc-ps/pubs/tobac-tabac/expecting-grossesse/index-eng.php.
55 Allen AM, Prince CB, Dietz PM. Postpartum depressive symptoms and smoking relapse. Am J Prev Med. Jan. 2009;36(1):9-12. [pmid: 19095161].
56 Burns L, Mattick RP, Wallace C. Smoking patterns and outcomes in a population of pregnant women with other substance use disorders. Nicotine Tob Res. Jun. 2008;10(6):969-74. [pmid: 18584460].
57 Giglia RC, Binns CW, Alfonso HS. Which women stop smoking during pregnancy and the effect on breastfeeding duration. BMC Public Health. Jul. 26. 2006;6:195. [pmid: 16869976].
58 Holtrop JS, Meghea C, Raffo JE, et al. Smoking among pregnant women with Medicaid insurance: are mental health factors related?. Matern Child Health J. Nov. 2010;14(6):971-7. [pmid: 19838777].
59 Kendzor DE, Businelle MS, Costello TJ, et al. Breast feeding is associated with postpartum smoking abstinence among women who quit smoking due to pregnancy. Nicotine Tob Res. Oct. 2010;12(10):983-8. [pmid: 20713441].
60 Ma Y, Goins KV, Pbert L, et al. Predictors of smoking cessation in pregnancy and maintenance postpartum in low-income women. Matern Child Health J. Dec. 2005;9(4):393-402. [pmid: 16220356].
61 Madan AK, Barden CB, Beech B, et al. Multivariate analysis of factors associated with smoking cessation in women. J La State Med Soc. Mar-Apr. 2005;157(2):112-5. [pmid: 16022278].
62 Massey SH, Lieberman DZ, Reiss D, et al. Association of clinical characteristics and cessation of tobacco, alcohol, and illicit drug use during pregnancy. Am J Addict. Mar-Apr. 2011;20(2):143-50. [pmid: 21314757].
63 McBride CM, Curry SJ, Grothaus LC, et al. Partner smoking status and pregnant smoker's perceptions of support for and likelihood of smoking cessation. Health Psychol. Jan. 1998;17(1):63-9. [pmid: 9459072].
64 Ockene J, Ma Y, Zapka J, et al. Spontaneous cessation of smoking and alcohol use among low-income pregnant women. Am J Prev Med. Oct. 2002;23(3):150-9. [pmid: 12350446].
65 Sherwood NE, Hennrikus DJ, Jeffery RW, et al. Smokers with multiple behavioral risk factors: how are they different?. Prev Med. Oct. 2000;31(4):299-307. [pmid: 11006054].
66 Thyrian JR, Freyer-Adam J, Hannover W, et al. Population-based smoking cessation in women post partum: adherence to motivational interviewing in relation to client characteristics and behavioural outcomes. Midwifery. Apr. 2010;26(2):202-10. [pmid: 18653261].
67 Yu SM, Park CH, Schwalberg RH. Factors associated with smoking cessation among U.S. pregnant women. Matern Child Health J. Jun. 2002;6(2):89-97. [pmid: 12092985].
68 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. Available at www.effectivehealthcare.ahrq.gov.
69 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. J Clin Epidemiol. Oct. 2009;62(10):e1-34. [pmid: 19631507].
70 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
71 Higgins J, Altman D, Sterne J. Cochrane handbook for systematic reviews of interventions. Higgins J, Green S, editors. Version 5.1.0. West Sussex, England. The Cochrane Collaboration. 2011. Available at www.cochrane.org/training/cochrane-handbook.
72 Wells G, Shea B, O'Connell D, et al. Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa, Canada. Ottawa Hospital Research Institute. 2011. Available at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
73 Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
74 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No.10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. Available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
75 Lawrence T, Aveyard P, Croghan E. What happens to women's self-reported cigarette consumption and urinary cotinine levels in pregnancy?. Addiction. Sep. 2003;98(9):1315-20. [pmid: 12930219].
76 Brooks S. Handbook of Markov chain Monte Carlo. Boca Raton. CRC Press/Taylor & Francis. 2011. Available at.
77 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
78 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
79 Suplee PD. The importance of providing smoking relapse counseling during the postpartum hospitalization. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2005;34(6):703-12. [pmid: 16282228].
80 Phillips RM, Merritt TA, Goldstein MR, et al. Prevention of postpartum smoking relapse in mothers of infants in the neonatal intensive care unit. J Perinatol. May. 2012;32(5):374-80. [pmid: 21836549].
81 Jimenez-Muro A, Nerin I, Samper P, et al. A proactive smoking cessation intervention in postpartum women. Midwifery. 2012. Feb. 21. [pmid: 22361008].
82 Johnson JL, Ratner PA, Bottorff JL, et al. Preventing smoking relapse in postpartum women. Nurs Res. Jan-Feb. 2000;49(1):44-52. [pmid: 10667628].
83 Stotts AL, Groff JY, Velasquez MM, et al. Ultrasound feedback and motivational interviewing targeting smoking cessation in the second and third trimesters of pregnancy. Nicotine Tob Res. Aug. 2009;11(8):961-8. [pmid: 19553282].
84 Heil SH, Higgins ST, Bernstein IM, et al. Effects of voucher-based incentives on abstinence from cigarette smoking and fetal growth among pregnant women. Addiction. Jun. 2008;103(6):1009-18. [pmid: 18482424].
85 Albrecht SA, Caruthers D, Patrick T, et al. A randomized controlled trial of a smoking cessation intervention for pregnant adolescents. Nurs Res. Nov-Dec. 2006;55(6):402-10. [pmid: 17133147].
86 Dornelas EA, Magnavita J, Beazoglou T, et al. Efficacy and cost-effectiveness of a clinic-based counseling intervention tested in an ethnically diverse sample of pregnant smokers. Patient Educ Couns. Dec. 2006;64(1-3):342-9. [pmid: 16859864].
87 Rigotti NA, Park ER, Regan S, et al. Efficacy of telephone counseling for pregnant smokers: a randomized controlled trial. Obstet Gynecol. Jul. 2006;108(1):83-92. [pmid: 16816060].
88 Hajek P, West R, Lee A, et al. Randomized controlled trial of a midwife-delivered brief smoking cessation intervention in pregnancy. Addiction. Mar. 2001;96(3):485-94. [pmid: 11255587].
89 Ershoff DH, Quinn VP, Boyd NR, et al. The Kaiser Permanente prenatal smoking-cessation trial: when more isn't better, what is enough?. Am J Prev Med. Oct. 1999;17(3):161-8. [pmid: 10987630].
90 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Reducing smoking during pregnancy and postpartum: physician's advice supported by individual counseling. Prev Med. May-Jun. 1998;27(3):422-30. [pmid: 9612832].
91 Gielen AC, Windsor R, Faden RR, et al. Evaluation of a smoking cessation intervention for pregnant women in an urban prenatal clinic. Health Educ Res. Jun. 1997;12(2):247-54. [pmid: 10168576].
92 Hartmann KE, Thorp JM Jr., Pahel-Short L, et al. A randomized controlled trial of smoking cessation intervention in pregnancy in an academic clinic. Obstet Gynecol. Apr. 1996;87(4):621-6. [pmid: 8602320].
93 Windsor RA, Cutter G, Morris J, et al. The effectiveness of smoking cessation methods for smokers in public health maternity clinics: a randomized trial. Am J Public Health. Dec. 1985;75(12):1389-92. [pmid: 4061709].
94 Ershoff DH, Quinn VP, Mullen PD. Relapse prevention among women who stop smoking early in pregnancy: a randomized clinical trial of a self-help intervention. Am J Prev Med. May-Jun. 1995;11(3):178-84. [pmid: 7662397].
95 Gadomski A, Adams L, Tallman N, et al. Effectiveness of a combined prenatal and postpartum smoking cessation program. Matern Child Health J. Feb. 2011;15(2):188-97. [pmid: 20091107].
96 Wisborg K, Henriksen TB, Secher NJ. A prospective intervention study of stopping smoking in pregnancy in a routine antenatal care setting. Br J Obstet Gynaecol. Nov. 1998;105(11):1171-6. [pmid: 9853765].
97 Ondersma SJ, Svikis DS, Lam PK, et al. A randomized trial of computer-delivered brief intervention and low-intensity contingency management for smoking during pregnancy. Nicotine Tob Res. Mar. 2012;14(3):351-60. [pmid: 22157229].
98 Windsor R, Woodby L, Miller T, et al. Effectiveness of Smoking Cessation and Reduction in Pregnancy Treatment (SCRIPT) methods in Medicaid-supported prenatal care: Trial III. Health Educ Behav. Aug. 2011;38(4):412-22. [pmid: 21551424].
99 Reitzel LR, Vidrine JI, Businelle MS, et al. Preventing postpartum smoking relapse among diverse low-income women: a randomized clinical trial. Nicotine Tob Res. Apr. 2010;12(4):326-35. [pmid: 20154055].
100 Cinciripini PM, Blalock JA, Minnix JA, et al. Effects of an intensive depression-focused intervention for smoking cessation in pregnancy. J Consult Clin Psychol. Feb. 2010;78(1):44-54. [pmid: 20099949].
101 Hennrikus D, Pirie P, Hellerstedt W, et al. Increasing support for smoking cessation during pregnancy and postpartum: results of a randomized controlled pilot study. Prev Med. Mar. 2010;50(3):134-7. [pmid: 20079760].
102 Oncken C, Dornelas E, Greene J, et al. Nicotine gum for pregnant smokers: a randomized controlled trial. Obstet Gynecol. Oct. 2008;112(4):859-67. [pmid: 18827129].
103 Bullock L, Everett KD, Mullen PD, et al. Baby BEEP: A randomized controlled trial of nurses' individualized social support for poor rural pregnant smokers. Matern Child Health J. May. 2009;13(3):395-406. [pmid: 18496746].
104 Pollak KI, Oncken CA, Lipkus IM, et al. Nicotine replacement and behavioral therapy for smoking cessation in pregnancy. Am J Prev Med. Oct. 2007;33(4):297-305. [pmid: 17888856].
105 Ruger JP, Weinstein MC, Hammond SK, et al. Cost-effectiveness of motivational interviewing for smoking cessation and relapse prevention among low-income pregnant women: a randomized controlled trial. Value Health. Mar-Apr. 2008;11(2):191-8. [pmid: 17854434].
106 Pbert L, Ockene JK, Zapka J, et al. A community health center smoking-cessation intervention for pregnant and postpartum women. Am J Prev Med. Jun. 2004;26(5):377-85. [pmid: 15165653].
107 Malchodi CS, Oncken C, Dornelas EA, et al. The effects of peer counseling on smoking cessation and reduction. Obstet Gynecol. Mar. 2003;101(3):504-10. [pmid: 12636954].
108 Stotts AL, Diclemente CC, Dolan-Mullen P. One-to-one: a motivational intervention for resistant pregnant smokers. Addict Behav. Mar-Apr. 2002;27(2):275-92. [pmid: 11817768].
109 Solomon LJ, Secker-Walker RH, Flynn BS, et al. Proactive telephone peer support to help pregnant women stop smoking. Tob Control. Suppl 3. 2000;9:III72-4. [pmid: 10982914].
110 Donatelle RJ, Prows SL, Champeau D, et al. Randomised controlled trial using social support and financial incentives for high risk pregnant smokers: significant other supporter (SOS) program. Tob Control. Suppl 3. 2000;9:III67-9. [pmid: 10982912].
111 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Smoking relapse prevention during pregnancy. A trial of coordinated advice from physicians and individual counseling. Am J Prev Med. Jul. 1998;15(1):25-31. [pmid: 9651635].
112 Lowe JB, Windsor R, Balanda KP, et al. Smoking relapse prevention methods for pregnant women: a formative evaluation. Am J Health Promot. Mar-Apr. 1997;11(4):244-6. [pmid: 10165516].
113 Secker-Walker RH, Solomon LJ, Geller BM, et al. Modeling smoking cessation: exploring the use of a videotape to help pregnant women quit smoking. Women Health. 1997;25(1):23-35. [pmid: 9253136].
114 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Smoking relapse prevention counseling during prenatal and early postnatal care. Am J Prev Med. Mar-Apr. 1995;11(2):86-93. [pmid: 7632455].
115 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Individualized smoking cessation counseling during prenatal and early postnatal care. Am J Obstet Gynecol. Nov. 1994;171(5):1347-55. [pmid: 7977545].
116 Price JH, Krol RA, Desmond SM, et al. Comparison of three antismoking interventions among pregnant women in an urban setting: a randomized trial. Psychol Rep. Apr. 1991;68(2):595-604. [pmid: 1862191].
117 Ershoff DH, Mullen PD, Quinn VP. A randomized trial of a serialized self-help smoking cessation program for pregnant women in an HMO. Am J Public Health. Feb. 1989;79(2):182-7. [pmid: 2913837].
118 Bauman KE, Bryan ES, Dent CW, et al. The influence of observing carbon monoxide level on cigarette smoking by public prenatal patients. Am J Public Health. Sep. 1983;73(9):1089-91. [pmid: 6881407].
119 Burling TA, Bigelow GE, Robinson JC, et al. Smoking during pregnancy: Reduction via objective assessment and directive advice. Behavior Therapy. 1991;22(1):31-40.
120 El-Mohandes AA, Windsor R, Tan S, et al. A Randomized Clinical Trial of Trans-Dermal Nicotine Replacement in Pregnant African-American Smokers. Matern Child Health J. 2012. Jul. 4. [pmid: 22761006].
121 Tuten M, Fitzsimons H, Chisolm MS, et al. Contingent incentives reduce cigarette smoking among pregnant, methadone-maintained women: Results of an initial feasibility and efficacy randomized clinical trial. Addiction. 2012;107(10):1868-77. [pmid: 22716774].
122 Coleman T, Cooper S, Thornton JG, et al. A randomized trial of nicotine-replacement therapy patches in pregnancy. N Engl J Med. Mar. 1. 2012;366(9):808-18. [pmid: 22375972].
123 Naughton F, Prevost AT, Gilbert H, et al. Randomized controlled trial evaluation of a tailored leaflet and SMS text message self-help intervention for pregnant smokers (MiQuit). Nicotine Tob Res. May. 2012;14(5):569-77. [pmid: 22311960].
124 Cope GF, Nayyar P, Holder R. Feedback from a point-of-care test for nicotine intake to reduce smoking during pregnancy. Ann Clin Biochem. Nov. 2003;40(Pt 6):674-9. [pmid: 14629807].
125 Lawrence T, Aveyard P, Evans O, et al. A cluster randomised controlled trial of smoking cessation in pregnant women comparing interventions based on the transtheoretical (stages of change) model to standard care. Tob Control. Jun. 2003;12(2):168-77. [pmid: 12773727].
126 Moore L, Campbell R, Whelan A, et al. Self help smoking cessation in pregnancy: cluster randomised controlled trial. BMJ. Dec. 14. 2002;325(7377):1383. [pmid: 12480850].
127 Eades SJ, Sanson-Fisher RW, Wenitong M, et al. An intensive smoking intervention for pregnant Aboriginal and Torres Strait Islander women: a randomised controlled trial. Med J Aust. Jul. 2. 2012;197(1):42-6. [pmid: 22762231].
128 Hotham ED, Gilbert AL, Atkinson ER. A randomised-controlled pilot study using nicotine patches with pregnant women. Addict Behav. Apr. 2006;31(4):641-8. [pmid: 15985339].
129 Panjari M, Bell R, Bishop S, et al. A randomized controlled trial of a smoking cessation intervention during pregnancy. Aust N Z J Obstet Gynaecol. Aug. 1999;39(3):312-7. [pmid: 10554941].
130 Walsh RA, Redman S, Brinsmead MW, et al. A smoking cessation program at a public antenatal clinic. Am J Public Health. Jul. 1997;87(7):1201-4. [pmid: 9240113].
131 O'Connor AM, Davies BL, Dulberg CS, et al. Effectiveness of a pregnancy smoking cessation program. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 1992;21(5):385-92. [pmid: 1403224].
132 Tappin DM, Lumsden MA, Gilmour WH, et al. Randomised controlled trial of home based motivational interviewing by midwives to help pregnant smokers quit or cut down. BMJ. Aug. 13. 2005;331(7513):373-7. [pmid: 16096304].
133 Hegaard HK, Kjaergaard H, Moller LF, et al. Multimodal intervention raises smoking cessation rate during pregnancy. Acta Obstet Gynecol Scand. Sep. 2003;82(9):813-9. [pmid: 12911442].
134 Hjalmarson AI, Hahn L, Svanberg B. Stopping smoking in pregnancy: effect of a self-help manual in controlled trial. Br J Obstet Gynaecol. Mar. 1991;98(3):260-4. [pmid: 2021564].
135 Miller WR, Rollnick S. Ten things that motivational interviewing is not. Behav Cogn Psychother. Mar. 2009;37(2):129-40. [pmid: 19364414].
136 Ratner PA, Johnson JL, Bottorff JL, et al. Twelve-month follow-up of a smoking relapse prevention intervention for postpartum women. Addict Behav. Jan-Feb. 2000;25(1):81-92. [pmid: 10708321].
137 Aveyard P, Lawrence T, Croghan E, et al. Is advice to stop smoking from a midwife stressful for pregnant women who smoke? Data from a randomized controlled trial. Prev Med. May. 2005;40(5):575-82. [pmid: 15749141].
138 Lawrence T, Aveyard P, Cheng KK, et al. Does stage-based smoking cessation advice in pregnancy result in long-term quitters? 18-month postpartum follow-up of a randomized controlled trial. Addiction. Jan. 2005;100(1):107-16. [pmid: 15598198].
139 Ershoff DH, Quinn VP, Mullen PD, et al. Pregnancy and medical cost outcomes of a self-help prenatal smoking cessation program in a HMO. Public Health Rep. Jul-Aug. 1990;105(4):340-7. [pmid: 2116634].
140 Li CQ, Windsor RA, Perkins L, et al. The impact on infant birth weight and gestational age of cotinine-validated smoking reduction during pregnancy. JAMA. Mar. 24-31. 1993;269(12):1519-24. [pmid: 8445814].
141 Higgins ST, Heil SH, Dumeer AM, et al. Smoking status in the initial weeks of quitting as a predictor of smoking-cessation outcomes in pregnant women. Drug Alcohol Depend. Nov. 8. 2006;85(2):138-41. [pmid: 16720082].
142 Albrecht SA, Higgins LW, Lebow H. Knowledge about the deleterious effects of smoking and its relationship to smoking cessation among pregnant adolescents. Adolescence. Winter. 2000;35(140):709-16. [pmid: 11214209].
143 Higgins TM, Higgins ST, Heil SH, et al. Effects of cigarette smoking cessation on breastfeeding duration. Nicotine Tob Res. May. 2010;12(5):483-8. [pmid: 20339141].
144 Albrecht SA, Higgins LW, Stone C. Factors relating to pregnant adolescents' decisions to complete a smoking cessation intervention. J Pediatr Nurs. Oct. 1999;14(5):322-8. [pmid: 10554445].
145 Albrecht SA, Reynolds MD, Salamie D, et al. A comparison of saliva cotinine, carbon monoxide levels, and self-report as indicators of smoking cessation in the pregnant adolescent. Journal of Addictions Nursing. 1999;11(3):93-101.
146 Berg CJ, Park ER, Chang Y, et al. Is concern about post-cessation weight gain a barrier to smoking cessation among pregnant women?. Nicotine Tob Res. Jul. 2008;10(7):1159-63. [pmid: 18629725].
147 Rigotti NA, Park ER, Chang Y, et al. Smoking cessation medication use among pregnant and postpartum smokers. Obstet Gynecol. Feb. 2008;111(2 Pt 1):348-55. [pmid: 18238972].
148 Finkelstein EA, Linnan LA, Tate DF, et al. A pilot study testing the effect of different levels of financial incentives on weight loss among overweight employees. J Occup Environ Med. Sep. 2007;49(9):981-9. [pmid: 17848854].
149 Volpp KG, John LK, Troxel AB, et al. Financial incentive-based approaches for weight loss: a randomized trial. JAMA. Dec. 10. 2008;300(22):2631-7. [pmid: 19066383].
150 Topp L, Day CA, Wand H, et al. A randomised controlled trial of financial incentives to increase hepatitis B vaccination completion among people who inject drugs in Australia. Prev Med. 2013. Apr. 29. [pmid: 23639625].
151 Petry NM, Rash CJ, Byrne S, et al. Financial reinforcers for improving medication adherence: findings from a meta-analysis. Am J Med. Sep. 2012;125(9):888-96. [pmid: 22800876].