# Methods

The methods for this Evidence Report follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”68 The main sections in this chapter reflect the elements of established protocol; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.69

## Review Protocol

We prepared final Key Questions and submitted them to AHRQ for review. We identified Technical Experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP) included individuals with expertise in smoking cessation strategies in pregnant women, lead authors of ongoing reviews of cessation interventions, and maternal-child experts from the federal government. The TEP included 10 members serving as technical or clinical experts. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and Key Questions;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Provide input on the information and domains included in evidence tables.

## Literature Search Strategy

### Search Strategy

We searched MEDLINE^®^, CINAHL^®^, and PsycINFO^®^. Search results were limited to papers published in English. Search strategies used a combination of subject headings (i.e., controlled vocabulary) and keywords. (Appendix A). We also searched the reference lists of included publications and recent systematic reviews related to smoking cessation interventions for pregnant women. Searches were executed between October 2012 and January 2013.

The Scientific Resource Center requested published and/or unpublished information from companies that currently manufacture pharmacologic aids, including nicotine replacement products, for smoking cessation.

### Search Terms

Each search strategy used a combination of subject headings (i.e., controlled vocabulary) and keywords appropriate for each database (Appendix A). The search strategies included terms related to the range of interventions used to promote and maintain smoking cessation during pregnancy and the postpartum period. We excluded undesired publication types (e.g. case reports, letters). We did not restrict to any particular study design to allow capture of all desired study types, including randomized controlled trials (RCTs) to address all Key Questions and prospective cohort studies relevant to Key Questions 3, 4, and 5.

## Inclusion and Exclusion Criteria

The inclusion and exclusion criteria for the review were derived from our understanding of the literature and refinement of the review topic with the Task Order Officer and the topic nominators. We sought studies that evaluated that impact of smoking cessation interventions on smoking cessation in pregnancy (Table 2). Thus, for this review, the population of interest was pregnant or postpartum (i.e., within 6 months of birth) women who currently smoked or who had quit smoking during the index pregnancy with a biochemically validated measure of cessation, as self-reported cessation tends to be overstated. We placed no limits on publication dates but required that studies be published in English. Two team members independently reviewed the titles and abstracts of the non-English-language literature published since 1990 located via the MEDLINE search (Appendix A) and determined that few studies would meet the inclusion criteria. Most non-English-language studies were cross sectional or were not original research.

Table 2 Inclusion and exclusion criteria

Category | Criteria
Study population | Pregnant or postpartum (up to 6 months post-birth at initiation of the intervention) women who smoke or quit smoking during the index pregnancy
Time period | Database inception to present
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - KQs 1–5: RCT; - KQs 3–5: Prospective cohort study; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies targeting women who smoke and meet the population criteria as described above; - Studies that address one or both of the following:; ○ Treatment modality aimed at smoking cessation in a relevant population; ○ Outcomes related to interventions; primary outcomes of interest include smoking cessation, continuous abstinence, smoking relapse, harms of intervention to the mother or fetus, gestational age, NICU admission, birth weight, and preterm birth.; - Studies must include extractable data presented in text or tables (vs. solely in figures) on relevant outcomes

Abbreviations: KQ = Key Question; NICU = neonatal intensive care unit; RCT = randomized controlled trial.

Studies were required to include a minimum of 20 participants with data in each study arm. The team established this minimum sample size to balance the need for smaller studies of specialized populations (e.g., studies in specific ethnic groups) with the need to preserve methodologic rigor.

For Key Questions 1 and 2, we accepted only RCTs. Prospective cohort studies were admitted for Key Questions 3, 4, and 5.

## Study Selection

We developed individual abstract and full-text screening forms for the Key Questions (Appendix B and C). We revised the forms following testing by the team. The forms were adapted for use in the Web-based systematic review product, DistillerSR (Evidence Partners, Ottawa, Canada). We conducted screening in two phases: abstract and full-text screening. Publications were promoted to full-text review when one reviewer indicated that the publication met all inclusion criteria or when the title and abstract did not provide adequate information to make a determination. Two reviewers independently reviewed each publication at the full-text screening phase. Discordant classifications were resolved in team meetings with senior investigators.

## Quality (Risk of Bias) Assessment of Individual Studies

Two senior team members independently assessed risk of bias in the included studies; disagreements were resolved through discussion or adjudication by a senior investigator. We used the Cochrane Risk of Bias Tool70, 71 (Appendix C) to assess methodological quality of RCTs and the Newcastle-Ottawa Assessment Scale72 (Appendix E) to assess quality of nonrandomized studies (i.e., cohort studies). The Newcastle-Ottawa Quality Assessment Scale includes three broad perspectives for assessment of observational studies: selection of study groups, comparability of study groups, and ascertainment of the outcome of interest. The Cochrane Risk of Bias tool includes criteria for judging risk of bias in RCTs for specific elements from five fundamental domains: sequence generation, allocation concealment, blinding, outcome data, and selective reporting (Appendix D).

To account for inherent limitations of the literature and our prespecified criterion for acceptable outcomes (i.e., biochemically validated smoking status), we modified criteria for judging risk of bias in the “selective outcome reporting” domain. Selective outcome reporting refers to the selection of a subset of analyses for publication based on results.73 Risk of bias may be present if study authors fail to report or incompletely report prespecified outcomes.74 In the case of this review, we included studies on the basis of their reporting of validated outcomes rather than on the basis of an intervention that arguably could affect a range of outcomes. Whether other outcomes were also collected and presented was not germane to our analysis. Therefore, we uniformly assessed the risk of bias as “low” for “selective outcome reporting” for all included studies. Studies that used intention-to-treat analyses were generally judged to have a low risk of bias for the “incomplete outcome data” domain. As we do not contact study authors for information, risk of bias for this domain was downgraded for studies that did not clearly report an intention-to-treat analysis or provide an explanation for missing data.

From the final assessment of risk of bias for the individual domains for RCTs, an overall assessment of risk of bias was calculated based on prespecified thresholds. The overall risk of bias assessment was then expressed as one of three final study quality ratings: studies assessed as having a high risk of bias were categorized as “poor” quality studies; studies having a medium risk of bias were categorized as “fair” quality studies; and studies assessed as low risk of bias were categorized as “good” quality studies. The conversion thresholds for “good,” “fair,” and “poor” quality designations are presented in Appendix F. A summary of all component items and overall risk of bias/quality score for each included study is provided in Appendix I.

## Data Extraction

We created uniform evidence tables to extract data and facilitate data synthesis. We collected data related to population characteristics, intervention characteristics, and outcomes. Outcome data that relied exclusively on self-report were not included, given strong existing evidence on variability and relatively low accuracy of self-assessed smoking status among pregnant women.12, 75 The outcome of interest (smoking cessation) had to be confirmed by one or more biochemical measurements (e.g., urinary, salivary, or serum cotinine, expired carbon monoxide, serum thiocyanate). Where possible, we extracted data on possible confounders, including age, parity, and baseline smoking levels. The final evidence tables are provided in Appendix H.

## Data Synthesis

We analyzed the effectiveness data in two ways. First, we divided the studies into categories reflecting broad approaches to cessation intervention and described the studies qualitatively within Key Question 1. The categories were established a priori as accepted approaches to intervening during pregnancy to encourage women to stop smoking.54 During data extraction it became apparent that study interventions were often heterogeneous, consisting of numerous and varied approaches. Studies that purport to evaluate the effects of a single intervention are almost always multicomponent in practice. Furthermore, the control arm (e.g., treatment as usual, control group, placebo) frequently receives some level of care, such as cessation counseling, that is a typical component of a smoking intervention.

As an alternative approach to the analysis of the effectiveness data, we conducted a meta-analysis using data from the good and fair quality RCTs to quantify the relative influence of intervention components across the body of literature. This analysis served in part to answer Key Question 4 and to provide a quantitative basis for assessing strength of evidence (see below), in addition to providing a basis for users of the report to make intervention decisions.

The association of smoking cessation intervention components with quit rates was meta-analyzed using a logistic mixed-effects model, estimated using Markov chain Monte Carlo methods.76The model was used to characterize quit rates across studies and estimate factors associated with intervention efficacy. Thus, we treat y_i_, the number of quitters in some study arm i, as a binomial random variable:

y_i_ ∼ Bin(n_i_, p_i_)

where n_i_ is the number of individuals in the arm and p_i_ the latent quit probability. This probability, in turn, is modeled as a function of several components:

logit(p_i_) = μ_j[i]_ + α × stage_i_ + X_i_ β

Here, μj[i] is a baseline random effect belonging to the study j corresponding to arm I, which accounts for the heterogeneity among studies. This random effect was modeled using a t-distribution, which is more robust than a typical Gaussian random effects. Xi is a matrix of indicators corresponding to each of the intervention factors included in the analysis (Clinic Reinforcement, Feedback, Incentives, Information, Peer Support, Personal Followup, Quit Guide, NRT, Prescription to Quit, and Other) and β is a vector of associated parameters describing their effect on expected quit rate. Finally, α describes the effect of the pregnancy stage at which the intervention is applied, which was divided into four intervals: prenatal; 0 to 3 months postpartum; 3 to 6 months postpartum; and 6 to 12 months postpartum.

This model was coded in PyMC version 3 (https://github.com/pymc-devs/pymc), which implements several MCMC algorithms for fitting Bayesian hierarchical models. All model parameters were assigned non-informative prior distributions, and the model was run for 100,000 iterations using a slice sampler.76 Convergence of the chain was checked through visual inspection of the traces of all parameters, and via the Gelman-Rubin diagnostic. The fit of the model was checked via posterior predictive checks, which compare data simulated from the posterior distribution to the observed data. This exercise showed no substantial lack of fit for any of the studies included in the dataset.

Data for Key Questions 2, 3, and 5 were described qualitatively. Key Question 2 was organized by the infant outcomes being assessed, Key Question 3 was organized by the categories of interventions used in Key Question 1, and Key Question 5 was organized by factors that modify success of the intervention and factors related to probability of cessation.

## Strength of the Body of Evidence

Two senior investigators graded the body of evidence and the final assignment was reviewed with the project team. We achieved alignment through group discussion with careful attention to application of consistent standards across each area item being graded. As indicated in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”68, 77 we assessed strength of evidence as “high,” “moderate,” or “low” based on four major domains: risk of bias (low, medium, high); consistency (inconsistency not present, inconsistency present, unknown or not applicable); directness (direct, indirect); and precision (precise, imprecise) of the evidence. When no studies were available for an outcome or comparison of interest or if the available evidence was weak (i.e. from studies with high risk of bias), we graded the evidence as insufficient. The strength of evidence grades and definitions are presented in Table 3.

Table 3 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

For risk of bias, we started our assessment at “low” because only RCTs were included in the assessment. We reduced the strength of evidence risk of bias to “medium” when the evidence was from a mix of good and fair quality studies. For consistency, we required the majority of studies to report outcomes in the same direction. Precision was assessed based on the confidence bounds. Because we only accepted studies that used biochemically validated outcome measures, all outcomes were considered “direct.”

We assessed the strength of evidence for effectiveness, infant outcomes, and harms of interventions. Because of the heterogeneity of interventions within categories of approaches, we focused our strength of evidence assessment on the components that could be meta-analyzed, and thus contributed quantitative data to our understanding of smoking cessation in pregnancy. We used the standard EPC approach to strength of evidence with the exception that Bayesian confidence bounds do not carry the same interpretation as classical (non-Bayesian) confidence intervals.

If the posterior probabilities based on the Bayesian credible intervals (BCIs) suggested greater than 80 percent likelihood that the true effect was greater than the null, we considered the estimate of the effect to be positive and therefore assessed the strength of the evidence that there was benefit from the intervention.

We required all studies to be good quality to be considered low risk of bias. For consistency, we required that the BCI of the estimate not cross the null. All outcomes were assessed as direct because we stipulated that all smoking cessation outcomes had to be confirmed by biochemical validation. For precision, we considered a difference of less than three between the lower and upper BCI of the estimate to be precise. For effectiveness, we assessed strength of evidence based on the good and fair quality included studies because there were enough of these studies to form a “best evidence” set that would not be obscured by biased and poorly conducted studies. To support this decision, we assessed the likelihood that inclusion of the poor quality studies would change the strength of evidence determination.

For infant outcomes (KQ2) and harms of interventions (KQ3) we included poor-quality studies in the strength-of-evidence assessment. These Key Questions warrant a more expansive assessment of the literature because they focus on outcomes that are rarely reported.

## Applicability

We assessed applicability of results according to EPC methods guidance78 by describing elements of the literature that would affect end users' ability to apply our findings in a real-world setting. We used the PICOTS (population, intervention, comparator(s), outcome, timing, and setting) framework to identify the factors likely to affect the generalizability of the synthesized results.

For this particular review, the most likely factors to affect applicability are the patient population (e.g. whether or not results are available to assess the utility of given interventions in target populations) and the intervention (e.g., the difficulty of applying the intervention in a nonresearch setting given available resources). We summarized the applicability of the body of evidence by noting where data were available for specific populations and making relative assessments of applicability for intervention components in the context of resource considerations.

## Peer Review and Public Commentary

Experts in smoking cessation and care of pregnant and postpartum women were invited to provide external peer review. The draft report was posted for 4 weeks to elicit public comment. We addressed all reviewer comments by revising the text as appropriate. Responses to peer and public review comments are itemized in a “Disposition of Comments” report, which will be available on the AHRQ Web site approximately 3 months after the posting of this final review.