# Introduction

## Background

Nearly 443,000 U.S. deaths are attributable annually to cigarette smoking, which makes tobacco, including secondhand smoke, the most preventable cause of disease, disability, and death in the United States.1, 2 Smoking is also associated with staggering estimates of 5.1 million years of potential life lost and $96.8 billion in lost productivity per year in the United States alone.3 Globally, smoking-related deaths are estimated to exceed 8 million by 2030.^4^ Smoking is linked to cancer, heart disease, lung disease, and stroke1 and places women at greater overall risk for disease than men.5, 6 Smoking also raises a woman's risk for breast, cervical, and ovarian cancer; infertility; and early menopause.7 Leading causes of smoking-related deaths among women are lung cancer, heart disease, and chronic lung disease.2

An estimated 19.8 million women in the United States smoke.8 Nationally, 23 percent of women report smoking in the 3 months before pregnancy, while 13 percent report smoking in the last 3 months of pregnancy. Rates vary significantly by state, with up to 30 percent of women in some states reporting continued tobacco use in the third trimester. Fewer than half of pregnant smokers report successfully quitting during pregnancy.1 Furthermore, self-report leads to an overestimation of cessation rates in pregnancy.9 Nondisclosure of smoking status among pregnant smokers is common and ranges from 25^10^ to 49 percent11 in published reports.

Compared with nonsmokers, those who smoked around the time of their pregnancy were more likely to be younger (<25 years old), be non-Hispanic white, have 12 or fewer years of education, be unmarried, have an annual income of less than $15,000, be underweight, have an unintended pregnancy, be first-time mothers, initiate prenatal care later, be Medicaid-enrolled, and receive WIC during pregnancy.12 These national data are compatible with similar reports from states, health systems, and from smoking intervention studies.

### Adverse Outcomes Associated With Smoking During Pregnancy

Smoking during pregnancy can result in significant complications for the pregnant woman, her fetus, and members of the woman's household who are exposed to secondhand smoke. Smoking is associated with increased risk of placental abruption, anemia, preterm birth, chronic hypertension, and placenta previa.13-16 Health risks to the fetus include low birth weight, restricted growth, and fetal death.15, 17-23

Maternal smoking also remains a significant issue of concern after birth; estimates from the research literature indicate that 60 to 80 percent of women who quit smoking during pregnancy resume tobacco use in the first six to 12 months postpartum.24 Infants and children of women who smoke during pregnancy face a higher risk of sudden infant death syndrome25, 26 and other conditions including respiratory infections, impaired lung growth, otitis media, necrotizing enterocolitis, and infectious diseases.27-31 Infants and children are also affected by secondhand or environmental tobacco smoke, including significant nicotine exposure via breast milk among breastfed children. The 2006 U.S. Surgeon General's report, Health Consequences of Involuntary Exposure to Tobacco Smoke, noted that exposed children are at increased risk for sudden infant death syndrome, acute respiratory infections, otitis media, and more severe asthma.32 Passive smoke exposure has also been associated with bronchiolitis and bronchitis.33, 34 Recent global estimates suggest that 165,000 children under age 5 die annually from lower respiratory infection caused by exposure to secondhand smoke.35

### Measurement of Tobacco Exposure During Pregnancy

Measurement of smoking status is commonly assessed through self-report and can be confirmed using biological markers. Pregnant women are more likely to underreport their smoking status than nonpregnant women10 likely due to the stigmatization of smoking during pregnancy.36 Multiple studies of representative samples of pregnant women using biochemical measurements have confirmed high levels of patient non-disclosure.9, 11, 37-41 Therefore it is important to use biochemical validation of smoking status rather than relying solely on self-report.

Biochemical validation of smoking includes measures of cotinine from saliva, urine or serum, thiocyanate, or expired carbon monoxide. Although these measures do not verify continuous abstinence they are accepted standards for evaluating point prevalence smoking status. Cotinine, the major proximate metabolite of nicotine, is the most useful and popular marker. It has a half-life of 15 to 40 hours, and measured cotinine levels in the body correlate with the quantity of nicotine absorbed.36 Cotinine can be measured in serum, but saliva and urine sample collection is easier and less invasive. Cotinine is measured in nanograms per milliliter (ng/ml). The cut point for smoking status depends upon the type of sample (plasma or saliva: 15 ng/ml; urine: 50 ng/ml).42 Thiocyanate, a metabolite of hydrogen cyanide gas, can be measured in blood, urine, and saliva. It has a half-life of 10 to 14 days but has low sensitivity and specificity making it less useful.36 Cotinine and thiocyanate cannot be used in studies of NRT. Expired carbon monoxide can be assessed using a handheld breath analyzer and is reported in parts per million (ppm). Carbon monoxide has a short half-life of 4 to 5 hours. The cut point for smoking status is generally between 8 to 10 ppm,42 however, environmental sources can produce levels comparable to those of current smokers.36

### Interventions

Multiple interventions to promote smoking cessation exist and include advice and counseling, self-help materials, nicotine replacement therapy (NRT), antidepressants including bupropion (Zyban^®^), and pharmacologic cessation aids such as varenicline (Chantix^®^). While these pharmacologic aids may limit the exposure of tobacco smoke, little is known about the potential adverse effects on short- and long-term reproductive outcomes. The U.S. Food and Drug Administration (FDA) places the transdermal nicotine patch in pregnancy category D, which indicates there are known risks to the fetus, but potential benefits may outweigh risks in some cases. The other nicotine replacement products, as well as varenicline and bupropion are category C medications, meaning animal studies have shown adverse fetal effects and no adequate human studies are available, but potential benefit may outweigh risk.43-47 The American College of Obstetricians and Gynecologists does not recommend pharmacologic interventions as first-line therapies in pregnant women due to lack of evidence on safety and efficacy.48, 49

Previous systematic reviews have typically reported limited effectiveness for most interventions in pregnant smokers, though some have reported positive results. Overall, the findings from existing systematic reviews50-54 suggest that NRT, behavioral and educational cessation strategies, and multicomponent interventions may be beneficial to women who smoke in pregnancy or the postpartum period. Despite these previous systematic review efforts, however, the efficacy of specific components and the impact of these various strategies on smoking and infant outcomes in pregnant and postpartum women remain unclear.

Other research has also shown that characteristics of women most likely to quit before or during pregnancy and to sustain cessation postpartum differ in important and predictable ways from those who do not attempt cessation or who relapse at various points.55-67 Factors that can potentially predict successful smoking cessation include level of nicotine dependence, number and duration of prior quit attempts, concomitant substance or alcohol use, partner smoking status, and employment and timing of return to work. Previous reviews have not adequately characterized how such factors may modify the effects of interventions on cessation, birth weight, gestational age, and longer term outcomes such as childhood asthma exacerbations. Better understanding of these potential effect modifiers is key to optimal implementation of cessation strategies in pregnant and postpartum populations.

## Scope and Key Questions

This review evaluates the effectiveness of interventions intended to achieve smoking cessation during pregnancy and the postpartum period. The current review stems from an interest in better understanding how cessation interventions may affect critical outcomes. The added value of this review is that it updates the evidence from prior systematic reviews, includes child outcomes, and identifies patient and intervention characteristics that modify the effects of interventions.

### Scope of the Review

This review is focused on the evidence available to inform health care providers regarding the provision of smoking cessation strategies for their patients. The relevant population for this review includes pregnant and postpartum woman who are current smokers or recent quitters. The literature reflects various strategies to promote smoking cessation and relapse prevention. Interventions of interest include any behavioral, psychosocial, pharmacologic, or educational intervention intended to promote individual changes in cigarette consumption among pregnant smokers and recent quitters in prenatal and postpartum period. Interventions targeting the behavior of smokers' partners or providers exclusively were not included. Interventions of interest are those that were conducted in or originated from a health care setting. The review does not include public health initiatives or system-level smoking cessation research.

Smoking outcomes are limited to biochemically validated reports of smoking cessation during pregnancy or in the postpartum period. Biochemical validation of smoking status includes measures of cotinine from saliva, urine or serum, expired carbon monoxide, or serum thiocyanate. Although these measures do not verify continuous abstinence they are accepted standards for evaluating point prevalence of smoking status. The review does not report smoking reduction.

Because there is a high risk of relapse among individuals who attempt to quit smoking, we assessed relapse prevention outcomes in pregnancy and after parturition from studies of smoking cessation interventions for women defined as recent quitters. The review also reports infant and/or child outcomes (Key Question 2) from studies evaluating smoking cessation interventions, but does not include analysis of information about the effects of maternal smoking on child health. Data on harms or adverse effects of included interventions were captured in Key Question 3. The aim of Key Question 4 is to obtain information on components of the interventions that may have an impact on patient outcomes, while Key Question 5 is included to capture characteristics that potentially modify outcomes from eligible studies. We explicitly defined eligibility criteria for these Key Questions using a PICOTS (population, intervention, comparator(s), outcome, timing, and setting) structure (Table 1).

Table 1 PICOTS

PICOTS | Criteria
Population | - Pregnant or postpartum (≤6 months post-birth) women who smoke or quit smoking in the index pregnancy; - Infants and children of pregnant or postpartum (≤ 6 months post-birth) women receiving smoking cessation interventions; - Subgroups of pregnant and/or postpartum women by level of nicotine dependence, prior quit attempts, concomitant substance or alcohol abuse, partner smoking status, and/or employment
Intervention | Any smoking cessation intervention, including pharmacologic and nonpharmacologic interventions
Comparator | - Different intervention; - Usual care; - Placebo
Outcomes | KQ1; - Smoking cessation (biochemically validated); - Continuous abstinence (biochemically validated); - Relapse; KQ2; - Preterm birth; - Gestational age; - Birth weight; - Neonatal death; - NICU admission; - Asthma exacerbation; - Asthma hospitalization; - Otitis media; - Upper respiratory infection; KQ3 Harms (e.g., weight gain, emotional stress, adverse events associated with medication to the mother or fetus) KQs 4 and 5; - Smoking cessation (biochemically validated); - Continuous abstinence (biochemically validated); - Relapse
Timing | Any length of followup
Setting | Clinician-initiated intervention or an intervention that intersects clinical care

Abbreviations: KQ = Key Question; NICU = neonatal intensive care unit; PICOTS = population, intervention, comparator, outcome, timing, setting.

### Key Questions

Key Question 1:

What is the effectiveness of interventions intended to achieve or maintain smoking cessation in women who are pregnant or postpartum for promoting smoking cessation, relapse prevention, and continuous abstinence?

Key Question 2:

What is the effectiveness of interventions intended to achieve or maintain smoking cessation in women who are pregnant or postpartum for improving infant and child outcomes?

Key Question 3:

What are the harms of interventions intended to achieve or maintain smoking cessation in women who are pregnant or postpartum?

Key Question 4:

What is the effect of components of the smoking cessation intervention, including who delivered the intervention (physician, nurse, midwife, etc.), the intervention itself, and where the intervention was delivered (clinic, hospital setting, etc.) on cessation of smoking or durability of cessation in women who are pregnant or postpartum?

Key Question 5:

What is the effect of patient characteristics on outcomes of smoking cessation interventions (successful/unsuccessful cessation, relapse) in women who are pregnant or postpartum?

## Analytic Framework

We developed the analytic framework (Figure 1) illustrating the population, interventions, and outcomes that guided the literature search, study eligibility, screening, and synthesis.

Figure 1 Analytic framework

Abbreviations: KQ = Key Question; NICU = neonatal intensive care unit.

The analytic framework illustrates the population, intervention, intermediate and long-term outcomes and harms that will guide the literature search and evidence synthesis. Pregnant or postpartum (i.e., within 6 months of birth) women who smoke or quit smoking in the index pregnancy are exposed to one or more pharmacologic and nonpharmacologic smoking cessation interventions. Smoking cessation interventions may lead to intermediate outcomes for the mother (e.g., smoking cessation, cessation followed by relapse, or preterm birth) or for her infant (e.g., birthweight). Smoking cessation interventions may also be associated with infant or child outcomes (e.g., gestational age; neonatal death; NICU admission; asthma exacerbation; asthma hospitalization; otitis media; and upper respiratory infection). The key questions (KQs) are designated by circles; placement indicates relationship to the population, intervention, or outcomes. Five key questions address: outcomes of smoking cessation for the mother (KQ1) and the child (KQ2); harms to the mother or child (KQ3); intervention components that may impact effectiveness (KQ4); and patient characteristics that may affect how well an intervention promotes cessation (KQ5).

## Organization of This Report

In addition to this introductory chapter, this report documents the review methodology (Chapter 2) and presents the key findings and synthesis of study data for all five Key Questions (Chapter 3). We discuss these findings in the context of what is known, discuss limitations of the evidence and this review, and suggest opportunities for future research in Chapter 4. We also provide an assessment of the strength of evidence for the effectiveness of individual intervention components as well as for infant outcomes and harms in the final Chapter.

We have included a list of the abbreviation and acronyms used throughout the report and appendices at the end of the Discussion Chapter and preceding the list of references. Supplementary material, including screening forms, search strategies, complete study data, and a list of excluded studies is available in eight appendices.