# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Sue Cooper, Ph.D.
  University of Nottingham
  Nottingham, England
- Janice Gomersall, M.D.
  Medicaid Medical Directors Learning Network
  Missoula, MT
- Suzanne G. Haynes, Ph.D.
  Department of Health and Human Services Office on Women's Health
  Washington, DC
- Jennifer Prah Ruger, Ph.D., M.Sc., M.A., M.S.L.
  University of Pennsylvania
  Perelman School of Medicine
  Philadelphia, PA
- Mary Ellen Wewers, R.N., Ph.D., M.P.H.
  Ohio State University
  Columbus, OH