# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Susan A. Albrecht, Ph.D., CRNP, FAAN
  University of Pittsburgh
  Pittsburgh, PA
- Timothy J. Coleman, M.D.
  University of Nottingham
  Nottingham, England
- Beth Collins Sharp, Ph.D., R.N.
  Women's Health and Gender Research
  Agency for Healthcare Research and Quality
  Rockville, MD
- Denise Dougherty, Ph.D.
  Extramural Research, Education and Priority Populations
  Agency for Healthcare Research and Quality
  Rockville, MD
- Mary Ann Faucher, CNM, M.P.H., Ph.D., FACNM
  Baylor University
  Waco, TX
- Stephen T. Higgins, Ph.D.
  University of Vermont
  Burlington, VT
- Evan R. Myers, M.D., M.P.H.
  Duke University Medical Center
  Durham, NC
- Sharon T. Phelan, M.D., FACOG
  University of New Mexico School of Medicine
  Albuquerque, NM
- Leah M. Ranney, Ph.D.
  University of North Carolina at Chapel Hill
  Chapel Hills, NC
- Richard A. Windsor, Ph.D., M.S., M.P.H.
  George Washington University Medical Center
  Washington, DC